# APPENDIX B BENCHMARK DOSE MODELING RESULTS

## Modeling Procedure for Continuous Noncancer Data

Benchmark dose (BMD) modeling of continuous data is conducted with EPA’s BMD Software (BMDS, Version 3.2). All continuous models available within the software are fit using a benchmark response (BMR) of 1 standard deviation (SD) relative risk or 10% extra risk when a biologically determined BMR is available (e.g., BMR of 10% relative deviation [RD] for body weight based on a biologically significant weight loss of 10%), as outlined in the Benchmark Dose Technical Guidance (U.S. EPA, 2002). A BMR of 10% RD for relative liver weights is considered a minimally biologically significant response in adult animals and was applied in this assessment for BMD modeling purposes. The default BMR of 1 SD also was applied for comparison. An adequate fit is judged on the basis of a χ^2^ goodness-of-fit p-value (p > 0.1), the magnitude of the scaled residuals near the BMR, and a visual inspection of the model fit. In addition to these three criteria for judging adequacy of model fit, whether the variance across dose groups is homogeneous is determined. If a homogeneous variance model is deemed appropriate on the basis of the statistical test provided by BMDS (i.e., Test 2), the final BMD results are estimated from a homogeneous variance model. When the test for homogeneity of variance is rejected (p < 0.1), the model is rerun with the variance modeled as a power function of the mean to account for this nonhomogeneous variance. If this nonhomogeneous variance model does not adequately fit the data (i.e., Test 3; p < 0.1), the data set is considered unsuitable for BMD modeling. Among all models providing adequate fit, the lowest BMD lower confidence limit (BMDL) or the benchmark concentration lower confidence limit (BMCL) is selected if the BMDL or BMCL estimate from different models vary by greater than threefold. Otherwise, the BMDL or BMCL from the model with the lowest Akaike’s information criterion (AIC) is selected as a potential point of departure (POD) from which to derive the oral reference dose or inhalation reference concentration (RfD or RfC).

## Modeling Procedure for Dichotomous Noncancer Data

The BMD modeling of dichotomous data is conducted with the EPA’s BMDS, Version 3.2. The Gamma, Logistic, Log-Logistic, Probit, Log-Probit, Hill, Multistage, and Weibull dichotomous models available within the software are fit using a BMR of 10% extra risk. In general, the BMR should be near the low end of the observable range of increased risk in the study. BMRs that are too low can result in widely disparate BMDL estimates from different models (i.e., model dependence is high). Adequacy of model fit is judged on the basis of the χ^2^ goodness-of-fit p-value (p > 0.1), magnitude of scaled residuals (absolute value <2.0), and visual inspection of the model fit. Among all models providing adequate fit, the BMDL from the model with the lowest AIC is selected as a potential POD, if the BMDLs are sufficiently close (less than approximately threefold); if the BMDLs are not sufficiently close (greater than approximately threefold), model dependence is indicated, and the model with the lowest reliable BMDL is selected.

## Model Predictions for Increased Relative Liver Weight in Male Rats (CERI, 2002c)

The procedure outlined above for continuous data was applied to the data for increased relative liver weight in adult male Crj:CD (SD) IGS (SPF) rats exposed to PFPrA for 28 days via gavage (CERI, 2002c). The BMD modeling results are summarized in Table B-1 and Figure B-1. The constant variance model provided adequate fit to the variance data, and adequate fit to the means was provided by some included models. The BMDLs for the models providing adequate fit were sufficiently close (differed by <threefold), so the model with the lowest AIC (Hill) was selected. For increased relative liver weight, the BMDL_10RD_ of 6.3 mg/kg-day (BMDL_1SD_ of 5.6 mg/kg-day for comparison) from this model was selected.

Table B-1 BMD Modeling Results for Increased Relative Liver Weight in Adult Male Crj:CD (SD) IGS (SPF) Rats Exposed to PFPrA for 28 Days via Gavage^a^

Model | df | χ^2^ Goodness-of-Fit p-Value^b^ | Scaled Residual at Dose Nearest BMD | AIC | BMD_10RD_ (mg/kg-d) | BMDL_10RD_ (mg/kg-d)
Exponential 2 | 3 | 0.005050662 | 2.262925904 | 27.21560892 | 122.4887085 | 96.33617836
Exponential 3 | 3 | 0.005050662 | 2.262802575 | 27.2156088 | 122.4882507 | 96.3740821
Exponential 4 | 2 | 0.594805118 | 0.791602093 | 17.43812865 | 20.47462463 | 9.993505528
Exponential 5 | 2 | 0.594801226 | 0.79264636 | 17.43814174 | 20.5040741 | 9.9951759
Hill * | 2 | 0.839332468 | 0.393780633 | 16.7493825 | 14.69985034 | 6.271785406
Polynomial 4 | 3 | 0.007285773 | 2.184615038 | 26.42770209 | 109.9206543 | 83.70900173
Polynomial 3 | 3 | 0.007285773 | 2.184614997 | 26.42770209 | 109.9206543 | 83.70900173
Polynomial 2 | 3 | 0.007285773 | 2.18461501 | 26.42770209 | 109.9206543 | 83.70900173
Power | 3 | 0.007285773 | 2.184615695 | 26.42770209 | 109.9206792 | 83.7162667
Linear | 3 | 0.007285773 | 2.184615019 | 26.42770209 | 109.9206543 | 83.70900173

a CERI (2002c).

b Values <0.10 failed to meet conventional goodness-of-fit criteria.

* Selected model (bold). Lowest AIC among models with adequate fit was selected (Hill).

AIC = Akaike’s information criterion; BMD = maximum likelihood estimate of the dose associated with the selected BMR; BMDL = 95% lower confidence limit on the BMD (subscripts denote BMR: i.e., 10RD = dose associated with 10% relative deviation from the control); BMR = benchmark response; df = degree(s) of freedom.

Figure B-1 Fit of Hill Model to Data for Increased Relative Liver Weight in Adult Male Crj:CD (SD) IGS (SPF) Rats Exposed to PFPrA for 28 Days via Gavage (CERI, 2002c)

Fit of Hill Model to Data for Increased Relative Liver Weight in Adult Male Crj:CD(SD) IGS (SPF) Rats Exposed to PFPrA for 28 Days via Gavage.

BMD Model Output for Figure B-1:

## Model Predictions for Increased Serum Alanine Aminotransferase (ALT) in Male Rats (CERI, 2002c)

The procedure outlined above for continuous data was applied to the data for increased serum ALT in adult male Crj:CD (SD) IGS (SPF) rats exposed to PFPrA for 28 days via gavage (CERI, 2002c). The BMD modeling results are summarized in Table B-2 and Figure B-2. The constant variance model provided adequate fit to the variance data, and adequate fit to the means was provided by all included models. The BMDLs for the models providing adequate fit were not sufficiently close (differ by >threefold), so the model with the lowest BMDL (Hill) was selected. For increased serum ALT, the BMDL_1SD_ of 28 mg/kg-day from this model was selected.

Table B-2 BMD Modeling Results for Increased Serum ALT in Adult Male Crj:CD (SD) IGS (SPF) Rats Exposed to PFPrA for 28 days via Gavage^a^

Model | df | χ^2^ Goodness-of-Fit p-Value^b^ | Scaled Residual at Dose Nearest BMD | AIC | BMD_1SD_ (mg/kg-d) | BMDL_1SD_ (mg/kg-d)
Exponential 2 | 3 | 0.725145 | 0.495322432 | 166.1551966 | 137.6285 | 103.6144
Exponential 3 | 3 | 0.7251452 | 0.495266835 | 166.1551956 | 137.6445 | 103.6143
Exponential 4 | 2 | 0.6611853 | −0.108470434 | 167.6658274 | 86.36887 | 34.31788
Exponential 5 | 2 | 0.6611853 | −0.108457685 | 167.6658274 | 86.36948 | 34.31813
Hill * | 2 | 0.6635677 | −0.118454015 | 167.6586338 | 85.62671 | 28.43509
Polynomial 4 | 3 | 0.7661823 | 0.379605768 | 165.9835564 | 124.7527 | 90.53213
Polynomial 3 | 3 | 0.7661823 | 0.379605711 | 165.9835564 | 124.7527 | 90.53213
Polynomial 2 | 3 | 0.7661823 | 0.3796057 | 165.9835564 | 124.7527 | 90.53213
Power | 3 | 0.7661823 | 0.379605707 | 165.9835564 | 124.7526 | 90.53205
Linear | 3 | 0.7661823 | 0.379605721 | 165.9835564 | 124.7527 | 90.53213

a CERI (2002c).

b Values <0.10 failed to meet conventional goodness-of-fit criteria.

* Selected model (bold). Lowest AIC among models with adequate fit was selected (Hill).

AIC = Akaike’s information criterion; ALT = alanine aminotransferase; BMD = maximum likelihood estimates of the dose associated with the selected BMR; BMDL = 95% lower confidence limit on the BMD (subscripts denote BMR: i.e., 1SD = dose associated with 1 standard deviation relative risk from the control); BMR = benchmark response; df = degree(s) of freedom.

Figure B-2 Fit of Hill Model to Data for Increased Serum ALT in Adult Male Crj:CD (SD) IGS (SPF) Rats Exposed to PFPrA for 28 days via Gavage (CERI, 2002c)

Fit of Hill Model to Data for Increased Serum ALT in Adult Male Crj:CD (SD) IGS (SPG) Rats Exposed to PFPrA for 28 days via Gavage.

BMD Model Output for Figure B-2:

## Model Predictions for Increased Serum Alkaline Phosphatase (ALP) in Male Rats (CERI, 2002c)

The procedure outlined above for continuous data was applied to the data for increased serum ALP in adult male Crj:CD (SD) IGS (SPF) rats exposed to PFPrA for 28 days via gavage (CERI, 2002c). The BMD modeling results are summarized in Table B-3 and Figure B-3. The constant variance model provided adequate fit to the variance data, and adequate fit to the means was provided by some included models. The BMDLs for the models providing adequate fit were sufficiently close (differed by <threefold), so the model with the lowest AIC (Exponential Degree 5) was selected. For increased serum ALP, the BMDL_1SD_ of 20 mg/kg-day from this model was selected.

Table B-3 BMD Modeling Results for Increased Serum ALP in Adult Male Crj:CD (SD) IGS (SPF) Rats Exposed to PFPrA for 28 Days via Gavage^a^

Model | df | χ^2^ Goodness-of-Fit p-Value^b^ | Scaled Residual at Dose Nearest BMD | AIC | BMD_1SD_ (mg/kg-d) | BMDL_1SD_ (mg/kg-d)
Exponential 2 | 3 | 0.0473274 | −0.467410275 | 356.8601623 | 298.0884 | 180.9615
Exponential 3 | 3 | 0.0473274 | −0.467408907 | 356.8601623 | 298.0878 | 180.9639
Exponential 4 | 2 | 0.2900059 | −1.0137466 | 353.3986597 | 41.09192 | 13.77903
Exponential 5 * | 2 | 0.5081367 | 0.446996822 | 353.3608541 | 67.12098 | 20.33889
Hill | 2 | 0.5081348 | −0.001142051 | 353.3608582 | 34.13729 | 20.52392
Polynomial 4 | 3 | 0.0516934 | −0.53163545 | 356.663328 | 284.0054 | 163.4765
Polynomial 3 | 3 | 0.0516934 | −0.53163533 | 356.663328 | 284.0054 | 163.4765
Polynomial 2 | 3 | 0.0516934 | −0.531635319 | 356.663328 | 284.0054 | 163.4765
Power | 3 | 0.0516934 | −0.531635379 | 356.663328 | 284.0054 | 163.479
Linear | 3 | 0.0516934 | −0.531635714 | 356.663328 | 284.0054 | 163.4765

a CERI (2002c).

b Values <0.10 fail to meet conventional goodness-of-fit criteria.

* Selected model (bold). Lowest AIC among models with adequate fit was selected (Exponential 5).

AIC = Akaike’s information criterion; ALP = alkaline phosphatase; BMD = maximum likelihood estimates of the dose associated with the selected BMR; BMDL = 95% lower confidence limit on the BMD (subscripts denote BMR: i.e., 1SD = 1 dose associated with 1 standard deviation relative risk from the control); BMR = benchmark response; df = degree(s) of freedom.

Figure B-3 Fit of Exponential Degree 5 Model to Data for Increased Serum ALP in Adult Male Crj:CD (SD) IGS (SPF) Rats Exposed to PFPrA for 28 Days via Gavage (CERI, 2002c)

Fit of Exponential Degree 5 Model to Data for Increased Serum ALP in Adult Male Crj:CD (SD) IGS (SPG) Rats Exposed to PFPrA for 28 Days via Gavage.

BMD Model Output for Figure B-3:

## Model Predictions for Increased Hepatocyte Hypertrophy in Male Rats (CERI, 2002c)

The procedure outlined above for dichotomous data was applied to the data for increased hepatocyte hypertrophy in adult male Crj:CD (SD) IGS (SPF) rats exposed to PFPrA for 28 days via gavage (CERI, 2002c). The BMD modeling results are summarized in Table B-4 and Figure B-4. All models provided adequate fit (p-value > 0.10). The BMDLs for the models providing adequate fit were not sufficiently close (differed by >threefold), so the model with the lowest BMDL (Multistage Degree 1) was selected. For increased hepatocyte hypertrophy, the BMDL_10ER_ of 7.9 mg/kg-day from this model was selected.

Table B-4 BMD Modeling Results for Increased Hepatocyte Hypertrophy in Adult Male Crj:CD (SD) IGS (SPF) Rats Exposed to PFPrA for 28 Days via Gavage^a^

Model | df | χ^2^ Goodness-of-Fit p-Value^b^ | Scaled Residual at Dose Nearest BMD | AIC | BMD_10ER_ (mg/kg-d) | BMDL_0.1ER_ (mg/kg-d)
Dichotomous Hill | 1 | 0.9994976 | 2.89723E–06 | 13.63817081 | 71.52739 | 22.82469
Gamma | 1 | 0.9904814 | 0.000386722 | 13.63845452 | 60.62737 | 16.55655
Log-Logistic | 3 | 1 | −7.48247E–10 | 9.638170614 | 71.55622 | 22.82473
Multistage 3 | 3 | 0.9980426 | 0.026748569 | 9.713472066 | 51.37595 | 12.69572
Multistage 2 | 3 | 0.9833786 | −0.384943695 | 9.957035722 | 41.5625 | 12.92712
Multistage 1 * | 2 | 0.3982919 | −0.950683507 | 14.89786409 | 15.01799 | 7.890077
Weibull | 3 | 0.9997399 | 0.013825013 | 9.657704573 | 57.16347 | 15.74647
Logistic | 3 | 1 | 1.48722E–06 | 9.638184036 | 73.04749 | 31.07119
Log-Probit | 2 | 0.9999999 | 5.62727E–08 | 11.63817039 | 69.91623 | 22.30673
Probit | 3 | 0.9999977 | 0.000912285 | 9.63902246 | 64.88286 | 28.34315

a CERI (2002c).

b Values <0.10 fail to meet conventional goodness-of-fit criteria.

* Selected model (bold). Lowest AIC among models with adequate fit was selected (Hill).

AIC = Akaike’s information criterion; ALP = alkaline phosphatase; BMD = maximum likelihood estimate of the dose associated with the selected BMR; BMDL = 95% lower confidence limit on the BMD (subscripts denote BMR: i.e., 10ER = dose associated with 10% extra risk from the control); BMR = benchmark response; df = degree(s) of freedom.

Figure B-4 Fit of Multistage Degree 1 Model to Data for Increased Serum ALP in Adult Male Crj:CD (SD) IGS (SPF) Rats Exposed to PFPrA for 28 Days via Gavage (CERI, 2002c)

Fit of Multistage Degree 1 Model to Data for Increased Serum ALP in Adult Male Crj:CD (SD) IGS (SPG) Rats Exposed to PFPrA for 28 Days via Gavage.

BMD Model Output for Figure B-4: