# APPENDIX A SYSTEMATIC LITERATURE SEARCH METHODS AND RESULTS

## Methods

The following describes the systematic review methods used to collect epidemiological and toxicological evidence for ∼150 PFAS as part of the larger PFAS systematic review effort described in Carlson et al. (2022); Radke et al. (2022)^3^. The methods outlined below are taken from (Carlson et al., 2022) and further details can be found directly in the published manuscript. Perfluoropropanoic acid (PFPrA) was part of the list of 150 PFAS, and for the purposes of this summary, we isolated the PFPrA-specific results found as a result of the processes outlined below.

### Populations, Exposures, Comparators, and Outcomes (PECO) Criteria and Supplemental Material Tagging

PECO criteria are used to focus the scope of an evidence map or systematic review by defining the research question(s), search terms, and inclusion/exclusion criteria. The PECO criteria for PFPrA are presented in Table A-1. In addition to PECO-relevant studies, studies that did not meet PECO criteria but contained “potentially relevant” supplemental material were tracked during the literature screening process. Supplemental material was tagged by category, as outlined in Table A-2. Note that “supplemental” material does not refer to findings contained in the supplement of papers identified.

### Literature Search and Screening Strategies

#### Database Search Term Development

Chemical search terms were used to search for relevant literature in the databases listed below. The detailed search strategy for each database, including specific search stings are presented in the supplemental materials of Carlson et al. (2022).

- PubMed (National Library of Medicine)
- Web of Science (Thomson Reuters)
- ToxLine via TOXNET (included in the 2019 search; no longer operational in the 2020 or 2021 search updates)^5^

The literature search for the ∼150 PFAS consisted only of the chemical name, synonyms, and trade names and no additional limits, with the exception of the Web of Science (WoS) search strategy. Due to the specifics of searching WoS, a chemical name-based search can retrieve a very large number of off-topic references. Given the number of PFAS included in the 150 PFAS screening effort, a more targeted WoS search strategy was used to identify the records most likely applicable to human health (see supplemental materials of Carlson et al. (2022)). Chemical synonyms for PFAS were identified by using synonyms in the Dashboard (U.S. EPA, 2021a) indicated as “valid” or “good.” The preferred chemical name (as presented in the Dashboard), CASRN, and synonyms were then shared with EPA information specialists who used these inputs to develop search strategies tailored for PubMed, Web of Science, and ToxLine (see supplemental materials of Carlson et al. (2022)).

### Database Searches

The database searches were conducted by an EPA information specialist in August 2019 for the 150 PFAS, and searches were updated in December 2020 and again in December 2021. All records were stored in EPA’s Health and Environmental Research Online (HERO) database (U.S. EPA, 2019a, b). The HERO database (https://heronet.epa.gov/heronet/index.cfm/content/home) (U.S. EPA (https://hero.epa.gov/hero/index.cfm/reference/details/reference_id/7310517)) is used to provide access to the references used in the EPA’s scientific assessments, including this effort. After deduplication in HERO using unique identifiers (e.g., PMID, WoSID, or DOI) and citations, the references went through an additional round of deduplication using ICF’s Deduper tool (described in detail in the supplemental materials of Carlson et al. (2022), “DeDuper”), which uses a two-phase approach to identify duplicates by a) locating duplicates using automated logic and b) employing machine learning built from Python’s Dedupe package to predict likely duplicates which are then verified manually (Magnuson et al., 2018). Following deduplication, SWIFT-Review (https://www.sciome.com/swift-review/) software (Sciome, 2021; Howard et al., 2016) was used to identify which of the unique references were most relevant for human health risk assessment. In brief, SWIFT-Review was used to filter the unique references based on the software’s preset literature search strategies (titled “evidence stream”). These evidence streams were developed by information specialists and can be used to separate the references most relevant to human health from those that are not (e.g., environmental fate studies). References are tagged to a specific evidence stream if the search terms from that evidence stream appear in the title, abstract, keyword, and/or medical subject headings (MeSH) fields of that reference. For the PFAS 150 SEM, the following SWIFT-Review evidence stream were applied: human, animal models for human health, and in vitro studies. Specific details on the evidence stream search strategies are available through Sciome’s SWIFT-Review documentation at https://www.sciome.com/wp-content/uploads/2019/08/SWIFT-Review-Search-Strategies-Evidence-Stream.docx. Studies not retrieved using the search strategies were not considered further.

#### Other Resources Consulted

The literature search strategies described above are intentionally broad; however, it is still possible that some studies were not captured (e.g., cases where the specific chemical is not mentioned in title, abstract, or keyword content; “gray” literature that is not indexed in the databases listed above). Additionally, if incomplete citation information was provided (e.g., if reference lists searched did not include titles) no additional searching was conducted. Thus, in addition to the databases identified above, the sources below were used to identify studies that could have been missed during the database searches. Additional descriptions of these sources can be found in Table 4 of Carlson et al. (2022).

- Reference list from the PFAS-Tox Database, a 2019 evidence map of 29 PFAS (Pelch et al., 2019), available at https://public.tableau.com/profile/the.endocrine.disruption.exchange#!/vizhome/PFASToxDatabase/PFASDatabase-BETA and https://pfastoxdatabase.org/. (PFASToxDatabase)
- Reference lists from all PECO-relevant animal and epidemiological studies identified in the database searches meeting PECO criteria (see supplemental materials of Carlson et al. (2022))
- National Toxicology Program (NTP) database of study results and research projects. The was accomplished by personal communication with NTP rather than manual search of the NTP database for all the PFAS included in the evidence map.
- References from EPA’s CompTox Chemicals Dashboard ToxValDB (Toxicity Values Database) (U.S. EPA, 2018) to identify studies or assessments that present POD information. ToxValDB collates publicly available toxicity dose-effect related summary values typically used in risk assessments. Many of the PODs presented in ToxValDB are based on gray literature studies or assessments not available in databases such as PubMed and WoS, etc. It is important to note that ToxValDB entries have not undergone quality control to ensure accuracy or completeness and may not include recent studies.
  ○ ToxValDB includes POD data collected from data sources within ACToR (Aggregated Computational Toxicology Resource) and ToxRefDB (Toxicity Reference Database) and no-observed and lowest-observed (adverse) effect level (NOEL, NOAEL, LOEL, LOAEL) data extracted from repeated dose toxicity studies submitted under REACH (Registration, Evaluation, Authorisation and Restriction of Chemicals). Also included are reference dose and concentration values (RfDs and RfCs) from EPA’s Integrated Risk Information System (IRIS) and dose descriptors from EPA’s Provisional Peer-Reviewed Toxicity Values (PPRTV) documents. Acute toxicity information in ToxValDB comes from several sources, including Organization for Economic Cooperation and Development (OECD) eChemPortal, National Library of Medicine (NLM), Hazardous Substances Data Bank (HDSB), ChemIDplus via EPA Toxicity Estimation Software Tool (TEST), and the European Union (EU) Joint Research Centre (JRC) AcutoxBase and the EU COSMOS project and the European Chemicals Agency (ECHA) registration dossiers to identify data submitted by registrants, available at http://echa.europa.eu/information-on-chemicals/information-from-existing-substances-regulation. (ECHA, 2020)

Records from these other sources were uploaded into DistillerSR (Evidence Partners, 2022) and annotated with respect to source of the record. The specific methods and results for searching each source are described below. Results of searches of these sources is summarized to include the source type or name, the search string (when applicable), the number of results present within the resource, and the URL (when available and applicable).

##### ECHA

A search of the ECHA registered substances database was conducted using the CASRN. The registration dossier associated with the CASRN was retrieved by navigating to and clicking the eye-shaped view icon displayed in the chemical summary panel. The General Information tab and all subpages under the Toxicological Information tab were downloaded in PDF format, including all nested reports that had unique URLs. In addition, the data were extracted from each dossier page and used to populate an Excel tracking sheet with this data. Extracted fields included data from the general information page regarding the registration type and publication dates, and on a typical ECHA dossier page the primary fields reported in the administrative data, data source, and effect levels sections. Each study summary resulted in more than one row in the tracking sheet if more than one data source or effect level was reported.

At this stage, each reference was reviewed for inclusion based on PECO criteria. ECHA dossiers without information under the ToxCategory column were excluded from review because these refer to data extracted from the General Information tab. Toxicological and end point summary pages, study protocols, and dossiers with data waiving were also excluded from review. When a reference that was considered relevant reported data from a named study or lab report, a citation for the full study was either retrieved or generated in HERO and verified that it was not already identified from the peer-reviewed literature search prior to moving forward to screening in DistillerSR. If citation information was not available and a full text could not be retrieved, ECHA and ToxValDB references were compared using information on the chemical, points of departure, study type, species, strain, sex, exposure route and method, and critical effect to determine whether any of these references were previously accounted for in ToxValDB. When there were no overlaps between references, a citation was created in HERO using the information provided in the ECHA dossier. The generated PDF for the dossier was used as the full text for screening, and these citations were annotated accordingly for Tableau and HAWC visualizations by adding “(ECHA)” to the citation.

##### EPA CompTox chemical dashboard (ToxValDB)

ToxValDB data was retrieved for the PFAS chemicals from the EPA CompTox Dashboard (U.S. EPA, 2018). Data available from the Hazard tab for each chemical was exported from the Dashboard by U.S. EPA staff and provided as an Excel file output. Using this ToxValDB POD summary file, citations were identified for references that apply to human health PODs. A citation for each reference, except those indicated as “ECHA” or “ECHA IUCLID,” was either retrieved or generated in HERO and verified that it was not already identified from the database search prior to moving forward to screening in DistillerSR.

References in ToxValDB described as from an ECHA or ECHA IUCLID source were confirmed to be accounted for in the ECHA results retrieved above. A comparison was performed between 25% of the ECHA references from ToxValDB and the full ECHA results retrieved above, and although the comparison noted discrepancies (5 out of 34), these were found to be inaccuracies in ToxValDB, most likely because the data was removed or modified during an update to ECHA since the last time ToxValDB imported ECHA data. That is, the ECHA dossiers retrieved above were determined to be more accurate and up to date than the ToxValDB ECHA entries and could supersede the ECHA data from ToxValDB.

#### Screening and Tagging Process

After selection of evidence steams and chemicals in SWIFT-Review as described in the “Database Searches” section, the filtered studies were imported into SWIFT-Active Screener (version 1.061; Sciome LLC) for title or abstract (TIAB) screening. SWIFT-Active Screener is a web-based collaborative software application that uses active machine-learning approaches to reduce the screening effort (Howard et al., 2020). The screening process was designed to prioritize records that appeared to meet PECO criteria or that included supplemental material content based on TIAB content (i.e., both types of records were screened as “include” for active-learning purposes). Studies were screened in SWIFT-Active Screener until the software indicated a likelihood of 95% that all relevant studies had been captured. This threshold is comparable to human error rates (Bannach-Brown et al., 2018; Howard et al., 2016; Cohen et al., 2006) and is used as a metric to evaluate machine-learning performance. Any studies in “partially screened” status at the time of reaching the 95% threshold were fully screened.

Studies that met these criteria from TIAB screening were then imported into DistillerSR (Evidence Partners, 2022) for more specific TIAB tagging (i.e., to separate studies meeting PECO criteria versus supplemental content and to tag the specific type of supplemental content and, if necessary, the chemical). Supplemental content tags are described in Table A-2. For studies meeting PECO criteria at the DistillerSR TIAB level, full text articles were retrieved through EPA’s HERO database. References that could be retrieved within 45 days were identified to be unavailable.

Studies identified via the gray literature searches were imported directly into DistillerSR at the TIAB phase. References identified in the gray searches that had previously been screened as not relevant to PECO criteria at either the SWIFT-Review or SWIFT-Active Screener stage were rescreened in Distiller.

Two independent reviewers conducted each level of screening (TIAB and full text). At all levels (SWIFT-Active Screener TIAB, DistillerSR TIAB, and DistillerSR full-text review), any conflicts in screening were resolved by discussion between the two independent reviewers; a third reviewer was consulted if any conflicts remained thereafter. Conflicts between screeners in applying the supplemental tags were resolved by discussion at both the TIAB and full-text levels, erring on the side of over tagging at the TIAB level. At the TIAB level, articles without an abstract were screened based on title (title should indicate clear relevance), and number of pages (articles two pages or fewer in length were assumed to be records with no original data) For additional information, please see Table A-2 for supplemental categorization information. All studies identified as supplemental material at TIAB and full-text levels were tagged to their respective chemical(s) using the preferred chemical names. All studies identified as PECO were tagged to the preferred chemical name after the full-text screening stage. A caveat to tagging at the TIAB level was that tagging was based only on information provided in the abstract and could therefore miss additional details that may have been provided in the full text of the manuscript. Additionally, sources that did not list a specific PFAS in the TIAB (i.e., included terms like “PFAS”) were tagged to “chemical not specified.” However, if any PFAS were specified, they were tagged and the “chemical not specified” tag was not selected, even though it was possible that additional PFAS chemicals were reported in the full text. All chemical tagging was reviewed by an expert in chemistry (with a doctoral or similar degree). Where chemical identity presented in the manuscript was unclear, the original authors were contacted to resolve the chemical species.

### Data Extraction of Study Methods and Findings

#### Animal Toxicology Studies

Studies that met PECO criteria after full-text review were summarized using custom forms (a standard operating procedure for populating the forms is included in the supplemental material of Carlson et al. (2022)) in DistillerSR. For animal studies, the following study summary information was captured in a literature inventory: PFAS assessed, study type [acute (<24 hours), short term (1–30 days), subchronic (30–90 days), chronic (>90 days), developmental, peripubertal, multigenerational], route of exposure, species, sex, and health system(s) assessed. For epidemiological studies, the following study summary information was captured in a literature inventory: PFAS assessed, sex, population, study design, exposure measurement (e.g., blood, feces), and health system(s) assessed. Summaries were then extracted into DistillerSR by one team member, and the extracted data were checked for quality by at least one other team member. The data from these summary literature inventories were exported from DistillerSR to an Excel format and then modified and transformed using Excel’s ‘Get and Transform’ features for import into Tableau visualization software (https://www.tableau.com/) (version 2019.4; Tableau Software LLC) (Tableau Software, 2023). These data transformations include pivoting multiple columns of data to single columns, appending data from multiple literature inventories, and merging detailed reference information and chemical ID information into the dataset.

The literature inventory was used to prioritize animal toxicological studies with exposure to the 150 PFAS for repeat dose studies of 21-day and longer durations, or with study designs focusing on exposure windows targeting reproduction or development. Studies meeting these exposure timing and duration parameters were moved forward for study evaluation (described in the next section) and endpoint-level data extraction. Animal toxicology studies not meeting these criteria did not move forward and were summarized at the literature inventory level only.

Data extraction was conducted for prioritized animal toxicology studies by two members of the evaluation team using EPA’s version of Health Assessment Workspace Collaborative (HAWC) (U.S. EPA, 2021b), a free and open source web-based software application designed to manage and facilitate the process of conducting literature assessments. Data extracted included basic study information (e.g., full citation, funding, author-reported conflicts of interest); experiment details (e.g., study type, chemical name, chemical source, and purity); animal group specifics (species, strain, sex, age at exposure and assessment, husbandry); dosing regimen; endpoints evaluated; and results (qualitative or quantitative) by endpoint. Authors were not contacted for information that was not reported in a study. Data extraction was performed by one member of the evaluation team (primary extractor) and checked by a second member for completeness and accuracy (secondary extractor). Data extraction results were used to create HAWC visualizations (e.g., exposure-response arrays) by health system and effect for each PFAS chemical. The detailed HAWC extractions for animal studies are available for download from EPA HAWC in Excel format at https://hawcprd.epa.gov/assessment/100500085/downloads/ (U.S. EPA, 2020d). The data extraction output will also be available as an excel file from the Dashboard ToxValDB database in a future release.

Subsequent to HAWC data extraction, an EPA toxicologist reviewed each study to identify study-level, no-observed-adverse-effect levels [NOAELs] and lowest-observed-adverse-effect levels [LOAELs]. These judgments were made at the individual study level.

#### Epidemiology Studies

Epidemiological studies did not undergo full endpoint-level data extraction. A more detailed analysis of these studies, however, is being pursued as part of a separate activity (Radke et al., 2022).

### Study Evaluation

Study evaluation was conducted for prioritized animal toxicological studies (≥21-day exposure durations or exposure occurring during reproduction or development) and human epidemiological studies by two reviewers using EPA’s version of HAWC (U.S. EPA, 2021b). Reviews were made by toxicologists or epidemiologists with multiple years of experience in developing chemical human health assessments. During study evaluation, in each evaluation domain, at least two reviewers reached a consensus rating of Good, Adequate, Deficient, Not Reported or Critically Deficient as defined in HAWC. Key study evaluation considerations were potential sources of bias (factors affecting the magnitude or direction of an effect in systematic way) or insensitivity (factors limiting detection of a true effect). Core and prompting questions used to guide the judgment for each domain are described in more detail in the IRIS Handbook (U.S. EPA, 2020b). After a consensus rating was reached, the reviewers considered the identified strengths and limitations to reach an overall study confidence rating of High, Medium, Low, or Uninformative for each health outcome. The definitions below follow the standard template language that is used in systematic evidence maps developed by the EPA and have only been adjusted, where appropriate, for the specific needs of the PFAS 150 SEM.

- High: A well-conducted study with no notable deficiencies or concerns identified for the outcome(s) of interest; the potential for bias is unlikely or minimal, and the study used sensitive methodology. “High” confidence studies generally reflect judgments of good across all or most evaluation domains.
- Medium: A study where some deficiencies or concerns were noted for the outcome(s) of interest, but the limitations are unlikely to be of a notable degree. Generally, “medium” confidence studies will include adequate or good judgments across most domains, with the impact of any identified limitation not being judged as severe.
- Low: A study where one or more deficiencies or concerns were noted for the outcome(s) of interest, and the potential for bias or inadequate sensitivity could have a significant impact on the study results or their interpretation. Typically, “low” confidence studies would have a deficient evaluation for one or more domains, although some “medium” confidence studies may have a deficient rating in domain(s) considered to have less influence on the magnitude or direction of the results. Generally, in an assessment context (or a full systematic review), low confidence results are given less weight in comparison with high or medium confidence results during evidence synthesis and integration and are generally not used as the primary sources of information for hazard identification or derivation of toxicity values unless they are the only studies available. Studies rated as low confidence only because of sensitivity concerns about biases toward the null would require additional consideration during evidence synthesis.
- Uninformative: A study where serious flaw(s) make the results unusable for informing hazard identification for the outcome(s) of interest. Studies with critically deficient judgments in any evaluation domain will almost always be classified as “uninformative” (see explanation above). Studies with multiple deficient judgments across domains may also be considered uninformative. As mentioned above, although outside the scope of this SEM, in an assessment or full systematic review, uninformative studies would not be considered during the synthesis and integration of evidence for hazard identification or for dose response but might be used to highlight possible research gaps. Thus, data from studies deemed uninformative are not depicted in the results displays included in this SEM.

Rationales for each study evaluation classification, including a description of how domain ratings impacted the overall study confidence rating, are available in the supplemental materials of Carlson et al. (2022) and are documented and retrievable in HAWC (https://hawcprd.epa.gov/summary/visual/assessment/100500085/animal-study-evaluation-heatmap) (U.S. EPA, 2020c).

Table A-1 Populations, Exposures, Comparators, and Outcomes (PECO) Criteria

PECO element | Description
[underlined: P]opulations | Human: Any population and lifestage (occupational or general population, including children and other potentially sensitive populations).; Animal: Nonhuman mammalian animal species (whole organism) of any lifestage (including preconception, in utero, lactation, peripubertal, and adult stages).
[underlined: E]xposures | Relevant forms: PFPrA-specific results isolated from search for ~150 PFAS chemicals + Nafion represented by ~170 PFAS structures and substances previously identified.; Human: Any exposure to PFAS via the oral and inhalation routes because these are the most relevant routes of human exposure and typically the most useful for developing human health toxicity values. Studies are also included if biomarkers of PFAS exposure are evaluated (e.g., measured PFAS or metabolite in tissues or bodily fluids) but the exposure route is unclear or reflects multiple routes. Other exposure routes, including dermal, and mixture-only studies (i.e., without effect estimates for individual PFAS of interest) are tracked during title and abstract screening and are tagged as supplemental material.; Animal: Any exposure to PFAS via oral or inhalation routes. Studies involving exposures to mixtures are included only if a treatment group consists of exposure to a PFAS alone. Other exposure routes, including dermal or injection, and mixture-only studies are tagged as supplemental material.
[underlined: C]omparators | Human: A comparison or referent population exposed to lower levels (or no exposure/exposure below detection limits) or exposed for shorter periods of time. Worker surveillance studies are considered to meet PECO criteria, however, even if no referent group is presented. Case reports describing findings in 1–3 people in nonoccupational or occupational settings are tracked as supplemental material.; Animal: A concurrent control group exposed to vehicle-only treatment or untreated control (control could be a baseline measurement).
[underlined: O]utcomes | All health outcomes (cancer and noncancer).

Table A-2 Major categories of “potentially relevant supplemental material”

Category | Description
In vitro, ex vivo, or in silico “mechanistic” studies | In vitro, ex vivo, or in silico studies reporting measurements related to a health outcome that inform the biological or chemical events associated with phenotypic effects, in both mammalian and nonmammalian model systems.
Absorption, distribution, metabolism, and excretion (ADME) | ADME studies are primarily controlled experiments where defined exposures usually occur by intravenous, oral, inhalation, or dermal routes, and the concentration of particles, a chemical, or its metabolites in blood or serum, other body tissues, or excreta are then measured. These data are used to estimate the amount absorbed (A), distributed to different organs (D), metabolized (M), and/or excreted/eliminated (E) through urine, breath, feces, etc. ADME data can also be collected from human subjects who have had environmental or workplace exposures that are not quantified or fully defined. However, to be useful, such data must involve either repeated measurements over a time period when exposure is known (e.g., is zero because previous exposure ended) or time- and subject-matched tissue or excreta concentrations (e.g., plasma and urine, or maternal and cord blood). ADME data, especially metabolism and tissue partition coefficient information, can be generated using in vitro model systems. Although in vitro data may not be as definitive as in vivo data, these studies should also be tracked as ADME. For large evidence bases it may be appropriate to separately track the in vitro ADME studies. Note: Studies describing environmental fate and transport or metabolism in bacteria are not tagged as ADME.
Classical pharmacokinetic (PK) model Studies, or physiologically based pharmacokinetic (PBPK) modeling studies | [underlined: Classical PK or dosimetry modeling studies]: Classical PK or dosimetry modeling usually divides the body into just one or two compartments, which are not specified by physiology, where movement of a chemical into, between, and out of the compartments is quantified empirically by fitting model parameters to ADME data.; [underlined: PBPK or mechanistic dosimetry modeling studies:] PBPK models represent the body as various compartments (e.g., liver, lung, slowly perfused tissue, richly perfused tissue) to quantify the movement of chemicals or particles into and out of the body (compartments) by defined routes of exposure, metabolism, and elimination, and thereby estimate concentrations in blood or target tissues.
Nonmammalian model systems | Studies in nonmammalian model systems, e.g., Xenopus species, fish, birds, Caenorhabditis elegans.
Transgenic mammalian model systems | Transgenic studies in mammalian model systems.
Non-oral or non-inhalation routes of administration | Studies in which humans or animals (whole organism) were exposed via a non-oral or non-inhalation route (e.g., injection, dermal exposure).
Exposure characteristics (no health outcome assessment) | Exposure characteristic studies which include data that are unrelated to health outcomes but which provide information on exposure sources or measurement properties of the environmental agent (e.g., demonstrate a biomarker of exposure).
Mixture studies | Mixture studies that are not considered PECO-relevant because they do not contain an exposure or treatment group assessing only the chemical of interest. This category is generally used for experimental studies and generally does not apply to epidemiological studies where the exposure source may be unclear.
Case reports | Case reports describing health outcomes after exposure will be tracked as potentially relevant supplemental information when the number of subjects is three or fewer.
Records with no original data | Records that do not contain original data, such as other agency assessments, informative scientific literature reviews, editorials, or commentaries.
Conference abstracts | Records that do not contain sufficient documentation to support study evaluation and data extraction.
European Chemicals Agency (ECHA) read-across | Data on a nonrelevant chemical that makes inferences about a relevant PFAS chemical.
Presumed duplicate | Duplicate studies (e.g., published vs. unpublished reports) identified during data extraction and study quality evaluation.

5 As part of a broader National Library of Medicine (NLM) reorganization, TOXNET has moved and most of NLM’s toxicology information services have been integrated into other NLM products and services.