# REFERENCES

3M (3M Company). (1988). Correspondence to D. R. Ricker regarding summary of acute toxicity tests for T-4201 conducted by Hazleton Laboratories. (3M-EPA-00307697).
Ahrens L. (2011). Polyfluoroalkyl compounds in the aquatic environment: a review of their occurrence and fate [Review]. J Environ Monit 13: 20–31. 10.1039/c0em00373e.21031178
ATSDR (Agency for Toxic Substances and Disease Registry). (2021). Toxicological profile for perfluoroalkyls [ATSDR Tox Profile]. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service. 10.15620/cdc:59198.
Bailey SA; Zidell RH; Perry RW. (2004). Relationships between organ weight and body/brain weight in the rat: What is the best analytical endpoint? Toxicol Pathol 32: 448–466. 10.1080/01926230490465874.15204968
Beach SA; Newsted JL; Coady K; Giesy JP. (2006). Ecotoxicological evaluation of perfluorooctanesulfonate (PFOS) [Review]. Rev Environ Contam Toxicol 186: 133–174. 10.1007/0-387-32883-1_5.16676904
Buck RC; Franklin J; Berger U; Conder JM; Cousins IT; de Voogt P; Jensen AA; Kannan K; Mabury SA; van Leeuwen SP. (2011). Perfluoroalkyl and polyfluoroalkyl substances in the environment: terminology, classification, and origins [Review]. Integr Environ Assess Manag 7: 513–541. 10.1002/ieam.258.21793199
Calafat AM; Kato K; Hubbard K; Jia T; Botelho JC; Wong LY. (2019). Legacy and alternative per- and polyfluoroalkyl substances in the U.S. general population: Paired serum-urine data from the 2013–2014 National Health and Nutrition Examination Survey. Environ Int 131: 105048. 10.1016/j.envint.2019.105048.31376596
Calafat AM; Wong LY; Kuklenyik Z; Reidy JA; Needham LL. (2007). Polyfluoroalkyl chemicals in the US population: Data from the National Health and Nutrition Examination Survey (NHANES) 2003–2004 and comparisons with NHANES 1999–2000. Environ Health Perspect 115: 1596–1602. 10.1289/ehp.10598.18007991
Cenariu D; Iluta S; Zimta AA; Petrushev B; Qian L; Dirzu N; Tomuleasa C; Bumbea H; Zaharie F. (2021). Extramedullary Hematopoiesis of the Liver and Spleen [Review]. J Clin Med 10. 10.3390/jcm10245831.
DeWitt JC. (2015). Toxicological effects of perfluoroalkyl and polyfluoroalkyl substances. New York, NY: Springer International. 10.1007/978-3-319-15518-0.
ECHA (European Chemicals Agency). (2020a). Information on Chemicals [Database]. Helsinki, Finland: European Chemicals Agency, European Union. Retrieved from https://echa.europa.eu/information-on-chemicals
ECHA (European Chemicals Agency). (2020b). Registration Dossier: Lithium bis(trifluoromethylsulfonyl)imide (90076–65-6): Acute Toxicity: dermal: 001 Key | Experimental result. https://echa.europa.eu/registration-dossier/-/registered-dossier/18080/7/3/4/?documentUUID=7ce61072-e263–48a8-b8a8–638d0d13c1e1.
ECHA (European Chemicals Agency). (2020c). Registration Dossier: Lithium bis(trifluoromethylsulfonyl)imide (90076–65-6): Acute Toxicity: dermal: 002 Key | Experimental result. https://echa.europa.eu/registration-dossier/-/registered-dossier/18080/7/3/4/?documentUUID=2af3c36c-51f1–468d-9400-cf3fef7f51dd.
ECHA (European Chemicals Agency). (2020d). Registration Dossier: Lithium bis(trifluoromethylsulfonyl)imide (90076–65-6): Acute Toxicity: dermal: Other | No specified result type. https://echa.europa.eu/registration-dossier/-/registered-dossier/13025/7/3/4.
ECHA (European Chemicals Agency). (2020e). Registration Dossier: Lithium bis(trifluoromethylsulfonyl)imide (90076–65-6): Acute Toxicity: oral: 001 Key | Experimental result. https://echa.europa.eu/registration-dossier/-/registered-dossier/18080/7/3/2/?documentUUID=ceeffcc8-c080–4224-8fce-1920324a7808.
ECHA (European Chemicals Agency). (2020f). Registration Dossier: Lithium bis(trifluoromethylsulfonyl)imide (90076–65-6): Acute Toxicity: oral: 002 Key | Experimental result. https://echa.europa.eu/registration-dossier/-/registered-dossier/18080/7/3/2/?documentUUID=336e00b6–567b-4890-a27c-e5dd580b321d.
ECHA (European Chemicals Agency). (2020g). Registration Dossier: Lithium bis(trifluoromethylsulfonyl)imide (90076–65-6): Acute Toxicity: oral: 003 Supporting | Experimental result. https://echa.europa.eu/registration-dossier/-/registered-dossier/18080/7/3/2/?documentUUID=7c4ce82e-05b8–4709-a767–6a7d0f5ab52c.
ECHA (European Chemicals Agency). (2020h). Registration Dossier: Lithium bis(trifluoromethylsulfonyl)imide (90076–65-6): Developmental toxicity/teratogenicity: Key | Experimental Result. https://echa.europa.eu/registration-dossier/-/registered-dossier/18080/7/9/3.
ECHA (European Chemicals Agency). (2020i). Registration Dossier: Lithium bis(trifluoromethylsulfonyl)imide (90076–65-6): Eye irritation: 001 Key | Experimental result. https://echa.europa.eu/registration-dossier/-/registered-dossier/18080/7/4/3/?documentUUID=c64a4dda-9764–4f2c-ad1c-774c1fd70b5c.
ECHA (European Chemicals Agency). (2020j). Registration Dossier: Lithium bis(trifluoromethylsulfonyl)imide (90076–65-6): Eye irritation: 001 Other | No specified result type. https://echa.europa.eu/registration-dossier/-/registered-dossier/13025/7/4/3/?documentUUID=be4d6eae-ad2c-43a4-a460–308283d8c449.
ECHA (European Chemicals Agency). (2020k). Registration Dossier: Lithium bis(trifluoromethylsulfonyl)imide (90076–65-6): Eye irritation: 002 Key | Experimental result. https://echa.europa.eu/registration-dossier/-/registered-dossier/18080/7/4/3/?documentUUID=aaecdc3c-efc9–49ea-b014–01dc677b5758.
ECHA (European Chemicals Agency). (2020l). Registration Dossier: Lithium bis(trifluoromethylsulfonyl)imide (90076–65-6): Eye irritation: 003 Supporting | Experimental result. https://echa.europa.eu/registration-dossier/-/registered-dossier/18080/7/4/3/?documentUUID=a2724d5e-fced-426f-bf67-ddb5d1c366c7.
ECHA (European Chemicals Agency). (2020m). Registration Dossier: Lithium bis(trifluoromethylsulfonyl)imide (90076–65-6): Genetic toxicity: in vitro: 001 Key | Experimental result. https://echa.europa.eu/registration-dossier/-/registered-dossier/18080/7/7/2/?documentUUID=dae86f4a-a82c-406a-9b38–866230b2c2f4.
ECHA (European Chemicals Agency). (2020n). Registration Dossier: Lithium bis(trifluoromethylsulfonyl)imide (90076–65-6): Genetic toxicity: in vitro: 003 Key | Experimental result. https://echa.europa.eu/registration-dossier/-/registered-dossier/18080/7/7/2/?documentUUID=6433cc9d-df5a-4aa8-b89b-61d505e506df.
ECHA (European Chemicals Agency). (2020o). Registration Dossier: Lithium bis(trifluoromethylsulfonyl)imide (90076–65-6): Genetic toxicity: in vitro: 006 Key | Experimental result. https://echa.europa.eu/registration-dossier/-/registered-dossier/18080/7/7/2/?documentUUID=bd0849c1–1683-4af0-bdec-7306f9cec6bb.
ECHA (European Chemicals Agency). (2020p). Registration Dossier: Lithium bis(trifluoromethylsulfonyl)imide (90076–65-6): Genetic toxicity: in vitro: 007 Supporting | Experimental result. https://echa.europa.eu/registration-dossier/-/registered-dossier/18080/7/7/2/?documentUUID=55784324–72e4–4336-bbf7–123ea525c221.
ECHA (European Chemicals Agency). (2020q). Registration Dossier: Lithium bis(trifluoromethylsulfonyl)imide (90076–65-6): Genetic toxicity: in vitro: 008 Supporting | Experimental result. https://echa.europa.eu/registration-dossier/-/registered-dossier/18080/7/7/2/?documentUUID=c2a18dc4-c2c2–465e-a9ff-195bb83dbc0a.
ECHA (European Chemicals Agency). (2020r). Registration Dossier: Lithium bis(trifluoromethylsulfonyl)imide (90076–65-6): Repeated dose toxicity: oral: 002 Key | Experimental result. https://echa.europa.eu/registration-dossier/-/registered-dossier/18080/7/6/2/?documentUUID=fe190204-fa2f-48a5-bf11–74b30c1e0b21.
ECHA (European Chemicals Agency). (2020s). Registration Dossier: Lithium bis(trifluoromethylsulfonyl)imide (90076–65-6): Skin irritation/corrosion: 001 Key | Experimental result. https://echa.europa.eu/registration-dossier/-/registered-dossier/18080/7/4/2/?documentUUID=ecf34ffd-1a1c-49c8-bb60-f52f9bfd267a.
ECHA (European Chemicals Agency). (2020t). Registration Dossier: Lithium bis(trifluoromethylsulfonyl)imide (90076–65-6): Skin irritation/corrosion: 002 Key | Experimental result. https://echa.europa.eu/registration-dossier/-/registered-dossier/18080/7/4/2/?documentUUID=e9664689–9fd6–4faf-84ee-d4f68afc622e.
ECHA (European Chemicals Agency). (2020u). Registration Dossier: Lithium bis(trifluoromethylsulfonyl)imide (90076–65-6): Skin irritation/corrosion: 003 Supporting | Experimental result. https://echa.europa.eu/registration-dossier/-/registered-dossier/18080/7/4/2/?documentUUID=c7892408–706c-426a-8c50-f66339fe2fb0.
ECHA (European Chemicals Agency). (2020v). Registration Dossier: Lithium bis(trifluoromethylsulfonyl)imide (90076–65-6): Skin sensitisation: 001 Key | Experimental result. https://echa.europa.eu/registration-dossier/-/registered-dossier/18080/7/5/2/?documentUUID=9b656fd5–4459-4ff3–8403-d18b311f7847.
ECHA (European Chemicals Agency). (2020w). Registration Dossier: Lithium bis(trifluoromethylsulfonyl)imide (90076–65-6): Skin sensitisation: 002 Key | Experimental result. https://echa.europa.eu/registration-dossier/-/registered-dossier/18080/7/5/2/?documentUUID=c3c6148f-e63a-4f80–9c2a-6239c9f16856.
ECHA (European Chemicals Agency). (2020x). Registration Dossier: Lithium bis(trifluoromethylsulfonyl)imide (90076–65-6): Skin sensitisation: 003 Supporting | Experimental result. https://echa.europa.eu/registration-dossier/-/registered-dossier/18080/7/5/2/?documentUUID=1b43f008–0633-478b-9a43-ee7c12ff14ac.
ECHA (European Chemicals Agency). (2020y). Registration Dossier: Lithium bis(trifluoromethylsulfonyl)imide (90076–65-6): Toxicity to reproduction: Key | Experimental Result. https://echa.europa.eu/registration-dossier/-/registered-dossier/18080/7/9/2.
Evidence Partners. (2022). DistillerSR. Retrieved from https://www.evidencepartners.com/products/distillersr-systematic-review-software/
Fenton SE; Ducatman A; Boobis A; DeWitt JC; Lau C; Ng C; Smith JS; Roberts SM. (2021). Per- and polyfluoroalkyl substance toxicity and human health review: Current state of knowledge and strategies for informing future research [Review]. Environ Toxicol Chem 40: 606–630. 10.1002/etc.4890.33017053
Fox JR; Hogan KA; Davis A. (2016). Dose-response modeling with summary data from developmental toxicity studies. Risk Anal 37: 905–917. 10.1111/risa.12667.27567129
Hall AP; Elcombe CR; Foster JR; Harada T; Kaufmann W; Knippel A; Küttler K; Malarkey DE; Maronpot RR; Nishikawa A; Nolte T; Schulte A; Strauss V; York MJ. (2012). Liver hypertrophy: A review of adaptive (adverse and non-adverse) changes—Conclusions from the 3rd International ESTP Expert Workshop [Review]. Toxicol Pathol 40: 971–994. 10.1177/0192623312448935.22723046
Hekster FM; Laane RWP, M; de Voogt P. (2003). Environmental and toxicity effects of perfluoroalkylated substances [Review]. In Ware GW (Ed.), Reviews of environmental contamination and toxicology: Continuation of residue reviews (pp. 99–121). New York, NY: Springer-Verlag. 10.1007/0-387-21731-2_4.
Howard BE; Phillips J; Miller K; Tandon A; Mav D; Shah MR; Holmgren S; Pelch KE; Walker V; Rooney AA; Macleod M; Shah RR; Thayer K. (2016). SWIFT-Review: A text-mining workbench for systematic review. Syst Rev 5: 87. 10.1186/s13643-016-0263-z.27216467
Huntingdon Research Center. (1992a). T-4201: Bacterial mutation assay. (3M-EPA-00308051; MIN 82/921076). St. Paul, MN: 3M Toxicology Services.
Huntingdon Research Center. (1992b). T-4201: Seven-day preliminary oral toxicity study in rats. (3M-EPA-00308332; 920962D/MIN 79/ST). St. Paul, MN: 3M Toxicology Services.
Huntingdon Research Center. (1993a). T-4201: 4-week oral toxicity study in rats with 2-week recovery period. (3M-EPA-00202912; MIN 80/921461). St. Paul, MN: 3M Toxicology Services.
Huntingdon Research Center. (1993b). T-4201: Analysis of metaphase chromosomes obtained from CHL cells cultured in vitro. (3M-EPA-00309109; MIN 84/930238). St. Paul, MN: 3M Toxicology Services.
Huntingdon Research Center. (1993c). T-4201: Metaphase chromosome analysis of human lymphocytes cultured in vitro. (3M-EPA-00307701; MIN 83/930237). St. Paul, MN: 3M Toxicology Services.
Huntingdon Research Center. (1993d). T-4201: Physico-chemical properties. (3M-EPA-00308451; MIN 78/921393). St. Paul, MN: 3M Toxicology Services.
Maronpot RR. (2014). Liver - Extramedullary hematopoiesis. In National Toxicology Program nonneoplastic lesion atlas. Research Triangle Park, NC: National Toxicology Program. https://ntp.niehs.nih.gov/nnl/hepatobiliary/liver/emh/index.htm.
NASEM (National Academies of Sciences, Engineering, and Medicine). (2018). Progress toward transforming the Integrated Risk Information System (IRIS) program: A 2018 evaluation. Washington, DC: National Academies Press. 10.17226/25086.
NASEM (National Academies of Sciences, Engineering, and Medicine). (2021). Review of U.S. EPA's ORD staff handbook for developing IRIS assessments: 2020 version. Washington, DC: National Academies Press. 10.17226/26289.
Radke EG; Braun JM; Meeker JD; Cooper GS. (2018). Phthalate exposure and male reproductive outcomes: A systematic review of the human epidemiological evidence [Review]. Environ Int 121: 764–793. 10.1016/j.envint.2018.07.029.30336412
Sciome (Sciome, LLC.). (2023). SWIFT-Active Screener. Retrieved from https://www.sciome.com/swift-activescreener/
Sunderland EM; Hu XC; Dassuncao C; Tokranov AK; Wagner CC; Allen JG. (2019). A review of the pathways of human exposure to poly- and perfluoroalkyl substances (PFASs) and present understanding of health effects [Review]. J Expo Sci Environ Epidemiol 29: 131–147. 10.1038/s41370-018-0094-1.30470793
U.S. EPA (U.S. Environmental Protection Agency). (1988). Recommendations for and documentation of biological values for use in risk assessment [EPA Report]. (EPA600687008). Cincinnati, OH. http://cfpub.epa.gov/ncea/cfm/recordisplay.cfm?deid=34855.
U.S. EPA (U.S. Environmental Protection Agency). (1991). Guidelines for developmental toxicity risk assessment. Fed Reg 56: 63798–63826.
U.S. EPA (U.S. Environmental Protection Agency). (1994). Methods for derivation of inhalation reference concentrations and application of inhalation dosimetry [EPA Report]. (EPA600890066F). Research Triangle Park, NC. https://cfpub.epa.gov/ncea/risk/recordisplay.cfm?deid=71993&CFID=51174829&CFTOKEN=25006317.
U.S. EPA (U.S. Environmental Protection Agency). (2002). A review of the reference dose and reference concentration processes. (EPA630P02002F). Washington, DC. https://www.epa.gov/sites/production/files/2014-12/documents/rfd-final.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2005). Guidelines for carcinogen risk assessment [EPA Report]. (EPA630P03001F). Washington, DC. https://www.epa.gov/sites/production/files/2013-09/documents/cancer_guidelines_final_3–25-05.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2011). Recommended use of body weight 3/4 as the default method in derivation of the oral reference dose. (EPA100R110001). Washington, DC. https://www.epa.gov/sites/production/files/2013-09/documents/recommended-use-of-bw34.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2012). Benchmark dose technical guidance [EPA Report]. (EPA100R12001). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. https://www.epa.gov/risk/benchmark-dose-technical-guidance.
U.S. EPA (U.S. Environmental Protection Agency). (2018). Chemistry Dashboard. Washington, DC. Retrieved from https://comptox.epa.gov/dashboard
U.S. EPA (U.S. Environmental Protection Agency). (2020). PFAS 150 (2020) downloads. https://hawc.epa.gov/assessment/100500085/downloads/.
U.S. EPA (U.S. Environmental Protection Agency). (2021a). CompTox Chemicals Dashboard: Perfluoropropanoic acid 422–64-0 | DTXSID8059970. https://comptox.epa.gov/dashboard/dsstoxdb/results?search=DTXSID8059970.
U.S. EPA (U.S. Environmental Protection Agency). (2021b). Health Assessment Workspace Collaborative (HAWC). https://hawc.epa.gov/portal/.
U.S. EPA (U.S. Environmental Protection Agency). (2021c). Human health toxicity values for hexafluoropropylene oxide (HFPO) dimer acid and its ammonium salt (CASRN 13252–13-6 and CASRN 62037–80-3). Also known as "GenX chemicals." Final report [EPA Report]. (EPA-822R-21–010). Washington, DC: U.S. Environmental Protection Agency, Office of Water.
U.S. EPA (U.S. Environmental Protection Agency). (2021d). Human health toxicity values for perfluorobutane sulfonic acid (CASRN 375–73-5) and related compound potassium perfluorobutane sulfonate (CASRN 29420–49-3) [EPA Report]. (EPA/600/R-20/345F). Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development. https://cfpub.epa.gov/ncea/risk/recordisplay.cfm?deid=350888.
U.S. EPA (U.S. Environmental Protection Agency). (2021e). Toxicological review of perfluorobutanoic acid (PFBA) and related compound ammonium perfluorobutanoic acid (public comment and external review draft, Aug 2021) [EPA Report]. (EPA/635/R-20/424a). Washington, DC: U.S. Environmental Protection Agency, Integrated Risk Information System. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=P1014IBF.txt.
U.S. EPA (U.S. Environmental Protection Agency). (2022). ORD staff handbook for developing IRIS assessments [EPA Report]. (EPA 600/R-22/268). Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development, Center for Public Health and Environmental Assessment. https://cfpub.epa.gov/ncea/iris_drafts/recordisplay.cfm?deid=356370.
U.S. EPA (U.S. Environmental Protection Agency). (2023). CompTox Chemicals Dashboard: Lithium bis[(trifluoromethyl)sulfonyl]azanide 90076–65-6 | DTXSID8044468. https://comptox.epa.gov/dashboard/chemical/details/DTXSID8044468.
Whalan JE. (2015). A toxicologisťs guide to clinical pathology in animals: Hematology, clinical chemistry, urinalysis. Switzerland: Springer International Publishing. 10.1007/978-3-319-15853-2.
Yamamoto K; Miwa Y; Abe-Suzuki S; Abe S; Kirimura S; Onishi I; Kitagawa M; Kurata M. (2016). Extramedullary hematopoiesis: Elucidating the function of the hematopoietic stem cell niche (Review) [Review]. Mol Med Rep 13: 587–591. 10.3892/mmr.2015.4621.26648325
Yost EE; Euling SY; Weaver JA; Beverly BE J; Keshava N; Mudipalli A; Arzuaga X; Blessinger T; Dishaw L; Hotchkiss A; Makris SL. (2019). Hazards of diisobutyl phthalate (DIBP) exposure: A systematic review of animal toxicology studies [Review]. Environ Int 125: 579–594. 10.1016/j.envint.2018.09.038.30591249