# AUTHORS, CONTRIBUTORS, AND REVIEWERS

Chemical Managers/ Authors
Elizabeth Oesterling Owens, PhD | U.S. EPA, Center for Public Health and Environmental Assessment
Lucina Lizarraga, PhD
Jason C. Lambert, PhD, DABT | U.S. EPA, Center for Computational Toxicology and Exposure
Contributors
Avanti Shirke, MPH | U.S. EPA, Center for Public Health and Environmental Assessment
Production Support
Dahnish Shams | U.S. EPA, Center for Public Health and Environmental Assessment
Jessica Soto-Hernandez
Ryan Jones
Samuel Thacker
Vicki Soto
Lauren Johnson | Student Services Contractor, Oak Ridge Associated Universities (ORAU)
Primary Internal Reviewers
Kathleen Newhouse, PhD | U.S. EPA, Center for Public Health and Environmental Assessment
J. Allen Davis, MSPH
Primary External Reviewers^1^
Gloria B. Post, PhD, DABT | New Jersey Department of Environmental Protection
Panagiotis G. Georgopoulos, PhD | Rutgers University
Penelope A. Rice, PhD, DABT | U.S. Food and Drug Administration
Executive Direction
Wayne Cascio, MD | CPHEA Center Director
V. Kay Holt | CPHEA Deputy Center Director
Samantha Jones, PhD | CPHEA Associate Director
Kristina Thayer, PhD | CPHEA Chemical and Pollutant Assessment Division Director

Questions regarding the content of this assessment should be directed to the EPA Office of Research and Development (ORD) Center for Public Health and Environmental Assessment (CPHEA) website at https://ecomments.epa.gov/.

1 Dr. Post and Dr. Rice conducted this review as independent consultants and not as a representative of the New Jersey Department of Environmental Protection or the U.S. Food and Drug Administration, respectively.