# DISCLAIMER

This human health assessment was developed by EPA’s Office of Research and Development (ORD) to respond to a request from the EPA Office of Enforcement and Compliance Assurance (OECA), in support of site-specific decision-making under the purview of the Safe Drinking Water Act. This document has been reviewed in accordance with EPA policy and approved for publication. This human health assessment has received internal peer review by at least two EPA/ORD/CPHEA scientists and an independent, external peer review by at least three scientific experts outside of EPA. All users should consider the information provided in this document to ensure that the toxicity value(s) are appropriate for the decision-context. Questions regarding the content of this assessment should be directed to the U.S. EPA website at https://ecomments.epa.gov/risk.

Any mention of trade names, products, or services does not imply an endorsement by the U.S. government or the U.S. EPA. EPA does not endorse any commercial products, services, or enterprises.