# CARCINOGENICITY ASSESSMENT

No studies have been identified that examine potential carcinogenicity of HQ-115 via any route of exposure.