# DERIVATION OF REFERENCE VALUES

The hazard and dose-response database for repeated exposure to HQ-115 is limited to studies via the oral route of exposure. There are no known inhalation studies for HQ-115. Several dermal studies were identified in which acute toxicity, skin irritation, and sensitivity to HQ-115 were evaluated in rabbits, rats, or guinea pigs (see Table 3). In general, HQ-115 caused slight to severe skin effects (e.g., erythema, edema, necrotic lesions) with a dermal LD50 across species and sexes tested of approximately ≥ 350 mg/kg. HQ-115 was also identified as an ocular irritant in rabbit and chicken eyes. No known studies have evaluated potential cancer effects of HQ-115 by any exposure route; however, several studies relevant to potential mutagenic/clastogenic cancer mechanism(s) were overwhelmingly negative. The purpose of this assessment is to inform human health hazard(s) associated with chronic duration/lifetime exposures to HQ-115. Therefore, only a noncancer chronic reference dose (RfD) is derived in this assessment for the oral route of exposure. The RfD derived in this assessment is an estimate of an oral exposure to the human population (including susceptible subgroups and lifestages) likely to be without an appreciable risk of adverse health effects over a lifetime.

## Derivation of Oral Reference Dose

No human epidemiological studies were identified for HQ-115. The repeated exposure oral route hazard and dose-response evidence base for HQ-115 is limited to one high confidence 28-day study (Huntingdon Research Center, 1993a), a low confidence 29-day study (ECHA, 2020r), and a low confidence one-generation reproductive/developmental study (ECHA, 2020h, y), all in SD rats. The 29-day and reproductive/developmental rat studies were available on the ECHA website only (original source studies were not available); as such, there were limitations in reporting of methods and results that resulted in the low confidence rating. However, the information from all three rat studies was deemed useful for informing health hazards following HQ-115 oral exposure(s) and were considered in the identification of candidate critical effects and PODs, and subsequent toxicity value derivation.

The 28-day (Huntingdon Research Center, 1993a), 29-day (ECHA, 2020r) and one-generation (ECHA, 2020h, y) rat studies were all reported to be conducted according to OECD guideline protocol and under GLP conditions. For all three studies, low, but adequate numbers of animals (n = 5–10) were tested across multiple dose groupings (ranging from 1.67–90 mg/kg-day) and involved the comprehensive evaluation of in-life health status, and blood/serum parameters, organ weights, gross pathology, and histopathology upon necropsy (see Animal Studies section). In the 28 and 29-day oral studies, the liver was consistently affected by oral HQ-115 exposure. This included increases in absolute and relative liver weights, gross enlargement of the liver, increased incidence of hepatocyte hypertrophy and/or vacuolation, and serum biomarkers indicative of hepatocellular (e.g., ALT) and hepatic biliary epithelium (e.g., ALP) injury in male and female rats. It was also noted in the 28-day study that extramedullary hematopoiesis was observed, albeit at low incidence, in the livers of HQ-115 treated male rats in the low-dose (1.67 mg/kg-day) group and in females in the mid-dose (10 mg/kg-day) group (Huntingdon Research Center, 1993a); this specific lesion is uncommon in adult rats and is further evidence of hepatocyte degeneration (Cenariu et al., 2021; Yamamoto et al., 2016; Maronpot, 2014). According to Hall et al. (2012), this constellation of effects is consistent with criteria supporting a determination of adverse liver effects. The dose-response data for liver injury in the 28-day study did not identify a sex-specific sensitivity as the effects, other than extramedullary hematopoiesis, occurred at the highest dose tested in male and female rats. In contrast, in the ECHA (2020r) 29-day study, male rats appeared to be more sensitive than females to liver injury. Increased liver weight, enlargement of the liver, and histopathological evidence was evident at ≥ 45 mg/kg-day in male rats; the same effects were observed only at the highest dose tested (90 mg/kg-day) in females. Hepatic serum biomarker (e.g., ALT, AST, ALP) and liver weight data in this study were only qualitatively reported; therefore, these endpoints were not considered further for dose-response modeling.

Effects in the kidneys were also reported following 28 days of exposure to HQ-115, mainly at the highest dose tested in rats (Huntingdon Research Center, 1993a). This included increases in absolute and relative kidney weights (> 10% in males at 60 mg/kg-day), increased BUN (males and females exposed to 60 mg/kg-day), decreased urinary pH (males and females exposed to ≥ 10 mg/kg-day), and increased urine volume (38% in males exposed to 60 mg/kg-day). Other health effects were also observed in rats after 28- or 29-days of oral HQ-115 exposure (e.g., clinical signs of toxicity, spleen weights; decreased blood cholesterol) but they generally either occurred at the highest tested dose, were sporadic, not dose-related, or were not supported by corroborative evidence of toxicity.

Effects of concern have also been observed following repeated oral HQ-115 exposure in a reproductive/developmental study design in rats (ECHA, 2020h, y). Significant toxicity occurred in parental (P0) rats at ≥ 30 mg/kg-day including mortality (1/10 males and 4/10 females died at 30 mg/kg-day; 1/10 males and all females died at 60 mg/kg-day), and severe clinical signs of toxicity (e.g., tremors and convulsions) in males and females at 60 mg/kg-day. Females in the 60 mg/kg-day group also experienced significant reproductive effects (e.g., 153% increase in post-implantation loss, absence of delivery). The developing rat fetus/neonate appeared to be particularly sensitive to HQ-115 exposure as increased mortality (PND 1 and 2), decreased body weight/body weight gain (PND 1 and 5), and decreased viability (PND 4) were observed in offspring at ≥ 15 mg/kg-day. Even at the lowest tested parental exposure dose (15 mg/kg-day), 20% of pups delivered died by PND 4 (see Figure 7) compared to 4% in the control group.

Liver effects in adults and decreased survival of birthed offspring were identified as potential critical effects for oral HQ-115 exposure. While the adult rats across the 28-/29-day and single generation reproductive studies also experienced significant clinical signs of toxicity, these effects generally occurred at the highest tested dose in each study and no corroborative neurotoxicity evaluations were included. As such, clinical signs of toxicity are of uncertain significance and were not considered further. Kidney effects were observed following 28 days of exposure but were also not considered further, since these effects were observed predominantly at the highest tested dose in a single study.

Both the HQ-115-induced liver effects, observed in male and female rats from the 28-day (Huntingdon Research Center, 1993a) and 29-day (ECHA, 2020r) studies, and decreased survival in postnatal rats (ECHA, 2020h, y) (see Table 4) were evaluated for amenability to Benchmark Dose (BMD) modeling. For liver weight changes from Huntingdon Research Center (1993a), relative liver weight, the preferred metric for this organ based on its proportional relationship to body weight (Bailey et al., 2004) was included in BMD modeling. Consistent with the EPA’s Benchmark Dose Technical Guidance (U.S. EPA, 2012), the BMDs and 95% lower confidence limit on the BMDs (BMDLs) for increased relative liver weight, serum ALP, and incidence of hepatocyte hypertrophy were estimated using a benchmark response (BMR) representative of a biologically and/or statistically significant level of change for continuous (e.g., relative liver weight; serum ALP) or dichotomous (e.g., incidence of hepatocyte hypertrophy) endpoints. For liver weight changes, a 10% increase over control is considered to be of biological significance for this assessment. For serum ALP, a 1 standard deviation (SD) change over control was used. For hepatocyte hypertrophy, a 10% increased incidence over control was used. Increased hepatocyte hypertrophy in male and female rats from the Huntingdon Research Center (1993a) study and in female rats from the ECHA (2020r) study was observed only in the highest dose group; therefore, the data were not amenable for BMD modeling. Instead, a NOAEL/LOAEL approach was used to estimate PODs for these endpoints. For quantal endpoints such as postnatal survival, the BMD Technical Guidance states “[b]iological considerations may warrant the use of a BMR of 5% or lower for some types of effects (e.g., frank effects) …” Incidences of PND4 survival were modeled by eliminating the high dose group because the mean number of pups/litter were not provided for this group in the ECHA (2020h, 2020y) report (see Appendix B for more details). The data were adjusted for litter effects using a Rao-Scott transformation. As increased treatment-related fetal mortality is considered a frank effect, a BMR of 1% extra risk was selected for derivation of the POD to account for the biological severity of this endpoint (i.e., mortality), consistent with prior assessments modeling fetal mortality (U.S. EPA, 2021e).

Table 4 Data for Liver Effects in Adult Rats and Developmental Effect in Birthed Offspring from Rat Toxicity Studies of HQ 115 Considered for BMDS Modeling

Huntingdon Research Center (1993a)
Dose, mg/kg-day^a^ | 0 | 1.67 | 10 | 60
Relative liver weight in males– (g/100g)^b^ | 5.83 ± 0.3 | 6 ± 0.23 (+3%) | 6.12 ± 0.404 (+5%) | 8.49 ± 0.427^***^ (+36%)
Relative liver weight in females- (g/100g)^b^ | 4.93 ± 0.248 | 5.33 ± 0.721 (+8%) | 5.34 ± 0.519 (+8%) | 7.33 ± 0.781^***^ (+49%)
Serum ALP in males- mU/mL ^b^ | 373 ± 65.98 | 373 ± 46.5 (−1%) | 350 ± 66.56 (−7%) | 498 ± 69.93^**^ (+32%)
Hepatocyte hypertrophy in males – incidence | 0/5 | 0/5 | 0/5 | 5/5
Hepatocyte hypertrophy in females – incidence | 0/5 | 0/5 | 0/5 | 4/5
ECHA (2020r)
Dose, mg/kg-day^a^ | 0 | 15 | 45 | 90
Hepatocyte hypertrophy in males – incidence | 0/5 | 0/5 | 4/5 | 5/5
Hepatocyte hypertrophy in females – incidence | 0/5 | 0/5 | 0/5 | 4/7
ECHA (2020h, 2020y)
Dose, mg/kg-day | 0 | 15 | 30 | 60
Viability index at PND 4 (%) | 95.7 | 79.6 | 47.5 | 0
Offspring loss at PND 4^c^ | 2.94 | 8.78 | 12.80 | -^d^

a Dosimetry: Oral rat exposures are expressed in mg/kg-day as reported by the study authors.

b Values expressed as mean ± SD. Parentheses show % change relative to control = ([treatment mean − control mean] ÷ control mean) × 100. Number of animals per dose group = 5.

c Viability indices reported were multiplied times total number of pups born to calculate the number of pups died at PND 4. The data represent the PND 4 offspring loss incidence adjusted for litter effects using a Rao-Scott transformation (see Appendix B for details).

d The high dose group was eliminated when modeling the offspring survival data because the ECHA (2020h, 2020y) report did not provide the number of pups/litter in this group (see Appendix A for more details).

** Statistically (p ≤ 0.01) significant change from control.

*** Statistically (p ≤ 0.001) significant change from control.

The results of the BMD modeling of the selected endpoints are provided in Table 5; the full BMD methods and results are provided in Appendix B.

In Recommended Use of Body Weight^3/4^ as the Default Method in Derivation of the Oral Reference Dose (U.S. EPA, 2011), the EPA endorses a hierarchy of approaches to derive human equivalent oral exposures from data from laboratory animal species, with the preferred approach being physiologically based toxicokinetic modeling. Without a complete physiologically-based toxicokinetic model, other approaches might include using available chemical-specific information (e.g., clearance or plasma half-life values). In the absence of chemical-specific models or data to inform the derivation of human equivalent oral exposures, the EPA recommends that doses be scaled allometrically using body weight (BW)^3/4^ as a default method to extrapolate toxicologically equivalent doses of orally administered agents from laboratory animals to humans for the purpose of deriving an RfD, under certain exposure conditions. More specifically, the use of BW^3/4^ scaling for deriving an RfD is recommended when the observed effects are associated with the parent compound or a stable metabolite, but not for portal-of-entry effects. For HQ-115, there are no data available to inform cross-species kinetics between rats and humans, as such, human equivalent dose PODs (POD_HED_) based on allometric scaling are provided in Table 5.

Table 5 Candidate PODs for Derivation of the Chronic RfD for HQ-115

Endpoint | POD type | POD mg/kg-day | POD_HED_^a^ mg/kg-day | Reference
Increased relative liver weight in adult males | BMDL_10RD_ | 14 | 3.4 | Huntingdon Research Center (1993a)
Increased relative liver weight in adult females | BMDL_10RD_ | 13 | 2.9 | Huntingdon Research Center (1993a)
Increased serum ALP in adult males | BMDL_1SD_ | 20 | 4.8 | Huntingdon Research Center (1993a)
Increased hepatocyte hypertrophy in adult males | NOAEL^b^ | 10 | 2.4 | Huntingdon Research Center (1993a)
Increased hepatocyte hypertrophy in adult females | NOAEL^b^ | 10 | 2.2 | Huntingdon Research Center (1993a)
Increased hepatocyte hypertrophy in adult males | BMDL_10ER_ | 11 | 2.6 | ECHA (2020r)
Increased hepatocyte hypertrophy in adult females | NOAEL^b^ | 45 | 9.9 | ECHA (2020r)
Decreased survival of offspring at PND 4 | BMDL_1ER_ | 0.39^c^ | 0.086 | ECHA (2020h, 2020y)

a HEDs were calculated using species specific application of a dosimetric adjustment factor (DAF) as recommended by U.S. EPA (2011). The DAFs are calculated as follows: DAF = (BW_a_^1/4^ ÷ BW_h_^1/4^), where BW_a_ = animal body weight, and BW_h_ = human body weight. Default body weight for male adult SD rats (0.267 kg [for subchronic duration]) and for female adult SD rats (0.204 kg [for subchronic duration]) and a reference body weight of 80 kg for humans, as recommended in U.S. EPA (1988), were used to calculate the DAFs.

b NOAEL is based on increased incidence of hepatocyte hypertrophy at highest dose compared to controls and any other treatment group.

c Reported means were modeled after adjusting for litter effects using a Rao-Scott transformation (Fox et al., 2016) and described in Appendix B. The Rao-Scott transformation entails dividing the PND4 offspring survival incidence by a design effect to approximate the true variance in the clustered data.

BMDL = 95% lower confidence limit on the BMD. Subscripts denote BMR: 0.1RD = dose associated with 10% relative deviation from the control; 1SD = dose associated with 1 standard deviation relative risk from the control; 0.01ER = dose associated with 1% extra risk from the control

As illustrated in Table 5, the candidate POD_HEDs_ for the constellation of liver effects from across the 28- and 29-day repeat-dose studies in adult rats ranged from 2.2–9.9 mg/kg-day. Increased hepatocyte hypertrophy in male and female rats (Huntingdon Research Center, 1993a) provided the lowest liver-specific candidate POD_HED_ at 2.2 mg/kg-day. Hepatocyte hypertrophy represents histological evidence of altered hepatocellular architecture and is part of a pattern or progression of chemical-induced alteration in the liver including increased overall size/mass of the organ, and release of serum biomarkers indicative of cell destruction (e.g., ALT from hepatocytes; ALP from biliary epithelium) (Hall et al., 2012). This progressive profile of liver injury supports identification of hepatocyte hypertrophy in male and female rats (Huntingdon Research Center, 1993a) at 2.2 mg/kg-day as a candidate POD for derivation of a RfD. Further, the POD_HEDs_ calculated for hepatocyte hypertrophy in male rats were within an order of magnitude across both the ECHA (2020r) and Huntingdon Research Center (1993a) studies.

The effects in offspring from the one-generation reproductive/developmental rat study (ECHA, 2020h, y) were of significant concern. Specifically, a significant decrease in survival of birthed offspring occurred at the lowest dose tested and resulted in a POD of 0.39 mg/kg-day (POD_HED_ of 0.086 mg/kg-day). Since effects were observed at the lowest dose tested, there is uncertainty around what dose would be required to obtain a NOAEL for this effect. Further, the lower bound estimate on the POD (i.e., BMDL) is below the range of the observed data (15 mg/kg-day–60 mg/kg-day). Considering the severity of this developmental effect at a POD_HED_ that is over an order of magnitude lower than the lowest liver effect-based POD_HED_ in adults, decreased survival of offspring at PND 4 was identified as a candidate critical effect, and was further evaluated for derivation of a chronic RfD (see Table 6).

Table 6 Candidate Chronic Reference Doses for HQ-115

Endpoint | POD_HED_ mg/kg-day | UF_H_ | UF_A_ | UF_S_ | UF_L_ | UF_D_ | UF_C_^a^ | Candidate RfD (mg/kg-day)
Increased hepatocyte hypertrophy in adult males and females; (Huntingdon Research Center, 1993a) | 2.2 | 10 | 3 | 10 | 1 | 10 | 3,000 | 7 × 10^−4^
Decreased survival of offspring at PND 4; (ECHA, 2020h, y) | 0.086 | 10 | 3 | 1 | 1 | 10 | 300 | 3 × 10^−4^

a UF_C_ = composite uncertainty factor; the multiplicative product of the individual uncertainty factors.

## Selection of the Chronic Reference Dose

Under EPA’s A Review of the Reference Dose and Reference Concentration Processes (U.S. EPA, 2002) and Methods for Derivation of Inhalation Reference Concentrations and Application of Inhalation Dosimetry (U.S. EPA, 1994), five possible areas of uncertainty and variability were considered in deriving the chronic RfD for HQ-115. Application of uncertainty factors (UF) across the two candidate critical effects revealed greater quantitative uncertainty associated with the hepatocyte hypertrophy effect and POD; a composite UF of 3,000 was identified for hepatocyte hypertrophy in adults whereas for offspring survival, a composite UF of 300 was applied (see Table 6). The distinction between the two candidate effects is that a subchronic-to-chronic duration UF (UF_S_) of 10 was applied to the hepatic POD_HED_ in adults as the study was 29 days in duration. For reduced offspring survival, a UF_S_ of 1 was applied since the developmental period, particularly in utero development, is recognized as a susceptible lifestage that may confer effects on an exposed individual or population over the course of a lifetime (U.S. EPA, 1991). As demonstrated in Table 6, the lower RfD of 3 × 10^−4^ mg/kg-day based on decreased survival of offspring is selected as the chronic RfD for HQ-115. Further, as TFSI is the desalted form of HQ-115 in aqueous environments, the RfD is also applicable to TFSI. Table 7 summarizes the uncertainty factors for the chronic RfD for HQ-115. Confidence in the chronic RfD for HQ-115 is low, as described in Table 8. The low confidence in the chronic RfD resulting from deficiencies in the principal study, quantitation of the PODHED and database indicate a high level of uncertainty in the derived RfD. Nevertheless, this RfD may be useful for some decision purposes (U.S. EPA, 2005).

Table 7 Uncertainty Factors for the Chronic RfD for HQ-115 (CASRN 90076-65-6)

UF | Value | Justification
UF_A_ | 3 | A UF_A_ of 3 is applied to account for uncertainty in characterizing the toxicokinetic and toxicodynamic differences between animals and humans following oral HQ-115 exposure. Cross-species dosimetric adjustment (HED calculation) between rats and humans was performed using allometric scaling (U.S. EPA, 2011), accounting for some aspects of the cross-species toxicokinetic processes. The application of a 3 represents residual toxicokinetic uncertainty and potential toxicodynamic differences across species.
UF_D_ | 10 | A UF_D_ of 10 is applied to account for deficiencies and uncertainties in the database. The database for repeated oral exposures to HQ-115 is limited to a 28-d, 29-d, and one-generation reproductive/developmental study, all in rats. There is no longer-duration repeat-dose studies, or, multi-generational reproductive/developmental toxicity studies, available following oral exposure.
UF_H_ | 10 | A UF_H_ of 10 is applied to account for interindividual variability in the susceptibility of the human population because of both intrinsic and extrinsic factors that can influence the response to dose, in the absence of chemical-specific information to assess toxicokinetic and toxicodynamic variability of HQ-115 in humans.
UF_L_ | 1 | A UF_L_ of 1 is applied because the POD is a BMDL.
UF_S_ | 1 | A UF_S_ of 1 is applied because the POD comes from a reproductive/developmental study in rats. A developmental period is recognized as a susceptible life stage in which exposure during certain time windows (e.g., gestational) is more relevant to the induction of developmental effects than lifetime exposure (U.S. EPA, 1991)
UF_C_ | 300 | Composite UF = UF_A_ × UF_D_ × UF_H_ × UF_L_ × UF_S_.

BMDL = benchmark dose lower confidence limit; HED = human equivalent dose.

POD = point of departure; RfD = reference dose; UF = uncertainty factor; UF_A_ = interspecies uncertainty factor; UF_C_ = composite uncertainty factor; UF_D_ = database uncertainty factor; UF_H_ = intraspecies uncertainty factor; UF_L_ = LOAEL-to-NOAEL uncertainty factor; UF_S_ = subchronic-to-chronic duration uncertainty factor.

Confidence in the chronic RfD for HQ-115 is low, as described in Table 8.

Table 8 Confidence Descriptors for the Chronic RfD for HQ 115 (CASRN 90076-65-6)

Confidence Categories | Designation | Discussion
Confidence in study | L | Confidence in the principal study (ECHA, 2020h, y) is low. The reproductive/developmental rat study was only available as a web report summary on the European Chemicals Agency public database. (see Figure 2 and information available on HAWC (https://hawcprd.epa.gov/summary/visual/assessment/100500265/HQ115_Study-Eval-Heatmap_Animal-studies/)).
Confidence in database | L | Confidence in the database for HQ-115 is low. The relevant oral exposure database consists of a 28-day, 29-day, and one-generation reproductive/developmental studies, all in rats. No longer-duration, repeat-dose toxicity studies are available following exposure via any route.
Confidence in quantification of the POD_HED_ | L | Confidence in the quantification of the POD is low based primarily on the estimated BMDL that is below the range of the observed data (see Appendix B for details).
Confidence in chronic RfD | L | The overall confidence in the chronic RfD is low based on the low confidence in the selected principal study and database deficiencies.

BMD = benchmark dose; BW = body weight; HED = human equivalent dose; POD = point of departure; RfD = reference dose

### DERIVIATION OF INHALATION REFERENCE CONCENTRATIONS

No studies have been identified that examine noncancer effects of HQ-115 via the inhalation exposure route.

### SUMMARY OF NONCANCER REFERENCE VALUES

A summary of the noncancer reference values is shown in Table 9.

Table 9 Summary of Noncancer Reference Values for HQ-115 (CASRN 90076-65-6)

Toxicity Type(units) | Species/Sex | Critical Effect | Reference Value (mg/kg-day) | POD Method | POD_HED_ (mg/kg-day) | UFC | Principal Study
Chronic RfD (mg/kg-day) | Rat/M and F | Decreased survival of offspring at PND 4 | 3 × 10^−4^ | BMDL_1ER_ | 0.086 | 300 | ECHA (2020h, 2020y)
Chronic RfC (mg/m^3^) | NDr

BMDL = benchmark dose lower confidence limit (subscripts denote benchmark response: i.e., 1ER = dose associated with a 1% extra risk in parameter); F = females; M = male(s); NDr = not derived; POD_HED_ = human equivalent point of departure; RfC = reference concentration; RfD = reference dose; UF_C_ = composite uncertainty factor.