# RESULTS

## Literature Search and Screening Results

The literature searches yielded 3,089 unique references for HQ-115 and TFSI. As shown in the literature search diagram below (see Figure 1), seven animal studies meeting the PECO criteria and thirty supplemental studies were identified. No human studies were identified. All studies meeting PECO criteria evaluated HQ-115 exposure and not TFSI. The database of animal toxicity studies consists of seven oral exposure studies in rats: one 7-day range finding study (Huntingdon Research Center, 1992b), two 28/29-day studies (ECHA, 2020r; Huntingdon Research Center, 1993a), a one-generation reproductive/developmental study (summarized in two reports) (ECHA, 2020h, y), and three acute studies (ECHA, 2020e, f, g; 3M, 1988). The 7-day range finding study and acute studies provide limited information for the evaluation of potential health effects after repeat-dose toxicity and the derivation of a chronic oral reference dose (RfD). Therefore, these studies were considered supplemental information and summarized under “Other Data.” Of the studies tagged as supplemental in Figure 1, eight were genotoxicity studies (see Table 2 for more details) and thirteen were non-oral/inhalation studies (i.e., three evaluated toxicities of HQ-115 after a single dermal dose, three evaluated skin irritation/corrosion, three evaluated skin sensitization, and four evaluated ocular irritation; see Table 3 for more details). These studies were also summarized under “Other Data.” The remaining supplemental studies in Figure 1 included two duplicate reports of PECO-relevant studies and seven abstracts with relevant supplemental information (e.g., genotoxicity, ADME and non-oral/inhalation route) but no underlying data; the latter were not advanced for evidence synthesis.

Figure 1 Literature Search Flow Diagram for HQ-115

Lithium bis[(trifluoromethyl)sulfonyl]azanide (HQ-115)^*^ (CASRN 90076-65-6)

* The systematic literature search and review included the desalted amide of HQ-115, 1,1,1-Trifluoro-N-[(trifluoromethyl)sulfonyl]methanesulfonamide (TFSI; CASRN 82113-65-3)

Lithium bis[(trifluoromethyl)sulfonyl]azanide Peer and Gray literature search. 1,423 studies were pulled from PubMed. 6,487 were pulled from WoS. 44 were pulled from ECHA. 19 were pulled from ToxVal. 6 selected non-CBI 3 M studies were submitted to EPA. A total of 3,089 studies were pulled after deduplication and 3072 were excluded. 17 studies were included for full text screening. 4 were excluded. 0 studies were human health effects studies and 7 were animal effects studies. 20 studies were tagged as supplemental. 8 of the supplemental studies were genotoxicity, 13 were non-oral/non-inhalation route, 2 were duplicates of PECO relevant data and 7 were abstract only.

## Human Studies

No human studies were identified that examine health effects of HQ-115.

## Animal Studies

The database of animal toxicity studies informing potential health effects associated with repeat-dose exposure to HQ-115 includes three gavage studies in rats: two 28/29 day studies (Huntingdon Research Center, 1993a); (ECHA, 2020r) and a one-generation reproductive/developmental study (summarized in two reports) (ECHA, 2020h, y). The 28-day study by Huntingdon Research Center (1993a) was rated as high confidence for all endpoints, while the 29-day study and one-generation reproductive/developmental study were rated as low confidence (ECHA, 2020h, y); (ECHA, 2020r) (see Figure 2). Concerns contributing to the low confidence rating for the ECHA (2020h, 2020y) studies included issues regarding observational bias for some endpoints (i.e., clinical signs, fetal malformations, neurobehavior), selective reporting, chemical administration, and exposure characterization (limited information on source and purity of test material), outcome assessment, and results presentation. Details on methods of endpoint assessment and results were limited. Additionally, most data were provided qualitatively, and the data that were provided quantitatively were incomplete (i.e., lack of information on variances, sample sizes and/or statistical analyses).

Figure 2 Study Evaluation for Animal Studies and All Health Outcomes

Interactive figure and additional study details available on HAWC (https://hawcprd.epa.gov/summary/visual/assessment/100500265/HQ115_Study-Eval-Heatmap_Animal-studies/).

For the ECHA, 2020r study, confounding/variable control and study design applicability had high confidence overall. Reporting and allocating had medium confidence overall. exposure characterization, results presentation, and overall confidence were reported as deficient or Low confidence. blinding and selective reporting/attrition were not reported. ECHA, 2020 h , y was reported as having high confidence for study design applicability. reporting, allocating, confounding/variable control had medium confidence overall. selective reporting/attrition, exposure characterization and overall confidence were low confidence. blinding was not reported. outcome assessment had a mix of medium to low confidence. results presentation had a mix of medium, low, and deficient metrics. For Huntingdon Research Center, 1993, reporting, allocation, confounding/variable control, selective reporting/attrition, exposure characterization, study design applicability, outcome assessment, results presentation, and overall confidence had high confidence. Blinding had medium confidence.

### Huntingdon Research Center (1993a)

Male and female 5-week-old Crl: CD (Sprague-Dawley) BR VAF Plus rats (5/group) were administered 0, 1.67, 10, or 60 mg/kg-day HQ-115 via gavage for 28 consecutive days (Huntingdon Research Center, 1993a). Five additional control and high-dose male and female rats were maintained for a 14-day recovery period. The study was conducted according to OECD and GLP guidelines and evaluated clinical signs, body weights, food intake, hematology, blood chemistry, urinalysis, organ weights (adrenals, brain, liver, kidneys, spleen, testes with epididymides, and ovaries) and histopathology (adrenals, liver, heart, kidneys, spleen, and any other abnormal tissue). As noted previously, there is high confidence in the study with no significant concerns or deficiencies in any of the study quality domains evaluated (see Figure 2).

During the exposure period, no statistically significant effects on body weight or food intake were reported in rats up to 60 mg/kg-day, except for a 5% increase in cumulative food intake in females exposed to 60 mg/kg-day. During the recovery period, body weight gain was significantly lower (32%, p < 0.05) in females treated with 60 mg/kg-day compared to controls. No mortalities occurred in any group, and no clinical signs of toxicity were observed in the 1.67 mg/kg-day group. Clinical signs of toxicity occurred in both males and females at 10 mg/kg-day, including piloerection (i.e., bristling of fur; 1/5 males and 1/5 females), which was accompanied by hypersensitivity (not further specified) and abnormal gait only for the affected female. In the 60 mg/kg-day group, clinical signs of toxicity included piloerection (10/10 males and 10/10 females), hypersensitivity (10/10 males and 10/10 females), abnormal gait (9/10 males and 10/10 females), body tremors (4/10 males), lethargy (4/10 males), and fur loss (3/10 males). No clinical signs were observed in the controls and in animals exposed to 60 mg/kg-day during the recovery period.

Increases in liver weights (absolute and relative to body weight) were observed in males and females (see Figure 3) at the highest dose (60 mg/kg-day). Relative liver weight^3^ increased significantly by 46% in males and 49% in females (p < 0.001); similar changes in absolute liver weight were observed. Relative, versus absolute, liver weight is generally the preferred metric in the presence of body weight differences among groups, based on its proportional relationship to body weight (Bailey et al., 2004). Changes in liver weights resolved after the recovery period.

Figure 3 Liver Weights Following Oral Exposure to HQ-115

Interactive figure available on HAWC (https://hawc.epa.gov/summary/data-pivot/assessment/100500265/HQ-115-HRC-1993-7376324-Liver-Weight/)

Liver Weights Following Oral Exposure to HQ-115. Huntingdon Research Center, 1993. 28-day oral study design. Endpoint Name: liver weight, relative. Animal description: Rat, Crl;Cd(Sd) Br Vaf/Plus male. Response Units: g/100g. The y axis is Dose (mg/kg-day) and begins at male 0 and goes up as follows: 1.67, 10, 60 then by female 0, 1.67, 10, 60. The x axis is labeled as percent control response beginning at -10 and going up increments of +10 up to 70. Percent control response for both female and male at 0 Dose was 0%. Percent control response for male at 1.67 was approximately 4 at 1.67 dose and approximately 8 for female. Percent control response for male at 10 was approximately 6 and approximately 8 for female. Percent control response for 60 were statistically significant for both male and female at approximately 46 and 48.

The liver weight increases were accompanied by noticeable enlargement of the liver at necropsy in the 60 mg/kg-day groups (5/5 males and 3/5 females). Microscopic examination of the liver revealed minimal to moderate generalized hepatocyte hypertrophy (5/5 males and 4/5 females) and centrilobular hepatocyte hypertrophy (1/5 females). Centrilobular hepatocyte vacuolation was observed in 1/5 males at 60 mg/kg-day and extramedullary hematopoiesis was observed in the liver of males (2/5) at 1.67 mg/kg-day and females (1/5) at 10 mg/kg-day, both lesions graded as minimal. These liver lesions were not observed in the controls or any other dose groups (see Figure 4). Extramedullary hematopoiesis is uncommon in adult rats and may be indicative of potential hepatocyte degeneration, pigment deposition, and/or fatty changes (Maronpot, 2014). Following the recovery period, an enlarged liver was observed in one out of five males in the 60 mg/kg-day group; however, livers were no longer visibly enlarged in females, and there was no evidence of hepatocyte hypertrophy. After recovery, incidence of extramedullary hematopoiesis (graded as minimal) was similar in the controls and in males exposed to 60 mg/kg-day (1/5). In females, minimal extramedullary hematopoiesis was notably higher in the 60 mg/kg-day group compared to the control group (1/5 at 0 mg/kg-day versus 4/5 at 60 mg/kg-day). Capsular inflammatory cells (graded as minimal) were reported in 1/5 males exposed at 60 mg/kg-day. Data for the recovery period is not shown in Figure 4. Overall, the results suggest a coherent pattern of liver injury with some evidence of hepatocyte degeneration (i.e., extramedullary hematopoiesis) after short-term HQ-115 exposure.

Figure 4 Liver Histopathology Following Oral Exposure to HQ-115

Interactive figure available on HAWC (https://hawc.epa.gov/summary/data-pivot/assessment/100500265/HQ-115-HRC-1993-7376324-Liver-Histopathology/)

Liver Histopathology Following Oral Exposure to HQ-115. The study design was 28 days oral. For endpoint name Centrilobular Hepatocyte Hypertrophy, female rats at a dose of 60 mg/kg-day had an incidence response of 20%. For endpoint name Generalized Hepatocyte Hypertrophy, males rats at a dose of 60 had an incidence response of 100%. Female rats had a incidence response of 80% at a dose of 60 mg/kg-day. For endpoint name Centrilobular Hepatocyte Vacuolation, male rats at a dose of 60 had a incidence response of 20%. For Endpoint Name Extrameduliary Hematopoiesis, male rats at a dose of 1.67 mg/kg-day had an incidence response of 40%. Female rats at a dose 10 mg/kg-day had an incidence response of 20%.

Serum enzyme and protein levels were also examined in the 28-day rat study. Alanine aminotransferase (ALT) and aspartate aminotransferase (AST) (i.e., glutamic pyruvic transaminase (GPT) and glutamic oxaloacetic transaminase (GOT)) are serum biomarkers of hepatocellular damage, while alkaline phosphatase (ALP) and gamma-glutamyl transferase (GGT) are markers of hepatobiliary damage. In males, ALP was increased significantly at the highest dose (32% at 60 mg/kg-day, p < 0.01) (see Figure 5). No dose-related or statistically significant changes in the levels of ALT, AST, and GGT were found in either males or females. Serum albumin levels were significantly increased in the high-dose male and female groups (14-15%, p < 0.01), and serum globulin was significantly decreased in the high-dose male group (15%, p <0.01) and in all female groups (6-11%, p < 0.05) but total serum protein levels were unaffected by exposure (Figure 5). Changes in blood proteins such as serum albumin/globulin (A/G) ratio, which can reflect issues with the liver, kidneys, or other organs (Whalan, 2015), was significantly increased in a dose-dependent manner in all dose groups in males and in females (10-35%, p < 0.05). Although results were not always coherent across endpoints, changes in some serum biomarkers provide support for potential liver damage in HQ-115-exposed animals (i.e., increased ALP and A/G ratio).

Figure 5 Select Blood Markers Related to Liver Function Following Oral Exposure to HQ 115

Interactive figure available on HAWC (https://hawc.epa.gov/summary/data-pivot/assessment/100500265/HQ-115-HRC-1993-7376324-Select-Clinical-Chemistry/)

Select Blood Markers Related to Liver Function Following Oral Exposure.

There were other statistically significant effects observed in the blood of HQ-115 exposed male and female rats. Cholesterol and triglyceride levels were significantly decreased in high-dose males (60% and 42%, respectively; p < 0.01), and cholesterol levels were decreased in all female dose groups in a dose-dependent manner (16–19%, p < 0.05). Decreases in serum lipids (i.e., triglycerides and cholesterol) have been observed in animals with exposure to other PFAS (ATSDR, 2021), although the specific biological significance of these changes is unclear. In addition, thrombotest time (which measures prothrombin time [PT]) was significantly increased in males exposed to ≥10 mg/kg-day (14–23%) in a dose-related manner, although it was not accompanied by changes in platelets. It is noted that the liver is responsible for the synthesis of most clotting factors.

Kidney-related effects were also reported in rats after HQ-115 exposure (HAWC link (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500265/HQ-115-HRC-1993-7376324-Kidney-Effects/)). Statistically significant increases (11%) in relative kidney weights were reported in males at the highest dose. Similarly, absolute kidney weights in males and females exposed to 60 mg/kg-day were increased by 11% and 9%, respectively; these changes were not statistically significant but were considered biologically significant (i.e., a ≥10% increase in absolute and relative liver and kidney weight is considered biologically significant by the EPA for the purposes of this assessment). In general, the kidney weight changes did not show a dose-response gradient and were not accompanied by any histological lesions. Effects in clinical biomarkers relevant to kidney function were also reported. In the 60 mg/kg-day groups, significantly increased blood urea nitrogen (BUN) was observed in males and females (33% and 27%, respectively; p < 0.01). Urinary pH was statistically significantly decreased (6–9%, p < 0.05) in both sexes exposed to ≥10 mg/kg-day, and urine volume increased by 38% in males exposed to 60 mg/kg-day (p < 0.05). Following the 14-day recovery period, urine pH remained statistically significantly decreased in rats previously exposed to 60 mg/kg-day; however, no changes in kidney weight or other biochemical indicators of kidney toxicity (i.e., BUN and urine volume) in either the blood or urine were observed. Although results were not coherent across all endpoints, increased kidney weight and altered kidney-related clinical biomarkers (i.e., increased BUN and decreased urinary pH in males and females and increased urine volume in males) at the high dose suggest potential kidney toxicity following HQ-115 exposure.

There were other health effects observed in rats after 28-day exposure, but they generally occurred at the highest dose only, were sporadic, or were not supported by corroborative evidence of toxicity. For example, in the 60 mg/kg-day males, absolute spleen weights were significantly increased by 21% (p < 0.05) and relative spleen weights were similarly increased (20%), although the changes were not statistically significant. The increases in spleen weights did not show a dose-response gradient and histological findings in the spleen were restricted to minimal extramedullary hematopoiesis observed in one high-dose male. Blood glucose concentration was significantly increased (12%, p < 0.05) in high-dose males only. Blood chloride concentrations were significantly decreased in males in the two highest dose groups, but only by 2% and 1%, respectively (p < 0.05). In the 60 mg/kg-day females, potassium concentration was 16% decreased (p < 0.01). None of these hematological changes persisted into the recovery period.

Additional changes that were not observed in animals evaluated immediately after exposure ended were seen in the recovery groups. Absolute brain weight was increased 7% in recovery males previously dosed with 60 mg/kg-day. In addition, enlarged lymph nodes were observed in 4/5 recovery male rats dosed with 60 mg/kg-day and in 1/5 recovery control males. Increased globulin and total protein levels and decreased absolute spleen weight (17%) were observed in recovery female rats dosed with 60 mg/kg-day. The biological significance of these effects is unclear in the absence of corroborative findings, including from histopathological evaluations of the brain, lymph nodes and spleen.

Overall, the findings in the high confidence study by Huntingdon Research Center (1993a) showed coherent evidence of liver effects in male and female rats following 28-days of exposure to HQ-115 mostly at the highest dose (60 mg/kg-day), including increased relative liver weights, hepatocyte lesions (mainly increased hepatocyte hypertrophy and possible degenerative changes [extramedullary hematopoiesis]), and some changes in serum biomarkers related to liver damage (primarily increased ALP in males). Clinical signs of toxicity (piloerection, hypersensitivity, abnormal gait, body tremors, lethargy, and fur loss) and indications of kidney toxicity (e.g., increased organ weight; increased BUN) were also reported in males and females at the highest dose (60 mg/kg-day).

### ECHA (2020r)

A chemical registrant 29-day study is summarized on the European Chemical Agency (ECHA) website in which the toxicity of HQ-115 after oral exposure in rats was evaluated (ECHA, 2020r). Male and female 6-week-old Sprague-Dawley rats (5/group) were administered 0, 15, 45, or 90 mg/kg-day HQ-115 via gavage for 29 consecutive days (ECHA, 2020r). Five additional control and high-dose male and female rats were maintained for a 14-day recovery period. The study was conducted according to OECD and GLP guidelines and evaluated clinical signs, functional observational battery, body weights, food intake, hematology, blood chemistry, urinalysis, organ weights, and histopathology. The original source studies were not available, resulting in a low confidence rating based on deficiencies in several study evaluation domains (see Figure 2), including the lack of details on methods of endpoint assessment and presentation of results in the available ECHA study summaries. In particular, details pertaining to organs weighed, tissues examined for histopathology, and blood chemistry and urinalysis were not reported, nor were the specific methods used for in-life or toxicological assessment reported; most data were reported qualitatively. Group means were provided for body weights, food intake and hematology but no information on variances or sample sizes was included.

Two mortalities in females in the high dose group occurred immediately after anesthesia for blood collection and were considered to be accidental.

During the exposure period, slightly reduced body weight gains were reported in males and females in the 45 mg/kg-day groups (8% males and 12% females) and in males in the 90 mg/kg-day group (10%); however, an increase in body weight gain was reported for females in the 90 mg/kg-day group (62%). The increase in body weight gain in females in the 90 mg/kg-day group was accompanied by significantly increased food consumption (39%, p < 0.01) during the treatment period. During the recovery period, no significant effects on body weight gain were reported, but a slightly higher food consumption was reported for both males and females.

There were no clinical signs of toxicity reported for the 15 mg/kg-day group. Clinical signs of toxicity occurred in both males and females at 45 mg/kg-day, including aggressive behavior (1/5 females) and hunched posture (1/5 males). At 90 mg/kg-day, clinical signs of toxicity included piloerection (3/5 males), ptyalism (i.e., overproduction of saliva) (1/5 males and 1/5 females), hunched posture (1/5 males), and aggressive behavior often associated with hypersensitivity to touch (3/10 males and 2/10 females). From the functional observation battery, a slight increase in motor activity in males and females, withdrawal following touch escape in males, and absence of auditory startle reflex in males were also observed in the animals exposed to 90 mg/kg-day (data not reported).

Increases in liver weights (absolute and relative) were reported in males in the two highest dose groups and in females in the highest dose group (data not reported). Changes in liver weights resolved after the recovery period. The liver weight increases were accompanied by noticeable enlargement of the liver at necropsy in males in the 45 mg/kg-day group (3/5) and in the 90 mg/kg-day groups (4/5 males and 4/7 females) along with several grey or white areas on the liver. These changes were no longer present after the recovery period. Microscopic examination of the liver revealed hepatocellular hypertrophy in males in the 45 mg/kg-day group (4/5) and in the 90 mg/kg-day groups (5/5 males and 4/7 females). This liver lesion was not observed in the controls or in any animal of the 15 mg/kg-day groups (Figure 6). It was not reported whether these microscopic changes were resolved following the recovery period.

Figure 6 Liver Histopathology Following Oral Exposure to HQ-115

Interactive figure available on HAWC (https://hawc.epa.gov/summary/data-pivot/assessment/100500265/HQ-115-ECHA-2020-8803688-Liver-Histopathology/)

Liver Histopathology Following Oral Exposure to HQ-115. Exposure lasted 29 days. the x axis is labeled as Incidence and begins at 0 and goes up in increments of .5 up to 5. Male Sprague-Dawley rats showed a Incidence of 80% at a dose of 45 mg/kg-day and an Incidence of 100% at a dose of 90 mg/kg-day. Female Sprague-Dawley Rats showed an Incidence of 57.1% at a dose of 90 mg/kg-day.

Serum enzyme levels were examined in the 29-day rat study, but results were only reported qualitatively. At 90 mg/kg-day, ALT (i.e., GPT) was significantly increased in males and females, and ALP was significantly increased in males (p < 0.01). It is unclear whether AST (i.e., GOT) levels were measured in the study. Effects on other clinical biomarkers relevant to liver function were also reported. The A/G ratio and albumin levels were increased in males and females in the high-dose groups. In addition, cholesterol and triglyceride levels were “slightly to moderately” decreased (p < 0.01%) in males and females of all dose groups in a dose-dependent manner.

Some variations were observed in the hematological parameters of exposed animals, but many of the changes were either slight or lacking a clear dose-response relationship (HAWC link (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500265/HQ-115-ECHA-2020-8803688-Hematology/)); therefore, the biological significance of these effects is unclear. In the 45 and 90 mg/kg-day dose groups, white blood cell (WBC) counts were increased (24–39% males and 16–37% females), driven by increased neutrophils (25–51% males and 38–59% females) and lymphocytes (19–43% males and 12–34% females). Red blood cell (RBC) counts were slightly decreased in all dose groups (6–8% males and 5–9% females), and at 45 and 90 mg/kg-day, decreased hemoglobin (4% males and 5–6% females) and decreased packed cell volume (5% males and 5–7% females) were also observed.

Additional health effects observed in rats following the 29-day exposure generally occurred at the highest dose only. Blood creatinine levels were slightly decreased in males and females exposed to 90 mg/kg-day, but no treatment-related effects were reported in urinalysis parameters (data not reported). Blood urea levels were slightly increased in males and slightly decreased in females of all dose groups (data not reported). It is unclear if the kidneys were weighed or examined for histopathology. In females, an increased incidence of thyroid follicular cell hypertrophy (3/7) and decreased diameter of the follicular lumen (3/7) were observed at 90 mg/kg-day. These microscopic findings were also observed in males at the highest dose, but the incidence was equivalent to that of the controls (2/5). An increased incidence of dilated lumen in the uterus (4/7) was observed in females of the 90 mg/kg-day group and in 1/5 females in the 45 mg/kg-day; this was not observed in the control or low dose group. This effect was attributed by study authors to variations in the estrous cycle, but no other details were provided. In addition, minimal foamy alveolar macrophages were observed in the lungs of all males and two females in the 90 mg/kg-day group, compared to only one male and one female in the control group.

Despite deficiencies in several study evaluation domains (including lack of details on methods of endpoint assessment and presentation of results; Figure 2) that to some extent limit interpretation of results, the low confidence ECHA (2020r) study provided sufficient information to identify potential health effects associated with short-term duration oral exposure to HQ-115. The study reported coherent liver effects in male and female rats at ≥ 45 mg/kg-day across organ weights (increased absolute and relative liver weights), histopathology (hepatocyte hypertrophy) and serum biomarkers of liver damage (primarily increased ALT and ALP). It should also be noted that the liver effects are consistent with the findings from the high confidence study by Huntingdon Research Center (1993a). Other possible exposure-related effects were observed in rats mostly at the highest dose (90 mg/kg-day) including clinical signs (piloerection, ptyalism, hunched posture, and aggressive behavior often associated with hypersensitivity to touch) and histopathological lesions (thyroid and uterus lesions in females and lung lesions in males and females).

### ECHA (2020h, 2020y)

A one-generation reproduction/developmental exposure study in rats (summarized in two reports from the registrant) is available on the ECHA website that evaluates the effects of HQ-115 (ECHA, 2020h, y). Ten-week-old male and 9-week-old female Sprague-Dawley rats were administered 0, 15, 30, or 60 mg/kg-day HQ-115 via daily gavage. Ten males per group were dosed for at least 28 days (for 2 weeks before mating and for up to 2 weeks during mating) and were euthanized after mating. Ten females per group were also dosed for 2 weeks before mating, during mating, and continued until lactational day 4. The study was conducted according to OECD and GLP guidelines and evaluated parental mortality, clinical signs, body weights, food intake, organ weights (epididymides and testes), gross pathology, histopathology (epididymides, mammary glands, ovaries, prostate, seminal vesicles, testes, uterus, and vagina), reproductive parameters (pre-coital time, fertility and gestation indexes, post implantation loss, number of corpora lutea and implantation sites), and developmental effects including live birth index, number of stillborn pups, litter size, sex ratio, pup mortality, clinical signs, body weight, body weight gain, and malformations (including a soft tissue examination with detailed examination of the heart and great vessels). The original source studies were not available, resulting in a low confidence rating based on deficiencies in several study evaluation domains (Figure 2), including the lack of details on methods of endpoint assessment and presentation of results in the available ECHA study summaries. Some concerns were raised regarding methods used for evaluating subjective measures such as pup malformations, histopathology, and reproductive performance, since no specific information was provided. Additionally, most data were provided qualitatively, and the data that were provided quantitatively (mortality, clinical signs and histopathology) did not include statistical analyses. Furthermore, number of corpora lutea and implantation sites were not reported in the results.

Mortalities were reported for both parental males and females in the two highest dose groups, with one male in the 30 mg/kg-day group found dead on day 27 and one male in the 60 mg/kg-day group euthanized moribund on day 2. Four females were euthanized in the 30 mg/kg-day group, because one did not deliver and three had dead litters. No females in the 60 mg/kg-day group survived until scheduled termination; one was found dead, and nine were euthanized (two did not deliver, two were found moribund, and five had dead litters).

In the parental males, body weight was decreased (4.6%, p < 0.01) in the 60 mg/kg-day group on day 8 of dosing, and body weight gain was 38% decreased (p < 0.05) during the first week of dosing. In parental females, there were no effects on body weights during the pre-mating and gestation periods. Body weight and body weight change were both decreased in the 15 and 30 mg/kg-d groups during lactation in a dose-related manner, but the decrease was only statistically significant for body weight change at 15 mg/kg-day (38%, p < 0.05). Body weight was unchanged in the 60 mg/kg-day group, but this was reported to be due to a large variance in this group. Mean food consumption in females was decreased (p < 0.01) from 15 mg/kg-day during lactation, but not pre-mating or during gestation. Mean food consumption in males decreased in the first week of treatment of ≥15 mg/kg-day and returned towards controls in subsequent weeks (data not reported).

There were no clinical signs of toxicity observed in the 15 mg/kg-day group. Clinical signs of toxicity occurred in both males and females in the 60 mg/kg-day groups, including tremors, clonic contraction, convulsions, tonic contraction, hypoactivity, prostration, decrease in grasping reflex, locomotory difficulties and/or hypersensitivity to the touch (incidence not reported). Tremors, convulsions, and tonic contraction were also observed in one male in the 30 mg/kg-day group. No exposure-related effects were reported for organ weights, gross pathology, or histopathology (no other details were provided).

Reproductive parameters were affected in parental females exposed to HQ-115, although few details were provided. In the 60 mg/kg-day group, the mean pre-coital time (mean number of days taken to mate) was slightly increased due to one female which mated after 13 days and was noted to be “blocked in diestrus for several days” (data not reported). A lower number of pregnancies was observed at 30 and 60 mg/kg-day (9/10 and 8/10 compared to 10/10 in control and the 15 mg/kg-day group), fertility and gestation indices decreased (data not reported), and post-implantation loss increased (153%) at the highest dose (60 mg/kg-day). Alterations in indicators of estrus cyclicity compared to controls were observed in females exposed to 60 mg/kg-day, including increased incidence and severity of ovarian follicle development in unscheduled dead, or surviving females (data not reported). Basophilic corpora lutea were observed in 3/10 females and oocytes in the lumen of oviducts were observed in 2/10 females. These changes suggest possible effects on estrous cyclicity, although an evaluation of cycle stage was not conducted. Few females in the high-dose group delivered (number not reported), and all their pups were found dead in the first four days after birth. There were no effects observed in the live birth index or number of stillborn pups (data not reported). The mean number of pups per litter was comparable in the low- and mid-dose groups compared to controls (14.1, 15.2 and 13.3. for the control, low-dose, and mid-dose groups), as well as the number of male and female pups per litter (data not reported).

Pup mortality, clinical signs, body weight, and malformations were assessed until postnatal day (PND) 5. The percentage of pups found dead was increased in a dose-dependent manner in all dose groups, and deaths mostly occurred on PNDs 1 and 2 (data not reported). Decreases in mean pup body weight and body weight gain were also observed in all dosed groups in comparison to the control group on PNDs 1 and 5 (data not reported). The viability index on PND4 was also reduced in all dosed groups, with no pups in the 60 mg/kg-day group surviving, 47.5% in the 30 mg/kg-day group surviving, 79.6% in the 15 mg/kg-day group surviving, and 95.7% in the control group surviving until PND 4 (see Figure 7). There was a dose-related increase in the number of litters with pups with absence of milk in the stomach observed in all dose groups (data not reported). At necropsy on PND 5, there were no exposure-related findings from the soft tissue evaluation with detailed examination of the heart and cardiovascular system (no other details were provided).

Figure 7 Pup Viability Index Following Oral Exposure to HQ-115

Interactive figure available on HAWC (https://hawc.epa.gov/summary/data-pivot/assessment/100500265/HQ-115-ECHA-2020b-88036968803697-Develop/)

Pup viability Index Following Oral Exposure to HQ-115. The x axis is labeled as response and starts at 0% and goes up by increments of 10 up to 100%. The y axis is labeled as Dose. F1 rat, Sprague-Dawley had a response of approximately 95% at 0 dose., a response of 80% at a dose of 15. and approximately 47% at a dose of 27.

Despite deficiencies in several study evaluation domains (including lack of details on methods of endpoint assessment and presentation of results; Figure 2) that to some extent limit interpretation of results, the low confidence ECHA (2020h, 2020y) study reported coherent reproductive and developmental effects at doses that also induced general systemic toxicity in parental animals. The one-generation reproductive/developmental study reported decreases in body weight gain and food consumption at ≥ 15 mg/kg-day and increased mortality and clinical signs of toxicity in parental male and female rats at ≥ 30 mg/kg-day. Developmental effects included increased pup mortality on PND 1 and 2, decreased pup body weight/body weight gain on PND 1 and 5, decreased viability index on PND 4 and gross pathological examination observations in dead pups (absence of milk in the stomach) at ≥ 15 mg/kg-day. Effects on reproduction were observed primarily at the highest dose (60 mg/kg-day), involving decreases in number of pregnancies and fertility and gestational indexes, possible changes in the estrous cycle, and increases in pre-coital time and implantation loss.

## Other Data

Available data that provide supporting information for the evaluation of potential health effects following exposure or treatment to HQ-115 consist of genotoxicity studies, short-term and acute oral exposure studies, and non-oral/inhalation studies. These include one 7-day range finding study (Huntingdon Research Center, 1992b), three acute studies (ECHA, 2020e, f, g; 3M, 1988), eight genotoxicity studies (see Table 2 for more details), and thirteen non-oral/inhalation studies (i.e. three evaluated toxicity of HQ-115 after a single dermal dose, three evaluated skin irritation/corrosion, three evaluated skin sensitization, and four evaluated ocular irritation; see Table 3 for more details).

### Genotoxicity Data

Genotoxicity studies conducted on HQ-115 include four studies that used the Ames test and a fifth study that used the mammalian cell gene mutation assay to evaluate mutagenicity. Three chromosomal aberration (CA) studies were also available. Results from these studies are listed in Table 2.

For the four Ames test studies, various strains of Salmonella typhimurium and Escherichia coli were exposed to concentrations ranging from 21 to 10,000 μg/plate for two to three days, with and without S-9 activation (ECHA, 2020m, p, q; Huntingdon Research Center, 1992a). In all four studies, HQ-115 was not found to have potential for mutagenicity in these bacterial systems. A fifth study assessed the mutagenicity of HQ-115 in mouse lymphoma L5178Y cells (ECHA, 2020o). Mouse lymphoma L5178Y cells were exposed to concentrations of HQ-115 ranging from 0.63 to 10 mM for 3 hours or 0.16 to 7.5 mM for 24 hours without activation or 0.63 to 10 mM for 3 hours with S-9 activation. HQ-115 did not show any mutagenic activity in this mammalian cell system.

The ability for HQ-115 to cause CAs was tested in vitro in two studies using human lymphocytes (ECHA, 2020n; Huntingdon Research Center, 1993c) and in a study using Chinese hamster lung fibroblasts (Huntingdon Research Center, 1993b). One study exposed human lymphocytes to concentrations of 156, 625, or 1,250 μg/mL for 18 or 32 hours without S-9 activation, or to concentrations of 625, 2,500, or 5,000 μg/mL for 18 or 32 hours with S-9 activation (Huntingdon Research Center, 1993c). The second study exposed human lymphocytes to concentrations ranging from 2.5 to 10 mM, with and without activation, for 3, 20, or 44 hours (ECHA, 2020n). In both studies, the proportion of aberrant cells was not significantly increased in any of the exposure conditions in comparison to the solvent control, demonstrating that HQ-115 did not have clastogenic activity in this in vitro system.

A CA study was also conducted in Chinese hamster lung fibroblasts (Huntingdon Research Center, 1993b). Chinese hamster lung fibroblasts were exposed to concentrations of 1,250, 2,500, or 5,000 μg/mL HQ-115 for 6 hours with cell collection 18 hours later, with and without S-9 activation. Chinese hamster lung fibroblasts were also exposed to concentrations of 625, 1,250, or 2,500 μg/mL HQ-115 for 24 hours with an immediate cell collection, without S-9 activation, and to concentrations of 1,250, 2,000, or 3,500 μg/mL HQ-115 for 48 hours with an immediate cell collection, without S-9 activation. In the presence of S-9 activation, a significant increase in the proportion of aberrant cells was observed in cells exposed to 5,000 μg/mL HQ-115 for 6 hours. Without S-9 activation, a significant increase in the proportion of aberrant cells was observed in cells exposed to all three concentrations analyzed (≥1,250 μg/mL) for 6 hours, 2,500 μg/mL for 24 hours, and ≥2,000 μg/mL for 48 hours. Additionally, in cells exposed to 3,500 μg/mL for 48 hours without activation, a significant increase in the proportion of polyploidy cells was also observed. These results demonstrate that HQ-115 does have the potential for both clastogenic activity and polyploidy-inducing activity in this in vitro system.

Table 2 Summary of HQ-115 Genotoxicity Data

Endpoint | Test System | Concentrations Tested | Results Without Activation | Results With External Activation | Comments | References
In vitro genotoxicity studies in prokaryotic organisms
Ames Assay (Revertant colonies) | Salmonella typhimurium (TA 98, 100, 1535, 1537, 1538), Escherichia Coli (WP2 uvrA) | 0, 312.5, 625, 1,250, 2,500, 5,000 μg/plate for 3 days with and without activation. | Negative | Negative | No evidence of mutagenicity. | Huntingdon Research Center (1992a)
Ames Assay (Revertant colonies) | Salmonella typhimurium (TA 98, 100, 102, 1535, 1537), Escherichia Coli (WP2 uvrA) | 0, 312.5, 625, 1,250, 2,500, 5,000 μg/plate for 48 to 72 hours with and without activation. | Negative | Negative | No evidence of mutagenicity. | ECHA (2020m)
Ames Assay (Revertant colonies) | Salmonella typhimurium (TA 98, 100) | 0, 21, 62, 185, 556, 1,667 μg/plate for 3 days with and without activation. | Negative | Negative | No evidence of mutagenicity. | ECHA (2020p)
Ames Assay (Revertant colonies) | Salmonella typhimurium (TA 98, 100, 1535, 1537, 1538) | 0, 333, 667, 1,000, 3,330, 6,670, 10,000 μg/plate for 48 hours with and without activation. | Negative | Negative | No evidence of mutagenicity. | ECHA (2020q)
In vitro genotoxicity studies in mammalian cells
Mammalian Cell Gene Mutation | Mouse lymphoma L5178Y cells | 0, 0.63, 1.25, 2.5, 5, 7.5, 10 mM for 3 hours with and without activation; 0, 0.16, 0.31, 0.63, 1.25, 2.5, 7.5 mM for 24 hours without activation. | Negative | Negative | | ECHA (2020o)
Chromosomal Aberration | Human lymphocytes | 0, 2.5, 5, 10 mM for 3 hours without activation; 0, 0.63, 1.25, 2.5 mM for 20 hours; 0, 1.25 mM for 44 hours. 0, 2.5, 5, 10 mM for 20 hours with activation; 0, 10 mM for 44 hours. | Negative | Negative | No evidence of clastogenic effects. | ECHA (2020n)
Chromosomal Aberration | Human lymphocytes | 0, 156, 625, 1,250 μg/mL for 18 or 32 hours without activation; 0, 625, 2,500, 5,000 μg/mL for 18 or 32 hours with activation. | Negative | Negative | No evidence of clastogenic effects. | Huntingdon Research Center (1993c)
Chromosomal Aberration | Chinese hamster lung fibroblasts | 0, 1,250, 2,500, 5,000 μg/mL for 6 hours with or without activation; 0, 625, 1,250, 2,500 μg/mL for 24 hours; 0, 1,250, 2,000, 3,500 μg/mL for 48 hours. | Increase in the proportion of aberrant cells at ≥1,250 μg/mL for ≥6 hours. Increase in the proportion of polyploidy cells at 3,500 μg/mL for 48 hours. | Increase in the proportion of aberrant cells at 5,000 μg/mL for 6 hours. | Evidence of clastogenic and polyploidy-inducing activity. | Huntingdon Research Center (1993b)

### Supporting Animal Toxicity Studies

Other studies identified for HQ-115 included one 7-day range finding study via the oral route with limited utility for informing potential health effects after repeat-dose exposure and three acute studies that assess the toxicity of HQ-115 after a single oral dose. Additionally, three studies that evaluate the toxicity of HQ-115 after a single dermal dose, three studies that evaluate skin irritation/corrosion, three studies assess skin sensitization, and four studies that assess ocular irritation were identified. Data from these studies are summarized below and additional details regarding methods and results are listed in Table 3.

#### Short-term (7-day range finding study)

Huntingdon Research Center (1992b)

Male and female 5-week-old Crl: CD (Sprague-Dawley) BR VAF Plus rats (3/group) were dosed with 0, 10, 30, 50, or 100 mg/kg-day HQ-115 via oral gavage for up to 7 days (Huntingdon Research Center, 1992b). The study was conducted in compliance with GLP standards and evaluated clinical signs, body weights, food intake, organ weights (liver, kidneys, and spleen), and gross pathology. Study confidence was not evaluated since this was a dose-range finding study conducted for only 7 days.

Food consumption was slightly reduced in the females dosed with 50 mg/kg-day HQ-115 and was reduced in both males and females in the 100 mg/kg-day groups. Body weight gains of males and females in the 100 mg/kg-day groups were also lower than controls. There were no mortalities in any of the groups; however, the animals receiving 100 mg/kg-day were sacrificed after the second day of exposure due to severe clinical signs of toxicity. No signs of toxicity were observed in the 10 or 30 mg/kg-day groups. In males and females in the 50 mg/kg-day group, clinical signs of toxicity included high stepping gait, piloerection, and hypersensitivity. In the 100 mg/kg-day group, clinical signs included piloerection, hunched posture, abnormal gait, pallor to the extremities, body tremors, lethargy, and loose feces.

Absolute liver weights increased 14–16% at ≥ 30 mg/kg-day in males and 8–19% at ≥ 30 mg/kg-day in females. There were no changes in spleen or kidney weights and no exposure-related macroscopic findings at necropsy. Due to severe clinical signs of toxicity observed at 100 mg/kg-day, a high dose of 60 mg/kg-day was set for the 28-day exposure study (Huntingdon Research Center, 1993a).

#### Acute Oral Toxicity

There are three single-dose studies available that evaluate the toxicity of HQ-115 after oral exposure in rats (ECHA, 2020e, f, g; 3M, 1988). In one study, five male and five female Sprague-Dawley rats per group were dosed with 50, 500, or 5,000 mg/kg HQ-115 via oral gavage (ECHA, 2020f; 3M, 1988). In the 50 mg/kg group, all animals survived; one animal had diarrhea, and one animal had an enlarged pelvis in the right kidney upon necropsy. No other clinical signs, changes in body weight gain, or gross pathological abnormalities were noted. In the 500 mg/kg group, clinical signs of toxicity included subconvulsive jerking, prostration, dyspnea, hypoactivity, ataxia, stained fur of the face and genitals, and hypersensitivity. Nine of the ten animals died. At necropsy, red areas in the glandular mucosa of the stomach and nasal discharge were noted. In the 5,000 mg/kg group, all the animals died within 15 minutes of dose administration, and necropsy revealed diffusely light testes, red areas in the glandular mucosa of the stomach, tan kidneys, and nasal discharge. The acute oral median lethal dose (LD50) of HQ-115 was calculated by the study authors to be 160 mg/kg (95% confidence interval 40–560 mg/kg) for male Sprague-Dawley rats and 210 mg/kg (95% confidence interval 50–870 mg/kg) for female Sprague-Dawley rats.

A second study dosed three male and three female Sprague-Dawley rats per group with either 25 or 200 mg/kg HQ-115 (ECHA, 2020e). In the 25 mg/kg group, all animals survived, after that dyspnea and piloerection were noted in all males one hour after treatment. In the 200 mg/kg group, 2/3 males died within 4 hours and 15 minutes of exposure, but all females survived. Clinical signs of toxicity included hypoactivity followed by sedation, dyspnea, tonic-clonic convulsions, hypersalivation, and piloerection. No changes in body weight gain or gross pathology were noted. The acute oral LD50 of HQ-115 was estimated by the study authors to be > 200 mg/kg for male and female Sprague-Dawley rats, combined.

The third study dosed three female Wistar rats with 200 mg/kg (ECHA, 2020g). One animal was found dead on the day of dosing. Clinical signs of toxicity included sluggishness, blepharospasm, convulsions, pallor, and coma. No changes in body weight gain were noted. The acute oral LD50 of HQ-115 was estimated by the study authors to be > 200 mg/kg for female Wistar rats.

#### Acute Dermal Toxicity

There are three studies available that evaluate the systemic toxicity of HQ-115 after a single dermal administration of HQ-115 (ECHA, 2020b, c, d). In one study, five male and five female New Zealand White (NZW) rabbits were dermally administered 200, 350, 500, or 2,000 mg/kg HQ-115 (ECHA, 2020b). All animals survived in the 200 mg/kg group, while 2/5 males and 0/5 females died in the 350 mg/kg group, and all animals died in the two highest dose groups. All mortality occurred within two days of dosing. Clinical signs of toxicity included hypoactivity, loss of appetite, staggered gait, subconvulsive jerking, miosis, excessive salivation, aggressive behavior, tremors, prostration, shallow breathing, and clonic convulsions. No effects on body weight were observed. Slight to severe erythema, slight edema and desquamation, subcutaneous hemorrhaging, and possible necrosis were observed at the site of application, but no other changes in gross pathology were noted. The acute dermal LD50 of HQ-115 was calculated by the study authors to be 371 mg/kg (95% confidence interval 254‒542 mg/kg) for male NZW rabbits and 418 mg/kg (95% confidence interval 329‒486 mg/kg) for female NZW rabbits.

In a second study, five male and five female Sprague-Dawley rats were dermally administered 2,000 mg/kg HQ-115 (ECHA, 2020c). All animals survived and no clinical signs were noted; however, a reduction in body weight gain or slight body weight loss was observed in 3/5 females over the 14-day observation period. No cutaneous reactions or changes in gross pathology were observed. The acute dermal LD50 of HQ-115 was estimated by the study authors to be > 2,000 mg/kg for male and female Sprague-Dawley rats.

In the third study, male and female animals were dermally administered HQ-115 under occlusive conditions, and an LD50 was determined (ECHA, 2020d). However, no details were available for the species, number of animals, or doses applied. The acute dermal LD50 of HQ-115 was calculated by the study authors to be 400 mg/kg (95% confidence interval 329−486 mg/kg) for males and females.

#### Acute Skin Irritation/Corrosion

Three studies are available that evaluate the ability for HQ-115 to cause skin irritation and corrosion in NZW rabbits (ECHA, 2020s, t, u). Reversible erythema and no edema were noted in one study using only one female rabbit (ECHA, 2020u), and very slight to severe erythema with slight edema was noted in a second study, which used three male rabbits (ECHA, 2020t). In the third study, irreversible erythema with necrosis and irreversible edema were observed in 3/3 rabbits, and the study concluded that HQ-115 is corrosive to the skin (ECHA, 2020s; 3M, 1988).

#### Skin Sensitization

Three studies are available that evaluate the ability for HQ-115 to cause skin sensitization in guinea pigs (ECHA, 2020v, w, x). Two studies found no evidence of skin sensitization (ECHA, 2020w, x); although one of those studies noted slight skin irritation following the intradermal injection of HQ-115, no response was noted after the initial or challenge dermal applications (ECHA, 2020w). The third study noted discrete to severe erythema, dryness of the skin, edema and/or brownish discoloration of the skin in 19/20 animals after the first challenge with 50% HQ-115, but these effects were only seen in 1/20 animals after a second challenge with 10% HQ-115 (ECHA, 2020v). The study authors concluded that HQ-115 induced delayed contact hypersensitivity in only 5% of guinea pigs.

#### Ocular Irritation

Four studies are available that assess the ability of HQ-115 to cause ocular irritation (ECHA, 2020k, l). One study was an ex vivo study in chicken eyes (ECHA, 2020l). After 10 seconds of exposure to 30 mg of HQ-115, corneal swelling, severe corneal opacity, and severe fluorescein retention indicating epithelial cell damage were observed.

Two studies assessed ocular irritation in NZW rabbits following in vivo exposure to HQ-115 for 72 hours (ECHA, 2020i, k; 3M, 1988). In one study, the eyes of three NZW rabbits were exposed to 90 mg of HQ-115 for 72 hours and observed for irritation for 21 days after exposure (ECHA, 2020k; 3M, 1988). Irreversible corneal opacity and epithelial peeling, iris effects, conjunctival lesions, and chemosis were observed. In the second study, the left eyes of three male NZW rabbits were exposed to 100 mg of HQ-115 for 72 hours and observed for irritation for 22 days after exposure. Very slight to marked chemosis and redness of the conjunctiva were noted, along with a clear to whiteish purulent discharge; some of these effects persisted to the end of the observation period in 2/3 rabbits. Reversible discoloration in the conjunctivae was also observed in two animals, and reversible slight iritis and corneal opacities were observed in all animals.

In a fourth study, HQ-115 was applied to the eyes of three animals; however, information on the sex, species, dose, and duration of the study was not provided (ECHA, 2020j). HQ-115 was found to cause irritation of the conjunctivae, with a mean score of 3/3; chemosis, with a mean score of 3.3/4; corneal opacity, with a mean score of 2–3.3/4; and iris effects, with a mean score of 1/2.

Table 3 Other Supporting Animal Toxicity Studies

Test Type | Materials and Methods | Results | References
Short-term
Short-term range finding | Male and female 5-week-old Crl: CD (Sprague Dawley) BR VAF Plus rats (3/group) were dosed with 0, 10, 30, 50, or 100 mg/kg-day HQ 115 via oral gavage for up to 7 days. The study was conducted in compliance with Good Laboratory Practice (GLP) standards (EPA and OECD) and evaluated clinical signs, body weights, food intake, organ weights (liver, kidneys, and spleen), and gross pathology. | Food consumption was reduced in the females ≥ 50 mg/kg-day and reduced in males at 100 mg/kg-day. Body weight gains reduced in males and females at 100 mg/kg-day. Clinical signs observed at ≥50 mg/kg-day. Rats at 100 mg/kg-day were sacrificed after the second day of exposure due to severe clinical signs of toxicity. Absolute liver weights increased 14–16% at ≥ 30 mg/kg-day in males and 8–19% at ≥ 30 mg/kg-day in females. Due to severe clinical signs of toxicity observed at 100 mg/kg-day, a high dose of 60 mg/kg-day was set for the 28-day exposure study. | ECHA (2020f); Huntingdon Research Center (1992b); 3M (1988)
Mortality following acute oral and dermal exposure
Acute oral mortality | Male and female Sprague-Dawley rats (5/sex/group) were dosed with 50, 500, or 5,000 mg/kg HQ-115. Rats were assessed for mortality, clinical signs, and body weight gain over a period of 2 weeks, and a macroscopic necropsy was performed. | Mortality at ≥500 mg/kg; clinical signs at 500 mg/kg including clonic convulsions, hypoactivity, and hypersensitivity to touch.; Red glandular mucosa of the stomach, nasal discharge, and discoloration of the testes and kidneys. Oral LD50 in males: 160 mg/kg (95% CI 40–560 mg/kg); Oral LD50 in females: 210 mg/kg (95% CI: 50–870 mg/kg). | ECHA (2020f); 3M (1988)
Acute oral mortality | Male and female Sprague-Dawley rats (3/sex/group) were dosed with 25 or 200 mg/kg HQ-115. Rats were assessed for mortality, clinical signs, and body weight gain over a period of 2 weeks, and a macroscopic necropsy was performed. | Mortality at 200 mg/kg; clinical signs at 20 mg/kg including dyspnea and piloerection in 3/3 males; clinical signs at 200 mg/kg including dyspnea, piloerection, hypoactivity and sedation, tonic-clonic convulsions, and hypersalivation in all animals. Oral LD50 > 200 mg/kg. | ECHA (2020e)
Acute oral mortality | Three female Wistar rats were dosed with 200 mg/kg HQ-115. Rats were assessed for mortality, clinical signs, and body weight at an unspecified timepoint. | Mortality; clinical signs including sluggishness, blepharospasm, convulsions, pallor, and/or coma. Oral LD50 > 200 mg/kg. | ECHA (2020g)
Acute dermal toxicity | Male and female NZW rabbits (5/group) were dermally dosed with 200, 350, 500, or 2,000 mg/kg HQ-115 under semi-occlusive conditions. Mortality, clinical signs, body weight, and dermal reactions were assessed over a 2-week observation period, and a macroscopic necropsy was performed. | Mortality at ≥350 mg/kg; clinical signs including hypoactivity, loss of appetite, staggered gait, subconvulsive jerking, miosis, excessive salivation, aggressive behavior, tremors, prostration, shallow breathing, and clonic convulsions. Slight to severe erythema, slight edema and desquamation, subcutaneous hemorrhaging, and possible necrosis. Dermal LD50 in males: 371 mg/kg (95% CI 254–542 mg/kg); Dermal LD50 in females: 418 mg/kg (95% CI: 329–486 mg/kg). | ECHA (2020b)
Acute dermal toxicity | Male and female Sprague-Dawley rats (5/sex) were dermally dosed with 2,000 mg/kg HQ-115 under semi-occlusive conditions. Mortality, clinical signs, body weight, and dermal reactions were assessed over a 2-week observation period, and a macroscopic necropsy was performed. | Reduced body weight gain or slight body weight loss. Dermal LD50 in males and females > 2,000 mg/kg. | ECHA (2020c)
Acute dermal toxicity | Test material was applied under occlusive coverage and LD50 was determined in male and female animals (species and number not specified) | Dermal LD50 in males and females: 400 mg/kg (95% CI: 329–486). No details of the results or observations were reported. | ECHA (2020d)
Other health effects following dermal or ocular exposure
Skin irritation/corrosion | Three NZW rabbits (sex not specified) were dermally dosed with 0.5 mL HQ-115 for 4 hours under semi-occlusive conditions, and the degrees of erythema and edema were assessed using the Draize technique over a 2-week observation period. | Irreversible erythema with necrosis: mean score of 3/4; irreversible edema: mean score of 2.33/4. | ECHA (2020s); 3M (1988)
Skin irritation/corrosion | Three male NZW rabbits were dermally dosed with 500 mg HQ-115 for 4 hours under semi-occlusive conditions, and dermal irritation was evaluated over a period of 2 weeks. | Very slight to severe erythema (grades 1–4), slight edema (grade 2), and skin dryness. | ECHA (2020t)
Skin irritation/corrosion | One female NZW rabbit was dermally dosed with 500 mg HQ-115 for 4 hours under semi-occlusive conditions, and the degrees of erythema and edema were assessed daily for 3 days using the Draize technique. | Reversible erythema: mean score of 0.66/4; edema: mean score of 0/4. | ECHA (2020u)
Skin sensitization | Male and female Hartley guinea pigs (10/sex) were intradermally injected with 0.1% w/w HQ-115 in saline and cutaneously dosed with 50% HQ-115 on day 8 and challenged on day 22 with a cutaneous dose of 50% HQ-115 in saline and again on day 40 with 10% HQ-115 in saline. Animals were assessed for cutaneous reactions, clinical signs, and body weight. | Discrete to severe erythema, dryness of the skin, edema and/or brownish discoloration were observed in 19/20 animals after the first challenge with 50% HQ-115. Discrete erythema, dryness of skin, and brownish area was observed in 1/20 animals after the second challenge with 10% HQ-115. No clinical signs of toxicity or changes in body weight gain were noted. | ECHA (2020v)
Skin sensitization | Female Dunkin-Hartley guinea pigs (10/group) were intradermally injected with 0.5% w/w HQ-115 in water and cutaneously dosed with 20% HQ-115 in water and challenged again after two weeks with a cutaneous dose of either 5% or 10% HQ-115 in water. Animals were assessed for cutaneous reactions, clinical signs, and body weight. | Slight skin irritation following intradermal injection. No dermal responses following the initial topical application or the challenge application. | ECHA (2020w)
Skin sensitization | Five male Dunkin-Hartley guinea pigs were intradermally injected with 0.3% w/w HQ-115 in corn oil, cutaneously dosed with 10% HQ-115 in corn oil one week later and challenged two weeks later with a cutaneous dose of 3% HQ-115 in corn oil. Animals were assessed for cutaneous reactions. | No effects noted. | ECHA (2020x)
Ocular irritation | Ex vivo chicken eyes were exposed to 30 mg HQ-115 for 10 seconds and assessed for corneal effects such as swelling, opacity, and fluorescein retention by damaged epithelial cells. | Increased corneal thickness, severe corneal opacity, and severe fluorescein retention. | ECHA (2020l)
Ocular irritation | Three male NZW rabbits were ocularly administered 100 mg HQ-115 for 72 hours, and the degree of ocular irritation was assessed over a period of 22 days. | Very slight to marked chemosis (grades 1 to 3), very slight to marked redness of the conjunctiva (grades 1 to 3) and a clear to whiteish purulent discharge; irreversible in 2/3 animals. Reversible brownish or whiteish area in the conjunctivae in 2/3 animals; reversible slight iritis (grade 1), reversible slight corneal opacity (grade 1 or 2). | ECHA (2020i)
Ocular irritation | Three NZW rabbits (sex not specified) were ocularly administered 90 mg HQ-115 for 7 hours, and the degree of ocular irritation was assessed using the Draize technique over a period of 3 weeks. | Irreversible corneal opacity: mean score of 2–3/4; irreversible iris effects: mean score of 1/2; irreversible conjunctival lesions: mean score of 3/3; irreversible chemosis: mean score of 3–4/4. | ECHA (2020k); 3M (1988)
Ocular irritation | HQ-115 was applied to the eyes of three animals (sex, species and duration not specified) and ocular irritation was scored for conjunctivae, chemosis, corneal opacity, and iris. | Conjunctivae: mean score of 3/3; chemosis: mean score of 3.3/4; corneal opacity: mean score of 2–3.3/4; iris: mean score of 1/1. | ECHA (2020j)

LD50 = median lethal dose; CI = confidence interval

3 Study authors reported group mean values for "adjusted" (i.e., relative) liver weights but did not provide a measure of variance. Relative liver weights (g/100g) were calculated for the purposes of this assessment using individual animal body weight and absolute liver weight data. One-way ANOVA was used to evaluate differences in mean vales among treatment groups, followed by Holm-Sidak t-tests for pairwise comparisons (control vs treatment groups). Refer to HAWC Huntingdon Research Center (1993a) for additional details.