# METHODS

For this assessment, the general systematic review steps common to other assessments (e.g., in Integrated Risk Information System [IRIS]) were applied, including the development of populations, exposures, comparators, and outcomes (PECO) criteria for inclusion and literature search and screening of multiple databases for relevant articles.

Briefly, methods used here are consistent with the ORD Staff Handbook for Developing IRIS Assessments (Version 2.0, referred to as the “IRIS Handbook”) (U.S. EPA, 2022). These methods were reviewed by the National Academy of Sciences (NASEM, 2021, 2018) and used in other peer-reviewed systematic reviews (Yost et al., 2019; Radke et al., 2018). The purpose of this human health assessment is to develop scientifically supported chronic toxicity values, where data are available. Less emphasis is placed on providing definitive judgments of the integrated weight of evidence.

The systematic review methods used to collect epidemiologic and toxicological evidence for HQ115 (and TFSI) are described in detail in Appendix A. In addition to database searches, nonconfidential business information (non-CBI) industry studies were identified that included toxicological evidence for HQ-115. Since February 2020, EPA has requested, pursuant to section 308 of the Clean Water Act, 33 U.S.C. § 1318, that 3M provide information on its use and possible release of certain PFAS, such as HQ-115. Under that agreement, 3M shared internal files of memos, reports, interim or final data summaries or studies, correspondence, etc. that included non-CBI content for HQ-115. The available information for HQ-115 received from 3M was screened for relevance to the PECO criteria (see Figure 1). Literature identified as relevant from the database searches or non-CBI data repositories underwent data extraction and study evaluation (see documentation in HAWC: https://hawcprd.epa.gov/assessment/100500265/