# INTRODUCTION

Per- and polyfluoroalkyl substances (PFAS) are a large group of anthropogenic chemicals that include the well-known C8 species, perfluorooctanoic acid (PFOA), perfluorooctane sulfonic acid (PFOS), and thousands of other structurally diverse fluorinated species. The universe of environmentally relevant PFAS, including parent chemicals, metabolites, and abiotic degradants, is greater than 12,000 substances.^2^

PFAS have strong, stable carbon-fluorine (C-F) bonds, making them resistant to hydrolysis, photolysis, microbial degradation, and metabolism (Ahrens, 2011; Buck et al., 2011; Beach et al., 2006). The chemical structures of many PFAS make them repel water and oil, remain chemically and thermally stable, and exhibit surfactant properties. These properties make PFAS useful for commercial and industrial applications and purposes, but also make some PFAS persistent in the human body and the environment (Calafat et al., 2019; Calafat et al., 2007). Due to their widespread use, physicochemical properties, persistence, and bioaccumulation potential, many PFAS occur in exposure media (e.g., air, water, sediment), and in tissues and blood of aquatic and terrestrial organisms, and humans.

Humans are widely exposed to PFAS (Sunderland et al., 2019), and PFAS have been shown to pose ecological and human health hazards (Fenton et al., 2021); (DeWitt, 2015); (Hekster et al., 2003); (U.S. EPA, 2021c, d). Most of the available toxicity data, however, are limited to relatively few, well-studied PFAS (e.g., PFOA, PFOS, GenX chemicals, PFBS and others). Most of the PFAS structures listed in EPA’s CompTox Chemicals Dashboard^2^ are data poor, having little to no data that might inform potential hazards to human health. One of these PFAS, lithium bis[(trifluoromethyl)sulfonyl] azanide (HQ-115; CASRN 90076-65-6), or its desalted amide 1,1,1-Trifluoro-N-[(trifluoromethyl)sulfonyl] methanesulfonamide (TFSI; CASRN 82113-65-3), has been detected in surface and waste waters in or around manufacturing facilities. This assessment applies to TFSI, as well as salts (including non-metal or alkali metal salts) that would be expected to fully dissociate in aqueous solutions of pH ranging from 4-9 (e.g., in the human body). The synthesis of evidence and toxicity value derivation presented in this assessment focuses on the forms of HQ-115 with currently available toxicity data. HQ-115 is a short-chain PFAS and is a lithium salt that presents as a white powder. The corresponding desalted amide form of HQ-115, TFSI, is also presented for completeness. The molecular formula and experimental or predicted physical-chemical properties of HQ-115 and TFSI are presented in Table 1.

Table 1 Physical and Chemical Properties of HQ-115 and TFSI

Property or Endpoint (unit) | HQ-115 | TFSI | Reference
Structure | picture of the chemical structure of Lithium bis[(trifluoromethyl)sulfonyl]azanide | Picture of chemical structure of 1,1,1-Trifluoro-N-(trifluoromethanesulfonyl)methanesulfonamide | (U.S. EPA, 2023)
CASRN | 90076-65-6 | 82113-65-3 | (U.S. EPA, 2023)
DTXSID | 8044468 (https://comptox.epa.gov/dashboard/dsstoxdb/results?search=DTXSID8044468) | 2045026 (https://comptox.epa.gov/dashboard/chemical/details/DTXSID2045026) | (U.S. EPA, 2023)
Synonyms | Lithium bis[(trifluoromethyl)sulfonyl]azanide; Lithium bis(trifluoromethanesulfonyl)azanide; Methanesulfonamide, 1,1,1-trifluoro-N-[(trifluoromethyl)sulfonyl]-, lithium salt (1:1); Methanesulfonamide, 1,1,1-trifluoro-N-[(trifluoromethyl)sulfonyl]-, lithium salt; Lithium Trifluoromethanesulfonimide; Fluorad Brand Lithium-; Trifluoromethanesulphonimide HQ-115; Fluorad HQ 115; Fluorinert HQ 115; Fluorinert HQ 115J | 1,1,1-Trifluoro-N-(trifluoromethanesulfonyl)methanesulfonamide; 1,1,1-Trifluoro-N-[(trifluoromethyl)sulfonyl]methanesulfonamide; Methanesulfonamide, 1,1,1-trifluoro-N-[(trifluoromethyl)sulfonyl]- | (U.S. EPA, 2023)
Molecular formula | C_2_F_6_LiNO_4_S_2_ | C_2_HF_6_NO_4_S_2_
Molecular weight (g/mol) | 287.08 | 281.14
Physical description | White powder | – | Huntingdon Research Center (1993d)
Odor | NA | NA
Melting point (°C) | 232.0 – 233.0 (experimental) | 51.5 (experimental) | HQ-115: Huntingdon Research Center (1993d); TFSI: U.S. EPA (2023)
Boiling point (°C) | 308 (predicted average) | 90.5 (experimental) | (U.S. EPA, 2023)
Density (g/cm^3^) | 2.1984 (experimental) | 1.94 (predicted average) | HQ-115: Huntingdon Research Center (1993d); TFSI: (U.S. EPA, 2023)
Vapor pressure (Pa at 25°C) | 4 × 10^−6^ | 0.270 (mmHg) (predicted average) | HQ-115: Huntingdon Research Center (1993d); TFSI: U.S. EPA (2023)
Henry’s law constant | 3.13 × 10^−5^ (predicted average) | 3.13 × 10^−5^ (predicted average) | (U.S. EPA, 2023)
Water solubility (g/L at 20°C) | 1.73 × 10^3^ | 0.931 (mol/L) (predicted average) | HQ-115: Huntingdon Research Center (1993d); TFSI: U.S. EPA (2023)
Log K_ow_ (at 19°C) | −1.46 | 1.96 (predicted average) | HQ-115: Huntingdon Research Center (1993d); TFSI: U.S. EPA (2023)
Bioconcentration factor | 9.23 (predicted average) | 9.23 (predicted average) | (U.S. EPA, 2023)

NA – Not available

2 https://comptox.epa.gov/dashboard/chemical_lists/PFASMASTER