# APPENDIX B BENCHMARK DOSE MODELING RESULTS

## MODELING PROCEDURE FOR CONTINUOUS NONCANCER DATA

Benchmark dose (BMD) modeling of continuous data is conducted with U.S. EPA’s BMDS (Version 3.2). All continuous models available within the software are fit using a BMR of 1 standard deviation (SD) relative risk or 10% extra risk when a biologically determined BMR is available (e.g., BMR 10% relative deviation [RD] for body weight based on a biologically significant weight loss of 10%), as outlined in the Benchmark Dose Technical Guidance (U.S. EPA, 2012). A BMR 10% RD for relative liver weights is considered a minimally biologically significant response in adult animals and was applied in this assessment for BMD modeling purposes. The default BMR of 1 SD was also applied for comparison. An adequate fit is judged based on the χ2 goodness-of-fit p-value (p > 0.1), magnitude of the scaled residuals near the BMR, and visual inspection of the model fit. In addition to these three criteria for judging adequacy of model fit, a determination is made as to whether the variance across dose groups is homogeneous. If a homogeneous variance model is deemed appropriate based on the statistical test provided by BMDS (i.e., Test 2), the final BMD results are estimated from a homogeneous variance model. If the test for homogeneity of variance is rejected (p < 0.1), the model is run again while modeling the variance as a power function of the mean to account for this nonhomogeneous variance. If this nonhomogeneous variance model does not adequately fit the data (i.e., Test 3; p < 0.1), the data set is considered unsuitable for BMD modeling. Among all models providing adequate fit, the lowest BMDL/benchmark concentration lower confidence limit (BMCL) is selected if the BMDL/BMCL estimates from different models vary >threefold; otherwise, the BMDL/BMCL from the model with the lowest AIC is selected as a potential POD from which to derive the oral reference dose or inhalation reference concentration (RfD/RfC).

### Model Predictions for Increased Relative Liver Weight in Male Rats (Huntingdon Research Center, 1993a)

The procedure outlined above for continuous data was applied to the data for increased relative liver weight in adult male Sprague-Dawley rats exposed to HQ-115 for 28-days via gavage (Huntingdon Research Center, 1993a). The BMD modeling results are summarized in Table B-1 and Figure B-1. The constant variance model provided adequate fit to the variance data, and adequate fit to the means was provided by some included models. The BMDLs for the models providing adequate fit are sufficiently close (i.e., differ by <threefold), so the model with the lowest AIC (Exponential 2) is selected. For increased relative liver weight, the BMDL_0.1RD_ of 14 mg/kg-day (BMDL_1SD_ of 7.0 mg/kg-day for comparison) from this model is selected.

Table B-1 BMD Modeling Results for Increased Relative Liver Weight in Adult Male Sprague Dawley Rats Exposed to HQ-115 for 28-days via Gavage^a^

Model | DF | χ2 Goodness-of-Fit p-Value^b^ | Scaled Residual at Dose Nearest BMD | AIC | BMD_0.1RD_ (mg/kg-day) | BMDL_0.1RD_ (mg/kg-day)
Exponential 2 * | 3 | 0.6509146 | −0.637400425 | 19.09914662 | 15.33998 | 13.80754
Exponential 3 | 3 | 0.4840391 | −0.115321927 | 20.73014256 | 20.08106 | 13.91567
Exponential 4 | 2 | 0.2320233 | −0.922398938 | 21.66880815 | 13.15046 | 8.804435
Exponential 5 | 2 | NA | −0.099536679 | 22.75712659 | 19.74813 | 9.771961
Hill | 2 | NA | −6.71756E-08 | 22.89858063 | 10.92925 | 10.13297
Polynomial 3 | 3 | 0.5274632 | −0.082359162 | 20.63966939 | 22.25161 | 11.877
Polynomial 2 | 3 | 0.5128267 | −0.097445089 | 20.66868822 | 20.68894 | 11.86638
Power | 3 | 0.4725079 | −0.101732001 | 20.75649816 | 19.73489 | 11.83528
Linear | 3 | 0.4909204 | −0.920196343 | 19.6633396 | 13.1662 | 11.54847

a Huntingdon Research Center (1993a)

b Values <0.10 fail to meet conventional goodness-of-fit criteria.

* Selected model. Lowest AIC among models with adequate fit was selected (Exponential 2).

AIC = Akaike’s information criterion; BMD = maximum likelihood estimates of the dose associated with the selected BMR; BMDL = 95% lower confidence limit on the BMD (subscripts denote BMR: i.e., 0.1RD = dose associated with 10% relative deviation from the control); BMR = benchmark response; DF = degree(s) of freedom.

Figure B-1 Fit of Exponential 2 Model to Data for Increased Relative Liver Weight in Adult Male Sprague Dawley Rats Exposed to HQ-115 for 28-days via Gavage (Huntingdon Research Center, 1993a)

Frequentist Exponential Degree 2 Model with BMR of 0.1 Rel. Dev. for the BMD and 0.95 Lower Confidence Limit for the BMDL. The x axis was dose beginning at 0 and going up in increments of 10 up to 60. The y axis was response and begins at 0 and goes up in increments of 1 up to 10. estimated probability began at a response of 6 at a dose of 0 and began rising exponentially and ended a response of approximately 8.5 at 60 dose.

BMD Model Output for Figure B-1:

BMD Model Output. BMD=15.33997536. BMDL=13.80753986. BMDU=17.27022042. AIC=19.09914662. Test 4 p-value=0.65091464. D.O.F.=2. # of parameters=3. variable a=5.841243596. variable b=0.006213193. log-alpha=-2.183272059. size 5 with a dose of 0 had an estimated median of 5.841243596, a calculated median 5.83, observed mean 5.83, Calculated standard deviation and observed standard deviation of 0.3, and a scaled residual of -0.074899989. size 5 with a dose of 1.67 had an estimated median of 5.902168062, a calculated median 6, observed mean 6, Calculated standard deviation and observed standard deviation of 0.323, and a scaled residual of 0.651714167. size 5 with a dose of 10 had an estimated median of 6.215683233, a calculated median 6.12, observed mean 6.12, Calculated standard deviation and observed standard deviation of 0.404, and a scaled residual of -0.637400425. size 5 with a dose of 60 had an estimated median of 8.480210881, a calculated median 6.12, observed mean 6.12, Calculated standard deviation and observed standard deviation of 0.427, and a scaled residual of 0.06521089. All doses had a estimated SD of .33566688. Model A1 had a log likelihood of -6.120196542 and 5 parameters and an AIC of 22.2403931. Model A2 had a log likelihood of -5.690398018 and 8 parameters and an AIC of 22.2403931. Model A3 had a log likelihood of -6.120196542 and 5 parameters and an AIC of 22.2403931. The fitted model has a log likelihood of -6.549573308 and 3 parameters and an AIC of 19.0991466. R model has a log likelihood of -30.97718767 and 2 parameters and an AIC of 65.9543753. Test 1 had a -2*log likelihood ratio of 50.57357931 and a test df of 6 and a p-value of <0.0001. Test 2 had a -2*log likelihood ratio of 0.859597047 and a test df of 3 and a p-value of 0.83516537. Test 3 had a -2*log likelihood ratio of 0.859597047 and a test df of 3 and a p-value of 0.83516537. Test 4 had a -2*log likelihood ratio of 0.858753533 and a test df of 2 and a p-value of 0.65091464.

### Model Predictions for Increased Relative Liver Weight in Female Rats (Huntingdon Research Center, 1993a)

The procedure outlined above for continuous data was applied to the data for increased relative liver weight in adult female Sprague-Dawley rats exposed to HQ-115 for 28-days via gavage (Huntingdon Research Center, 1993a). The BMD modeling results are summarized in Table B-2 and Figure B-2. The constant variance model provided adequate fit to the variance data, and adequate fit to the means was provided by some included models. The BMDLs for the models providing adequate fit are sufficiently close (i.e., differ by <threefold), so the model with the lowest AIC (Exponential 2) is selected. For increased relative liver weight, the BMDL_0.1RD_ of 13 mg/kg-day (BMDL_1SD_ of 13 mg/kg-day for comparison) from this model is selected.

Table B-2 BMD Modeling Results for Increased Relative Liver Weight in Adult Female Sprague Dawley Rats Exposed to HQ-115 for 28-days via Gavage^a^

Model | DF | χ2 Goodness-of-Fit p-Value^b^ | Scaled Residual at Dose Nearest BMD | AIC | BMD_0.1RD_ (mg/kg-day) | BMDL_0.1RD_ (mg/kg-day)
Exponential 2 * | 3 | 0.580854184 | −0.229508825 | 39.23315775 | 15.58828354 | 12.8318022
Exponential 3 | 3 | 0.580854184 | −0.229508824 | 39.23315775 | 15.58828354 | 12.90292523
Exponential 4 | 2 | 0.280880663 | −0.395577083 | 41.30947057 | 13.16383839 | 5.076241807
Exponential 5 | 2 | NA | −0.310280854 | 43.28181445 | 14.29707527 | 5.100821344
Hill | 2 | NA | 0.000290368 | 43.47104918 | 10.77030376 | 9.68809745
Polynomial 3 | 3 | 0.301753616 | −0.133487493 | 41.21307494 | 17.64292717 | 10.57351397
Polynomial 2 | 3 | 0.298889025 | −0.153432611 | 41.22579116 | 16.8901062 | 10.56759096
Power | 3 | 0.288011245 | −0.234437131 | 41.2755413 | 15.3631902 | 10.54407169
Linear | 3 | 0.562517519 | −0.376977672 | 39.2973127 | 13.40214729 | 10.53416722

a Huntingdon Research Center (1993a)

b Values <0.10 fail to meet conventional goodness-of-fit criteria.

* Selected model. Lowest AIC among models with adequate fit was selected (Exponential 2).

AIC = Akaike’s information criterion; BMD = maximum likelihood estimates of the dose associated with the selected BMR; BMDL = 95% lower confidence limit on the BMD (subscripts denote BMR: i.e., 0.1RD = dose associated with 10% relative deviation from the control); BMR = benchmark response; DF = degree(s) of freedom.

Figure B-2 Fit of Exponential 2 Model to Data for Increased Relative Liver Weight in Adult Female Sprague Dawley Rats Exposed to HQ-115 for 28-days via Gavage (Huntingdon Research Center, 1993a)

Frequentist Exponential Degree 2 Model with BMR of 0.1 Rel. Dev. for the BMD and 0.95 Lower Confidence Limit for the BMDL. The x-axis is labeled as dose and begins at 0 and goes up in increments of 10 up to 60. The y-axis is labeled as response and begins at 0 and goes up in increments of 1 up to 9. estimated probability begins at a response of 5 and has an exponential curve ending at a response of 7.5 at a dose of 60.

BMD Model Output for Figure B-2:

BMD Model Output. BMD=15.58828354. BMDL=12.8318022. BMDU=19.9271384. AIC=39.23315775. Test 4 p-value=0.580854184. D.O.F.=2. # of parameters=3. variable a=5.076904278. variable b=0.006114221. log-alpha=-1.176219177. size 5 with a dose of 0 had an estimated median of 5.076904278, a calculated median 4.93, observed mean 4.93, Calculated standard deviation and observed standard deviation of 0.248, and a scaled residual of -0.591469281. size 5 with a dose of 1.67 had an estimated median of 5.129008837, a calculated median 5.33, observed mean 5.33, Calculated standard deviation and observed standard deviation of 0.721, and a scaled residual of 0.809235106. size 5 with a dose of 10 had an estimated median of 5.397003515, a calculated median 5.34, observed mean 5.34, Calculated standard deviation and observed standard deviation of 0.519, and a scaled residual of -0.229508825. size 5 with a dose of 60 had an estimated median of 7.326917982, a calculated median 7.33, observed mean 7.33, Calculated standard deviation and observed standard deviation of 0.781, and a scaled residual of 0.012408888. All doses had a estimated SD of .33566688. Model A1 had a log likelihood of -16.07332335 and 5 parameters and an AIC of 42.1466467. Model A2 had a log likelihood of -13.02496418 and 8 parameters and an AIC of 42.0499284. Model A3 had a log likelihood of -16.120196542 and 5 parameters and an AIC of 42.1466467. The fitted model has a log likelihood of -16.161657888 and 3 parameters and an AIC of 39.2331578. R model has a log likelihood of -29.95010849 and 2 parameters and an AIC of 63.900217. Test 1 had a -2*log likelihood ratio of 33.85028862 and a test df of 6 and a p-value of <0.0001. Test 2 had a -2*log likelihood ratio of 6.096718329 and a test df of 3 and a p-value of 0.10699832. Test 3 had a -2*log likelihood ratio of 6.096718329 and a test df of 3 and a p-value of 0.10699832. Test 4 had a -2*log likelihood ratio of 1.086511056 and a test df of 2 and a p-value of 0.58085418.

### Model Predictions for Increased Serum Alkaline Phosphatase (ALP) in Male Rats (Huntingdon Research Center, 1993a)

The procedure outlined above for continuous data was applied to the data for increased serum ALP in adult male Sprague-Dawley rats exposed to HQ-115 for 28-days via gavage (Huntingdon Research Center, 1993a). The BMD modeling results are summarized in Table B-3 and Figure B.3. The constant variance model provided adequate fit to the variance data, and adequate fit to the means was provided by some included models. The BMDLs for the models providing adequate fit are sufficiently close (i.e., differ by <threefold), so the model with the lowest AIC (Polynomial 3) is selected. For increased serum ALP, the BMDL_1SD_ of 20 mg/kg-day from this model is selected.

Table B-3 BMD Modeling Results for Increased Serum ALP in Adult Male Sprague Dawley Rats Exposed to HQ-115 for 28-days via Gavage^a^

Model | DF | χ2 Goodness-of-Fit p-Value^b^ | Scaled Residual at Dose Nearest BMD | AIC | BMD_1SD_ (mg/kg-day) | BMDL_1SD_ (mg/kg-day)
Exponential 2 | 3 | 0.3935975 | −1.116441047 | 225.8345199 | 28.65812 | 20.47051
Exponential 3 | 3 | 0.4277735 | −0.000367753 | 226.5985278 | 54.07861 | 22.10717
Exponential 4 | 2 | 0.1474102 | −1.192086208 | 228.0685144 | 26.60986 | 18.23585
Exponential 5 | 2 | NA | 1.42987E-06 | 228.5985331 | 53.36477 | 20.04494
Hill | 2 | 0.4277784 | −0.638841924 | 226.5985146 | 24.76762 | 10.46479
Polynomial 3 * | 3 | 0.7190527 | 0.003027651 | 224.6293083 | 45.43407 | 20.05904
Polynomial 2 | 3 | 0.6625539 | 0.020226862 | 224.7929738 | 39.54769 | 19.7528
Power | 3 | 0.4277785 | 1.93353E-09 | 226.5985142 | 57.70082 | 20.11989
Linear | 3 | 0.3503375 | −1.191779857 | 226.0673836 | 26.61979 | 17.99996

a Huntingdon Research Center (1993a)

b Values <0.10 fail to meet conventional goodness-of-fit criteria.

* Selected model. Lowest AIC among models with adequate fit was selected (Polynomial 3).

AIC = Akaike’s information criterion; BMD = maximum likelihood estimate of the dose associated with the selected BMR; BMDL = 95% lower confidence limit on the BMD (subscripts denote BMR: i.e., 1SD = dose associated with 1 standard deviation relative risk from the control); BMR = benchmark response; DF = degree(s) of freedom.

Figure B-3 Fit of Polynomial 3 Model to Data for Increased Serum ALP in Adult Female Sprague Dawley Rats Exposed to HQ-115 for 28-days via Gavage (Huntingdon Research Center, 1993a)

Frequentist Polynomial Degree 3 Model with BMR of Std. Dev. for the BMD and 0.95 Lower Confidence Limit for the BMDL. X axis is labeled as Dose and begins at 0 and goes up in increments of 10 up to 60. y axis is labeled as response and begins at 0 and goes up to 700. Estimated probability begin at a response of approximately 370 and rises exponentially ending at approximately 500 at 60.

BMD Model Output for Figure B-3:

BMD=45.4340744. BMDL=20.05903987. BMDU=55.38452434. AIC=224.6293083. Test 4 p-value-0.719052678. D.O.F.=2. there are 5 parameters. variable g=366.1548637. variables beta1 and beta2 are bounded. variable beta3 are .000610036. variable alpha=3273.412651. dose 0 had an estimated median of 366.1548637, a calculated median of 376, an observed mean of 376, a calculated standard deviation of 65.98, an observed standard deviation of 65.98 and a scaled residual of 0.384774566. dose 1.67 had an estimated median of 366.1577049, a calculated median of 373, an observed mean of 373, a calculated standard deviation of 46.5, an observed standard deviation of 46.5 and a scaled residual of 0.267415046. dose 10 had an estimated median of 366.7648992, a calculated median of 350, an observed mean of 350, a calculated standard deviation of 66.56, an observed standard deviation of 66.56 and a scaled residual of 0.655217624. dose 60 had an estimated median of 497. 9225322, a calculated median of 498, an observed mean of 498, a calculated standard deviation of 69.93, an observed standard deviation of 69.93 and a scaled residual of 0.003027651. Model A1 had a log likelihood of 108.9848335 with 5 parameters and an AIC of 227.969667. A2 had a log likelihood of 108.5193477 with 9 parameter and an AIC of 233.038695. A3 had a log likelihood of 108.9848335 with 5 parameters and an AIC of 227.969667. fitted model had a log likelihood of 109.3146542 with 3 parameters and an AIC of 224.629308. r model had a log likelihood of 116.2033758 with 2 parameters and an AIC of 236.406752. Test 1 had a likelihood ratio of 15.3680561, a test df of 6 and a p-value of 0.01757934. Test 2 had a likelihood ratio of .930971534, a test df of 3 and a p-value of 0.81794796. Test 3 had a likelihood ratio of .930971534, a test df of 3 and a p-value of 0.81794796. Test 4 had a likelihood ratio of .659641315, a test df of 2 and a p-value of 0.71905268.

## MODELING PROCEDURE FOR DICHOTOMOUS NONCANCER DATA

The BMD modeling of dichotomous data is conducted with the EPA’s BMDS (Version 3.2). For these data, the Gamma, Logistic, Log-Logistic, Probit, Log-Probit, Hill, Multistage, and Weibull dichotomous models available within the software are fit using a BMR of 10% extra risk for hepatocyte hypertrophy and 1% extra risk for postnatal survival. In general, the BMR should be near the low end of the observable range of increased risk in the study. BMRs that are too low can result in widely disparate BMDL estimates from different models (high model dependence). Adequacy of model fit is judged based on the χ2 goodness-of-fit p-value (p > 0.1), magnitude of scaled residuals (absolute value < 2.0), and visual inspection of the model fit. Among all models providing adequate fit, the BMDL from the model with the lowest AIC is selected as a potential POD, if the BMDLs are sufficiently close (less than approximately threefold); if the BMDLs are not sufficiently close (greater than approximately threefold), model dependence is indicated, and the model with the lowest reliable BMDL is selected.

### Model Predictions for Increased Hepatocyte Hypertrophy in Male Rats (ECHA, 2020r)

The procedure outlined above for dichotomous data was applied to the data for increased hepatocyte hypertrophy in adult male Sprague-Dawley rats exposed to HQ-115 for 29-days via gavage (ECHA, 2020r). The BMD modeling results are summarized in Table B-4 and Figures B-4 and B-5. All models provided adequate fit (p-value >0.10). The BMDLs for the models providing adequate fit are not sufficiently close (i.e., differ by > threefold), so the model with the lowest BMDL (Multistage Degree 1) is typically selected. However, the model fit to the observed data in the lowest dose group is very poor, with the model greatly over-estimating the response (model response ∼ 35% compared to observed response of 0%) (Figure B-4). Further, the scaled residual for the lowest dose group in the Multistage Degree 1 model (∼−1.56) is much larger than other models. Therefore, the results of the Multistage Degree 1 model are discounted and the model with the lowest AIC is selected, in this case the Probit model (see Figure B-5). For increased hepatocyte hypertrophy, the BMDL_10ER_ of 11 mg/kg-day from this model is selected.

Table B-4 BMD Modeling Results for Increased Hepatocyte Hypertrophy in Adult Male Sprague Dawley Rats Exposed to HQ-115 for 29-days via Gavage^a^

Model | DF | χ2 Goodness-of-Fit p-Value^b^ | Scaled Residual at Dose Nearest BMD | AIC | BMD_10ER_ (mg/kg-day) | BMDL_10ER_ (mg/kg-day)
Dichotomous Hill | 1 | 0.9999973 | −1.30663E-06 | 9.004035141 | 36.82923 | 10.74789
Gamma | 1 | 0.9999702 | −0.047769458 | 7.008661768 | 26.92559 | 9.371798
Log-Logistic | 3 | 0.9999583 | −0.000317122 | 9.004191008 | 34.80681 | 10.74744
Multistage 3 | 3 | 0.9592595 | −0.530058626 | 7.574609393 | 18.66666 | 5.174987
Multistage 2 | 3 | 0.8181974 | −0.889461309 | 8.644065015 | 12.70375 | 4.166214
Multistage 1 | 2 | 0.2016205 | −0.00027635 | 14.21740302 | 3.912017 | 2.125352
Weibull | 3 | 0.9996698 | −0.106368736 | 7.026891958 | 28.54683 | 8.493537
Logistic | 3 | 0.9999756 | 2.69659E-05 | 9.004121944 | 36.68174 | 11.57507
Log-Probit | 2 | 0.9999999 | −5.67797E-09 | 9.00402454 | 33.11154 | 10.82091
Probit * | 3 | 1 | 2.12552E-06 | 7.004025481 | 34.38414 | 10.71614

a ECHA (2020r)

b Values <0.10 fail to meet conventional goodness-of-fit criteria.

* Selected model. Lowest AIC among models with adequate fit was selected (Probit).

AIC = Akaike’s information criterion; ALP = alkaline phosphatase; BMD = maximum likelihood estimate of the dose associated with the selected BMR; BMDL = 95% lower confidence limit on the BMD (subscripts denote BMR: i.e., 10ER = dose associated with 10% extra risk from the control); BMR = benchmark response; DF = degree(s) of freedom.

Figure B-4 Fit of Multistage Degree 1 Model to Data for Increased Hepatocyte Hypertrophy in Adult Male Sprague Dawley Rats Exposed to HQ-115 for 29-days via Gavage (ECHA, 2020r)

Frequentist Multistage Degree 1 Model with BMR of 10% Extra Risk for the BMD and 0.95 Lower Confidence Limit for the BMDL. X axis is labeled as Dose and begins at 0 and goes up in increments of 10 up to 90. Y axis is labeled as Response and begins at 0 and goes up in increments of .1 up to 1. Estimated probability begins at 0 for dose and response and increases gradually and ends at approximately .9 at a dose of 90.

Figure B-5 Fit of Probit Model to Data for Increased Hepatocyte Hypertrophy in Adult Male Sprague Dawley Rats Exposed to HQ-115 for 29-days via Gavage

Frequentist Probit Model with BMR of 10% Extra Risk for the BMD and 0.95 Lower Confidence Limit for the BMDL. The x axis was labeled as dose beginning at 0 and going up in increments of 10 up to 90. The y-axis was labeled as response and began at 0 and went up in increments of 0.1 up to 1. Estimated probability begins at a dose and response of 0 and stays at 0 until a dose of approximately 30 where the response begins to sharply rise to 1 at a dose of 50 before leveling out for the rest of the doses.

BMD Model Output for Figure B-5:

BMD Model Output. BMD=34.3841428.. BMDL=10.71614352. BMDU=39.2848155. AIC=7.004025481. p-value=1. D.O.F.=3. Chi squared= 6.22743E-07. # of parameters=2. variable a=-8.158380125. variable b=bounded. size 5 with a dose of 0 had an estimated probability of 1.69774E-16, an expected of 8.48869E-16. observed is 0. a scaled residual of -2.914E-08. size 5 with a dose of 15 had an estimated probability of 1.24548E-07, an expected of 6.22739E-07, observed of 4, and a scaled residual of -0.0007891. size 5 with a dose of 45 had an estimated probability of 0.79999962, an expected of 3.999998099, observed of 4, and a scaled residual of -2.126E-06. size 5 with a dose of 90 had an estimated probability of 1, an expected of 5, and observed of 5 and a scaled residual of 0. All doses had a estimated SD of .33566688. Model A1 had a log likelihood of -6.120196542 and 5 parameters and an AIC of 22.2403931. Model A2 had a log likelihood of -5.690398018 and 8 parameters and an AIC of 22.2403931. Model A3 had a log likelihood of -6.120196542 and 5 parameters and an AIC of 22.2403931. The fitted model has a log likelihood of -6.549573308 and 3 parameters and an AIC of 19.0991466. R model has a log likelihood of -30.97718767 and 2 parameters and an AIC of 65.9543753. Test 1 had a -2*log likelihood ratio of 50.57357931 and a test df of 6 and a p-value of <0.0001. Test 2 had a -2*log likelihood ratio of 0.859597047 and a test df of 3 and a p-value of 0.83516537. Test 3 had a -2*log likelihood ratio of 0.859597047 and a test df of 3 and a p-value of 0.83516537. Test 4 had a -2*log likelihood ratio of 0.858753533 and a test df of 2 and a p-value of 0.65091464.

### Model Predictions for Decreased Survival of Offspring at PND4 (ECHA, 2020h, y)

The procedure outlined above for dichotomous data was applied to the data for decreased survival of offspring at PND4 in Sprague-Dawley rats exposed to HQ-115 via gavage for 2 weeks before mating, during mating, and until lactational day 4 (ECHA, 2020h); (ECHA, 2020y). The total number of pups (N) in each dose group was estimated from the mean number of pups/litter and the number of pregnancies (14.1 × 10 = 141 in the control group; 15.2 × 10 = 152 at 15 mg/kg-day; 13.3 × 9 = 120 pups at 30 mg/kg-day) (see Table B-5). The (ECHA, 2020h) (ECHA, 2020y) report did not provide the mean number of fetuses/litter at 60 mg/kg-day, although mortality was reported at 100% for this group; therefore, the data was modeled without the highest dose group. The EPA’s Benchmark Dose Technical Guidance (U.S. EPA, 2012) document allows for data to be adjusted by eliminating the high-dose group. Because the focus of BMD analysis is on the low-dose regions of the response curve, elimination of the high-dose group is deemed reasonable. Incidences of PND4 survival were estimated from the reported litter means and viability indices (95.7%, 79.6% and 47.5% for the control, 15 mg/kg-day and 30 mg/kg-day groups, respectively). Viability indices were multiplied times total number of pups born to calculate the number of pups died on PND4. The data were modeled with standard BMDS 3.2 dichotomous models after adjusting for litter effects using a Rao-Scott transformation. Normally, individual animal data are necessary to account for intralitter correlation present in nested developmental toxicity data (i.e., the observation that pups from one litter are more likely to respond like one another compared to pups from another litter). But in this situation, litter level data was not available and instead an approximate approach was used. Briefly, the numbers of offspring survival were scaled by a design effect in order to approximate the true variance of the clustered data. This transformation is called the Rao-Scott transformation and has been shown to reasonably approximate the variance due to clustering and intralitter correlation in developmental toxicity data (Fox et al., 2016). Details of the Rao-Scott transformation are shown in Table B-5. The BMD modeling results are summarized in Table B-6 and Figure B-6.

Given that the offspring survival data only had three dose groups after dropping the high dose, only models with two parameters (Multistage degree 1, Logistic, and Probit) were used to model the data. All the models fit to the data provided an adequate fit (p-value <0.1). The BMDLs for the models providing adequate fit are not sufficiently close (i.e., differ by > threefold), so the model with the lowest BMDL (Multistage Degree 1) is selected. Therefore, for decreased PND4 offspring survival, the BMDL_1ER_ of 0.39 mg/kg-day from this model is selected.

Table B-5 PND4 Offspring Survival Data Selected for Dose-Response Modeling for HQ-115^a^

Dose^b^ | N | Incidence | Percent Survival | Average Design Effect^c^ | RS -N^d^ | RS-Incidence^d^
0 | 141 | 6 | 0.04255 | 2.039078599 | 69.15 | 2.94
15 | 152 | 31 | 0.20395 | 3.531493605 | 43.04 | 8.78
30 | 120 | 63 | 0.525 | 4.921092443 | 24.38 | 12.80

Data highlighted in gray was used for dose-response modeling for HQ-115

a ECHA (2020h, 2020y)

b The high-dose group was eliminated when modeling the offspring survival data because the ECHA (2020h, 2020y) report did not provide the number of pups/litter in this group to estimate the N and survival incidence.

c Average design effect is the average of least squares regression and orthogonal regression design effects (Fox et al., 2016).

d The Rao-Scott transformation (RS) entails dividing the PND4 offspring survival incidence and N by a design effect to approximate the true variance in the clustered data.

Table B-6 BMD Modeling Results for Decreased Survival of Offspring at PND4 Exposed to HQ-115 via Gavage^a^

Model | DF | χ2 Goodness-of-Fit p-Value^b^ | Scaled Residual for Dose Group near BMD | AIC | BMD | BMDL_1ER_
Multistage Degree 1 * | 2 | 0.3065854 | 0.118017736 | 107.2412552 | 0.565085 | 0.388646
Logistic | 2 | 0.8030267 | −0.149037404 | 105.683223 | 1.866252 | 1.26928
Probit | 2 | 0.9943732 | −0.003702164 | 105.6055555 | 1.632659 | 1.125964

a (ECHA, 2020h); ECHA (2020y)

b Values <0.10 fail to meet conventional goodness-of-fit criteria.

* Selected model. Lowest BMDL among models with adequate fit was selected (Multistage 1).

AIC = Akaike’s information criterion; ALP = alkaline phosphatase; BMD = maximum likelihood estimate of the dose associated with the selected BMR; BMDL = 95% lower confidence limit on the BMD (subscripts denote BMR: i.e., 0.01ER = dose associated with 1% extra risk from the control); BMR = benchmark response; DF = degree(s) of freedom.

Figure B-6 Fit of Multistage Degree 1 Model to Data for Decreased Survival of Offspring at PND4s Exposed to HQ-115 via Gavage (ECHA, 2020h), (ECHA, 2020y)

Frequentist Multistage Degree 1 Model with BMR of 1% Extra Risk for the BMD and 0.95 Lower Confidence Limit for the BMDL. The x axis is labeled as Dose and begins at a 0 and goes up in increments of 5 and ends at 30. The y axis is labeled as Response and begins at 0 and goes up in increments of 0.1 up to 1. The Estimated Probability began at approximately 0 for both response and dose and rose exponentially ending at a response of approximately 0.4 at a dose of 30.

BMD Model Output for Figure B-6:

BMD=0.56085113. BMDL=0.388646102. BMDU=0.894064467. AIC= 107.2412552. P-value-0.306585438. D.O.F=1. Chi squared=1.045328481. Slope factor=0.025730349. 2 parameters. variable = estimated 0.03968888. variable bl= estimated 0.017785533. dose 0 has an estimated probability of 0.03968888. Expected=2.744486032. Observed=2.94. size=69.15. scaled residual=0.11801774. dose 15 has an estimated probability of 0.264556061. expected=11.38649288. Observed=8.78. size=43.04. scaled residual=-0.7724343. dose 30 had an estimated probability of 0.436768173. expected probability of 10.64840806. observed=12.8. size=24.38. scaled residual=0.65935236. full model had a log likelihood of -50.80274538 with 3 parameters. fitted model had a log likelihood of -51.62062761 with 2 parameters, a deviance of 1.635764444, a test d.f. of 1 and a p-value of 0.2009076. reduced model had a log likelihood of -64.28318787 with 3 parameters, a deviance of 25.32512054, a test d.f. of 2 and a p-value of <0.0001.