# APPENDIX A ASYSTEMATIC LITERATURE SEARCH METHODS AND RESULTS

## Methods

The following describes the systematic review methods used to collect available epidemiologic and toxicological data for Lithium bis[(trifluoromethyl)sulfonyl]azanide (HQ-115) and 1,1,1-Trifluoro-N-[(trifluoromethyl)sulfonyl]methanesulfonamide (TFSI). The methods used here are consistent with the ORD Staff Handbook for Developing Integrated Risk Information System Assessments (Version 2.0, referred to as the draft “IRIS Handbook”) (U.S. EPA, 2022).

### Populations, Exposures, Comparators, and Outcomes (PECO) Criteria and Supplemental Material Tagging

PECO criteria are used to focus the scope of an evidence map or systematic review by defining the research question(s), search terms, and inclusion/exclusion criteria. The PECO criteria for HQ-115 is presented in Table A-1. In addition to PECO-relevant studies, studies that did not meet PECO criteria but contained “potentially relevant” supplemental material were tracked during the literature screening process. Supplemental material was tagged by category, as outlined in Table A-2. Note that “supplemental” material does not refer to findings contained in the supplement of papers identified.

### Literature Search and Screening Strategies

#### Database Search Term Development

The databases listed below were searched for literature containing the chemical search terms. Full details of the search strategy (including the search strings) for each database are presented in detail in EPA’s Health and Environmental Research Online (HERO) database (https://heronet.epa.gov/heronet/index.cfm/project/page/project_id/3044). The HERO database (https://hero.epa.gov/) is used to provide access to the scientific literature used in EPA’s science assessments, including this effort.

- PubMed (National Library of Medicine)
- Web of Science (WOS, Thomson Reuters)

The literature search for HQ-115 and TFSI focused on the chemical name (and synonyms or trade names) with no additional limits. Chemical synonyms were identified by using synonyms in the Dashboard (U.S. EPA, 2021a). The preferred chemical name (as presented in the Dashboard), Chemical Abstract Services Registry Number (CASRN), and synonyms were then shared with EPA information specialists who used these inputs to develop search strategies tailored for PubMed, and WOS.

#### Database Searches

The database searches were conducted by an EPA information specialist in August 2021 and updated in November 2022. All records were stored in EPA’s HERO database. References were deduplicated in HERO by an EPA information specialist using unique identifiers (e.g., PMID, WOSID, or DOI) and reference information (Title, Author, Year, Journal, etc). Following deduplication, SWIFT-Review software (Sciome, 2023; Howard et al., 2016) was used to identify which of the unique references were most relevant for human health risk assessment. In brief, SWIFT-Review was used to+ filter the unique references based on the software’s preset literature search strategies (titled “evidence stream”). These evidence streams were developed by information specialists and can be used to separate the references most relevant to human health from those that are not (e.g., environmental fate studies). References are tagged to a specific evidence stream if the search terms from that evidence stream appear in the title, abstract, keyword, and/or medical subject headings (MeSH) fields of that reference. For this assessment, the following SWIFT-Review evidence stream filters were applied: human, animal models for human health, and in vitro studies. Specific details on the evidence stream search strategies are available through Sciome’s SWIFT-Review documentation at https://www.sciome.com/wp-content/uploads/2019/08/SWIFT-Review-Search-Strategies-Evidence-Stream.docx. Studies not retrieved using the search strategies were not considered further

#### Other Resources Consulted

The literature search strategies described above are designed to be broad, but like any search strategy, studies may be missed (e.g., cases where the specific chemical is not mentioned in title, abstract, or keyword content; “grey” literature that is not indexed in the databases listed above). Additionally, if incomplete citation information was provided (e.g., if reference lists searched did not include titles) no additional searching was conducted. Thus, in addition to the databases identified above, the sources below were used to identify studies that may have been missed during the database search:

- The Endocrine Disruptor Exchange (TEDX).https://pfastoxdatabase.org/
- National Toxicology Program (NTP) database of Chemical Effects in Biological Systems (CEBS). https://cebs.niehs.nih.gov/cebs/
- References from EPA’s CompTox Chemicals Dashboard ToxValDB (Toxicity Values Database) (U.S. EPA, 2018) to identify studies or assessments that present point of departure (POD) information. ToxValDB collates publicly available toxicity dose-effect related summary values typically used in risk assessments. Many of the PODs presented in ToxValDB are based on grey literature studies or assessments not available in databases such as PubMed, Web of Science (WoS), etc. It is important to note that ToxValDB entries have not undergone quality control to ensure accuracy or completeness and may not include recent studies.
  ○ ToxValDB includes POD data collected from data sources within ACToR (Aggregated Computational Toxicology Resource) and ToxRefDB (Toxicity Reference Database) and no-observed and lowest-observed (adverse) effect level (NOEL, NOAEL, LOEL, LOAEL) data extracted from repeated dose toxicity studies submitted under REACH (Registration, Evaluation, Authorisation and Restriction of Chemicals). Also included are reference dose and concentration values (RfDs and RfCs) from EPA’s Integrated Risk Information System (IRIS) and dose descriptors from EPA’s Provisional Peer-Reviewed Toxicity Values (PPRTV) documents. Acute toxicity information in ToxValDB comes from several sources, including Organization for Economic Cooperation and Development (OECD) eChemPortal, National Library of Medicine (NLM), Hazardous Substances Data Bank (HDSB), ChemIDplus via EPA Toxicity Estimation Software Tool (TEST), and the European Union (EU) Joint Research Centre (JRC) AcutoxBase and the EU COSMOS project and the European Chemicals Agency (ECHA) registration dossiers to identify data submitted by registrants, available at http://echa.europa.eu/information-on-chemicals/information-from-existing-substances-regulation. (ECHA, 2020)
- European Chemicals Agency (ECHA) registration dossiers to identify data submitted by registrants, available at http://echa.europa.eu/information-on-chemicals/information-from-existing-substances-regulation. (ECHA, 2020a).

Each grey literature source was searched using specific identifiers required by the source (CASRN or DSSTox substance identifier (DTXSID)). If no results were retrieved using these identifiers, HQ-115 was searched on the chemical name if allowed by the source, no additional limits were used. Chemical identifiers for the chemical were identified through searching by chemical name, CASRN or DTXSID in the Dashboard (U.S. EPA, 2021a).

#### Screening and Tagging Process

The studies identified from the database searches were imported into DistillerSR (Evidence Partners, 2022) for title or abstract (TIAB) and full text screening. DistillerSR is a web-based collaborative software application to track literature and screening responses from two independent reviewers; each reviewer screens each title and abstract or full text to identify references as meeting PECO criteria, containing potentially supplemental content and what type of supplemental content, as well as references that do not meet PECO criteria or do not contain supplemental information. Supplemental content tags are described in Table A-2. References were first screened for PECO criteria at the DistillerSR TIAB level, then any references potentially meeting PECO again by reviewing the full text of the reference. If PECO relevance was unclear at the TIAB level, screeners erred on inclusion and moved those references forward to full text screening. Conflicts between the independent reviewers were resolved by discussion.

Declassified CBI studies obtained were title or abstract (TIAB) and full text screened for meeting PECO criteria, containing potentially supplemental content and what type of supplemental content, as well as references that do not meet PECO criteria or do not contain supplemental information.

No human epidemiological studies were identified as PECO relevant or supplemental. Animal studies that met PECO criteria after full-text review and were repeat dose studies of 21-day and longer durations, or with study designs focusing on exposure windows targeting reproduction or development, were prioritized for evaluation and extraction. Studies meeting these exposure timing and duration parameters were moved forward for study evaluation (described in next section) and endpoint level data extraction. All other animal studies identified as PECO relevant or supplemental were not evaluated or extracted, but methods and results (if reported) were summarized in this assessment document.

### Data Extraction of Study Methods and Findings

Data extraction was conducted for prioritized animal toxicology studies by two members of the evaluation team using EPA’s version of Health Assessment Workspace Collaborative (HAWC) (U.S. EPA, 2021b), a free and open source web-based software application designed to manage and facilitate the process of conducting literature assessments. Data extracted included basic study information (e.g., full citation, funding, author-reported conflicts of interest); experiment details (e.g., study type, chemical name, chemical source, and purity); animal group specifics (species, strain, sex, age at exposure and assessment, husbandry); dosing regimen; endpoints evaluated; and results (qualitative or quantitative) by endpoint. No attempts were made to contact authors for information that was not reported in a study. Data extraction was performed by one member of the evaluation team (primary extractor) and checked by a second member for completeness and accuracy (secondary extractor). Data extraction results were used to create HAWC visualizations to highlight observed effects that informed the assessment. The detailed HAWC extraction for animal studies are available for download from EPA HAWC in Excel format at https://hawc.epa.gov/assessment/public/ (U.S. EPA, 2020).

Subsequent to HAWC data extraction, a toxicologist reviewed each study to identify study level no observed adverse effect levels [NOAELs] and lowest observed adverse effect levels [LOAELs]. These judgements were made at the individual study level.

### Study Evaluation

Study evaluation was conducted for prioritized animal toxicology studies (≥21 day exposure durations or exposure occurring during reproduction or development) by two reviewers using EPA’s version of HAWC (U.S. EPA, 2021b). Reviews were made by toxicologists with multiple years of experience in developing chemical human health assessments. During study evaluation, in each evaluation domain, at least two reviewers reached a consensus rating of Good, Adequate, Deficient, Not Reported or Critically Deficient as defined in HAWC. Key concerns were potential sources of bias (factors that could systematically affect the magnitude or direction of an effect in either direction) or insensitivity (factors that limit the ability of a study to detect a true effect). Core and prompting questions used to guide the judgment for each domain are described in more detail in the IRIS Handbook (U.S. EPA, 2022). No attempts were made to contact authors for information that was not reported in a study. Once the evaluation domains were rated, the identified strengths and limitations were considered to reach an overall study confidence rating of High, Medium, Low, or Uninformative for a specific health outcome. The ratings, which reflect a consensus judgment between reviewers, are defined as follows:

- High: A well-conducted study with no notable deficiencies or concerns identified for the outcome(s) of interest; the potential for bias is unlikely or minimal, and the study used sensitive methodology. “High” confidence studies generally reflect judgments of good across all or most evaluation domains.
- Medium: A study where some deficiencies or concerns were noted for the outcome(s) of interest, but the limitations are unlikely to be of a notable degree. Generally, “medium” confidence studies will include adequate or good judgments across most domains, with the impact of any identified limitation not being judged as severe.
- Low: A study where one or more deficiencies or concerns were noted for the outcome(s) of interest, and the potential for bias or inadequate sensitivity could have a significant impact on the study results or their interpretation. Typically, “low” confidence studies would have a deficient evaluation for one or more domains, although some “medium” confidence studies may have a deficient rating in domain(s) considered to have less influence on the magnitude or direction of the results. Generally, in an assessment context (or a full systematic review), low confidence results are given less weight compared to high or medium confidence results during evidence synthesis and integration and are generally not used as the primary sources of information for hazard identification or derivation of toxicity values unless they are the only studies available. Studies rated as “low” confidence only because of sensitivity concerns about biases towards the null would require additional consideration during evidence synthesis.
- Uninformative: A study where serious flaw(s) make the results unusable for informing hazard identification for the outcome(s) of interest. Studies with critically deficient judgments in any evaluation domain will almost always be classified as “uninformative” (see explanation above). Studies with multiple deficient judgments across domains may also be considered “uninformative.” As mentioned above, although outside the scope of this assessment, in an assessment or full systematic review uninformative studies would not be considered during the synthesis and integration of evidence for hazard identification or for dose response but might be used to highlight possible research gaps. Thus, data from studies deemed uninformative are not depicted in the results displays included in this assessment.

Rationales for each study evaluation classification, including a brief description of any identified strengths and/or limitations from the domains and their potential impact on the overall confidence determination, are documented and retrievable in HAWC, https://hawc.epa.gov/.

Table A-1 PECO Criteria

PECO element | Description
[underlined: P]opulations | Human: Any population and life stage (occupational or general population, including children and other potentially sensitive populations).; Animal: Nonhuman mammalian animal species (whole organism) of any lifestage (including preconception, in utero, lactation, peripubertal, and adult stages).
[underlined: E]xposures | Two relevant forms:; 1 HQ-115, LiTFSI, lithium bis[(trifluoromethyl)sulfonyl]azanide, Methanesulfonamide, 1,1,1-trifluoro-N-[(trifluoromethyl)sulfonyl]-, lithium salt (1:1), Fluorad HO 115, or any other synonyms found on the CompTox Dashboard page (https://comptox.epa.gov/dashboard/dsstoxdb/results?search=DTXSID8044468#synonyms).; 2 1,1,1-Trifluoro-N-[(trifluoromethyl)sulfonyl]methanesulfonamide, HNTf2, or any other synonyms found on the CompTox Dashboard page (https://comptox.epa.gov/dashboard/dsstoxdb/results?search=DTXSID2045026).; Human: Any exposure to via the oral and inhalation routes. Studies will also be included if biomarkers of HQ-115 exposure are evaluated (e.g., measured HQ-115 in tissues or bodily fluids) but the exposure route is unclear or reflects multiple routes. Other exposure routes, including dermal will be tracked during title and abstract screening and tagged as potentially relevant supplemental information.; Animal: Any exposure via the oral and inhalation routes. Studies involving exposures to mixtures will be included only if they include an arm with exposure to a HQ-115 alone. Other exposure routes, including dermal or injection, will be tracked during title and abstract screening and tagged as potentially relevant supplemental information.
[underlined: C]omparators | Human: A comparison or referent population exposed to lower levels (or no exposure/exposure below detection limits) of HQ-115, or exposure to HQ-115 for shorter periods of time. However, worker surveillance studies are considered to meet PECO criteria even if no referent group is presented. Case reports describing findings in 1–3 people in non-occupational or occupational settings will be tracked as potentially relevant supplemental information.; Animal: A concurrent control group exposed to vehicle only treatment and/or untreated control (control could be a baseline measurement). Acute toxicity studies without a control group are considered to meet PECO criteria if the outcome is mortality and the baseline of alive can be used as the comparator.
[underlined: O]utcomes | All health outcomes (cancer and noncancer).

Table A-2 Major categories of potentially relevant supplemental material

Category | Description
In vitro, ex vivo, or in silico “mechanistic” studies | In vitro, ex vivo, or in silico studies reporting measurements related to a health outcome that inform the biological or chemical events associated with phenotypic effects, in both mammalian and non-mammalian model systems.
Absorption, Distribution, Metabolism, and Excretion (ADME) | ADME studies are primarily controlled experiments where defined exposures usually occur by intravenous, oral, inhalation, or dermal routes, and the concentration of particles, a chemical, or its metabolites in blood or serum, other body tissues, or excreta are then measured. These data are used to estimate the amount absorbed (A), distributed to different organs (D), metabolized (M), and/or excreted/eliminated (E) through urine, breathe, feces, etc.; - ADME data can also be collected from human subjects who have had environmental or workplace exposures that are not quantified or fully defined. However, to be useful such data must involve either repeated measurements over a time-period when exposure is known (e.g., is zero because previous exposure ended) *or* time- and subject-matched tissue or excreta concentrations (e.g., plasma and urine, or maternal and cord blood).; - ADME data, especially metabolism and tissue partition coefficient information, can be generated using in vitro model systems. Although in vitro data may not be as definitive as in vivo data, these studies should also be tracked as ADME. For large evidence bases it may be appropriate to separately track the in vitro ADME studies.; *Studies describing environmental fate and transport or metabolism in bacteria are not tagged as ADME.
Classical Pharmacokinetic (PK) Model Studies, or Physiologically based Pharmacokinetic (PBPK) Model studies | [underlined: Classical PK or Dosimetry Model Studies]: Classical PK or dosimetry modeling usually divides the body into just one or two compartments, which are not specified by physiology, where movement of a chemical into, between, and out of the compartments is quantified empirically by fitting model parameters to ADME data.; [underlined: PBPK or Mechanistic Dosimetry Model Studies:] PBPK models represent the body as various compartments (e.g., liver, lung, slowly perfused tissue, richly perfused tissue) in order to quantify the movement of chemicals or particles into and out of the body (compartments) by defined routes of exposure, metabolism and elimination, and thereby estimate concentrations in blood or target tissues.
Non-mammalian model systems | Studies in non-mammalian model systems, e.g., Xenopus, fish, birds, C. elegans.
Transgenic mammalian model systems | Transgenic studies in mammalian model systems.
Non-oral or non-inhalation routes of administration | Studies in which humans or animals (whole organism) were exposed via a non-oral or non-inhalation route (e.g., injection, dermal exposure).
Exposure characteristics (no health outcome assessment) | Exposure characteristic studies include data that are unrelated to health outcomes, but which provide information on exposure sources or measurement properties of the environmental agent (e.g., demonstrate a biomarker of exposure).
Mixture studies | Mixture studies that are not considered PECO-relevant because they do not contain an exposure or treatment group assessing only the chemical of interest. This category is generally used for experimental studies and generally does not apply to epidemiological studies where the exposure source may be unclear.
Case reports | Case reports describing health outcomes after exposure will be tracked as potentially relevant supplemental information when the number of subjects is ≤ 3.
Records with no original data | Records that do not contain original data, such as other agency assessments, informative scientific literature reviews, editorials, or commentaries.
Conference abstracts | Records that do not contain sufficient documentation to support study evaluation and data extraction.
Republished PECO relevant data | PECO relevant publications that report on the same study as another PECO relevant reference. For example, ECHA dossiers and industry correspondence letters that report data from the same single study.