# COMMONLY USED ABBREVIATIONS AND ACRONYMS

AIC: Akaike’s information criterion
ALP: alkaline phosphatase
ALT: alanine aminotransferase
AST: aspartate aminotransferase
BMCL: benchmark concentration lower confidence limit
BMD: benchmark dose
BMDL: benchmark dose lower confidence limit
BMDS: Benchmark Dose Software
BMR: benchmark response
BW: body weight
CASRN: Chemical Abstracts Service registry number
CBI: nonconfidential business information
CERI: Chemicals Evaluation and Research Institute
CPHEA: Center for Public Health and Environmental Assessment
DTXSID: DSSTox substance identifier
EPA: Environmental Protection Agency
FT3: free triiodothyronine
FT4: free thyroxine
GGT: γ-glutamyl transferase
GLP: Good Laboratory Practice
HbA1c: form of hemoglobin linked to sugar
HED: human equivalent dose
HERO: Health and Environmental Research Online
IRIS: Integrated Risk Information System
LOAEL: lowest-observed-adverse-effect level
NLM: National Library of Medicine
NOAEL: no-observed-adverse-effect level
NTP: National Toxicology Program
OECD: Organization for Economic Cooperation and Development
ORD: Office of Research and Development
PBPK: physiologically based pharmacokinetic
PECO: populations, exposures, comparators, and outcomes
PFAS: per- and polyfluoroalkyl substances
PFOA: perfluorooctanoic acid
PFOS: perfluorooctane sulfonic acid
PFPrA: perfluoropropanoic acid
POD: point of departure
POD_HED_: human equivalent
QA: quality assurance
RD: relative deviation
RfC: inhalation reference concentration
RfD: oral reference dose
SD: standard deviation
TGAb: thyroglobulin antibody
TIAB: title or abstract
TMAb: thyroid microsomal antibody
TSH: thyroid stimulating hormone
UF: uncertainty factor
UF_A_: interspecies uncertainty factor
UF_C_: composite uncertainty factor
UF_D_: database uncertainty factor
UF_H_: intraspecies uncertainty factor
UF_L_: LOAEL-to-NOAEL uncertainty factor UF_S_ subchronic-to-chronic uncertainty factor
U.S.: United States of America
WoS: Web of Science