# REFERENCES

AAPD (American Academy of Pediatric Dentistry). (2020). Perinatal and infant oral health care. In The reference manual of pediatric dentistry. Chicago, IL. https://www.aapd.org/globalassets/media/policies_guidelines/bp_perinataloralhealthcare.pdf.
Abdelouahab, N; Ainmelk, Y; Takser, L. (2011). Polybrominated diphenyl ethers and sperm quality. Reprod Toxicol 31: 546–550. 10.1016/j.reprotox.2011.02.005.21338668
Abdelouahab, N; Langlois, MF; Lavoie, L; Corbin, F; Pasquier, JC; Takser, L. (2013). Maternal and cord-blood thyroid hormone levels and exposure to polybrominated diphenyl ethers and polychlorinated biphenyls during early pregnancy. Am J Epidemiol 178: 701–713. 10.1093/aje/kwt141.23924579
Abellan, A; Sunyer, J; Garcia-Esteban, R; Basterrechea, M; Duarte-Salles, T; Ferrero, A; Garcia-Aymerich, J; Gascon, M; Grimalt, JO; Lopez-Espinosa, MJ; Zabaleta, C; Vrijheid, M; Casas, M. (2019). Prenatal exposure to organochlorine compounds and lung function during childhood. Environ Int 131: 105049. 10.1016/j.envint.2019.105049.31362153
Abrahamson, LJ; Allen, JR. (1973). The biological response of infant nonhuman primates to a polychlorinated biphenyl. Environ Health Perspect 4: 81–86.4198473
Adams, J; Barone, S, Jr; Lamantia, A; Philen, R; Rice, DC; Spear, L; Susser, E. (2000). Workshop to identify critical windows of exposure for children's health: Neurobehavioral Work Group summary [Review]. Environ Health Perspect 108: 535–544. 10.1289/ehp.00108s3535.10852852
Agay-Shay, K; Martinez, D; Valvi, D; Garcia-Esteban, R; Basagaña, X; Robinson, O; Casas, M; Sunyer, J; Vrijheid, M. (2015). Exposure to Endocrine-Disrupting Chemicals during Pregnancy and Weight at 7 Years of Age: A Multi-pollutant Approach. Environ Health Perspect 123: 1030–1037. 10.1289/ehp.1409049.25956007
Al-Hussaini, TK; Abdelaleem, AA; Elnashar, I; Shabaan, OM; Mostafa, R; El-Baz, MAH; El-Deek, SEM; Farghaly, TA. (2018). The effect of follicullar fluid pesticides and polychlorinated biphenyls concentrations on intracytoplasmic sperm injection (ICSI) embryological and clinical outcome. Eur J Obstet Gynecol Reprod Biol 220: 39–43. 10.1016/j.ejogrb.2017.11.003.29154179
Alaluusua, S; Kiviranta, H; Leppäniemi, A; Hölttä, P; Lukinmaa, PL; Lope, L; Järvenpää, AL; Renlund, M; Toppari, J; Virtanen, H. (2002). Natal and neonatal teeth in relation to environmental toxicants. Pediatr Res 52: 652. 10.1203/01.PDR.0000031926.09665.F1.12409509
Alampi, JD; Lanphear, BP; Braun, JM; Chen, A; Takaro, TK; Muckle, G; Arbuckle, TE; McCandless, LC. (2021). Association between gestational exposure to toxicants and autistic behaviors using Bayesian quantile regression. Am J Epidemiol 190: 1803–1813. 10.1093/aje/kwab065.33779718
Allen, JR; Abrahamson, LJ; Norback, DH. (1973). Biological effects of polychlorinated biphenyls and triphenyls on the subhuman primate. Environ Res 6: 344–354. 10.1016/0013-9351(73)90047-9.4270482
Allen, JR; Barsotti, DA; Carstens, LA. (1980). Residual effects of polychlorinated biphenyls on adult nonhuman primates and their offspring. J Toxicol Environ Health 6: 55–66. 10.1080/15287398009529830.6770099
Allen, JR; Carstens, LA; Abrahamson, LJ. (1976). Responses of rats exposed to polychlorinated biphenyls for fifty-two weeks I. Comparison of tissue levels of PCB and biological changes. Arch Environ Contam Toxicol 4: 404–419.826224
Allen, JR; Carstens, LA; Barsotti, DA. (1974a). Residual effects of short-term, low-level exposure of nonhuman primates to polychlorinated biphenyls. Toxicol Appl Pharmacol 30: 440–451. 10.1016/0041-008X(74)90265-8.4141140
Allen, JR; Cartens, LA; Abrahamson, LJ; Marlar, RJ. (1975). Responses of rats and nonhuman primates to 2,5,2',5'-tetrachlorobiphenyl. Environ Res 9: 265–273. 10.1016/0013-9351(75)90006-7.808412
Allen, JR; Norback, DH; Hsu, IC. (1974b). Tissue modifications in monkeys as related to absorption, distribution, and excretion of polychlorinated biphenyls. Arch Environ Contam Toxicol 2: 86–95. 10.1007/BF01985803.4208176
Alvares, AP; Fischbein, A; Anderson, KE; Kappas, A. (1977). Alterations in drug metabolism in workers exposed to polychlorinated biphenyls. Clin Pharmacol Ther 22: 140–146. 10.1002/cpt1977222140.407043
Álvarez-Pedrerol, M; Ribas-Fitó, N; Torrent, M; Carrizo, D; Garcia-Esteban, R; Grimalt, JO; Sunyer, J. (2008a). Thyroid disruption at birth due to prenatal exposure to beta-hexachlorocyclohexane. Environ Int 34: 737–740. 10.1016/j.envint.2007.12.001.18207242
Álvarez-Pedrerol, M; Ribas-Fitó, N; Torrent, M; Carrizo, D; Grimalt, JO; Sunyer, J. (2008b). Effects of PCBs, p,p'-DDT, p,p'-DDE, HCB and beta-HCH on thyroid function in preschool children. Occup Environ Med 65: 452–457. 10.1136/oem.2007.032763.17933884
Alvarez-Silvares, E; Fernández-Cruz, T; Domínguez-Vigo, P; Rubio-Cid, P; Seoane-Pillado, T; Martínez-Carballo, E. (2021). Association between placenta concentrations polybrominated and polychlorinated biphenyls and gestational diabetes mellitus: a case-control study in northwestern Spain. Environ Sci Pollut Res Int 28: 10292–10301. 10.1007/s11356-021-12377-z.33462692
Aminov, Z; Carpenter, DO. (2020). Serum concentrations of persistent organic pollutants and the metabolic syndrome in Akwesasne Mohawks, a Native American community. Environ Pollut. 10.1016/j.envpol.2020.114004.
Ampleman, MD; Martinez, A; Dewall, J; Rawn, DF; Hornbuckle, KC; Thorne, PS. (2015). Inhalation and dietary exposure to PCBs in urban and rural cohorts via congener-specific measurements. Environ Sci Technol 49: 1156–1164. 10.1021/es5048039.25510359
Andrews, JE. (1989). Polychlorinated biphenyl (Aroclor 1254) induced changes in femur morphometry calcium metabolism and nephrotoxicity. Toxicology 57: 83–96. 10.1016/0300-483X(89)90036-X.2501909
APA (American Psychiatric Association). (2013). Diagnostic and statistical manual of mental disorders (5th ed.). Arlington, VA. 10.1176/appi.books.9780890425596.
Arena, SM; Greeley, EH; Halbrook, RS; Hansen, LG; Segre, M. (2003). Biological effects of gestational and lactational PCB exposure in neonatal and juvenile C57BL/6 mice. Arch Environ Contam Toxicol 44: 272–280. 10.1007/s00244-002-2022-5.12520400
Arguello, G; Balboa, E; Arrese, M; Zanlungo, S. (2015). Recent insights on the role of cholesterol in non-alcoholic fatty liver disease [Review]. Biochim Biophys Acta 1852: 1765–1778. 10.1016/j.bbadis.2015.05.015.26027904
Arisi, M; Manganoni, AM; de Palma, G; Magoni, M; Donato, F; Scarcella, C; Orizio, G; Pavoni, L; Moggio, E; Venturini, M; Rossi, M; Tomasi, C; Calzavara-Pinton, PG. (2021). Neoplastic and inflammatory skin disorders and serum levels of polychlorinated biphenyls in a population living in a highly polluted area. Eur J Dermatol 31: 41–47. 10.1684/ejd.2021.3966.33586660
Arnold, DL; Bryce, F; Karpinski, K; Mes, J; Fernie, S; Tryphonas, H; Truelove, J; McGuire, PF; Burns, D; Tanner, JR; Stapley, R; Zawidzka, ZZ; Basford, D. (1993). Toxicological consequences of Aroclor 1254 ingestion by female rhesus (Macaca mulatta) monkeys. Part 1B. Prebreeding phase: Clinical and analytical laboratory findings. Food Chem Toxicol 31: 811–824. 10.1016/0278-6915(93)90219-O.8258410
Arnold, DL; Bryce, F; McGuire, PF; Stapley, R; Tanner, JR; Wrenshall, E; Mes, J; Fernie, S; Tryphonas, H; Hayward, S; Malcolm, S. (1995). Toxicological consequences of aroclor 1254 ingestion by female rhesus (Macaca mulatta) monkeys. Part 2. Reproduction and infant findings. Food Chem Toxicol 33: 457–474. 10.1016/0278-6915(95)00018-W.7797173
Arnold, DL; Bryce, F; Mes, J; Tryphonas, H; Hayward, S; Malcolm, S. (1999). Toxicological consequences of feeding PCB congeners to infant rhesus (Macaca mulatta) and cynomolgus (Macaca fascicularis) monkeys. Food Chem Toxicol 37: 153–167. 10.1016/S0278-6915(98)00120-3.10227739
Arnold, DL; Bryce, FR; Clegg, DJ; Cherry, W; Tanner, JR; Hayward, S. (2000). Dosing via gavage or diet for reproduction studies: A pilot study using two fat-soluble compounds—Hexachlorobenzene and Aroclor 1254. Food Chem Toxicol 38: 697–706. 10.1016/S0278-6915(00)00060-0.10908817
Arnold, DL; Nera, EA; Stapley, R; Bryce, F; Fernie, S; Tolnai, G; Miller, D; Hayward, S; Campbell, JS; Greer, I. (1997). Toxicological consequences of Aroclor 1254 ingestion by female rhesus (Macaca mulatta) monkeys and their nursing infants. Part 3: Post-reproduction and pathological findings. Food Chem Toxicol 35: 1191–1207. 10.1016/S0278-6915(97)85470-1.9449225
Arnold, HM; Bruno, JP; Sarter, M. (2003). Assessment of sustained and divided attention in rats [Editorial]. Curr Protoc Neurosci 22: 8.5E.1–8.5E.13. 10.1002/0471142301.ns0805es22.
Arrebola, JP; González-Jiménez, A; Fornieles-González, C; Artacho-Cordón, F; Olea, N; Escobar-Jiménez, F; Fernández-Soto, ML. (2015). Relationship between serum concentrations of persistent organic pollutants and markers of insulin resistance in a cohort of women with a history of gestational diabetes mellitus. Environ Res 136: 435–440.25460665
Arzuaga, X; Smith, MT; Gibbons, CF; Skakkebæk, NE; Yost, EE; Beverly, BEJ; Hotchkiss, AK; Hauser, R; Pagani, RL; Schrader, SM; Zeise, L; Prins, GS. (2019). Proposed key characteristics of male reproductive toxicants as an approach for organizing and evaluating mechanistic evidence in human health hazard assessments. Environ Health Perspect 127: 1–12. 10.1289/EHP5045.
ATSDR (Agency for Toxic Substances and Disease Registry). (2000). Toxicological profile for polychlorinated biphenyls (PCBs) [ATSDR Tox Profile]. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service. http://www.atsdr.cdc.gov/toxprofiles/tp.asp?id=142&tid=26.
ATSDR (Agency for Toxic Substances and Disease Registry). (2011). Addendum to the toxicological profile for polychlorinated biphenyls. Atlanta, GA. https://www.atsdr.cdc.gov/toxprofiles/pcbs_addendum.pdf .
Attfield, KR; Pinney, SM; Sjödin, A; Voss, RW; Greenspan, LC; Biro, FM; Hiatt, RA; Kushi, LH; Windham, GC. (2019). Longitudinal study of age of menarche in association with childhood concentrations of persistent organic pollutants. Environ Res 176: 1–8. 10.1016/j.envres.2019.108551.
Aulerich, RJ; Bursian, SJ; Breslin, WJ; Olson, BA; Ringer, RK. (1985). Toxicological manifestations of 2,4,5,2',4',5'-, 2,3,6,2',3',6'-, and 3,4,5,3',4',5'-hexachlorobiphenyl and Aroclor 1254 in mink. J Toxicol Environ Health 15: 63–70. 10.1080/15287398509530636.3920403
Aulerich, RJ; Ringer, RK. (1977). Current status of PCB toxicity to mink, and effect on their reproduction. Arch Environ Contam Toxicol 6: 279–292. 10.1007/BF02097769.409355
Aulerich, RJ; Ringer, RK; Iwamoto, S. (1973). Reproductive failure and mortality in mink fed on Great Lakes fish. J Reprod Fertil Suppl 19: 365–376.
Axmon, A; Rylander, L; Strömberg, U; Jönsson, B; Nilsson-Ehle, P; Hagmar, L. (2004). Polychlorinated biphenyls in serum and time to pregnancy. Environ Res 96: 186–195. 10.1016/j.envres.2003.10.002.15325879
Axmon, A; Thulstrup, AM; Rignell-Hydbom, A; Pedersen, HS; Zvyezday, V; Ludwicki, JK; Jonsson, BAG; Toft, G; Bonde, JP; Hagmar, L. (2006). Time to pregnancy as a function of male and female serum concentrations of 2,2 ' 4,4 ' 5,5 '-hexachlorobiphenyl (CB-153) and 1,1-dichloro-2,2-bis (p-chlorophenyl)-ethylene (p,p '-DDE). Hum Reprod 21: 657–665. 10.1093/humrep/dei397.16361295
Azushima, K; Gurley, SB; Coffman, TM. (2018). Modelling diabetic nephropathy in mice [Review]. 14: 48–56. 10.1038/nrneph.2017.142.
Bach, MA; Samms-Vaughan, M; Hessabi, M; Bressler, J; Lee, M; Zhang, J; Shakespeare-Pellington, S; Grove, ML; Loveland, KA; Rahbar, MH. (2020). Association of polychlorinated biphenyls and organochlorine pesticides with autism spectrum disorder in Jamaican children. Research in Autism Spectrum Disorders 76: 101587. 10.1016/j.rasd.2020.101587.32661462
Bäcklin, BM; Madej, A; Forsberg, M. (1997). Histology of ovaries and uteri and levels of plasma progesterone, oestradiol-17β and oestrone sulphate during the implantation period in mated and gonadotrophin-releasing hormone-treated mink (Mustela vison) exposed to polychlorinated biphenyls. J Appl Toxicol 17: 297–306. 10.1002/(SICI)1099-1263(199709)17:5<297::AID-JAT445>3.0.CO;2-N.9339742
Baker, EL, Jr; Landrigan, PJ; Glueck, CJ; Zack, MM, Jr; Liddle, JA; Burse, VW; Housworth, WJ; Needham, LL. (1980). Metabolic consequences of exposure to polychlorinated biphenyls (PCB) in sewage sludge. Am J Epidemiol 112: 553–563. 10.1093/oxfordjournals.aje.a113024.6775528
Bannach-Brown, A; Przybyła, P; Thomas, J; Rice, ASC; Ananiadou, S; Liao, J; Macleod, MR. (2018). Machine learning algorithms for systematic review: reducing workload in a preclinical review of animal studies and reducing human screening error (pp. 1–26). bioRxiv. 10.1101/255760.
Barankin, B; Dekoven, J. (2002). Psychosocial effect of common skin diseases [Review]. Can Fam Physician 48: 712–716.12046366
Barfield, RJ; Auerbach, P; Geyer, LA; McIntosh, TK. (1979). Ultrasonic vocalizations in rat sexual behavior. Am Zool 19: 469–480. 10.1093/icb/19.2.469.
Barker, DJ. (2006). Adult consequences of fetal growth restriction [Review]. Clin Obstet Gynecol 49: 270–283. 10.1097/00003081-200606000-00009.16721106
Barone, S, Jr; Das, KP; Lassiter, TL; White, LD. (2000). Vulnerable processes of nervous system development: A review of markers and methods [Review]. Neurotoxicology 21: 15–36.10794382
Barrett, JE; Vanover, KE. (2004). Assessment of learning and memory using the autoshaping of operant responding in mice. Curr Protoc Neurosci 25: 8.5F.1–8.5F.8. 10.1002/0471142301.ns0805fs25.
Barsotti, DA; Marlar, RJ; Allen, JR. (1976). Reproductive dysfunction in rhesus monkeys exposed to low levels of polychlorinated biphenyls (Aroclor 1248). Food Cosmet Toxicol 14: 99–103. 10.1016/S0015-6264(76)80251-9.817997
Bastomsky, CH; Solymoss, B; Zsigmond, G; Wyse, JM. (1975). On the mechanism of polychlorinated biphenyl-induced hypobilirubinaemia. Clin Chim Acta 61: 171–174. 10.1016/0009-8981(75)90311-3.805678
Baumann, M; Deml, E; Schaffer, E; Greim, H. (1983). Effects of polychlorinated-biphenyls at low-dose levels in rats. Arch Environ Contam Toxicol 12: 509–515. 10.1007/BF01056545.6416187
Bavithra, S; Selvakumar, K; Sundareswaran, L; Arunakaran, J. (2017). Neuroprotective effect of melatonin against PCBs induced behavioural, molecular and histological changes in cerebral cortex of adult male wistar rats. Neurochem Res 42: 428–438. 10.1007/s11064-016-2087-6.27804010
Bell, GA; Perkins, N; Buck Louis, GM; Kannan, K; Bell, EM; Gao, C; Yeung, EH. (2019). Exposure to persistent organic pollutants and birth characteristics: The upstate KIDS study. Epidemiology 30 Suppl. 2: S94–S100. 10.1097/EDE.0000000000001095.
Bell, MR; Thompson, LM; Rodriguez, K; Gore, AC. (2016). Two-hit exposure to polychlorinated biphenyls at gestational and juvenile life stages: 1. Sexually dimorphic effects on social and anxiety-like behaviors. Horm Behav 78: 168–177. 10.1016/j.yhbeh.2015.11.007.26592453
Belles-Isles, M; Ayotte, P; Dewailly, E; Weber, JP; Roy, R. (2002). Cord blood lymphocyte functions in newborns from a remote maritime population exposed to organochlorines and methylmercury. J Toxicol Environ Health A 65: 165–182. 10.1080/152873902753396794.11820504
Benson, K; Yang, E; Dutton, N; Sjodin, A; Rosenbaum, PF; Pavuk, M. (2018). Polychlorinated biphenyls, indicators of thyroid function and thyroid autoantibodies in the Anniston Community Health Survey I (ACHS-I). Chemosphere 195: 156–165. 10.1016/j.chemosphere.2017.12.050.29268174
Berger, DF; Lombardo, JP; Jeffers, PM; Hunt, AE; Bush, B; Casey, A; Quimby, F. (2001). Hyperactivity and impulsiveness in rats fed diets supplemented with either Aroclor 1248 or PCB-contaminated St. Lawrence River fish. Behav Brain Res 126: 1–11. 10.1016/S0166-4328(01)00244-3.11704246
Bergkvist, C; Berglund, M; Glynn, A; Julin, B; Wolk, A; Åkesson, A. (2016). Dietary exposure to polychlorinated biphenyls and risk of myocardial infarction in men - A population-based prospective cohort study. Environ Int 88: 9–14. 10.1016/j.envint.2015.11.020.26690540
Bergkvist, C; Berglund, M; Glynn, A; Wolk, A; Åkesson, A. (2015). Dietary exposure to polychlorinated biphenyls and risk of myocardial infarction - a population-based prospective cohort study. Int J Cardiol 183: 242–248. 10.1016/j.ijcard.2015.01.055.25679993
Bergkvist, C; Kippler, M; Larsson, SC; Berglund, M; Glynn, A; Wolk, A; Åkesson, A. (2014). Dietary exposure to polychlorinated biphenyls is associated with increased risk of stroke in women. J Intern Med 276: 248–259. 10.1111/joim.12194.24428778
Bergman, A; Bäcklin, BM; Järplid, B; Grimelius, L; Wilande, E. (1992). Influence of commercial polychlorinated biphenyls and fractions thereof on liver histology in female mink (Mustela vison). Ambio 21: 591–595.
Berkowitz, GS; Lapinski, RH; Wolff, MS. (1996). The role of DDE and polychlorinated biphenyl levels in preterm birth. Arch Environ Contam Toxicol 30: 139–141.8579383
Berlin, M; Barchel, D; Brik, A; Kohn, E; Livne, A; Keidar, R; Tovbin, J; Betser, M; Moskovich, M; Mandel, D; Lubetzky, R; Ovental, A; Factor-Litvak, P; Britzi, M; Ziv-Baran, T; Koren, R; Klieger, C; Berkovitch, M; Matok, I; Marom, R. (2021). Maternal and Newborn Thyroid Hormone, and the Association With Polychlorinated Biphenyls (PCBs) Burden: The EHF (Environmental Health Fund) Birth Cohort. Front Pediatr 9: 705395. 10.3389/fped.2021.705395.34589452
Bernardo, BA; Lanphear, BP; Venners, SA; Arbuckle, TE; Braun, JM; Muckle, G; Fraser, WD; McCandless, LC. (2019). Assessing the relation between plasma PCB concentrations and elevated autistic behaviours using Bayesian predictive odds ratios. Int J Environ Res Public Health 16: 457. 10.3390/ijerph16030457.30764478
Bero, L; Anglemyer, A; Vesterinen, H; Krauth, D. (2016). The relationship between study sponsorship, risks of bias, and research outcomes in atrazine exposure studies conducted in non-human animals: Systematic review and meta-analysis [Review]. Environ Int 92-93: 597–604. 10.1016/j.envint.2015.10.011.26694022
Bertazzi, PA; Riboldi, L; Pesatori, A; Radice, L; Zocchetti, C. (1987). Cancer mortality of capacitor manufacturing workers. Am J Ind Med 11: 165–176. 10.1002/ajim.4700110206.3103429
Birnbaum, LS; Cummings, AM. (2002). Dioxins and endometriosis: A plausible hypothesis [Review]. Environ Health Perspect 110: 15–21.11781160
Bjørndal, B; Burri, L; Staalesen, V; Skorve, J; Berge, RK. (2011). Different adipose depots: Their role in the development of metabolic syndrome and mitochondrial response to hypolipidemic agents. Journal of Obesity 2011: 490650. 10.1155/2011/490650.21403826
Blake, K; Benghuzzi, H; Cason, Z; Tsao, A; Puckett, A. (2000). The role of the route of administration of poly-chlorinated biphenyls (PCBs) on the reproductive and vital organs of adult female rats. In WA Waugaman; JC Miller (Eds.), Biomedical sciences instrumentation (Vol 36) (pp. 159–164). Research Triangle Park, NC: Instrument Society of America.
Blanck, HM; Marcus, M; Tolbert, PE; Schuch, C; Rubin, C; Henderson, AK; Zhang, RH; Hertzberg, VS. (2004). Time to menopause in relation to PBBs, PCBs, and smoking. Maturitas 49: 97–106. 10.1016/j.maturitas.2003.10.011.15474753
Bloom, MS; Buck Louis, GM; Schisterman, EF; Liu, A; Kostyniak, PJ. (2007). Maternal serum polychlorinated biphenyl concentrations across critical windows of human development. Environ Health Perspect 115: 1320–1324. 10.1289/ehp.10086.17805422
Bloom, MS; Buck Louis, GM; Sundaram, R; Maisog, JM; Steuerwald, AJ; Parsons, PJ. (2015). Birth outcomes and background exposures to select elements, the Longitudinal Investigation of Fertility and the Environment (LIFE). Environ Res 138: 118–129. 10.1016/j.envres.2015.01.008.25707016
Bloom, MS; Fujimoto, VY; Storm, R; Zhang, L; Butts, CD; Sollohub, D; Jansing, RL. (2017). Persistent organic pollutants (POPs) in human follicular fluid and in vitro fertilization outcomes, a pilot study. Reprod Toxicol 67: 165–173. 10.1016/j.reprotox.2017.01.004.28089717
Bloom, MS; Weiner, JM; Vena, JE; Beehler, GP. (2003). Exploring associations between serum levels of select organochlorines and thyroxine in a sample of New York state sportsmen: The New York State Angler Cohort Study. Environ Res 93: 52–66. 10.1016/S0013-9351(02)00085-3.12865048
Bolden, AL; Rochester, JR; Schultz, K; Kwiatkowski, CF. (2017). Polycyclic aromatic hydrocarbons and female reproductive health: A scoping review [Review]. Reprod Toxicol 73: 61–74. 10.1016/j.reprotox.2017.07.012.28739294
Bonnyns, M; Bastomsky, CH. (1976). Polychlorinated biphenyl-induced modification of lymphocyte response to plant mitogens in rats. Experientia 32: 522–523. 10.1007/BF01920835.817932
Bouchard, MF; Oulhote, Y; Sagiv, SK; Saint-Amour, D; Weuve, J. (2014). Polychlorinated biphenyl exposures and cognition in older U.S. adults: NHANES (1999–2002). Environ Health Perspect 122: 73–78. 10.1289/ehp.1306532.24275543
Boucher, O; Burden, MJ; Muckle, G; Saint-Amour, D; Ayotte, P; Dewailly, É; Nelson, CA; Jacobson, SW; Jacobson, JL. (2012a). Response inhibition and error monitoring during a visual go/no-go task in Inuit children exposed to lead, polychlorinated biphenyls, and methylmercury. Environ Health Perspect 120: 608–615. 10.1289/ehp.1103828.22142904
Boucher, O; Jacobson, SW; Plusquellec, P; Dewailly, É; Ayotte, P; Forget-Dubois, N; Jacobson, JL; Muckle, G. (2012b). Prenatal methylmercury, postnatal lead exposure, and evidence of attention deficit/hyperactivity disorder among Inuit children in Arctic Québec. Environ Health Perspect 120: 1456–1461. 10.1289/ehp.1204976.23008274
Boucher, O; Muckle, G; Ayotte, P; Dewailly, E; Jacobson, SW; Jacobson, JL. (2016). Altered fine motor function at school age in Inuit children exposed to PCBs, methylmercury, and lead. Environ Int 95: 144–151. 10.1016/j.envint.2016.08.010.27575364
Bowers, WJ; Nakai, JS; Chu, I; Wade, MG; Moir, D; Yagminas, A; Gill, S; Pulido, O; Meuller, R. (2004). Early developmental neurotoxicity of a PCB/organochlorine mixture in rodents after gestational and lactational exposure. Toxicol Sci 77: 51–62. 10.1093/toxsci/kfg248.14514954
Bowman, RE; Heironimus, MP. (1981). Hypoactivity in adolescent monkeys perinatally exposed to PCBs and hyperactive as juveniles. Neurobehav Toxicol Teratol 3: 15–18.
Bowman, RE; Heironimus, MP; Allen, JR. (1978). Correlation of PCB body burden with behavioral toxicology in monkeys. Pharmacol Biochem Behav 9: 49–56. 10.1016/0091-3057(78)90012-6.100792
Bowman, RE; Heironimus, MP; Barsotti, DA. (1981). Locomotor hyperactivity in PCB-exposed rhesus monkeys. Neurotoxicology 2: 251–268.6798510
Boyer, JL. (2013). Bile formation and secretion [Review]. Compr Physiol 3: 1035–1078. 10.1002/cphv.c120027.23897680
Branchi, I; Alleva, E; Costa, LG. (2002). Effects of perinatal exposure to a polybrominated diphenyl ether (PBDE 99) on mouse neurobehavioural development. Neurotoxicology 23: 375–384. 10.1016/S0161-813X(02)00078-5.12387364
Brandt-Rauf, PW; Niman, HL. (1988). Serum screening for oncogene proteins in workers exposed to PCBs. Br J Ind Med 45: 689–693. 10.1136/oem.45.10.689.3143397
Braun, AA; Skelton, MR; Vorhees, CV; Williams, MT. (2011). Comparison of the elevated plus and elevated zero mazes in treated and untreated male Sprague-Dawley rats: effects of anxiolytic and anxiogenic agents. Pharmacol Biochem Behav 97: 406–415. 10.1016/j.pbb.2010.09.013.20869983
Braun, JM; Kalkbrenner, AE; Just, AC; Yolton, K; Calafat, AM; Sjödin, A; Hauser, R; Webster, GM; Chen, A; Lanphear, BP. (2014). Gestational exposure to endocrine-disrupting chemicals and reciprocal social, repetitive, and stereotypic behaviors in 4- and 5-year-old children: the HOME study. Environ Health Perspect 122: 513–520. 10.1289/ehp.1307261.24622245
Brazil, C; Swan, SH; Drobnis, EZ; Liu, F; Wang, C; Redmon, JB; Overstreet, JW. (2004). Standardized methods for semen evaluation in a multicenter research study. J Androl 25: 635–644. 10.1002/j.1939-4640.2004.tb02835.x.15223853
Bremmer, JH; Troost, LM; Kuipers, G; de Koning, J; Sein, AA. (1994). Emissions of dioxins in the Netherlands. (RIVM Report No. 770501018). Bilthoven, Netherlands: National Institute for Public Health and the Environment. https://rivm.openrepository.com/handle/10029/10495.
Brezner, E; Terkel, J; Perry, AS. (1984). The effect of Aroclor 1254 (PCB) on the physiology of reproduction in the female rat—I. Comp Biochem Physiol C Toxicol Pharmacol 77: 65–70. 10.1016/0742-8413(84)90131-2.
Broding, HC; Schettgen, T; Hillert, A; Angerer, J; Goen, T; Drexler, H. (2008). Subjective complaints in persons under chronic low-dose exposure to lower polychlorinated biphenyls (PCBs). Int J Hyg Environ Health 211: 648–657. 10.1016/j.ijheh.2008.02.001.18396099
Brown, AS; Cheslack-Postava, K; Rantakokko, P; Kiviranta, H; Hinkka-Yli-Salomäki, S; McKeague, IW; Surcel, HM; Sourander, A. (2018). Association of maternal insecticide levels with autism in offspring from a national birth cohort. Am J Psychiatry 175: 1094–1101. 10.1176/appi.ajp.2018.17101129.30111184
Brown, DP. (1987). Mortality of workers exposed to polychlorinated biphenyls - An update. Arch Environ Health 42: 333–339. 10.1080/00039896.1987.9934355.3125795
Brown, DP; Jones, M. (1981). Mortality and industrial hygiene study of workers exposed to polychlorinated biphenyls. Arch Environ Health 36: 120–129. 10.1080/00039896.1981.10667615.6787990
Brown, JF, Jr; Lawton, RW; Ross, MR; Feingold, J. (1991). Assessing the human health effects of PCBs. Chemosphere 23: 1811–1815. 10.1016/0045-6535(91)90028-C.
Brown, NM; Lamartiniere, CA. (1995). Xenoestrogens alter mammary gland differentiation and cell proliferation in the rat. Environ Health Perspect 103: 708–713. 10.2307/3432863.7588483
Brucker-Davis, F; Ferrari, P; Boda-Buccino, M; Wagner-Mahler, K; Pacini, P; Gal, J; Azuar, P; Fenichel, P. (2011). Cord blood thyroid tests in boys born with and without cryptorchidism: Correlations with birth parameters and in utero xenobiotics exposure. Thyroid 21: 1133–1141. 10.1089/thy.2010.0459.21875366
Brucker-Davis, F; Ganier-Chauliac, F; Gal, J; Panaïa-Ferrari, P; Pacini, P; Fénichel, P; Hiéronimus, S. (2015). Neurotoxicant exposure during pregnancy is a confounder for assessment of iodine supplementation on neurodevelopment outcome. Neurotoxicol Teratol 51: 45–51. 10.1016/j.ntt.2015.07.009.26247661
Brucker-Davis, F; Wagner-Mahler, K; Bornebusch, L; Delattre, I; Ferrari, P; Gal, J; Boda-Buccino, M; Pacini, P; Tommasi, C; Azuar, P; Bongain, A; Fenichel, P. (2010). Exposure to selected endocrine disruptors and neonatal outcome of 86 healthy boys from Nice area (France). Chemosphere 81: 169–176. 10.1016/j.chemosphere.2010.06.068.20663538
Brucker-Davis, F; Wagner-Mahler, K; Delattre, I; Ducot, B; Ferrari, P; Bongain, A; Kurzenne, JY; Mas, JC; Fenichel, P; Area, CSGfN. (2008). Cryptorchidism at birth in Nice area (France) is associated with higher prenatal exposure to PCBs and DDE, as assessed by colostrum concentrations. Hum Reprod 23: 1708–1718. 10.1093/humrep/den186.18503055
Bruckner, JV; Jiang, WD; Brown, JM; Putcha, L; Chu, CK; Stella, VJ. (1977). The influence of ingestion of environmentally encountered levels of a commercial polychlorinated biphenyl mixture (Aroclor 1254) on drug metabolism in the rat. J Pharmacol Exp Ther 202: 22–31.406382
Bruckner, JV; Khanna, KL; Cornish, HH. (1973). Biological responses of the rat to polychlorinated biphenyls. Toxicol Appl Pharmacol 24: 434–448. 10.1016/0041-008X(73)90050-1.4634185
Bruckner, JV; Khanna, KL; Cornish, HH. (1974). Polychlorinated biphenyl-induced alteration of biologic parameters in the rat. Toxicol Appl Pharmacol 28: 189–199. 10.1016/0041-008X(74)90004-0.4137109
Brunstrom, B; Lund, BO; Bergman, A; Asplund, L; Athanassiadis, I; Athanasiadou, M; Jensen, S; Örberg, J. (2001). Reproductive toxicity in mink (Mustela vison) chronically exposed to environmentally relevant polychlorinated biphenyl concentrations. Environ Toxicol Chem 20: 2318–2327. 10.1002/etc.5620201026.11596766
Buck, GM; Mendola, P; Vena, JE; Sever, LE; Kostyniak, P; Greizerstein, H; Olson, J; Stephen, FD. (1999). Paternal Lake Ontario fish consumption and risk of conception delay, New York State Angler Cohort. Environ Res 80: S13–S18. 10.1006/enrs.1998.3926.10092415
Buck, GM; Vena, JE; Schisterman, EF; Dmochowski, J; Mendola, P; Sever, LE; Fitzgerald, E; Kostyniak, P; Greizerstein, H; Olson, J. (2000). Parental consumption of contaminated sport fish from Lake Ontario and predicted fecundability. Epidemiology 11: 388–393. 10.1097/00001648-200007000-00005.10874544
Buck Louis, GM; Chen, Z; Peterson, CM; Hediger, ML; Croughan, MS; Sundaram, R; Stanford, JB; Varner, MW; Fujimoto, VY; Giudice, LC; Trumble, A; Parsons, PJ; Kannan, K. (2012). Persistent lipophilic environmental chemicals and endometriosis: the ENDO study. Environ Health Perspect 120: 811–816. 10.1289/ehp.1104432.22417635
Buck Louis, GM; Rios, LI; McLain, A; Cooney, MA; Kostyniak, PJ; Sundaram, R. (2011a). Persistent organochlorine pollutants and menstrual cycle characteristics. Chemosphere 85: 1742–1748. 10.1016/j.chemosphere.2011.09.027.22018858
Buck Louis, GM; Schisterman, EF; Sweeney, AM; Wilcosky, TC; Gore-Langton, RE; Lynch, CD; Boyd Barr, D; Schrader, SM; Kim, S; Chen, Z; Sundaram, R. (2011b). Designing prospective cohort studies for assessing reproductive and developmental toxicity during sensitive windows of human reproduction and development--the LIFE Study. Paediatr Perinat Epidemiol 25: 413–424. 10.1111/j.1365-3016.2011.01205.x.21819423
Buck Louis, GM; Sundaram, R; Schisterman, EF; Sweeney, AM; Lynch, CD; Gore-Langton, RE; Maisog, J; Kim, S; Chen, Z; Barr, DB. (2013). Persistent environmental pollutants and couple fecundity: The LIFE study. Environ Health Perspect 121: 231–236. 10.1289/ehp.1205301.23151773
Buck Louis, GM; Weiner, JM; Whitcomb, BW; Sperrazza, R; Schisterman, EF; Lobdell, DT; Crickard, K; Greizerstein, H; Kostyniak, PJ. (2005). Environmental PCB exposure and risk of endometriosis. Hum Reprod 20: 279–285. 10.1093/humrep/deh575.15513976
Burns, JS; Lee, MM; Williams, PL; Korrick, SA; Sergeyev, O; Lam, T; Revich, B; Hauser, R. (2016). Associations of Peripubertal Serum Dioxin and Polychlorinated Biphenyl Concentrations with Pubertal Timing among Russian Boys. Environ Health Perspect 124: 1801–1807. 10.1289/EHP154.27187981
Burns, JS; Williams, PL; Sergeyev, O; Korrick, SA; Rudnev, S; Plaku-Alakbarova, B; Revich, B; Hauser, R; Lee, MM. (2020). Associations of peri-pubertal serum dioxins and polychlorinated biphenyls with growth and body composition among Russian boys in a longitudinal cohort. Int J Hyg Environ Health 223: 228–237. 10.1016/j.ijheh.2019.08.008.31466867
Burse, VW; Kimbrough, RD; Villanueva, EC; Jennings, RW; Linder, RE; Sovocool, GW. (1974). Polychlorinated biphenyls. Storage, distribution, excretion, and recovery: Liver morphology after prolonged dietary ingestion. Arch Environ Health 29: 301–307. 10.1080/00039896.1974.10666603.4215375
Bush, B; Bennett, AH; Snow, JT. (1986). Polychlorobiphenyl congeners, p,p'-DDE, and sperm function in humans. Arch Environ Contam Toxicol 15: 333–341. 10.1007/BF01066399.3090950
Bushnell, PJ; Moser, VC; MacPhail, RC; Oshiro, WM; Derr-Yellin, EC; Phillips, PM; Kodavanti, PRS. (2002). Neurobehavioral assessments of rats perinatally exposed to a commercial mixture of polychlorinated biphenyls. Toxicol Sci 68: 109–120. 10.1093/toxsci/68.1.109.12075116
Byrne, JJ; Carbone, JP; Hanson, EA. (1987). Hypothyroidism and abnormalities in the kinetics of thyroid hormone metabolism in rats treated chronically with polychlorinated biphenyl and polybrominated biphenyl. Endocrinology 121: 520–527. 10.1210/endo-121-2-520.3036477
Cao, J; Xu, X; Hylkema, MN; Zeng, EY; Sly, PD; Suk, WA; Bergman, Å; Huo, X. (2016). Early-life exposure to widespread environmental toxicants and health risk: A focus on the immune and respiratory systems [Review]. Ann Glob Health 82: 119–131. 10.1016/j.aogh.2016.01.023.27325070
Cao, Y; Winneke, G; Wilhelm, M; Wittsiepe, J; Lemm, F; Fürst, P; Ranft, U; Imöhl, M; Kraft, M; Oesch-Bartlomowicz, B; Krämer, U. (2008). Environmental exposure to dioxins and polychlorinated biphenyls reduce levels of gonadal hormones in newborns: Results from the Duisburg cohort study. Int J Hyg Environ Health 211: 30–39. 10.1016/j.ijheh.2007.04.005.17660003
Carter, JW; Clancy, J. (1980). Acutely administered polychlorinated biphenyls (PCBs) decrease splenic cellularity but increase its ability to cause graft versus host reactions in BALB/c mice. Immunopharmacology 2: 341–347. 10.1016/0162-3109(80)90018-1.6780487
Carter, JW; Koo, SI. (1984). Effects of dietary Aroclor 1254 (PCBs) on serum levels of lipoprotein cholesterol and tissue distribution of zinc, copper and calcium in Fischer rats. Nutr Rep Int 29: 223–232.
Carter, RJ; Morton, J; Dunnett, SB. (2001). Motor coordination and balance in rodents. Curr Protoc Neurosci 15: 8.12.11–18.12.14. 10.1002/0471142301.ns0812s15.
Casey, AC; Berger, DF; Lombardo, JP; Hunt, A; Quimby, F. (1999). Aroclor 1242 inhalation and ingestion by Sprague-Dawley rats. J Toxicol Environ Health A 56: 311–342. 10.1080/009841099158033.10094245
Chaker, L; Bianco, AC; Jonklaas, J; Peeters, RP. (2017). Hypothyroidism. Lancet 390: 1550–1562. 10.1016/S0140-6736(17)30703-1.28336049
Chang, KJ; Hsieh, KH; Lee, TP; Tang, SY; Tung, TC. (1981). Immunologic evaluation of patients with polychlorinated biphenyl poisoning: Determination of lymphocyte subpopulations. Toxicol Appl Pharmacol 61: 58–63. 10.1016/0041-008X(81)90007-7.6794186
Chao, HR; Wang, SL; Lin, LY; Lee, WJ; Päpke, O. (2007). Placental transfer of polychlorinated dibenzo-p-dioxins, dibenzofurans, and biphenyls in Taiwanese mothers in relation to menstrual cycle characteristics. Food Chem Toxicol 45: 259–265. 10.1016/j.fct.2006.07.032.17029725
Chao, WY; Hsu, CC; Guo, YL. (1997). Middle-ear disease in children exposed prenatally to polychlorinated biphenyls and polychlorinated dibenzofurans. Arch Environ Health 52: 257–262. 10.1080/00039899709602195.9210724
Chase, KH; Wong, O; Thomas, D; Berney, BW; Simon, RK. (1982). Clinical and metabolic abnormalities associated with occupational exposure to polychlorinated biphenyls (PCBs). J Occup Med 24: 109–114.6799628
Chen, YC; Guo, YL; Hsu, CC; Rogan, WJ. (1992). Cognitive development of Yu-Cheng ("oil disease") children prenatally exposed to heat-degraded PCBs. JAMA 268: 3213–3218. 10.1001/jama.1992.03490220057028.1433761
Chen, YC; Yu, ML; Rogan, WJ; Gladen, BC; Hsu, CC. (1994). A 6-year follow-up of behavior and activity disorders in the Taiwan Yu-cheng children. Am J Public Health 84: 415–421. 10.2105/AJPH.84.3.415.8129058
Cheslack-Postava, K; Rantakokko, PV; Hinkka-Yli-Salomäki, S; Surcel, HM; McKeague, IW; Kiviranta, HA; Sourander, A; Brown, AS. (2013). Maternal serum persistent organic pollutants in the Finnish Prenatal Study of Autism: A pilot study. Neurotoxicol Teratol 38: 1–5. 10.1016/j.ntt.2013.04.001.23591055
Chevrier, C; Warembourg, C; Gaudreau, E; Monfort, C; Le Blanc, A; Guldner, L; Cordier, S. (2013). Organochlorine pesticides, polychlorinated biphenyls, seafood consumption, and time-to-pregnancy. Epidemiology 24: 251–260. 10.1097/EDE.0b013e31827f53ec.23348067
Chevrier, J; Eskenazi, B; Bradman, A; Fenster, L; Barr, DB. (2007). Associations between prenatal exposure to polychlorinated biphenyls and neonatal thyroid-stimulating hormone levels in a Mexican-American population, Salinas Valley, California. Environ Health Perspect 115: 1490–1496. 10.1289/ehp.9843.17938741
Chevrier, J; Eskenazi, B; Holland, N; Bradman, A; Barr, DB. (2008). Effects of exposure to polychlorinated biphenyls and organochlorine pesticides on thyroid function during pregnancy. Am J Epidemiol 168: 298–310. 10.1093/aje/kwn136.18550560
Chhadva, P; Goldhardt, R; Galor, A. (2017). Meibomian gland disease: The role of gland dysfunction in dry eye disease. Ophthalmology 124: S20–S26. 10.1016/j.ophtha.2017.05.031.29055358
Cho, MR; Shin, JY; Hwang, JH; Jacobs, DR; Kim, SY; Lee, DH. (2011). Associations of fat mass and lean mass with bone mineral density differ by levels of persistent organic pollutants: National Health and Nutrition Examination Survey 1999–2004. Chemosphere 82: 1268–1276. 10.1016/j.chemosphere.2010.12.031.21196025
Christensen, K; Carlson, LM; Lehmann, GM. (2021). The role of epidemiology studies in human health risk assessment of polychlorinated biphenyls [Review]. Environ Res 194: 110662. 10.1016/j.envres.2020.110662.33385388
Christensen, KLY; Carrico, CK; Sanyal, AJ; Gennings, C. (2013). Multiple classes of environmental chemicals are associated with liver disease: NHANES 2003–2004. Int J Hyg Environ Health 216: 703–709. 10.1016/j.ijheh.2013.01.005.23491026
Chrostek, L; Supronowicz, L; Panasiuk, A; Cylwik, B; Gruszewska, E; Flisiak, R. (2014). The effect of the severity of liver cirrhosis on the level of lipids and lipoproteins. Clin Exp Med 14: 417–421. 10.1007/s10238-013-0262-5.24122348
Chu, I; Bowers, WJ; Caldwell, D; Nakai, J; Pulido, O; Yagminas, A; Wade, MG; Moir, D; Gill, S; Mueller, R. (2005). Toxicological effects of gestational and lactational exposure to a mixture of persistent organochlorines in rats: Systemic effects. Toxicol Sci 88: 645–655. 10.1093/toxsci/kfi335.16177236
Chu, I; Bowers, WJ; Caldwell, D; Nakai, J; Wade, MG; Yagminas, A; Li, N; Moir, D; El Abbas, L; Hakansson, H; Gill, S; Mueller, R; Pulido, O. (2008). Toxicological effects of in utero and lactational exposure of rats to a mixture of environmental contaminants detected in Canadian Arctic human populations. J Toxicol Environ Health A 71: 93–108. 10.1080/1528739070161281.18080900
Chu, I; Villeneuve, DC; Becking, GC; Iverson, F; Ritter, L; Valli, VE; Reynolds, LM. (1980). Short-term study of the combined effects of mirex, photomirex, and kepone with halogenated biphenyls in rats. J Toxicol Environ Health 6: 421–432. 10.1080/15287398009529861.6156243
Chung, YW; Clemens, LG. (1999). Effects of perinatal exposure to polychlorinated biphenyls on development of female sexual behavior. Bull Environ Contam Toxicol 62: 664–670.10353990
Chung, YW; Nunez, AA; Clemens, LG. (2001). Effects of neonatal polychlorinated biphenyl exposure on female sexual behavior. Physiol Behav 74: 363–370.11714501
Cirillo, PM; Cohn, BA; Krigbaum, NY; Lee, M; Brazil, C; Factor-Litvak, P. (2011). Effect of maternal coffee, smoking and drinking behavior on adult son's semen quality: Prospective evidence from the Child Health and Development Studies. J Dev Orig Health Dis 2: 375–386. 10.1017/S2040174411000584.25140488
Clark, SL; Miller, DP; Belfort, MA; Dildy, GA; Frye, DK; Meyers, JA. (2009). Neonatal and maternal outcomes associated with elective term delivery. Am J Obstet Gynecol 200: 156.el51–156.el54. 10.1016/j.ajog.2008.08.068.
Cocchi, D; Tulipano, G; Colciago, A; Sibilia, V; Pagani, F; Viganò, D; Rubino, T; Parolaro, D; Bonfanti, P; Colombo, A; Celotti, F. (2009). Chronic treatment with polychlorinated biphenyls (PCB) during pregnancy and lactation in the rat: Part 1: Effects on somatic growth, growth hormone-axis activity and bone mass in the offspring. Toxicol Appl Pharmacol 237: 127–136. 10.1016/j.taap.2009.03.008.19327374
Cohen, AM; Hersh, WR; Peterson, K; Yen, PY. (2006). Reducing workload in systematic review preparation using automated citation classification. J Am Med Inform Assoc 13: 206–219. 10.1197/jamia.M1929.16357352
Cohn, BA; Overstreet, JW; Fogel, RJ; Brazil, CK; Baird, DD; Cirillo, PM. (2002). Epidemiologic studies of human semen quality: considerations for study design. Am J Epidemiol 155: 664–671. 10.1093/aje/155.7.664.11914194
Çok, I; Donmez, MK; Satiroğlu, MH; Aydınuraz, B; Henkelmann, B; Shen, H; Kotalik, J; Schramm, KW. (2008). Concentrations of polychlorinated dibenzo-p-dioxins (PCDDs), polychlorinated dibenzofurans (PCDFs), and dioxin-like PCBs in adipose tissue of infertile men. Arch Environ Contam Toxicol 55: 143–152. 10.1007/s00244-0079094-1.18166985
Cok, I; Durmaz, TC; Durmaz, E; Satiroglu, MH; Kabukcu, C. (2009). Determination of organochlorine pesticide and polychlorinated biphenyl levels in adipose tissue of infertile men. Environ Monit Assess 162: 301–309. 10.1007/s1066-1009-0797-9.19252989
Colciago, A; Casati, L; Mornati, O; Vergoni, AV; Santagostino, A; Celotti, F; Negri-Cesi, P. (2009). Chronic treatment with polychlorinated biphenyls (PCB) during pregnancy and lactation in the rat: Part 2: Effects on reproductive parameters, on sex behavior, on memory retention and on hypothalamic expression of aromatase and 5alpha-reductases in the offspring. Toxicol Appl Pharmacol 239: 46–54. 10.1016/j.taap.2009.04.023.19464308
Cole, DC; Wainman, B; Sanin, L; Weber, JP; Muggah, H; Ibrahim, S. (2006). Environmental contaminant levels and fecundability among non-smoking couples. Reprod Toxicol 22: 13–19. 10.1016/j.reprotox.2005.12.001.16439098
Collins, WT; Capen, CC. (1980a). Ultrastructural and functional alterations of the rat thyroid gland produced by polychlorinated biphenyls compared with iodide excess and deficiency, and thyrotropin and thyroxine administration. Virchows Arch B Cell Pathol Incl Mol Pathol 33: 213–231. 10.1007/BF02899183.6110270
Collins, WT, Jr; Capen, CC. (1980b). Fine structural lesions and hormonal alterations in thyroid glands of perinatal rats exposed in utero and by the milk to polychlorinated biphenyls. Am J Pathol 99: 125–142.6767410
Colombi, A; Maroni, M; Ferioli, A; Castoldi, M; Jun, LK; Valla, C; Foa, V. (1982). Increase in urinary porphyrin excretion in workers exposed to polychlorinated biphenyls. J Appl Toxicol 2: 117–121. 10.1002/jat.2550020302.
Condorelli, RA; Cannarella, R; Calogero, AE; La Vignera, S. (2018). Evaluation of testicular function in prepubertal children [Review], Endocrine 62: 274–280. 10.1007/s12020-018-1670-9.29982874
Constantino, JN. (2011). The quantitative nature of autistic social impairment [Review]. Pediatr Res 69: 55R–62R. 10.1203/PDR.0b013e318212ec6e.
Cooper, G; Savitz, DA; Millikan, R; Chiu Kit, T. (2002). Organochlorine exposure and age at natural menopause. Epidemiology 13: 729–733. 10.1097/00001648-200211000-00021.12410018
Corey, DA; Juárez de Ku, LM; Bingman, VP; Meserve, LA. (1996). Effects of exposure to polychlorinated biphenyl (PCB) from conception on growth, and development of endocrine, neurochemical, and cognitive measures in 60 day old rats. 60: 131–143.
Corrigan, FM; Murray, L; Wyatt, CL; Shore, RF. (1998). Diorthosubstituted polychlorinated biphenyls in caudate nucleus in Parkinson's disease [Letter]. Exp Neurol 150: 339–342. 10.1006/exnr.1998.6776.9527905
Corrigan, FM; Wienburg, CL; Shore, RF; Daniel, SE; Mann, D. (2000). Organochlorine insecticides in substantia nigra in Parkinson's disease. J Toxicol Environ Health A 59: 229–234. 10.1080/009841000156907.10706031
Coté, S; Ayotte, P; Dodin, S; Blanchet, C; Mulvad, G; Petersen, HS; Gingras, S; Dewailly, E. (2006). Plasma organochlorine concentrations and bone ultrasound measurements: A cross-sectional study in peri-and postmenopausal Inuit women from Greenland. Environ Health 5: 33. 10.1186/1476-069X-5-33.17184534
Craig, EA; Yan, Z; Zhao, QJ. (2015). The relationship between chemical-induced kidney weight increases and kidney histopathology in rats. J Appl Toxicol 35: 729–736. 10.1002/jat.3036.25092041
Croes, K; Den Hond, E; Bruckers, L; Loots, I; Morrens, B; Nelen, V; Colles, A; Schoeters, G; Sioen, I; Covaci, A; Vandermarken, T; Van Larebeke, N; Baeyens, W. (2014). Monitoring chlorinated persistent organic pollutants in adolescents in Flanders (Belgium): concentrations, trends and dose-effect relationships (FLEHS II). Environ Int 71: 20–28. 10.1016/j.envint.2014.05.022.24950161
Crofton, KM; Ding, DL; Padich, R; Taylor, M; Henderson, D. (2000a). Hearing loss following exposure during development to polychlorinated biphenyls: A cochlear site of action. Hear Res 144: 196–204. 10.1016/S0378-5955(00)00062-9.10831878
Crofton, KM; Kodavanti, PRS; Derr-Yellin, EC; Casey, AC; Kehn, LS. (2000b). PCBs, thyroid hormones, and ototoxicity in rats: Cross-fostering experiments demonstrate the impact of postnatal lactation exposure. Toxicol Sci 57: 131–140. 10.1093/toxsci/57.1.131.10966519
Curran, CP; Nebert, DW; Genter, MB; Patel, KV; Schaefer, TL; Skelton, MR; Williams, MT; Vorhees, CV. (2011a). In utero and lactational exposure to PCBs in mice: adult offspring show altered learning and memory depending on Cyp1a2 and Ahr genotypes. Environ Health Perspect 119: 1286–1293. 10.1289/ehp.1002965.21571617
Curran, CP; Vorhees, CV; Williams, MT; Genter, MB; Miller, ML; Nebert, DW. (2011b). In utero and lactational exposure to a complex mixture of polychlorinated biphenyls: toxicity in pups dependent on the Cyp1a2 and Ahr genotypes. Toxicol Sci 119: 189–208. 10.1093/toxsci/kfq314.20961953
D'Errico, MN; De Tullio, G; Di Gioacchino, M; Lovreglio, P; Basso, A; Drago, I; Serra, R; Apostoli, P; Vacca, A; Soleo, L. (2012). Immune effects of polychlorinated biphenyls, smoking and alcohol. Int J Immunopathol Pharmacol 25: 1041–1054. 10.1177/039463201202500421.23298494
D'Errico, MN; Lovreglio, P; Drago, I; Apostoli, P; Soleo, L. (2016). Influence of occupational and environmental exposure to low concentrations of polychlorobiphenyls and a smoking habit on the urinary excretion of corticosteroid hormones. Int J Environ Res Public Health 13: 360. 10.3390/ijerph13040360.27023579
Dadhich, R; Ramasamy, R; Lipshultz, LI. (2015). The male infertility office visit. Minerva Urol Nefrol 67: 157–168.25604696
Dallaire, F; Dewailly, É; Muckle, G; Vézina, C; Jacobson, SW; Jacobson, JL; Ayotte, P. (2004). Acute infections and environmental exposure to organochlorines in Inuit infants from Nunavik. Environ Health Perspect 112: 1359–1364. 10.1289/ehp.7255.15471725
Dallaire, F; Dewailly, É; Vézina, C; Muckle, G; Weber, JP; Bruneau, S; Ayotte, P. (2006). Effect of prenatal exposure to polychlorinated biphenyls on incidence of acute respiratory infections in preschool Inuit children. Environ Health Perspect 114: 1301–1305. 10.1289/ehp.8683.16882544
Dallaire, R; Dewailly, É; Ayotte, P; Muckle, G; Laliberté, C; Bruneau, S. (2008). Effects of prenatal exposure to organochlorines on thyroid hormone status in newborns from two remote coastal regions in Québec, Canada. Environ Res 108: 387–392. 10.1016/j.envres.2008.08.004.18814871
Dallaire, R; Dewailly, É; Pereg, D; Dery, S; Ayotte, P. (2009a). Thyroid function and plasma concentrations of polyhalogenated compounds in Inuit adults. Environ Health Perspect 117: 1380–1386. 10.1289/ehp.0900633.19750101
Dallaire, R; Muckle, G; Dewailly, É; Jacobson, SW; Jacobson, JL; Sandanger, TM; Sandau, CD; Ayotte, P. (2009b). Thyroid hormone levels of pregnant Inuit women and their infants exposed to environmental contaminants. Environ Health Perspect 117: 1014–1020. 10.1289/ehp.0800219.19590699
Dalton, JE; Bolen, SD; Mascha, EJ. (2016). Publication Bias: The Elephant in the Review [Comment]. Anesth Analg 123: 812–813. 10.1213/ANE.0000000000001596.27636569
Daniels, JL; Longnecker, MP; Klebanoff, MA; Gray, KA; Brock, JW; Zhou, H; Chen, Z; Needham, LL. (2003). Prenatal exposure to low-level polychlorinated biphenyls in relation to mental and motor development at 8 months. Am J Epidemiol 157: 485–492. 10.1093/aje/kwg010.12631537
Darvill, T; Lonky, E; Reihman, J; Stewart, P; Pagano, J. (2000). Prenatal exposure to PCBs and infant performance on the Fagan Test of Infant Intelligence. Neurotoxicology 21: 1029–1038.11233749
Daugherty, A; Tall, AR; Daemen, MJA; Falk, E; Fisher, EA; García-Cardeña, G; Lusis, AJ; Owens, AP, III; Rosenfeld, ME; Virmani, R. (2017). Recommendation on design, execution, and reporting of animal atherosclerosis studies: A scientific statement from the American Heart Association [Review]. Arterioscler Thromb Vasc Biol 37: el31–el57. 10.1161/ATV.0000000000000062.
de Cock, M; de Boer, MR; Govarts, E; Iszatt, N; Palkovicova, L; Lamoree, MH; Schoeters, G; Eggesbø, M; Trnovec, T; Legler, J; van de Bor, M. (2017). Thyroid-stimulating hormone levels in newborns and early life exposure to endocrine-disrupting chemicals: analysis of three European mother-child cohorts. Pediatr Res 82: 429–437. 10.1038/pr.2017.50.28288144
De Leo, S; Lee, SY; Braverman, LE. (2016). Hyperthyroidism. Lancet 388: 906–918. 10.1016/S0140-6736(16)00278-6.27038492
de Oliveira, AA; Nunes, KP. (2021). Hypertension and erectile dysfunction: Breaking down the challenges [Review]. Am J Hypertens 34: 134–142. 10.1093/ajh/hpaa143.32866225
Demers, LM; Spencer, CA. (2003). Laboratory medicine practice guidelines. Laboratory support for the diagnosis and monitoring of thyroid disease. Clin Endocrinol 58: 138–140. 10.1089/105072503321086962.
Den Hond, E; Dhooge, W; Bruckers, L; Schoeters, G; Nelen, V; van De Mieroop, E; Koppen, G; Bilau, M; Schroijen, C; Keune, H; Baeyens, W; van Larebeke, N. (2011). Internal exposure to pollutants and sexual maturation in Flemish adolescents. J Expo Sci Environ Epidemiol 21: 224–233. 10.1038/ies.2010.2.20197795
Den Hond, E; Roels, HA; Hoppenbrouwers, K; Nawrot, T; Thijs, L; Vandermeulen, C; Winneke, G; Vanderschueren, D; Staessen, JA. (2002). Sexual maturation in relation to polychlorinated aromatic hydrocarbons: Sharpe and Skakkebaek's hypothesis revisited. Environ Health Perspect 110: 771–776. 10.1289/ehp.02110771.12153757
Denham, M; Schell, LM; Deane, G; Gallo, MV; Ravenscroft, J; DeCaprio, AP. (2005). Relationship of lead, mercury, mirex, dichlorodiphenyldichloroethylene, hexachlorobenzene, and polychlorinated biphenyls to timing of menarche among Akwesasne Mohawk girls. Pediatrics 115: e127–e134. 10.1542/peds.2004-1161.15653789
Dent, MP; Carmichael, PL; Jones, KC; Martin, FL. (2015). Towards a non-animal risk assessment for anti-androgenic effects in humans [Review]. Environ Int 83: 94–106. 10.1016/j.envint.2015.06.009.26115536
Desalegn, AA; Iszatt, N; Stigum, H; Jensen, TK; Eggesbø, M. (2021). A case-cohort study of perinatal exposure to potential endocrine disrupters and the risk of cryptorchidism in the Norwegian HUMIS study. Environ Int 157: 106815. 10.1016/j.envint.2021.106815.34388676
Dewailly, E; Ayotte, P; Bruneau, S; Gingras, S; Belles-Isles, M; Roy, R. (2000). Susceptibility to infections and immune status in Inuit infants exposed to organochlorines. Environ Health Perspect 108: 205–211. 10.1289/ehp.00108205.10706525
Dewailly, E; Bruneau, S; Ayotte, C; Laliberte, S; Gingras, D; Belanger, D; Ferron, L. (1993). Health status at birth of Inuit newborn prenatally exposed to organochlorines. Chemosphere 27: 359 – 366. 10.1016/0045-6535(93)90313-T.
Dickerson, SM; Cunningham, SL; Patisaul, HB; Woller, MJ; Gore, AC. (2011). Endocrine disruption of brain sexual differentiation by developmental PCB exposure. Endocrinology 152: 581–594. 10.1210/en.2010-1103.21190954
Dietert, RR; Etzel, RA; Chen, D; Halonen, M; Holladay, SD; Jarabek, AM; Landreth, K; Peden, DB; Pinkerton, K; Smialowicz, RJ; Zoetis, T. (2000). Workshop to identify critical windows of exposure for children's health: Immune and respiratory systems work group summary [Review]. Environ Health Perspect 108: 483–490. 10.2307/3454540.10852848
DiPietro, JA; Davis, MF; Costigan, KA; Barr, DB. (2014). Fetal heart rate and motor activity associations with maternal organochlorine levels: Results of an exploratory study. J Expo Sci Environ Epidemiol 24: 474–481. 10.1038/ies.2013.19.23591698
Dirinck, EL; Dirtu, AC; Govindan, M; Covaci, A; Jorens, PG; Van Gaal, LF. (2016). Endocrine-disrupting polychlorinated biphenyls in metabolically healthy and unhealthy obese subjects before and after weight loss: difference at the start but not at the finish. Am J Clin Nutr 103: 989–998. 10.3945/ajcn.115.119081.26961932
Dishaw, L; Yost, E; Arzuaga, X; Luke, A; Kraft, A; Walker, T; Thayer, K. (2020). A novel study evaluation strategy in the systematic review of animal toxicology studies for human health assessments of environmental chemicals [Review]. Environ Int 141: 105736. 10.1016/j.envint.2020.105736.32434117
Doi, H; Nishitani, S; Fujisawa, TX; Nagai, T; Kakeyama, M; Maeda, T; Shinohara, K. (2013). Prenatal exposure to a polychlorinated biphenyl (PCB) congener influences fixation duration on biological motion at 4-months-old: a preliminary study. PLoS ONE 8: e59196. 10.1371/journal.pone.0059196.23555630
Donat-Vargas, C; Bellavia, A; Berglund, M; Glynn, A; Wolk, A; Åkesson, A. (2020a). Cardiovascular and cancer mortality in relation to dietary polychlorinated biphenyls and marine polyunsaturated fatty acids: a nutritional-toxicological aspect of fish consumption. J Intern Med 287: 197–209. 10.1111/ioim.12995.31628875
Donat-Vargas, C; Gea, A; Sayon-Orea, C; de la Fuente-Arrillaga, C; Martinez-Gonzalez, MA; Bes-Rastrollo, M. (2015). Association between dietary intake of polychlorinated biphenyls and the incidence of hypertension in a Spanish cohort: The Seguimiento Universidad de Navarra project. Hypertension 65: 714–721. 10.1161/HYPERTENSIONAHA.114.04435.25646299
Donat-Vargas, C; Moreno-Franco, B; Laclaustra, M; Sandoval-Insausti, H; Jarauta, E; Guallar-Castillon, P. (2020b). Exposure to dietary polychlorinated biphenyls and dioxins, and its relationship with subclinical coronary atherosclerosis: The Aragon Workers' Health Study. Environ Int 136: 105433. 10.1016/j.envint.2019.105433.31918334
Dufour, P; Pirard, C; Petrossians, P; Beckers, A; Charlier, C. (2020). Association between mixture of persistent organic pollutants and thyroid pathologies in a Belgian population. Environ Res 181: 108922. 10.1016/j.envres.2019.108922.31759644
Dufour, P; Pirard, C; Seghaye, MC; Charlier, C. (2018). Association between organohalogenated pollutants in cord blood and thyroid function in newborns and mothers from Belgian population. Environ Pollut 238: 389–396. 10.1016/j.envpol.2018.03.058.29579638
Dunn, JD; Carter, JW; Henderson, DA. (1983). EFFECT OF POLYCHLORINATED-BIPHENYLS (AROCLOR 1254) ON RHYTHMIC PITUITARY-ADRENAL-FUNCTION. Bull Environ Contam Toxicol 31: 322–325.6414562
Dwan, K; Altman, DG; Arnaiz, JA; Bloom, J; Chan, AW; Cronin, E; Decullier, E; Easterbrook, PJ; Von Elm, E; Gamble, C; Ghersi, D; Ioannidis, JP; Simes, J; Williamson, PR. (2008). Systematic review of the empirical evidence of study publication bias and outcome reporting bias [Review]. PLoS ONE 3: e3081. 10.1371/journal.pone.0003081.18769481
Dwan, K; Gamble, C; Williamson, PR; Kirkham, JJ. (2013). Systematic review of the empirical evidence of study publication bias and outcome reporting bias - An updated review [Review]. PLoS ONE 8: e66844. 10.1371/journal.pone.0066844.23861749
Dziennis, S; Dongren, Y; Jian, C; Anderson, KA; Alkayed, NJ; Hurn, PD; Lein, PJ. (2008). Developmental Exposure to Polychlorinated Biphenyls Influences Stroke Outcome in Adult Rats. Environ Health Perspect 116: 474–480. 10.1289/ehp.10828.18414629
Edwards, MC; Gardner, ES; Chelonis, JJ; Schulz, EG; Flake, RA; Diaz, PF. (2007). Estimates of the validity and utility of the Conners' Continuous Performance Test in the assessment of inattentive and/or hyperactive-impulsive behaviors in children. J Abnorm Psychol 35: 393–404. 10.1007/s10802-007-9098-3.
Elabbas, LE; Herlin, M; Finnilä, MA; Rendel, F; Stern, N; Trossvik, C; Bowers, WJ; Nakai, J; Tuukkanen, J; Viluksela, M; Heimeier, RA; Akesson, A; Håkansson, H. (2011). In utero and lactational exposure to Aroclor 1254 affects bone geometry, mineral density and biomechanical properties of rat offspring. Toxicol Lett 207: 82–88. 10.1016/j.toxlet.2011.08.003.21856390
Elnar, AA; Diesel, B; Desor, F; Feidt, C; Bouayed, J; Kiemer, AK; Soulimani, R. (2012). Neurodevelopmental and behavioral toxicity via lactational exposure to the sum of six indicator non-dioxin-like-polychlorinated biphenyls (Σ6 NDL-PCBs) in mice. Toxicology 299: 44–54. 10.1016/j.tox.2012.05.004.22595366
Elsevier. (2017). Guidance notes for authors of systematic reviews, systematic maps and other related manuscripts. Available online at https://www.elsevier.com/journals/environment-international/0160-4120/guidance-notes (accessed November 8, 2019).
Emeville, E; Giton, F; Giusti, A; Oliva, A; Fiet, J; Thomé, JP; Blanchet, P; Multigner, L. (2013). Persistent organochlorine pollutants with endocrine activity and blood steroid hormone levels in middle-aged men. PLoS ONE 8: e66460. 10.1371/journal.pone.0066460.23785499
Emmett, EA. (1985). Polychlorinated biphenyl exposure and effects in transformer repair workers. Environ Health Perspect 60: 185–192. 10.2307/3429960.2863134
Emmett, EA; Maroni, M; Jefferys, J; Schmith, J; Levin, BK; Alvares, A. (1988a). Studies of transformer repair workers exposed to PCBs: II. Results of clinical laboratory investigations. Am J Ind Med 14: 47–62. 10.1002/ajim.4700140107.3136647
Emmett, EA; Maroni, M; Schmith, JM; Levin, BK; Jefferys, J. (1988b). Studies of transformer repair workers exposed to PCBs: I. Study design, PCB concentrations, questionnaire, and clinical examination results. Am J Ind Med 13: 415–427. 10.1002/ajim.4700130402.3129934
Emser, TS; Johnston, BA; Steele, JD; Kooij, S; Christiansen, H. (2018). Assessing ADHD symptoms in children and adults: evaluating the role of objective measures. Behavioral and Brain Functions 14: 11. 10.1186/s12993-018-0143-x.29776429
Eslami, B; Naddafi, K; Rastkari, N; Rashidi, BH; Djazayeri, A; Malekafzali, H. (2016). Association between serum concentrations of persistent organic pollutants and gestational diabetes mellitus in primiparous women. Environ Res 151: 706–712. 10.1016/j.envres.2016.09.002.27640070
Esser, A; Gaum, PM; Schettgen, T; Kraus, T; Gube, M; Lang, J. (2015). Effect of occupational polychlorinated biphenyls exposure on quality-adjusted life years over time at the HELPcB surveillance program. J Toxicol Environ Health A 78: 132–150. 10.1080/15287394.2014.946165.25424621
Esser, A; Gube, M; Schettgen, T; Kraus, T; Lang, J. (2014). QALY as evaluation tool in a health surveillance program. Int J Hyg Environ Health 217: 399–404. 10.1016/j.ijheh.2013.07.014.24054544
Evans, CA, Jr. (2009). The connection between oral health and overall health and well-being. In The US oral health workforce in the coming decade: Workshop summary (pp. 5–8). Washington, DC: National Academies Press. https://nap.nationalacademies.org/read/12669/chapter/3.
Everett, CJ; Thompson, OM. (2014). Dioxins, furans and dioxin-like PCBs in human blood: causes or consequences of diabetic nephropathy? Environ Res 132: 126–131. 10.1016/j.envres.2014.03.043.24769561
Everett, CJ; Thompson, OM. (2016). Association of dioxins, furans and dioxin-like PCBs in human blood with nephropathy among US teens and young adults. Rev Environ Health 31: 195–201. 10.1515/reveh-2015-0031.26982604
Faerch, K; Hojlund, K; Vind, BF; Vaag, A; Dalgard, C; Nielsen, F; Grandjean, P. (2012). Increased Serum Concentrations of Persistent Organic Pollutants among Prediabetic Individuals: Potential Role of Altered Substrate Oxidation Patterns. J Clin Endocrinol Metab 97: E1705–E1713. 10.1210/jc.2012-1342.22736774
Fairman, K; Li, M; Kabadi, SV; Lumen, A. (2020). Physiologically based pharmacokinetic modeling: A promising tool for translational research and regulatory toxicology [Review]. Curr Opin Toxicol 23–24: 17–22. 10.1016/j.cotox.2020.03.001.
Fanini, D; Palumbo, G; Giorgi, R; Pantaleoni, G. (1990). Behavioral effects of PCBs in mice. Behav Pharmacol 1: 505–510.11175436
Fein, GG; Jacobson, JL; Jacobson, SW; Schwartz, PM; Dowler, JK. (1984). Prenatal exposure to polychlorinated biphenyls: Effects on birth size and gestational age. J Pediatr 105: 315–320. 10.1016/S0022-3476(84)80139–0.6431068
Feldstein, AE; Wieckowska, A; Lopez, AR; Liu, YC; Zein, NN; McCullough, AJ. (2009). Cytokeratin-18 fragment levels as noninvasive biomarkers for nonalcoholic steatohepatitis: A multicenter validation study. Hepatology 50: 1072–1078. 10.1002/hep.23050.19585618
Fierens, S; Mairesse, H; Heilier, JF; De Burbure, C; Focant, JF; Eppe, G; De Pauw, E; Bernard, A. (2003). Short communication: Dioxin/polychlorinated biphenyl body burden, diabetes and endometriosis: Findings in a population-based study in Belgium. Biomarkers 8: 529–534. 10.1080/1354750032000158420.15195683
File, SE; Lippa, AS; Beer, B; Lippa, MT. (2004). Animal tests of anxiety. Curr Protoc Neurosci 26: 8.3.1–8.3.22. 10.1002/0471142301.ns0803s26.
Fimm, B; Sturm, W; Esser, A; Schettgen, T; Willmes, K; Lang, J; Gaum, PM; Kraus, T. (2017). Neuropsychological effects of occupational exposure to polychlorinated biphenyls. Neurotoxicology 63: 106–119. 10.1016/j.neuro.2017.09.011.28947237
Fischbein, A. (1985). Liver function tests in workers with occupational exposure to polychlorinated biphenyls (PCBs): Comparison with yusho and yu-cheng. Environ Health Perspect 60: 145–150. 10.2307/3429956.2863132
Fischbein, A; Wolff, MS; Lilis, R; Thornton, J; Selikoff, IJ. (1979). Clinical findings among PCB-exposed capacitor manufacturing workers. Ann N Y Acad Sci 320: 703–715. 10.1111/j.1749-6632.1979.tb56645.x.110206
Fitzgerald, EF; Belanger, EE; Gomez, MI; Cayo, M; McCaffrey, RJ; Seegal, RF; Jansing, RL; Hwang, SA; Hicks, HE. (2008). Polychlorinated biphenyl exposure and neuropsychological status among older residents of upper Hudson River communities. Environ Health Perspect 116: 209–215. 10.1289/ehp.10432.18288320
Fitzgerald, EF; Hwang, SA; Lambert, G; Gomez, M; Tarbell, A. (2005). PCB exposure and in vivo CYP1A2 activity among Native Americans. Environ Health Perspect 113: 272–277. 10.1289/ehp.7370.15743714
Fitzgerald, EF; Standfast, SJ; Youngblood, LG; Melius, JM; Janerich, DT. (1986). Assessing the health effects of potential exposure to PCBs, dioxins, and furans from electrical transformer fires: The Binghamton State Office Building medical surveillance program. Arch Environ Health 41: 368–376. 10.1080/00039896.1986.9935781.3113345
Fitzgerald, EF; Weinstein, AL; Youngblood, LG; Standfast, SJ; Melius, JM. (1989). Health effects three years after potential exposure to the toxic contaminants of an electrical transformer fire. Arch Environ Health 44: 214–221. 10.1080/00039896.1989.9935886.2506840
Forns, J; Mandal, S; Iszatt, N; Polder, A; Thomsen, C; Lyche, JL; Stigum, H; Vermeulen, R; Eggesbø, M. (2016). Novel application of statistical methods for analysis of multiple toxicants identifies DDT as a risk factor for early child behavioral problems. Environ Res 151: 91–100. 10.1016/j.envres.2016.07.014.27466755
Forns, J; Torrent, M; Garcia-Esteban, R; Cáceres, A; Pilar Gomila, M; Martinez, D; Morales, E; Julvez, J; Grimalt, JO; Sunyer, J. (2012). Longitudinal association between early life socio-environmental factors and attention function at the age 11 years. Environ Res 117: 54–59. 10.1016/j.envres.2012.04.007.22608140
Frazier, KS; Seely, JC; Hard, GC; Betton, G; Burnett, R; Nakatsuji, S; Nishikawa, A; Durchfeld-Meyer, B; Bube, A. (2012). Proliferative and nonproliferative lesions of the rat and mouse urinary system. Toxicol Pathol 40: 14S–86S. 10.1177/0192623312438736.22637735
Freeman, GB; Lordo, RA; Singer, AW; Peters, AC; Neal, BH; McConnell, EE; Mayes, BA. (2000). An assessment of neurotoxicity of Aroclors 1016, 1242, 1254, and 1260 administered in diet to Sprague-Dawley rats for one year. Toxicol Sci 53: 377–391. 10.1093/toxsci/53.2.377.10696786
Fukushi, J; Tokunaga, S; Nakashima, Y; Motomura, G; Mitoma, C; Uchi, H; Furue, M; Iwamoto, Y. (2016). Effects of dioxin-related compounds on bone mineral density in patients affected by the Yusho incident. Chemosphere 145: 25–33. 10.1016/j.chemosphere.2015.11.091.26650575
Gallo, MV; Ravenscroft, J; Carpenter, DO; Schell, LM; Akwesasne Task Force on the Environment. (2018). Persistent organic pollutants as predictors of increased FSH:LH ratio in naturally cycling, reproductive age women. Environ Res 164: 556–564. 10.1016/j.envres.2018.03.021.29621723
Gascon, M; Sunyer, J; Casas, M; Martínez, D; Ballester, F; Basterrechea, M; Bonde, JP; Chatzi, L; Chevrier, C; Eggesbø, M; Esplugues, A; Govarts, E; Hannu, K; Ibarluzea, J; Kasper-Sonnenberg, M; Klýmper, C; Koppen, G; Nieuwenhuijsen, MJ; Palkovicova, L; ... Vrijheid, M. (2014a). Prenatal exposure to DDE and PCB 153 and respiratory health in early childhood: A meta-analysis. Epidemiology 25: 544–553. 10.1097/EDE.0000000000000097.24776790
Gascon, M; Sunyer, J; Martínez, D; Guerra, S; Lavi, I; Torrent, M; Vrijheid, M. (2014b). Persistent organic pollutants and children's respiratory health: the role of cytokines and inflammatory biomarkers. Environ Int 69: 133–140. 10.1016/j.envint.2014.04.021.24837163
Gascon, M; Verner, MA; Guxens, M; Grimalt, JO; Forns, J; Ibarluzea, J; Lertxundi, N; Ballester, F; Llop, S; Haddad, S; Sunyer, J; Vrijheid, M. (2013). Evaluating the neurotoxic effects of lactational exposure to persistent organic pollutants (POPs) in Spanish children. Neurotoxicology 34: 9–15. 10.1016/j.neuro.2012.10.006.23085522
Gascon, M; Vrijheid, M; Martínez, D; Ballester, F; Basterrechea, M; Blarduni, E; Esplugues, A; Vizcaino, E; Grimalt, JO; Morales, E; Sunyer, J. (2012). Pre-natal exposure to dichlorodiphenyldichloroethylene and infant lower respiratory tract infections and wheeze. Eur Respir J 39: 1188–1196. 10.1183/09031936.00011711.22075485
Gaum, PM; Esser, A; Schettgen, T; Gube, M; Kraus, T; Lang, J. (2014). Prevalence and incidence rates of mental syndromes after occupational exposure to polychlorinated biphenyls. Int J Hyg Environ Health 217: 765–774. 10.1016/j.ijheh.2014.04.001.24951400
Gaum, PM; Gube, M; Esser, A; Schettgen, T; Quinete, N; Bertram, J; Putschogl, FM; Kraus, T; Lang, J. (2019). Depressive symptoms after PCB exposure: Hypotheses for underlying pathomechanisms via the thyroid and dopamine system. Int J Environ Res Public Health 16: 950. 10.3390/ijerph16060950.30884813
Gaum, PM; Gube, M; Schettgen, T; Putschögl, FM; Kraus, T; Fimm, B; Lang, J. (2017). Polychlorinated biphenyls and depression: Cross-sectional and longitudinal investigation of a dopamine-related neurochemical path in the German HELPcB surveillance program. Environ Health 16: 106. 10.1186/s12940-017-0316-3.29017568
Gaum, PM; Kuczynski, I; Schettgen, T; Putschögl, FM; Kraus, T; Fimm, B; Lang, J. (2021). Adverse health effects of PCBs on fine motor performance - Analysis of a neurophysiological pathway in the HELPcB surveillance program. Neurotoxicology 84: 146–154. 10.1016/j.neuro.2021.03.008.33774065
Gaum, PM; Lang, J; Esser, A; Schettgen, T; Neulen, J; Kraus, T; Gube, M. (2016). Exposure to polychlorinated biphenyls and the thyroid gland - examining and discussing possible longitudinal health effects in humans. Environ Res 148: 112–121. 10.1016/j.envres.2016.03.022.27038832
Gaum, PM; Vida, VS; Schettgen, T; Esser, A; Kraus, T; Gube, M; Lang, J. (2020). Cross-sectional and longitudinal effects of PCB exposure on human stress hormones in the German HELPcB surveillance program. Int J Environ Res Public Health 17: 4708. 10.3390/ijerph17134708.32629959
Geller, AM; Oshiro, WM; Haykal-Coates, N; Kodavanti, PR; Bushnell, PJ. (2001). Gender-dependent behavioral and sensory effects of a commercial mixture of polychlorinated biphenyls (Aroclor 1254) in rats. Toxicol Sci 59: 268–277. 10.1093/toxsci/59.2.268.11158720
Gennings, C; Sabo, R; Carney, E. (2010). Identifying subsets of complex mixtures most associated with complex diseases: Polychlorinated biphenyls and endometriosis as a case study. Epidemiology 21: S77–S84. 10.1097/EDE.0b013e3181ce946c.21422968
Gerhard, I; Daniel, V; Link, S; Monga, B; Runnebaum, B. (1998). Chlorinated hydrocarbons in women with repeated miscarriages. Environ Health Perspect 106: 675–681. 10.2307/3434097.9755145
Gerhard, I; Monga, B; Kraehe, J; Runnebaum, B. (1999). Chlorinated hydrocarbons in infertile women. Environ Res 80: 299–310. 10.1006/enrs.1998.3890.10330303
Gerstenberger, SL; Tripoli, V. (2001). Developmental landmarks in offspring of rats exposed singly and in combination to Aroclor 1016 and Levothyroxine. Bull Environ Contam Toxicol 67: 155–162. 10.1007/s00128-001-0105-z.11429671
Giboney, PT. (2005). Mildly elevated liver transaminase levels in the asymptomatic patient [Review]. Am Fam Physician 71: 1105–1110.15791889
Gilbert, ME; Mundy, WR; Crofton, KM. (2000). Spatial learning and long-term potentiation in the dentate gyrus of the hippocampus in animals developmentally exposed to Aroclor 1254. Toxicol Sci 57: 102–111. 10.1093/toxsci/57.1.102.10966516
Gillette, R; Reilly, MP; Topper, VY; Thompson, LM; Crews, D; Gore, AC. (2017). Anxiety-like behaviors in adulthood are altered in male but not female rats exposed to low dosages of polychlorinated biphenyls in utero. Horm Behav 87: 8–15. 10.1016/j.yhbeh.2016.10.011.27794483
Gladen, BC; Ragan, NB; Rogan, WJ. (2000). Pubertal growth and development and prenatal and lactational exposure to polychlorinated biphenyls and dichlorodiphenyl dichloroethene. J Pediatr 136: 490–496. 10.1016/S0022-3476(00)90012-X.10753247
Gladen, BC; Rogan, WJ. (1991). Effects of perinatal polychlorinated biphenyls and dichlorodiphenyl dichloroethene on later development. J Pediatr 119: 58–63. 10.1016/S0022-3476(05)81039-X.1906100
Gladen, BC; Rogan, WJ; Hardy, P; Thullen, J; Tingelstad, J; Tully, M. (1988). Development after exposure to polychlorinated biphenyls and dichlorodiphenyl dichloroethene transplacentally and through human milk. J Pediatr 113: 991–995. 10.1016/S0022-3476(88)80569-9.3142988
Gluckman, PD; Hanson, MA. (2006). The consequences of being born small - An adaptive perspective. Horm Res 65: 5–14. 10.1159/000091500.16612108
Glynn, A; Thuvander, A; Aune, M; Johannisson, A; Darnerud, PO; Ronquist, G; Cnattingius, S. (2008). Immune cell counts and risks of respiratory infections among infants exposed pre- and postnatally to organochlorine compounds: A prospective study. Environ Health 7: 62. 10.1186/1476-069x-7-62.19055819
Glynn, AW; Michaelsson, K; Lind, PM; Wolk, A; Aune, M; Atuma, S; Darnerud, PO; Mallmin, H. (2000). Organochlorines and bone mineral density in Swedish men from the general population. Osteoporos Int 11: 1036–1042. 10.1007/s001980070025.11256895
Goasdoue, K; Miller, SM; Colditz, PB; Björkman, ST. (2017). Review: The blood-brain barrier; protecting the developing fetal brain [Review]. Placenta 54: 111–116. 10.1016/j.placenta.2016.12.005.27939102
Goldey, ES; Crofton, KM. (1998). Thyroxine replacement attenuates hypothyroxinemia, hearing loss, and motor deficits following developmental exposure to Aroclor 1254 in rats. Toxicol Sci 45: 94–105. 10.1006/toxs.1998.2495.9848116
Goldey, ES; Kehn, LS; Lau, C; Rhenberg, GL; Crofton, KM. (1995). Developmental exposure to polychlorinated biphenyls (Aroclor 1254) reduces circulating thyroid hormone concentrations and causes hearing deficits in rats. Toxicol Appl Pharmacol 135: 77–88. 10.1006/taap.1995.1210.7482542
Goncharov, A; Haase, RF; Santiago-Rivera, A; Morse, G; Akwesasne Task Force on the Environment; McCaffrey, RJ; Rej, R; Carpenter, DO. (2008). High serum PCBs are associated with elevation of serum lipids and cardiovascular disease in a Native American population. Environ Res 106: 226–239. 10.1016/j.envres.2007.10.006.18054906
Gore, AC; Chappell, VA; Fenton, SE; Flaws, JA; Nadal, A; Prins, GS; Toppari, J; Zoeller, RT. (2015). EDC-2: The Endocrine Society's second Scientific Statement on endocrine-disrupting chemicals [Review]. Endocr Rev 36: E1–E150. 10.1210/er.2015-1010.26544531
Gounden, V; Bhatt, H; Jialal, I. (2021). Renal function tests [StatPearls]. Treasure Island, FL: StatPearls Publishing. Retrieved from http://www.ncbi.nlm.nih.gov/books/nbk507821/
Goutman, SA; Boss, J; Patterson, A; Mukherjee, B; Batterman, S; Feldman, EL. (2019). High plasma concentrations of organic pollutants negatively impact survival in amyotrophic lateral sclerosis. J Neurol Neurosurg Psychiatry 90: 907–912. 10.1136/jnnp-2018-319785.30760645
Govarts, E; Nieuwenhuijsen, M; Schoeters, G; Ballester, F; Bloemen, K; de Boer, M; Chevrier, C; Eggesbø, M; Guxens, M; Krämer, U; Legler, J; Martínez, D; Palkovicova, L; Patelarou, E; Ranft, U; Rautio, A; Petersen, MS; Slama, R; Stigum, H; ... Bonde, JP. (2012). Birth weight and prenatal exposure to polychlorinated biphenyls (PCBS) and dichlorodiphenyldichloroethylene (DDE): A meta-analysis within 12 European birth cohorts. Environ Health Perspect 120: 162–170. 10.1289/ehp.1103767.21997443
Grandjean, P; Grønlund, C; Kjær, IM; Jensen, TK; Sørensen, N; Andersson, AM; Juul, A; Skakkebæk, NE; Budtz-Jørgensen, E; Weihe, P. (2012a). Reproductive hormone profile and pubertal development in 14-year-old boys prenatally exposed to polychlorinated biphenyls. Reprod Toxicol 34: 498–503. 10.1016/j.reprotox.2012.07.005.22841741
Grandjean, P; Poulsen, LK; Heilmann, C; Steuerwald, U; Weihe, P. (2010). Allergy and sensitization during childhood associated with prenatal and lactational exposure to marine pollutants. Environ Health Perspect 118: 1429–1433. 10.1289/ehp.1002289.20562055
Grandjean, P; Weihe, P; Burse, VW; Needham, LL; Storr-Hansen, E; Heinzow, B; Debes, F; Murata, K; Simonsen, H; Ellefsen, P; Budtz-Jørgensen, E; Keiding, N; White, RF. (2001). Neurobehavioral deficits associated with PCB in 7-year-old children prenatally exposed to seafood neurotoxicants. Neurotoxicol Teratol 23: 305–317. 10.1016/S0892-0362(01)00155-6.11485834
Grandjean, P; Weihe, P; Nielsen, F; Heinzow, B; Debes, F; Budtz-Jørgensen, E. (2012b). Neurobehavioral deficits at age 7 years associated with prenatal exposure to toxicants from maternal seafood diet. Neurotoxicol Teratol 34: 466–472. 10.1016/j.ntt.2012.06.001.22705177
Granillo, L; Sethi, S; Keil, KP; Lin, Y; Ozonoff, S; Iosif, AM; Puschner, B; Schmidt, RJ. (2019). Polychlorinated biphenyls influence on autism spectrum disorder risk in the MARBLES cohort. Environ Res 171: 177–184. 10.1016/j.envres.2018.12.061.30665119
Grant, DL; Phillips, WE. (1974). The effect of age and sex on the toxicity of Aroclor 1254, a polychlorinated biphenyl, in the rat. Bull Environ Contam Toxicol 12: 145–152. 10.1007/BF01684951.4215511
Gray, KA; Klebanoff, MA; Brock, JW; Zhou, H; Darden, R; Needham, L; Longnecker, MP. (2005). In utero exposure to background levels of polychlorinated biphenyls and cognitive functioning among school-age children. Am J Epidemiol 162: 17–26. 10.1093/aje/kwi158.15961582
Grice, BA; Nelson, RG; Williams, DE; Knowler, WC; Mason, C; Hanson, RL; Bullard, KM; Pavkov, ME. (2017). Associations between persistent organic pollutants, type 2 diabetes, diabetic nephropathy and mortality. Occup Environ Med 74: 521–527. 10.1136/oemed-2016-103948.28438788
Grindler, NM; Allsworth, JE; Macones, GA; Kannan, K; Roehl, KA; Cooper, AR. (2015). Persistent organic pollutants and early menopause in U.S. Women. PLoS ONE 10: 1–12. 10.1371/journal.pone.0116057.
Gu, JY; Qian, CH; Tang, W; Wu, XH; Xu, KF; Scherbaum, WA; Schott, M; Liu, C. (2009). Polychlorinated biphenyls affect thyroid function and induce autoimmunity in Sprague-Dawley rats. Horm Metab Res 41: 471–474. 10.1055/s-0029-1220768.19530273
Guüil-Oumrait, N; Valvi, D; Garcia-Esteban, R; Guxens, M; Sunyer, J; Torrent, M; Casas, M; Vrijheid, M. (2021). Prenatal exposure to persistent organic pollutants and markers of obesity and cardiometabolic risk in Spanish adolescents. Environ Int 151: 106469. 10.1016/j.envint.2021.106469.33711537
Guo, LC; Pan, S; Yu, S; Liu, T; Xiao, J; Zhu, B; Qu, Y; Huang, W; Li, M; Li, X; Zeng, W; Rutherford, S; Lin, L; Zhang, Y; Ma, W. (2018). Human Sex Hormone Disrupting Effects of New Flame Retardants and Their Interactions with Polychlorinated Biphenyls, Polybrominated Diphenyl Ethers, a Case Study in South China. Environ Sci Technol 52: 13935–13941. 10.1021/acs.est.8b01540.30384584
Gupta, A; Srivastava, S; Bhatnagar, A. (2014). Cord blood thyroid stimulating hormone level - interpretation in light of perinatal factors. Indian Pediatr 51: 32–36. 10.1007/s13312-014-0330-2.24277962
Gustavsson, P; Hogstedt, C. (1997). A cohort study of Swedish capacitor manufacturing workers exposed to polychlorinated biphenyls (PCBs). Am J Ind Med 32: 234–239. 10.1002/(SICI)1097-0274(199709)32:3<234::AID-AJIM8>3.0.CO;2-X<234::AID-AJIM8>3.0.CO;2-X.9219652
Gustavsson, P; Hogstedt, C; Rappe, C. (1986). Short-term mortality and cancer incidence in capacitor manufacturing workers exposed to polychlorinated biphenyls (PCBs). Am J Ind Med 10: 341–344. 10.1002/ajim.4700100402.3098097
Ha, MH; Lee, DH; Jacobs, DR, Jr. (2007). Association between serum concentrations of persistent organic pollutants and self-reported cardiovascular disease prevalence: Results from the National Health and Nutrition Examination Survey, 1999–2002. Environ Health Perspect 115: 1204–1209. 10.1289/ehp.10184.17687448
Ha, MH; Lee, DH; Son, HK; Park, SK; Jacobs, DR, Jr. (2009). Association between serum concentrations of persistent organic pollutants and prevalence of newly diagnosed hypertension: results from the National Health and Nutrition Examination Survey 1999-2002. J Hum Hypertens 23: 274–286. 10.1038/jhh.2008.124.18843279
Haase, H; Fahlenkamp, A; Schettgen, T; Esser, A; Gube, M; Ziegler, P; Kraus, T; Rink, L. (2016). Immunotoxicity Monitoring in a Population Exposed to Polychlorinated Biphenyls. Int J Environ Res Public Health 13. 10.3390/ijerph13030295.
Haase, RF; McCaffrey, RJ; Santiago-Rivera, AL; Morse, GS; Tarbell, A. (2009). Evidence of an age-related threshold effect of polychlorinated biphenyls (PCBs) on neuropsychological functioning in a Native American population. Environ Res 109: 73–85. 10.1016/j.envres.2008.10.003.19041090
Habert, R; Livera, G; Rouiller-Fabre, V. (2014). Man is not a big rat: Concerns with traditional human risk assessment of phthalates based on their anti-androgenic effects observed in the rat foetus. 24: 1–13. 10.1186/2051-4190-24-14.
Hallgren, S; Darnerud, PO. (2002). Polybrominated diphenyl ethers (PBDEs), polychlorinated biphenyls (PCBs) and chlorinated paraffins (CPs) in rats-testing interactions and mechanisms for thyroid hormone effects. Toxicology 177: 227–243. 10.1016/S0300-483X(02)00222–6.12135626
Hamra, GB; Lyall, K; Windham, GC; Calafat, AM; Sjödin, A; Volk, H; Croen, LA. (2019). Prenatal Exposure to Endocrine-disrupting Chemicals in Relation to Autism Spectrum Disorder and Intellectual Disability. Epidemiology 30: 418–426. 10.1097/EDE.0000000000000983.30789431
Han, G; Ding, G; Lou, X; Wang, X; Han, J; Shen, H; Zhou, Y; Du, L. (2011). Correlations of PCBs, DIOXIN, and PBDE with TSH in children's blood in areas of computer e-waste recycling. Biomed Environ Sci 24: 112–116. 10.3967/0895-3988.2011.02.004.21565681
Han, X; Meng, L; Li, Y; Li, A; Turyk, ME; Yang, R; Wang, P; Xiao, K; Li, W; Zhao, J; Zhang, Q; Jiang, G. (2019). Associations between exposure to persistent organic pollutants and thyroid function in a case-control study of East China. Environ Sci Technol 53: 9866–9875. 10.1021/acs.est.9b02810.31355638
Hansell, MM; Ecobichon, DJ. (1974). Effects of chemically pure chlorobiphenyls on the morphology of rat liver. Toxicol Appl Pharmacol 28: 418–427. 10.1016/0041-008X(74)90227–0.4211968
Hansen, LG; Byerly, CS; Metcalf, RL; Bevill, RF. (1975). Effect of a polychlorinated biphenyl mixture on swine reproduction and tissue residues. Am J Vet Res 36: 23–26.803802
Hansen, S; Strøm, M; Olsen, SF; Dahl, R; Hoffmann, HJ; Granström, C; Rytter, D; Bech, BH; Linneberg, A; Maslova, E; Kiviranta, H; Rantakokko, P; Halldorsson, TI. (2015). In utero exposure to persistent organic pollutants and offspring allergic sensitization and lung function at 20 years of age. Clin Exp Allergy 46: 329–336. 10.1111/cea.12631.
Hansen, S; Strøm, M; Olsen, SF; Maslova, E; Rantakokko, P; Kiviranta, H; Rytter, D; Bech, BH; Hansen, LV; Halldorsson, TI. (2014). Maternal Concentrations of Persistent Organochlorine Pollutants and the Risk of Asthma in Offspring: Results from a Prospective Cohort with 20 Years of Follow-up. Environ Health Perspect 122: 93–99. 10.1289/ehp.1206397.24162035
Hany, J; Lilienthal, H; Sarasin, A; Roth-Härer, A; Fastabend, A; Dunemann, L; Lichtensteiger, W; Winneke, G. (1999). Developmental exposure of rats to a reconstituted PCB mixture or aroclor 1254: Effects on organ weights, aromatase activity, sex hormone levels, and sweet preference behavior. Toxicol Appl Pharmacol 158: 231–243. 10.1006/taap.1999.8710.10438656
Hara, I. (1985). Health status and PCBs in blood of workers exposed to PCBs and of their children. Environ Health Perspect 59: 85–90. 10.2307/3429879.3921370
Hatcher-Martin, JM; Gearing, M; Steenland, K; Levey, AI; Miller, GW; Pennell, KD. (2012). Association between polychlorinated biphenyls and Parkinson's disease neuropathology. Neurotoxicology 33: 1298–1304. 10.1016/j.neuro.2012.08.002.22906799
Haugen, TB; Tefre, T; Malm, G; Jönsson, BA; Rylander, L; Hagmar, L; Bjørsvik, C; Henrichsen, T; Sæther, T; Figenschau, Y; Giwercman, A. (2011). Differences in serum levels of CB-153 and p,p'-DDE, and reproductive parameters between men living south and north in Norway. Reprod Toxicol 32: 261–267. 10.1016/j.reprotox.2011.06.072.21736938
Hauser, R; Altshul, L; Chen, Z; Ryan, L; Overstreet, J; Schiff, I; Christiani, DC. (2002). Environmental organochlorines and semen quality: Results of a pilot study. Environ Health Perspect 110: 229–233.11882472
Hauser, R; Chen, Z; Pothier, L; Ryan, L; Altshul, L. (2003). The relationship between human semen parameters and environmental exposure to polychlorinated biphenyls and p,p'-DDE. Environ Health Perspect 111: 1505–1511. 10.1289/ehp.6175.12948891
Heilier, JF; Ha, AT; Lison, D; Donnez, J; Tonglet, R; Nackers, F. (2004). Increased serum polychlorobiphenyl levels in Belgian women with adenomyotic nodules of the rectovaginal septum [Letter]. Fertil Steril 81: 456–458. 10.1016/j.fertnstert.2003.07.011.14967391
Heilmann, C; Budtz-Jørgensen, E; Nielsen, F; Heinzow, B; Weihe, P; Grandjean, P. (2010). Serum concentrations of antibodies against vaccine toxoids in children exposed perinatally to immunotoxicants. Environ Health Perspect 118: 1434–1438. 10.1289/ehp.1001975.20562056
Heilmann, C; Grandjean, P; Weihe, P; Nielsen, F; Budtz-Jørgensen, E. (2006). Reduced antibody responses to vaccinations in children exposed to polychlorinated biphenyls. PLoS Med 3: e311. 10.1371/journal.pmed.0030311.16942395
Hennig, B; Meerarani, P; Slim, R; Toborek, M; Daugherty, A; Silverstone, AE; Robertson, LW. (2002). Proinflammatory properties of coplanar PCBs: in vitro and in vivo evidence. Toxicol Appl Pharmacol 181: 174–183. 10.1006/taap.2002.9408.12079426
Henrichs, J; Schenk, JJ; Barendregt, CS; Schmidt, HG; Steegers, EA; Hofman, A; Jaddoe, VW; Moll, HA; Verhulst, FC; Tiemeier, H. (2010). Fetal growth from mid- to late pregnancy is associated with infant development: The generation R study. Dev Med Child Neurol 52: 644–651. 10.1111/j.1469-8749.2009.03513.x.19832882
Henríquez-Hernández, LA; Boada, LD; Pérez-Arellano, JL; Carranza, C; Ruiz-Suárez, N; Jaen Sánchez, N; Valerón, PF; Zumbado, M; Camacho, M; Luzardo, OP. (2015). Relationship of polychlorinated biphenyls (PCBs) with parasitism, iron homeostasis, and other health outcomes: Results from a cross-sectional study on recently arrived African immigrants. Environ Res 150: 549–556. 10.1016/j.envres.2015.07.017.26253855
Herbstman, JB; Sjödin, A; Apelberg, BJ; Witter, FR; Halden, RU; Patterson, DG, Jr; Panny, SR; Needham, LL; Goldman, LR. (2008). Birth delivery mode modifies the associations between prenatal polychlorinated biphenyl (PCB) and polybrominated diphenyl ether (PBDE) and neonatal thyroid hormone levels. Environ Health Perspect 116: 1376–1382. 10.1289/ehp.11379.18941581
Hernandez Scudder, ME; Weinberg, A; Thompson, L; Crews, D; Gore, AC. (2020). Prenatal EDCs impair mate and odor preference and activation of the VMN in male and female rats. Endocrinology 161: bqaa124. 10.1210/endocr/b0aa124.32692847
Hernandez Scudder, ME; Young, RL; Thompson, LM; Kore, P; Crews, D; Hofmann, HA; Gore, AC. (2021). EDCs reorganize brain-behavior phenotypic relationships in rats. J Endocr Soc 5: bvab021. 10.1210/jendso/bvab021.33928200
Herr, DW; Goldey, ES; Crofton, KM. (1996). Developmental exposure to Aroclor 1254 produces low-frequency alterations in adult rat brainstem auditory evoked responses. Fundam Appl Toxicol 33: 120–128. 10.1006/faat.1996.0149.8812251
Herr, DW; Graff, JE; Derr-Yellin, EC; Crofton, KM; Kodavanti, PR. (2001). Flash-, somatosensory-, and peripheral nerve-evoked potentials in rats perinatally exposed to Aroclor 1254. Neurotoxicol Teratol 23: 591–601.11792527
Herrick, RF; Meeker, JD; Hauser, R; Altshul, L; Weymouth, GA. (2007). Serum PCB levels and congener profiles among US construction workers. Environ Health 6: 1–8. 10.1186/1476-069X-6-25.17233918
Hertz-Picciotto, I; Charles, MJ; James, RA; Keller, JA; Willman, E; Teplin, S. (2005). In utero polychlorinated biphenyl exposures in relation to fetal and early childhood growth. Epidemiology 16: 648–656. 10.1097/01.ede.0000173043.85834.f3.16135941
HHS (U.S. Department of Health and Human Services). (2000). Oral health in America: A report of the Surgeon General. Rockville, MD: U.S. Department of Health and Human Services, National Institute of Dental and Craniofacial Research, National Institutes of Health. https://www.nidcr.nih.gov/sites/default/files/2017-10/hck1ocv.%40www.surgeon.fullrpt.pdf.
Hipwell, AE; Kahn, LG; Factor-Litvak, P; Porucznik, CA; Siegel, EL; Fichorova, RN; Hamman, RF; Klein-Fedyshin, M; Harley, KG. (2019). Exposure to non-persistent chemicals in consumer products and fecundability: A systematic review. Hum Reprod Update 25: 51–71. 10.1093/humupd/dmy032.30307509
Hirota, Y; Hirohata, T; Kataoka, K; Shinohara, S. (1995). Blood polychlorinated biphenyls and manifestation of symptoms in chronic "Yusho" patients. Fukuoka Igaku Zasshi 86: 247–255.7628816
Hirota, Y; Hirohata, T; Kataoka, K; Shinohara, S; Tokiwa, H. (1993a). Laboratory findings in the medical examination of chronic "Yusho" (PCB poisoning) patients: With special reference to blood PCB and serum triglyceride. Fukuoka Igaku Zasshi 84: 287–293.8330847
Hirota, Y; Kataoka, K; Tokunaga, S; Hirohata, T; Shinohara, S; Tokiwa, H. (1993b). Association between blood polychlorinated biphenyl concentration and serum triglyceride level in chronic "Yusho" (polychlorinated biphenyl poisoning) patients. Int Arch Occup Environ Health 65: 221–225. 10.1007/BF00381194.8144231
Hodgson, S; Thomas, L; Fattore, E; Lind, PM; Alfven, T; Hellström, L; Håkansson, H; Carubelli, G; Fanelli, R; Jarup, L. (2008). Bone mineral density changes in relation to environmental PCB exposure. Environ Health Perspect 116: 1162–1166. 10.1289/ehp.11107.18795157
Holt, VL; Weiss, NS. (2000). Recommendations for the design of epidemiologic studies of endometriosis [Review]. Epidemiology 11: 654–659.11055625
Hood, A; Hashmi, R; Klaassen, CD. (1999). Effects of microsomal enzyme inducers on thyroid-follicular cell proliferation, hyperplasia, and hypertrophy. Toxicol Appl Pharmacol 160: 163–170. 10.1006/taap.1999.8752.10527915
Hornbuckle, K; Robertson, L. (2010). Polychlorinated biphenyls (PCBs): sources, exposures, toxicities [Editorial]. Environ Sci Technol 44: 2749–2751. 10.1021/es100801f.20384370
Hornshaw, TC; Safronoff, J; Ringer, RK; Aulerich, RJ. (1986). LC50 test results in polychlorinated biphenyl-fed mink: Age, season, and diet comparisons. Arch Environ Contam Toxicol 15: 717–723. 10.1007/BF01054918.3098191
Howard, BE; Phillips, J; Miller, K; Tandon, A; Mav, D; Shah, MR; Holmgren, S; Pelch, KE; Walker, V; Rooney, AA; Macleod, M; Shah, RR; Thayer, K. (2016). SWIFT-Review: A text-mining workbench for systematic review. Syst Rev 5: 87. 10.1186/s13643016-0263-z.27216467
Howard, BE; Phillips, J; Tandon, A; Maharana, A; Elmore, R; Mav, D; Sedykh, A; Thayer, K; Merrick, BA; Walker, V; Rooney, A; Shah, RR. (2020). SWIFT-Active Screener: Accelerated document screening through active learning and integrated recall estimation. Environ Int 138: 105623. 10.1016/j.envint.2020.105623.32203803
Høyer, BB; Ramlau-Hansen, CH; Pedersen, HS; Góralczyk, K; Chumak, L; Jönsson, BA; Bonde, JP; Toft, G. (2015). Motor development following in utero exposure to organochlorines: a follow-up study of children aged 5–9 years in Greenland, Ukraine and Poland. BMC Public Health 15: 146. 10.1186/s12889-015-1465-3.25885170
Hover, PB. (2005). Damage to ovarian development and function [Review]. Cell Tissue Res 322: 99–106. 10.1007/s00441-005-1083-y.15856308
Hu, D; Hornbuckle, KC. (2010). Inadvertent polychlorinated biphenyls in commercial paint pigments. Environ Sci Technol 44: 2822–2827. 10.1021/es902413k.19957996
Humblet, O; Williams, PL; Korrick, SA; Sergeyev, O; Emond, C; Birnbaum, LS; Burns, JS; Altshul, L; Patterson, DG, Jr; Turner, WE; Lee, MM; Revich, B; Hauser, R. (2011). Dioxin and polychlorinated biphenyl concentrations in mother's serum and the timing of pubertal onset in sons. Epidemiology 22: 827–835. 10.1097/EDE.0b013e318230b0d1.21968773
Hutzinger, O; Choudhry, GG; Chittim, BG; Johnston, LE. (1985). FORMATION OF POLYCHLORINATED DIBENZOFURANS AND DIOXINS DURING COMBUSTION, ELECTRICAL-EQUIPMENT FIRES AND PCB INCINERATION [Review]. Environ Health Perspect 60: 3–9. 10.1289/ehp.85603.
Hwang, BS; Chen, Z; M Buck Louis, G; Albert, PS. (2019). A Bayesian multi-dimensional couple-based latent risk model with an application to infertility. Biometrics 75: 315–325. 10.1111/biom.12972.30267541
IARC (International Agency for Research on Cancer). (2015). Polychlorinated and polybrominated biphenyls [IARC Monograph]. Lyon, France. http://monographs.iarc.fr/ENG/Monographs/vol107/index.php.
Iatropoulos, MJ; Bailey, J; Adams, HP; Coulston, F; Hobson, W. (1978). Response of nursing infant rhesus to Clophen A-30 or hexachlorobenzene given to their lactating mothers. Environ Res 16: 38–47. 10.1016/0013-9351(78)90139-1.98325
ICF (ICF International). (2018). DRAGON: An online tool for systematic review. Reston, VA. Retrieved from https://www.icf.com/resources/solutions-and-apps/dragon-online-tool-systematic-review
ICF (ICF International). (2021). Litstream. Reston, VA. Retrieved from https://www.icf.com/work/research-evaluation/litstream-systematic-literature-review
Imanishi, J; Nomura, H; Matsubara, M; Kita, M; Won, SJ; Mizutani, T; Kishida, T. (1980). Effect of polychlorinated biphenyl on viral infections in mice. Infect Immun 29: 275–277. 10.1128/iai.29.1.275-277.1980.6156912
Imanishi, J; Oku, T; Oishi, K; Kishida, T; Nomura, H; Mizutani, T. (1984). Reduced resistance to experimental viral and bacterial infections of mice treated with polychlorinated biphenyl. Biken J 27: 195–198.6443175
IPCS (International Programme on Chemical Safety). (2012). Guidance for immunotoxicity risk assessment for chemicals. (Harmonization Project Document No. 10). Geneva, Switzerland: World Health Organization. https://apps.who.int/iris/handle/10665/330098.
Itokawa, Y; Tabei, R; Kamohara, K; Fujiwara, K. (1975). Effect of simultaneous administration of polychlorinated biphenyls and alkylbenzene sulfonic acid salt in rats. Arch Environ Contam Toxicol 3: 115–131. 10.1007/BF02220782.808175
Jaacks, LM; Barr, DB; Sundaram, R; Maisog, JM; Zhang, C; Buck Louis, GM. (2016). Pre-pregnancy maternal exposure to polybrominated and polychlorinated biphenyls and gestational diabetes: a prospective cohort study. Environ Health 15: 11. 10.1186/s12940-016-0092-5.26792546
Jacobson, JL; Jacobson, SW. (1996). Intellectual impairment in children exposed to polychlorinated biphenyls in utero. N Engl J Med 335: 783–789. 10.1056/NEJM199609123351104.8703183
Jacobson, JL; Jacobson, SW. (2002). Breast-feeding and gender as moderators of teratogenic effects on cognitive development. Neurotoxicol Teratol 24: 349–358. 10.1016/S0892-0362(02)00197-6.12009490
Jacobson, JL; Jacobson, SW. (2003). Prenatal exposure to polychlorinated biphenyls and attention at school age. J Pediatr 143: 780–788. 10.1067/S0022-3476(03)00577-8.14657828
Jacobson, JL; Jacobson, SW; Humphrey, HEB. (1990). Effects of in utero exposure to polychlorinated biphenyls and related contaminants on cognitive functioning in young children. J Pediatr 116: 38–45. 10.1016/S0022-3476(05)81642-7.2104928
Jacobson, JL; Jacobson, SW; Padgett, RJ; Brumitt, GA; Billings, RL. (1992). Effects of prenatal PCB exposure on cognitive processing efficiency and sustained attention. Dev Psychol 28: 297–306. 10.1037/0012-1649.28.2.297.
Jan, J; Reinert, K. (2008). Dental caries in Faroese children exposed to polychlorinated biphenyls. Environ Toxicol Pharmacol 25: 188–191. 10.1016/j.etap.2007.10.014.21783858
Jan, J; Sovcikova, E; Kocan, A; Wsolova, L; Trnovec, T. (2007). Developmental dental defects in children exposed to PCBs in eastern Slovakia. Chemosphere 67: S350–S354. 10.1016/j.chemosphere.2006.05.148.17250867
Jensen, RG; Koch, A; Homøe, P; Bjerregaard, P. (2013). Tobacco smoke increases the risk of otitis media among Greenlandic Inuit children while exposure to organochlorines remain insignificant. Environ Int 54: 112–118. 10.1016/j.envint.2013.01.015.23434818
Jensen, TK; Timmermann, AG; Rossing, LI; Ried-Larsen, M; Grøntved, A; Andersen, LB; Dalgaard, C; Hansen, OH; Scheike, T; Nielsen, F; Grandjean, P. (2014). Polychlorinated biphenyl exposure and glucose metabolism in 9-year-old Danish children. J Clin Endocrinol Metab 99: E2643–E2651. 10.1210/jc.2014-1683.25093617
Jin, J; Wahlang, B; Shi, H; Hardesty, JE; Falkner, KC; Head, KZ; Srivastava, S; Merchant, ML; Rai, SN; Cave, MC; Prough, RA. (2020). Dioxin-like and non-dioxin-like PCBs differentially regulate the hepatic proteome and modify diet-induced nonalcoholic fatty liver disease severity. Med Chem Res 29: 1247–1263. 10.1007/s00044-020-02581-w.32831531
Johnstone, GJ; Ecobichon, DJ; Hutzinger, O. (1974). Influence of pure polychlorinated biphenyl compounds on hepatic function in rat. Toxicol Appl Pharmacol 28: 66–81. 10.1016/0041-008X(74)90132-X.4212422
Jonsson, HT; Keil, JE; Gaddy, RG; Loadholt, CB; Hennigar, GR; Walker, EM. (1975). Prolonged ingestion of commercial DDT and PCB; effects on progesterone levels and reproduction in the mature female rat. Arch Environ Contam Toxicol 3: 479–490. 10.1007/BF02220818.816261
Jorgensen, ME; Borch-Johnsen, K; Bjerregaard, P. (2008). A cross-sectional study of the association between persistent organic pollutants and glucose intolerance among Greenland Inuit. Diabetologia 51: 1416–1422. 10.1007/s00125-008-1066-0.18560802
Ju, Q; Zouboulis, CC; Xia, L. (2009). Environmental pollution and acne: Chloracne. Dermato-Endocrinology 1: 125–128. 10.4161/derm.1.3.7862.20436879
Jukic, AMZ; Weinberg, CR; Wilcox, AJ; McConnaughey, DR; Hornsby, P; Baird, DD. (2007). Accuracy of reporting of menstrual cycle length. Am J Epidemiol 167: 25–33. 10.1093/aje/kwm265.17928401
Jusko, TA; De Roos, AJ; Lee, SY; Thevenet-Morrison, K; Schwartz, SM; Verner, MA; Palkovicova Murinova, L; Drobná, B; Kočan, A; Fabišiková, A; Čonka, K; Trnovec, T; Hertz-Picciotto, I; Lawrence, BP. (2016). A birth cohort study of maternal and infant serum PCB-153 and DDE concentrations and responses to infant tuberculosis vaccination. Environ Health Perspect 124: 813–821. 10.1289/ehp.1510101.26649893
Jusko, TA; De Roos, AJ; Schwartz, SM; Lawrence, BP; Palkovicova, L; Nemessanyi, T; Drobna, B; Fabisikova, A; Kocan, A; Sonneborn, D; Jahnova, E; Kavanagh, TJ; Trnovec, T; Hertz-Picciotto, I. (2010). A cohort study of developmental polychlorinated biphenyl (PCB) exposure in relation to post-vaccination antibody response at 6-months of age. Environ Res 110: 388–395. 10.1016/j.envres.2010.02.010.20378105
Jusko, TA; Sisto, R; Iosif, AM; Moleti, A; Wimmerová, S; Lancz, K; Tihányi, J; Sovčiková, E; Drobná, B; Palkoviíová, L; Jureíková, D; Thevenet-Morrison, K; Verner, MA; Sonneborn, D; Hertz-Picciotto, I; Trnovec, T. (2014). Prenatal and postnatal serum PCB concentrations and cochlear function in children at 45 months of age. Environ Health Perspect 122: 1246–1252. 10.1289/ehp.1307473.25051575
Jusko, TA; Sonneborn, D; Palkovicova, L; Kocan, A; Drobna, B; Trnovec, T; Hertz-Picciotto, I. (2012). Pre- and postnatal polychlorinated biphenyl concentrations and longitudinal measures of thymus volume in infants. Environ Health Perspect 120: 595–600. 10.1289/ehp.1104229.22275729
Kahn, LG; Harley, KG; Siegel, EL; Zhu, Y; Factor-Litvak, P; Porucznik, CA; Klein-Fedyshin, M; Hipwell, AE. (2021). Persistent organic pollutants and couple fecundability: A systematic review [Review]. Hum Reprod Update 27: 339–366. 10.1093/humupd/dmaa037.33147335
Kahn, LG; Philippat, C; Nakayama, SF; Slama, R; Trasande, L. (2020). Endocrine-disrupting chemicals: Implications for human health [Review]. Lancet Diabetes Endocrinol 8: 703–718. 10.1016/S2213-8587(20)30129–7.32707118
Kaifie, A; Schettgen, T; Gube, M; Ziegler, P; Kraus, T; Esser, A. (2019). Functional and structural liver abnormalities in former PCB exposed workers - analyses from the HELPcB cohort. J Toxicol Environ Health A 82: 52–61. 10.1080/15287394.2018.1555728.30526399
Kanagawa, Y; Matsumoto, S; Koike, S; Tajima, B; Fukiwake, N; Shibata, S; Uchi, H; Furue, M; Imamura, T. (2008). Association of clinical findings in Yusho patients with serum concentrations of polychlorinated biphenyls, polychlorinated quarterphenyls and 2,3,4,7,8-pentachlorodibenzofuran more than 30 years after the poisoning event. Environ Health 7: 47. 10.1186/1476-069X-7-47.18831733
Karkaba, A; Soualeh, N; Soulimani, R; Bouayed, J. (2017). Perinatal effects of exposure to PCBs on social preferences in young adult and middle-aged offspring mice. Horm Behav 96: 137–146. 10.1016/j.yhbeh.2017.09.002.28935448
Karlsen, M; Grandjean, P; Weihe, P; Steuerwald, U; Oulhote, Y; Valvi, D. (2017). Early-life exposures to persistent organic pollutants in relation to overweight in preschool children. Reprod Toxicol 68: 145–153. 10.1016/j.reprotox.2016.08.002.27496715
Karmaus, W; Brooks, KR; Nebe, T; Witten, J; Obi-Osius, N; Kruse, H. (2005). Immune function biomarkers in children exposed to lead and organochlorine compounds: A cross-sectional study. Environ Health 4: 5. 10.1186/1476-069X-4-5.15831097
Kato, Y; Haraguchi, K; Yamazaki, T; Ito, Y; Miyajima, S; Nemoto, K; Koga, N; Kimura, R; Degawa, M. (2003). Effects of polychlorinated biphenyls, Kanechlor-500, on serum thyroid hormone levels in rats and mice. Toxicol Sci 72: 235–241. 10.1093/toxsci/kfg025.12660360
Kaya, H; Hany, J; Fastabend, A; Roth-Härer, A; Winneke, G; Lilienthal, H. (2002). Effects of maternal exposure to a reconstituted mixture of polychlorinated biphenyls on sex-dependent behaviors and steroid hormone concentrations in rats: Dose-response relationship. Toxicol Appl Pharmacol 178: 71–81. 10.1006/taap.2001.9318.11814327
Kerkvliet, NI; Kimeldorf, DJ. (1977). Inhibition of tumor-growth in rats by feeding a polychlorinated biphenyl, Aroclor 1254. Bull Environ Contam Toxicol 18: 243–246. 10.1007/BF01686073.407960
Khanjani, N; Sim, MR. (2007). Maternal contamination with PCBs and reproductive outcomes in an Australian population. J Expo Sci Environ Epidemiol 17: 191–195. 10.1038/sj.ies.7500495.16773124
Kilburn, KH; Warsaw, RH; Shields, MG. (1989). Neurobehavioral dysfunction in firemen exposed to polychlorinated biphenyls (PCBs): Possible improvement after detoxification. Arch Environ Health 44: 345–350. 10.1080/00039896.1989.9935904.2514627
Kim, S; Eom, S; Kim, HJ; Lee, JJ; Choi, G; Choi, S; Kim, S; Kim, SY; Cho, G; Kim, YD; Suh, E; Kim, SK; Kim, S; Kim, GH; Moon, HB; Park, J; Kim, S; Choi, K; Eun, SH. (2018). Association between maternal exposure to major phthalates, heavy metals, and persistent organic pollutants, and the neurodevelopmental performances of their children at 1 to 2 years of age-CHECK cohort study. Sci Total Environ 624: 377–384. 10.1016/j.scitotenv.2017.12.058.29258038
Kim, S; Park, J; Kim, HJ; Lee, JJ; Choi, G; Choi, S; Kim, S; Kim, SY; Moon, HB; Kim, S; Choi, K. (2015a). Association between several persistent organic pollutants and thyroid hormone levels in cord blood serum and bloodspot of the newborn infants of Korea. PLoS ONE 10: e0125213. 10.1371/journal.pone.0125213.25965908
Kim, SA; Kim, KS; Lee, YM; Jacobs, DR; Lee, DH. (2015b). Associations of organochlorine pesticides and polychlorinated biphenyls with total, cardiovascular, and cancer mortality in elders with differing fat mass. Environ Res 138: 1–7. 10.1016/j.envres.2015.01.021.25682252
Kimáková, T; Nevolná, Z; Vašková, J; Bencko, V. (2018). Retrospective assessment of specific effects of exposure of workers to PCBs in Slovakia. Ann Agric Environ Med 25: 421–427. 10.26444/aaem/86307.30260197
Kimbrough, RD; Doemland, ML; Mandel, JS. (2003). A mortality update of male and female capacitor workers exposed to polychlorinated biphenyls. J Occup Environ Med 45: 271–282. 10.1097/01.jom.0000052959.59271.59.12661184
Kimbrough, RD; Krouskas, CA; Xu, W; Shields, PG. (2015). Mortality among capacitor workers exposed to polychlorinated biphenyls (PCBs), a long-term update. Int Arch Occup Environ Health 88: 85–101. 10.1007/s00420-014-0940-y.24752866
Kippler, M; Larsson, SC; Berglund, M; Glynn, A; Wolk, A; Åkesson, A. (2016). Associations of dietary polychlorinated biphenyls and long-chain omega-3 fatty acids with stroke risk. Environ Int 94: 706–711. 10.1016/j.envint.2016.07.012.27473885
Kiriyama, S; Banjo, M; Matsushima, H. (1974). Effect of polychlorinated biphenyls (PCB) and related compounds on the weight of various organs and plasma and liver cholesterol in the rat. Nutr Rep Int 10: 79–88.
Kofoed, AB; Deen, L; Hougaard, KS; Petersen, KU; Meyer, HW; Pedersen, EB; Ebbehøj, NE; Heitmann, BL; Bonde, JP; Tøttenborg, SS. (2021). Maternal exposure to airborne polychlorinated biphenyls (PCBs) and risk of adverse birth outcomes. Eur J Epidemiol 36: 861–872. 10.1007/s10654-021-00793-x.34420151
Koldkjær, OG; Wermuth, L; Bjerregaard, P. (2003). Parkinson's disease among Inuit in Greenland: Organochlorines as risk factors. Int J Circumpolar Health 63: 366–368. 10.3402/ijch.v63i0.17937.
Koller, LD; Zinkl, JG. (1973). Pathology of polychlorinated biphenyls in rabbits. Am J Pathol 70: 363–378.4120300
Koopman-Esseboom, C; Morse, DC; Weisglas-Kuperus, N; Lutkeschipholt, IJ; Van der Paauw, CG; Tuinstra, LGM; Brouwer, A; Sauer, PJJ. (1994). Effects of dioxins and polychlorinated biphenyls on thyroid hormone status of pregnant women and their infants. Pediatr Res 36: 468–473. 10.1203/00006450-199410000-00009.7816522
Koopman-Esseboom, C; Weisglas-Kuperus, N; de Ridder, MAJ; Van der Paauw, CG; Tuinstra, LGM; Sauer, PJJ. (1996). Effects of polychlorinated biphenyl/dioxin exposure and feeding type on infants' mental and psychomotor development. Pediatrics 97: 700–706. 10.1542/peds.97.5.700.8628610
Korrick, SA; Lee, MM; Williams, PL; Sergeyev, O; Burns, JS; Patterson, DG; Turner, WE; Needham, LL; Altshul, L; Revich, B; Hauser, R. (2011). Dioxin exposure and age of pubertal onset among Russian boys. Environ Health Perspect 119: 1339–1344. 10.1289/ehp.1003102.21527364
Koskenniemi, JJ; Virtanen, HE; Kiviranta, H; Damgaard, I; Matomaki, J; Thorup, JM; Hurme, T; Skakkebaek, NE; Main, KM; Toppari, J. (2015). Association between levels of persistent organic pollutants in adipose tissue and cryptorchidism in early childhood: A case-control study. Environ Health 14: 78. 10.1186/s12940-015-0065-0.26403566
Koštiaková, V; Moleti, A; Wimmerová, S; Jusko, TA; Palkoviဝová Murínová, Ľ; Sisto, R; Richterová, D; Kováč, J; Čonka, K; Patayová, H; Tihanyi, J; Trnovec, T. (2016). DPOAEs in infants developmentally exposed to PCBs show two differently time spaced exposure sensitive windows. Chemosphere 161: 518–526. 10.1016/j.chemosphere.2016.07.045.27470944
Kostyniak, PJ; Hansen, LG; Widholm, JJ; Fitzpatrick, RD; Olson, JR; Helferich, JL; Kim, KH; Sable, HJK; Seegal, RF; Pessah, IN; Schantz, SL. (2005). Formulation and characterization of an experimental PCB mixture designed to mimic human exposure from contaminated fish. Toxicol Sci 88: 400–411. 10.1093/toxsci/kfi338.16177234
Kouidrat, Y; Pizzol, D; Cosco, T; Thompson, T; Carnaghi, M; Bertoldo, A; Solmi, M; Stubbs, B; Veronese, N. (2017). High prevalence of erectile dysfunction in diabetes: a systematic review and meta-analysis of 145 studies. Diabet Med 34: 1185–1192. 10.1111/dme.13403.28722225
Krampl, V; Kontseková, M. (1978). Effect of polychlorinated biphenyls on the elimination rate of antipyrine from plasma of rats and man. Bull Environ Contam Toxicol 20: 191–198. 10.1007/BF01683508.100158
Kreiss, K; Zack, MM; Kimbrough, RD; Needham, LL; Smrek, AL; Jones, BT. (1981). Association of blood pressure and polychlorinated biphenyl levels. JAMA 245: 2505–2509. 10.1001/jama.1981.03310490023017.6785463
Krishnan, K; Mittal, N; Thompson, LM; Rodriguez-Santiago, M; Duvauchelle, CL; Crews, D; Gore, AC. (2018). Effects of the Endocrine-Disrupting Chemicals, Vinclozolin and Polychlorinated Biphenyls, on Physiological and Sociosexual Phenotypes in F2 Generation Sprague-Dawley Rats. Environ Health Perspect 126: 97005. 10.1289/EHP3550.30212226
Krishnan, K; Rahman, S; Hasbum, A; Morales, D; Thompson, LM; Crews, D; Gore, AC. (2019). Maternal care modulates transgenerational effects of endocrine-disrupting chemicals on offspring pup vocalizations and adult behaviors. Horm Behav 107: 96–109. 10.1016/j.yhbeh.2018.12.009.30576639
Kristensen, SL; Ramlau-Hansen, CH; Ernst, E; Olsen, SF; Bonde, JP; Vested, A; Halldorsson, TI; Rantakokko, P; Kiviranta, H; Toft, G. (2016). Prenatal exposure to persistent organochlorine pollutants and female reproductive function in young adulthood. Environ Int 92–93: 366–372. 10.1016/j.envint.2016.04.024.
Krönke, AA; Jurkutat, A; Schlingmann, M; Poulain, T; Nüchter, M; Hilbert, A; Kiviranta, H; Körner, A; Vogel, M; Söder, O; Bornehag, CG; Kiess, W. (2022). Persistent organic pollutants in pregnant women potentially affect child development and thyroid hormone status. Pediatr Res 91: 690–698. 10.1038/s41390-021-01488-5.33824444
Krysiak-Baltyn, K; Toppari, J; Skakkebaek, NE; Jensen, TS; Virtanen, HE; Schramm, KW; Shen, H; Vartiainen, T; Kiviranta, H; Taboureau, O; Audouze, K; Brunak, S; Main, KM. (2012). Association between chemical pattern in breast milk and congenital cryptorchidism: modelling of complex human exposures. Int J Androl 35: 294–302. 10.1111/j.1365-2605.2012.01268.x.22519522
Kunita, N; Hori, S; Obana, H; Otake, T; Nishimura, H; Kashimoto, T; Ikegami, N. (1985). Biological effect of PCBs, PCQs and PCDFs present in the oil causing Yusho and Yu-Cheng. Environ Health Perspect 59: 79–84. 10.2307/3429878.3921369
Kunita, N; Kashimoto, T; Miyata, H; Fukushima, S; Hori, S; Obana, H. (1984). Causal agents of Yusho. Am J Ind Med 5: 45–58. 10.1002/ajim.4700050106.6422749
Kyriklaki, A; Vafeiadi, M; Kampouri, M; Koutra, K; Roumeliotaki, T; Chalkiadaki, G; Anousaki, D; Rantakokko, P; Kiviranta, H; Fthenou, E; Bitsios, P; Kyrtopoulos, SA; Kogevinas, M; Chatzi, L. (2016). Prenatal exposure to persistent organic pollutants in association with offspring neuropsychological development at 4years of age: The Rhea mother-child cohort, Crete, Greece. Environ Int 97: 204–211. 10.1016/j.envint.2016.09.012.27666324
Laisi, S; Kiviranta, H; Lukinmaa, PL; Vartiainen, T; Alaluusua, S. (2008). Molar-incisor-hypomineralisation and dioxins: New findings. Eur Arch Paediatr Dent 9: 224–227. 10.1007/BF03262639.19054476
Lala, V; Goyal, A; Bansal, P; Minter, DA. (2022). Liver function tests. In StatPearls. Treasure Island, FL: StatPearls Publishing. http://www.ncbi.nlm.nih.gov/books/nbk482489/.
Lambertino, A; Persky, V; Freels, S; Anderson, H; Unterman, T; Awadalla, S; Turyk, M. (2021). Associations of PCBS, dioxins and furans with follicle-stimulating hormone and luteinizing hormone in postmenopausal women: National Health and Nutrition Examination Survey 1999–2002. Chemosphere 262: 128309. 10.1016/j.chemosphere.2020.128309.33182091
Lambertino, A; Turyk, M; Anderson, H; Freels, S; Persky, V. (2011). Uterine leiomyomata in a cohort of Great Lakes sport fish consumers. Environ Res 111: 565–572. 10.1016/j.envres.2011.01.006.21310402
Landreth, KS. (2002). Critical windows in development of the rodent immune system [Review]. Hum Exp Toxicol 21: 493–498. 10.1191/0960327102ht287oa.12458906
Landreth, KS. (2005). Rodent immune system, development of the. In HW Vohr (Ed.), Encyclopedic reference of immunotoxicology (pp. 566–567). Berlin, Germany: Springer. 10.1007/3-540-27806-0_1297.
Langer, P; Kausitz, J; Tajtáková, M; Kocan, A; Bohov, P; Hanzen, E; Klimes, I. (2001). Further studies of blood levels of some tumor markers in the area polluted by polychlorinated biphenyls and control population. Neoplasma 48: 139–143.11478695
Langer, P; Kočan, A; Tajtáková, M; Petrík, J; Chovancová, J; Drobná, B; Jursa, S; Pavúk, M; Koška, J; Trnovec, T; Šeböková, E; Klimeš, I. (2003). Possible effects of polychlorinated biphenyls and organochlorinated pesticides on the thyroid after long-term exposure to heavy environmental pollution. J Occup Environ Med 45: 526–532. 10.1097/01.jom.0000058346.05741.b0.12762077
Langer, P; Kocan, A; Tajtaková, M; Petrik, J; Chovancova, J; Drobna, B; Jursa, S; Pavuk, M; Trnovec, T; Seböková, E; Klimes, I. (2005). Human thyroid in the population exposed to high environmental pollution by organochlorinated pollutants for several decades. Endocr Regul 39: 13–20.16107134
Langer, P; Kočan, A; Tajtaková, M; Petrík, J; Chovancová, J; Drobná, B; Jursa, S; Rádiková, Ž; Koška, J; Kšinantová, L; Hučková, M; Imrich, R; Wimmerová, S; Gašperíková, D; Shishiba, Y; Trnovec, T; Šeböková, E; Klimeš, I. (2007a). Fish from industrially polluted freshwater as the main source of organochlorinated pollutants and increased frequency of thyroid disorders and dysglycemia. Chemosphere 67: S379–S385. 10.1016/j.chemosphere.2006.05.132.17222442
Langer, P; Kocan, A; Tajtáková, M; Rádiková, Z; Petrík, J; Koska, J; Ksinantová, L; Imrich, R; Hucková, M; Chovancová, J; Drobná, B; Jursa, S; Bergman, A; Athanasiadou, M; Hovander, L; Gasperíková, D; Trnovec, T; Seböková, E; Klimes, I. (2007b). Possible effects of persistent organochlorinated pollutants cocktail on thyroid hormone levels and pituitary-thyroid interrelations. Chemosphere 70: 110–118. 10.1016/j.chemosphere.2007.06.046.17692893
Langer, P; Kocan, A; Tajtáková, M; Susienková, K; Rádiková, Z; Koska, J; Ksinantová, L; Imrich, R; Hucková, M; Drobná, B; Gasperíková, D; Trnovec, T; Klimes, I. (2009). Multiple adverse thyroid and metabolic health signs in the population from the area heavily polluted by organochlorine cocktail (PCB, DDE, HCB, dioxin). Thyroid Res 2: 3. 10.1186/1756-6614-2-3.19335881
Langer, P; Tajtakova, M; Guretzki, HJ; Kocan, A; Petrik, J; Chovancova, J; Drobna, B; Jursa, S; Pavuk, M; Trnovec, T; Sebokova, E; Klimes, I. (2002). High prevalence of anti-glutamic acid decarboxylase (anti-GAD) antibodies in employees at a polychlorinated biphenyl production factory. Arch Environ Health 57: 412–415. 10.1080/00039890209601429.12641181
Langer, P; Tajtaková, M; Kocan, A; Vlcek, M; Petrik, J; Chovancova, J; Drobna, B; Jursa, S; Pavuk, M; Trnovec, T; Sebokova, E; Klimes, I. (2006). Multiple organochlorine pollution and the thyroid. Endocr Regul 40: 46–52.17100546
Lasky, RE; Widholm, JJ; Crofton, KM; Schantz, SL. (2002). Perinatal exposure to Aroclor 1254 impairs distortion product otoacoustic emissions (DPOAEs) in rats. Toxicol Sci 68: 458–464. 10.1093/toxsci/68.2.458.12151642
Lawton, RW; Ross, MR; Feingold, J. (1986). Spirometric findings in capacitor workers occupationally exposed to polychlorinated biphenyls (PCBs). J Occup Med 28: 453–456. 10.1097/00043764-198606000-00014.3088230
Lawton, RW; Ross, MR; Feingold, J; Brown, JF, Jr. (1985). Effects of PCB exposure on biochemical and hematological findings in capacitor workers. Environ Health Perspect 60: 165–184.2863133
Lee, D; Lind, PM; Jacobs, DR, Jr; Salihovic, S; van Bavel, B; Lind, L. (2012). Background exposure to persistent organic pollutants predicts stroke in the elderly. Environ Int 47: 115–120. 10.1016/j.envint.2012.06.009.22809777
Lee, DH; Jacobs, DR; Kocher, T. (2008). Associations of Serum Concentrations of Persistent Organic Pollutants with the Prevalence of Periodontal Disease and Subpopulations of White Blood Cells. Environ Health Perspect 116: 1558–1562. 10.1289/ehp.11425.19057711
Lee, DH; Jacobs, DR; Porta, M. (2007a). Association of serum concentrations of persistent organic pollutants with the prevalence of learning disability and attention deficit disorder. J Epidemiol Community Health 61: 591–596. 10.1136/jech.2006.054700.17568050
Lee, DH; Lee, IK; Porta, M; Steffes, M; Jacobs, DR, Jr. (2007b). Relationship between serum concentrations of persistent organic pollutants and the prevalence of metabolic syndrome among non-diabetic adults: Results from the National Health and Nutrition Examination Survey 1999–2002. Diabetologia 50: 1841–1851. 10.1007/s00125-007-0755-4.17624515
Lee, DH; Steffes, M; Jacobs, DR, Jr. (2007c). Positive associations of serum concentration of polychlorinated biphenyls or organochlorine pesticides with self-reported arthritis, especially rheumatoid type, in women. Environ Health Perspect 115: 883–888. 10.1289/ehp.9887.17589595
Lee, DH; Steffes, MW; Sjödin, A; Jones, RS; Needham, LL; Jacobs, DR. (2010). Low dose of some persistent organic pollutants predicts type 2 diabetes: A nested case-control study. Environ Health Perspect 118: 1235–1242. 10.1289/ehp.0901480.20444671
Lee, DH; Steffes, MW; Sjödin, A; Jones, RS; Needham, LL; Jacobs, DR, Jr. (2011). Low dose organochlorine pesticides and polychlorinated biphenyls predict obesity, dyslipidemia, and insulin resistance among people free of diabetes. PLoS ONE 6: e15977. 10.1371/journal.pone.0015977.21298090
Lee, DY; Kim, E; Choi, MH. (2015). Technical and clinical aspects of cortisol as a biochemical marker of chronic stress. BMB Rep 48: 209–216. 10.5483/bmbrep.2015.48.4.275.25560699
Lee, E; Kinninger, A; Ursin, G; Tseng, C; Hurley, S; Wang, M; Wang, Y; Park, JS; Petreas, M; Deapen, D; Reynolds, P. (2020). Serum levels of commonly detected persistent organic pollutants and per- and polyfluoroalkyl substances (PFASs) and mammographic density in postmenopausal women. Int J Environ Res Public Health 17: 606. 10.3390/ijerph17020606.31963577
Lee, HA; Park, SH; Hong, YS; Ha, EH; Park, H. (2016). The effect of exposure to persistent organic pollutants on metabolic health among Korean children during a 1-year follow-up. Int J Environ Res Public Health 13: 270. 10.3390/ijerph13030270.26938545
Lee, YM; Kim, KS; Kim, SA; Hong, NS; Lee, SJ; Lee, DH. (2014). Prospective associations between persistent organic pollutants and metabolic syndrome: A nested case-control study. Sci Total Environ 496: 219–225. 10.1016/j.scitotenv.2014.07.039.25089684
Lee, YM; Kim, SA; Choi, GS; Park, SY; Jeon, SW; Lee, HS; Lee, SJ; Heo, S; Lee, DH. (2018). Association of colorectal polyps and cancer with low-dose persistent organic pollutants: A case-control study. PLoS ONE 13: e0208546. 10.1371/journal.pone.0208546.30521631
Lehmann, GM; Christensen, K; Maddaloni, M; Phillips, LJ. (2015). Evaluating health risks from inhaled polychlorinated biphenyls: research needs for addressing uncertainty. Environ Health Perspect 123: 109–113. 10.1289/ehp.1408564.25302536
Leijs, MM; Koppe, JG; Olie, K; de Voogt, P; van Aalderen, WMC; Ten Tusscher, GW. (2018). Exposure to Environmental Contaminants and Lung Function in Adolescents-Is There a Link? Int J Environ Res Public Health 15. 10.3390/ijerph15071352.
Leijs, MM; Koppe, JG; Olie, K; van Aalderen, WM; de Voogt, P; ten Tusscher, GW. (2009). Effects of dioxins, PCBs, and PBDEs on immunology and hematology in adolescents. Environ Sci Technol 43: 7946–7951. 10.1021/es901480f.19921918
Leijs, MM; Koppe, JG; Olie, K; van Aalderen, WMC; de Voogt, P; Vulsma, T; Westra, M; ten Tusscher, GW. (2008). Delayed initiation of breast development in girls with higher prenatal dioxin exposure; a longitudinal cohort study. Chemosphere 73: 999–1004. 10.1016/j.chemosphere.2008.05.053.18707752
Lenters, V; Iszatt, N; Forns, J; Čechová, E; Kočan, A; Legler, J; Leonards, P; Stigum, H; Eggesbø, M. (2019). Early-life exposure to persistent organic pollutants (OCPs, PBDEs, PCBs, PFASs) and attention-deficit/hyperactivity disorder: A multi-pollutant analysis of a Norwegian birth cohort. Environ Int 125: 33–42. 10.1016/j.envint.2019.01.020.30703609
Levin, ED; Schantz, SL; Bowman, RE. (1988). Delayed spatial alternation deficits resulting from perinatal PCB exposure in monkeys. Arch Toxicol 62: 267–273. 10.1007/BF00332486.3149182
Li, MC; Wu, HP; Yang, CY; Chen, PC; Lambert, GH; Leon Guo, Y. (2015). Gestational exposure to polychlorinated biphenyls and dibenzofurans induced asymmetric hearing loss: Yucheng children study. Environ Res 137: 65–71. 10.1016/j.envres.2014.12.002.25490244
Li, P; Dan, Y; Li, S; Zhang, Q; Su, Y; Lu, M. (2020). Serum levels of polychlorinated biphenyls and stroke risk among Chinese: A hospital-based case-control study. Acta Neurol Belg. 10.1007/s13760-020-01392-5.
Liberda, EN; Zuk, AM; Tsuji, LJS. (2019). Complex contaminant mixtures and their associations with intima-media thickness. BMC Cardiovasc Disord 19: 289. 10.1186/s12872-019-1246-5.31830904
Liberda, EN; Zuk, AM; Tsuji, LJS. (2021). Heart rate variation and human body burdens of environmental mixtures in the Cree First Nation communities of Eeyou Istchee, Canada. Environ Int 146: 106220. 10.1016/j.envint.2020.106220.33120227
Liebl, B; Schettgen, T; Kerscher, G; Broding, HC; Otto, A; Angerer, J; Drexler, H. (2004). Evidence for increased internal exposure to lower chlorinated polychlorinated biphenyls (PCB) in pupils attending a contaminated school. Int J Hyg Environ Health 207: 315–324. 10.1078/1438-4639-00296.15471095
Lilienthal, H; Hack, A; Roth-Härer, A; Grande, SW; Talsness, CE. (2006). Effects of developmental exposure to 2,2 ,4,4 ,5-pentabromodiphenyl ether (PBDE-99) on sex steroids, sexual development, and sexually dimorphic behavior in rats. Environ Health Perspect 114: 194–201. 10.1289/ehp.8391.16451854
Lilienthal, H; Neuf, M; Munoz, C; Winneke, G. (1990). Behavioral effects of pre- and postnatal exposure to a mixture of low chlorinated PCBs in rats. Fundam Appl Toxicol 15: 457–467. 10.1093/toxsci/15.3.457.2124194
Lilienthal, H; Winneke, G. (1991). Sensitive periods for behavioral toxicity of polychlorinated biphenyls: Determination by cross-fostering in rats. Fundam Appl Toxicol 17: 368–375. 10.1016/0272-0590(91)90226-T.1765224
Lim, JE; Lee, S; Lee, S; Jee, SH. (2018). Serum persistent organic pollutants levels and stroke risk. Environ Pollut 233: 855–861. 10.1016/j.envpol.2017.12.031.29248762
Lin, BG; Chen, CR; Chen, XC; Qiao, J; Yan, QX; Yang, P; Chen, WL; Li, LZ; Qiu, PC; Ding, C; Huang, DJ; Yu, YJ. (2021). Effects of organochlorine exposure on male reproductive disorders in an electronic waste area of South China. Environ Int 147: 106318. 10.1016/j.envint.2020.106318.33387882
Lin, KC; Guo, NW; Tsai, PC; Yang, CY; Guo, YL. (2008). Neurocognitive changes among elderly exposed to PCBs/PCDFs in Taiwan. Environ Health Perspect 116: 184–189. 10.1289/ehp.10134.18288316
Lin, KC; Huang, PC; Yeh, DS; Kuo, JR; Ke, PS. (2010). Comparing mini-mental state examination and attention and digit span in elderly exposed to polychlorinated biphenyls and polychlorinated dibenzofurans. Psychogeriatrics 10: 191–197. 10.1111/j.1479-8301.2010.00341.x.21159054
Lind, L; Salihovic, S; Lampa, E; Lind, PM. (2017). Mixture effects of 30 environmental contaminants on incident metabolic syndrome-A prospective study. Environ Int 107: 8–15. 10.1016/j.envint.2017.06.005.28648904
Lind, PM; van Bavel, B; Salihovic, S; Lind, L. (2012). Circulating levels of persistent organic pollutants (POPs) and carotid atherosclerosis in the elderly. Environ Health Perspect 120: 38–43. 10.1289/ehp.1103563.22222676
Linder, RE; Gaines, TB; Kimbrough, RD. (1974). The effect of polychlorinated biphenyls on rat reproduction. Food Cosmet Toxicol 12: 63–77. 10.1016/0015-6264(74)90322-8.4218577
Lipsky, MM; Klaunig, JE; Hinton, DE. (1978). Comparison of acute response to polychlorinated biphenyl in liver of rat and channel catfish: A biochemical and morphological study. J Toxicol Environ Health 4: 107–121. 10.1080/15287397809529648.416227
Litterst, CL; Farber, TM; Baker, AM; Van Loon, EJ. (1972). Effect of polychlorinated biphenyls on hepatic microsomal enzymes in the rat. Toxicol Appl Pharmacol 23: 112–122. 10.1016/0041–008X(72)90210–4.4341899
Liu, J; Liu, Y; Barter, RA; Klaassen, CD. (1995). Alteration of thyroid homeostasis by UDP-glucuronosyltransferase inducers in rats: a dose-response study. J Pharmacol Exp Ther 273: 977–985.7752103
Liu, X; Zhang, L; Chen, L; Li, J; Wang, J; Zhao, Y; Liu, L; Wu, Y. (2021). Identification and prioritization of the potent components for combined exposure of multiple persistent organic pollutants associated with gestational diabetes mellitus. J Hazard Mater 409: 124905. 10.1016/j.jhazmat.2020.124905.33412473
Liu, X; Zhang, L; Li, J; Wang, J; Meng, G; Chi, M; Zhao, Y; Wu, Y. (2019). Relative Effect Potency Estimates for Dioxin-Like Compounds in Pregnant Women with Gestational Diabetes Mellitus and Blood Glucose Outcomes Based on a Nested Case-control Study. Environ Sci Technol 53: 7792–7802. 10.1021/acs.est.9b00988.31149810
Lombardo, JP; Berger, DF; Hunt, A; Carpenter, DO. (2015). Inhalation of polychlorinated biphenyls (PCB) produces hyperactivity in rats. J Toxicol Environ Health A 78: 1142–1153. 10.1080/15287394.2015.1060913.26398098
Longnecker, MP; Gladen, BC; Patterson, DG, Jr; Rogan, WJ. (2000). Polychlorinated biphenyl (PCB) exposure in relation to thyroid hormone levels in neonates. Epidemiology 11: 249–254. 10.1097/00001648-200005000-00004.10784239
Longnecker, MP; Hoffman, HJ; Klebanoff, MA; Brock, JW; Zhou, H; Needham, L; Adera, T; Guo, X; Gray, KA. (2004). In utero exposure to polychlorinated biphenyls and sensorineural hearing loss in 8-year-old children. Neurotoxicol Teratol 26: 629–637. 10.1016/j.ntt.2004.04.007.15315812
Longnecker, MP; Klebanoff, MA; Brock, JW; Guo, X. (2005). Maternal levels of polychlorinated biphenyls in relation to preterm and small-for-gestational-age birth. Epidemiology 16: 641–647. 10.1097/01.ede.0000172137.45662.85.16135940
Loose, LD; Pittman, KA; Benitz, KF; Silkworth, JB; Mueller, W; Coulston, F. (1978a). Environmental chemical-induced immune dysfunction. Ecotoxicol Environ Saf 2: 173–198. 10.1016/0147-6513(78)90008–8.103706
Loose, LD; Silkworth, JB; Charbonneau, T; Blumenstock, F. (1981). Environmental chemical-induced macrophage dysfunction. Environ Health Perspect 39: 79–92. 10.1289/ehp.813979.7238456
Loose, LD; Silkworth, JB; Mudzinski, SP; Pittman, KA; Benitz, KF; Mueller, W. (1979). Modification of the immune response by organochlorine xenobiotics. Drug Chem Toxicol 2: 111–132. 10.3109/01480547908993185.121284
Loose, LD; Silkworth, JB; Pittman, KA; Benitz, KF; Mueller, W. (1978b). Impaired host resistance to endotoxin and malaria in polychlorinated biphenyl- and hexachlorobenzene-treated mice. Infect Immun 20: 30–35.97225
Lopez-Espinosa, MJ; Vizcaino, E; Murcia, M; Fuentes, V; Garcia, AM; Rebagliato, M; Grimalt, JO; Ballester, F. (2010). Prenatal exposure to organochlorine compounds and neonatal thyroid stimulating hormone levels. J Expo Sci Environ Epidemiol 20: 579–588. 10.1038/jes.2009.47.19707252
Lopez-Giacoman, S; Madero, M. (2015). Biomarkers in chronic kidney disease, from kidney function to kidney damage [Review]. World J Nephrol 4: 57–73. 10.5527/wjn.v4.i1.57.25664247
Lu, TS; Longnecker, MP; Zhou, H. (2017). Statistical inferences for data from studies conducted with an aggregated multivariate outcome-dependent sample design. Stat Med 36: 985–997. 10.1002/sim.7195.27966260
Lubet, RA; Lemaire, BN; Avery, D; Kouri, RE. (1986). Induction of immunotoxicity in mice by polyhalogenated biphenyls. Arch Toxicol 59: 71–77. 10.1007/BF00286726.3092783
Lucas, M; Dewailly, E; Muckle, G; Ayotte, P; Bruneau, S; Gingras, S; Rhainds, M; Holub, BJ. (2004). Gestational age and birth weight in relation to n-3 fatty acids among Inuit (Canada). Lipids 39: 617–626. 10.1007/s11745-004-1274-7.15588018
Lucion, AB; Bortolini, MC. (2014). Mother-pup interactions: rodents and humans [Review]. Front Endocrinol (Lausanne) 5: 17. 10.3389/fendo.2014.00017.24616713
Luderer, U; Eskenazi, B; Hauser, R; Korach, KS; McHale, CM; Moran, F; Rieswijk, L; Solomon, G; Udagawa, O; Zhang, L; Zlatnik, M; Zeise, L; Smith, MT. (2019). Proposed key characteristics of female reproductive toxicants as an approach for organizing and evaluating mechanistic data in hazard assessment. Environ Health Perspect 127: 75001. 10.1289/EHP4971.31322437
Lundkvist, U; Kindahl, H. (1989). Plasma concentrations of 15-keto-13,14-dihydro-PGF-2 alpha, oestrone sulphate, oestradiol-17 beta and progesterone in pregnant guinea-pigs treated with polychlorinated biphenyls. J Reprod Fertil 87: 55–62.2560062
Lundkvist, U; Kindahl, H; Madej, A. (1987). Urinary levels of estrone sulfate and 11-ketotetranor prostaglandin F metabolite in pregnant guinea pigs given Clophen A50 (polychlorinated biphenyls). Biol Reprod 36: 109–116. 10.1095/biolreprod36.1.109.3105611
Luster, Ml; Portier, C; Pait, DG; White, KL, Jr; Gennings, C; Munson, AE; Rosenthal, GJ. (1992). Risk assessment in immunotoxicology. I. Sensitivity and predictability of immune tests. Fundam Appl Toxicol 18: 200–210. 10.1016/0272-0590(92)90047-L.1534777
Lyall, K; Croen, LA; Sjödin, A; Yoshida, CK; Zerbo, O; Kharrazi, M; Windham, GC. (2017). Polychlorinated Biphenyl and Organochlorine Pesticide Concentrations in Maternal Mid-Pregnancy Serum Samples: Association with Autism Spectrum Disorder and Intellectual Disability. Environ Health Perspect 125: 474–480. 10.1289/EHP277.27548254
Lynch, CD; Jackson, LW; Kostyniak, PJ; McGuinness, BM; Buck Louis, GM. (2012). The effect of prenatal and postnatal exposure to polychlorinated biphenyls and child neurodevelopment at age twenty four months. Reprod Toxicol 34: 451–456. 10.1016/j.reprotox.2012.04.013.22569275
Madra, S; Styles, J; Smith, AG. (1995). Perturbation of hepatocyte nuclear populations induced by iron and polychlorinated biphenyls in C57BL/10ScSn mice during carcinogenesis. Carcinogenesis 16: 719–727. 10.1093/carcin/16.4.719.7728949
Maervoet, J; Vermeir, G; Covaci, A; Van Larebeke, N; Koppen, G; Schoeters, G; Nelen, V; Baeyens, W; Schepens, P; Viaene, MK. (2007). Association of thyroid hormone concentrations with levels of organochlorine compounds in cord blood of neotates. Environ Health Perspect 115: 1780–1786. 10.1289/ehp.10486.18087600
Magnusdottir, EV; Thorsteinsson, T; Thorsteinsdottir, S; Heimisdottir, M; Olafsdottir, K. (2005). Persistent organochlorines, sedentary occupation, obesity and human male subfertility. Hum Reprod 20: 208–215. 10.1093/humrep/deh569.15567884
Mai, JK; Paxinos, G. (2012). The human nervous system (3rd ed.). Cambridge, MA: Academic Press. 10.1016/C2009-0-02721-4.
Makris, SL; Thompson, CM; Euling, SY; Selevan, SG; Sonawane, B. (2008). A lifestage-specific approach to hazard and dose-response characterization for children's health risk assessment [Review]. Birth Defects Res B Dev Reprod Toxicol 83: 530–546. 10.1002/bdrb.20176.19085945
Mallin, K; McCann, K; D'Aloisio, A; Freels, S; Piorkowski, J; Dimos, J; Persky, V. (2004). Cohort mortality study of capacitor manufacturing workers, 1944–2000. J Occup Environ Med 46: 565–576. 10.1097/01.jom.0000128156.24767.12.15213519
Mallya, M; Ogilvy-Stuart, AL. (2018). Thyrotropic hormones. Best Pract Res Clin Endocrinol Metab 32: 17–25. 10.1016/j.beem.2017.10.006.29549956
Mangelsdorf, I; Buschmann, J; Orthen, B. (2003). Some aspects relating to the evaluation of the effects of chemicals on male fertility [Review]. Regul Toxicol Pharmacol 37: 356–369. 10.1016/S0273-2300(03)00026–6.12758216
Marks, KJ; Howards, PP; Smarr, MM; Flanders, WD; Northstone, K; Daniel, JH; Calafat, AM; Sjödin, A; Marcus, M; Hartman, TJ. (2021). Prenatal exposure to mixtures of persistent endocrine disrupting chemicals and early menarche in a population-based cohort of British girls. Environ Pollut 276: 116705. 10.1016/j.envpol.2021.116705.33592441
Maroni, M; Colombi, A; Antonini, C; Foa, V. (1980). Health effects of long-term occupational exposure to polychlorinated biphenyls. Dev Toxicol Environ Sci 8: 351–355.6458489
Marshall, WA; Tanner, JM. (1969). Variations in pattern of pubertal changes in girls. Arch Dis Child 44: 291–303. 10.1136/adc.44.235.291.5785179
Martínez-Zamora, MA; Mattioli, L; Parera, J; Abad, E; Coloma, JL; van Babel, B; Galceran, MT; Balasch, J; Carmona, F. (2015). Increased levels of dioxin-like substances in adipose tissue in patients with deep infiltrating endometriosis. Hum Reprod 30: 1059–1068. 10.1093/humrep/dev026.25743783
Mathiasen, J; Dicamillo, A. (2010). Social recognition assay in the rat. Curr Protoc Neurosci 53: 8.51.51–58.51.15. 10.1002/0471142301.ns0805is53.
Matovu, H; Li, ZM; Henkelmann, B; Bernhöft, S; De Angelis, M; Schramm, KW; Sillanpää, M; Kato, CD; Ssebugere, P. (2021). Multiple persistent organic pollutants in mothers' breastmilk: Implications for infant dietary exposure and maternal thyroid hormone homeostasis in Uganda, East Africa. Sci Total Environ 770: 145262. 10.1016/j.scitotenv.2021.145262.33513488
Mayes, BA; McConnell, EE; Neal, BH; Brunner, MJ; Hamilton, SB; Sullivan, TM; Peters, AC; Ryan, MJ; Toft, JD; Singer, AW; Brown, JF, Jr; Menton, RG; Moore, JA. (1998). Comparative carcinogenicity in Sprague-Dawley rats of the polychlorinated biphenyl mixtures Aroclors 1016, 1242, 1254, and 1260. Toxicol Sci 41: 62–76. 10.1006/toxs.1997.2397.9520342
Mayo Clinic. (2021). Oral health: A window to your overall health. Available online at https://www.mayoclinic.org/healthy-lifestyle/adult-health/in-depth/dental/art-20047475) (accessed February 16, 2023).
McGuinness, BM; Buck, GM; Mendola, P; Sever, LE; Vena, JE. (2001). Infecundity and consumption of polychlorinated biphenyl-contaminated fish. Arch Environ Health 56: 250–253. 10.1080/00039890109604449.11480501
Medehouenou, TC; Ayotte, P; Carmichael, PH; Kröger, E; Verreault, R; Lindsay, J; Dewailly, É; Tyas, SL; Bureau, A; Laurin, D. (2014). Plasma polychlorinated biphenyl and organochlorine pesticide concentrations in dementia: the Canadian Study of Health and Aging. Environ Int 69: 141–147. 10.1016/j.envint.2014.04.016.24846810
Medehouenou, TCM; Ayotte, P; Carmichael, PH; Kröger, É; Verreault, R; Lindsay, J; Dewailly, E; Tyas, SL; Bureau, A; Laurin, D. (2019). Exposure to polychlorinated biphenyls and organochlorine pesticides and risk of dementia, Alzheimer's disease and cognitive decline in an older population: a prospective analysis from the Canadian Study of Health and Aging. Environ Health 18: 57. 10.1186/s12940-019-0494-2.31200706
Meerts, IAT; Hoving, S; van den Berg, JHJ; Weijers, BM; Swarts, HJ; van der Beek, EM; Bergman, Å; Koeman, JH; Brouwer, A. (2004a). Effects of in utero exposure to 4-hydroxy-2,3,3',4',5-pentachlorobiphenyl (4-OH-CB107) on developmental landmarks, steroid hormone levels, and female estrous cyclicity in rats. Toxicol Sci 82: 259–267. 10.1093/toxsci/kfh251.15310862
Meerts, IAT; Lilienthal, H; Hoving, S; van der Berg, JHJ; Weijers, BM; Bergman, Å; Koeman, JH; Brouwer, A. (2004b). Developmental exposure to 4-hydroxy-2,3,3',4',5-pentachlorobiphenyl (4-OH-CB107): Long-term effects on brain development, behavior, and brain stem auditory evoked potentials in rats. Toxicol Sci 82: 207–218. 10.1093/toxsci/kfh252.15310863
Meijer, L; Martijn, A; Melessen, J; Brouwer, A; Weiss, J; de Jong, FH; Sauer, PJ. (2012). Influence of prenatal organohalogen levels on infant male sexual development: Sex hormone levels, testes volume and penile length. Hum Reprod 27: 867–872. 10.1093/humrep/der426.22215630
Mele, PC; Bowman, RE; Levin, ED. (1986). Behavioral evaluation of perinatal PCB exposure in rhesus monkeys: Fixed-interval performance and reinforcement-omission. Neurobehav Toxicol Teratol 8: 131–138.3086763
Mendiola, J; Stahlhut, RW; Jørgensen, N; Liu, F; Swan, SH. (2011). Shorter anogenital distance predicts poorer semen quality in young men in Rochester, New York. Environ Health Perspect 119: 958–963. 10.1289/ehp.1103421.21377950
Mendola, P; Buck, GM; Sever, LE; Vena, JE; Zielezny, M. (1995). Consumption of PCB contaminated fresh water fish and shortened menstrual cycle [Abstract]. Am J Epidemiol 141: S80.
Mendola, P; Buck, GM; Sever, LE; Zielezny, M; Vena, JE. (1997). Consumption of PCB-contaminated freshwater fish and shortened menstrual cycle length. Am J Epidemiol 146: 955–960.9400337
Meng, G; Feng, Y; Nie, Z; Wu, X; Wei, H; Wu, S; Yin, Y; Wang, Y. (2016a). Internal exposure levels of typical POPs and their associations with childhood asthma in Shanghai, China. Environ Res 146: 125–135. 10.1016/j.envres.2015.12.026.26748225
Meng, G; Nie, Z; Feng, Y; Wu, X; Yin, Y; Wang, Y. (2016b). Typical halogenated persistent organic pollutants in indoor dust and the associations with childhood asthma in Shanghai, China. Environ Pollut 211: 389–398. 10.1016/j.envpol.2015.12.006.26798999
Mennigen, JA; Thompson, LM; Bell, M; Tellez Santos, M; Gore, AC. (2018). Transgenerational effects of polychlorinated biphenyls: 1. Development and physiology across 3 generations of rats. Environ Health 17: 18. 10.1186/s12940-018-03625.29458364
Meserve, LA; Murray, BA; Landis, JA. (1992). Influence of maternal ingestion of Aroclor 1254 (PCB) or FireMaster BP-6 (PBB) on unstimulated and stimulated corticosterone levels in young rats. Bull Environ Contam Toxicol 48: 715–720. 10.1007/BF00195992.1324039
Meyer, AE; Miller, MM; Nelms Sprowles, JL; Levine, LR; Sable, HJ. (2015). A comparison of presynaptic and postsynaptic dopaminergic agonists on inhibitory control performance in rats perinatally exposed to PCBs. Neurotoxicol Teratol 50: 11–22. 10.1016/j.ntt.2015.05.009.26022001
Miller, LA; Royer, CM; Pinkerton, KE; Schelegle, ES. (2017a). Nonhuman Primate Models of Respiratory Disease: Past, Present, and Future. ILAR J 58: 1–12. 10.1093/ilar/ilx030.28586416
Miller, MM; Meyer, AE; Sprowles, JLN; Sable, HJK. (2017b). Cocaine self-administration in male and female rats perinatally exposed to PCBs: Evaluating drug use in an animal model of environmental contaminant exposure. Exp Clin Psychopharmacol 25: 114–124. 10.1037/pha0000113.28287790
Min, JY; Kim, R; Min, KB. (2014). Serum polychlorinated biphenyls concentrations and hearing impairment in adults. Chemosphere 102: 6–11. 10.1016/j.chemosphere.2013.11.046.24360845
Mínguez-Alarcón, L; Sergeyev, O; Burns, JS; Williams, PL; Lee, MM; Korrick, SA; Smigulina, L; Revich, B; Hauser, R. (2017). A Longitudinal Study of Peripubertal Serum Organochlorine Concentrations and Semen Parameters in Young Men: The Russian Children's Study. Environ Health Perspect 125: 460–466. 10.1289/EHP25.27713107
Mitchell, MM; Woods, R; Chi, LH; Schmidt, RJ; Pessah, IN; Kostyniak, PJ; Lasalle, JM. (2012). Levels of select PCB and PBDE congeners in human postmortem brain reveal possible environmental involvement in 15q11-q13 duplication autism spectrum disorder. Environ Mol Mutagen 53: 589–598. 10.1002/em.21722.22930557
Mitchell, SH. (2014). Assessing delay discounting in mice. Curr Protoc Neurosci 66: 8.30.31–38.30.12. 10.1002/0471142301.ns0830s66.
Miyashita, C; Araki, A; Mitsui, T; Itoh, S; Goudarzi, H; Sasaki, S; Kajiwara, J; Hori, T; Cho, K; Moriya, K; Shinohara, N; Nonomura, K; Kishi, R. (2018). Sex-related differences in the associations between maternal dioxin-like compounds and reproductive and steroid hormones in cord blood: The Hokkaido study. Environ Int 117: 175–185. 10.1016/j.envint.2018.04.046.29753148
Mlinarić, A; Horvat, M; Šupak Smolčić, V. (2017). Dealing with the positive publication bias: Why you should really publish your negative results [Review]. Biochemia Medica 27: 030201. 10.11613/BM.2017.030201.29180912
Mol, NM; Sørensen, N; Weihe, P; Andersson, AM; Jørgensen, N; Skakkebaek, NE; Keiding, N; Grandjean, P. (2002). Spermaturia and serum hormone concentrations at the age of puberty in boys prenatally exposed to polychlorinated biphenyls. Eur J Endocrinol 146: 357–363. 10.1530/eje.0.1460357.11888842
Monaikul, S; Eubig, P; Floresco, S; Schantz, S. (2017). Strategy set-shifting and response inhibition in adult rats exposed to an environmental polychlorinated biphenyl mixture during adolescence. Neurotoxicol Teratol 63: 14–23. 10.1016/j.ntt.2017.08.002.28822742
Monnet-Tschudi, F; Zurich, MG; Boschat, C; Corbaz, A; Honegger, P. (2006). Involvement of environmental mercury and lead in the etiology of neurodegenerative diseases [Review]. Rev Environ Health 21: 105–117. 10.1515/reveh.2006.21.2.105.16898674
Murai, K; Okamura, K; Tsuji, H; Kajiwara, E; Watanabe, H; Akagi, K; Fujishima, M. (1987). Thyroid function in "Yusho" patients exposed to polychlorinated biphenyls (PCB). Environ Res 44: 179–187. 10.1016/S0013-9351(87)80226–8.3121298
Murk, AJ; van den Berg, JH; Koeman, JH; Brouwer, A. (1991). The toxicity of tetrachlorobenzyltoluenes (Ugilec 141) and polychlorobiphenyls (Aroclor 1254 and PCB-77) compared in Ah-responsive and Ah-nonresponsive mice. Environ Pollut 72: 57–67. 10.1016/0269-7491(91)90155-p.15092114
Murphy, MO; Petriello, MC; Han, SG; Sunkara, M; Morris, AJ; Esser, K; Hennig, B. (2015). Exercise protects against PCB-induced inflammation and associated cardiovascular risk factors. Environ Sci Pollut Res Int 23: 2201–2211. 10.1007/s11356-0144062-6.25586614
Mustieles, V; Fernández, MF; Martin-Olmedo, P; González-Alzaga, B; Fontalba-Navas, A; Hauser, R; Olea, N; Arrebola, JP. (2017). Human adipose tissue levels of persistent organic pollutants and metabolic syndrome components: Combining a cross-sectional with a 10-year longitudinal study using a multi-pollutant approach. Environ Int 104: 48–57. 10.1016/j.envint.2017.04.002.28414931
Nagaoka, S; Kato, M; Aoyama, Y; Yoshida, A. (1986). Comparative studies on the hypercholesterolaemia induced by excess dietary tyrosine or polychlorinated biphenyls in rats. Br J Nutr 56: 509–517. 10.1079/BJN19860130.2890372
Nagayama, J; Kohno, H; Kunisue, T; Kataoka, K; Shimomura, H; Tanabe, S; Konishi, S. (2007a). Concentrations of organochlorine pollutants in mothers who gave birth to neonates with congenital hypothyroidism. Chemosphere 68: 972–976. 10.1016/j.chemosphere.2007.01.010.17307219
Nagayama, J; Tsuji, H; Iida, T; Nakagawa, R; Matsueda, T; Hirakawa, H; Yanagawa, T; Fukushige, J; Watanabe, T. (2007b). Immunologic effects of perinatal exposure to dioxins, PCBs and organochlorine pesticides in Japanese infants. Chemosphere 67: S393–S398. 10.1016/j.chemosphere.2006.05.134.17222440
Nakamoto, M; Arisawa, K; Uemura, H; Katsuura, S; Takami, H; Sawachika, F; Yamaguchi, M; Juta, T; Sakai, T; Toda, E; Mori, K; Hasegawa, M; Tanto, M; Shima, M; Sumiyoshi, Y; Morinaga, K; Kodama, K; Suzuki, T; Nagai, M; Satoh, H. (2013). Association between blood levels of PCDDs/PCDFs/dioxin-like PCBs and history of allergic and other diseases in the Japanese population. Int Arch Occup Environ Health 86: 849–859. 10.1007/s00420-012-0819-8.23014754
Nakanishi, Y; Nomoto, Y; Matsuki, A; Kunitake, R; Hara, N. (1995). Effect of polychlorinated biphenyls and polychlorinated dibenzofurans on leukocyte in peripheral blood and bronchoalveolar lavage fluid. Fukuoka Igaku Zasshi 86: 261–266.7628818
Nakanishi, Y; Shigematsu, N; Kurita, Y; Matsuba, K; Kanegae, H; Ishimaru, S; Kawazoe, Y. (1985). Respiratory involvement and immune status in Yusho patients. Environ Health Perspect 59: 31–36. 10.1289/ehp.59-1568074.3921360
Nakanishi, Y; Tokunaga, S; Takayama, K; Kuwano, K. (2005). Cardiac, pulmonary and renal function in Yusho patients. J Dermatol Sci (Suppl. 1): S33–S38. 10.1016/j.descs.2005.03.006.
Nam, Y; Shin, EJ; Shin, SW; Lim, YK; Jung, JH; Lee, JH; Ha, JR; Chae, JS; Ko, SK; Jeong, JH; Jang, CG; Kim, HC. (2014). YY162 prevents ADHD-like behavioral side effects and cytotoxicity induced by Aroclor1254 via interactive signaling between antioxidant potential, BDNF/TrkB, DAT and NET. Food Chem Toxicol 65: 280–292. 10.1016/j.fct.2013.12.046.24394491
Narbonne, JF. (1979). Effects of age and sex on liver responses to Phenoclor DP6, a polychlorinated biphenyl, in the rat. Bull Environ Contam Toxicol 22: 49–54. 10.1007/BF02026906.111739
Neblett, MF; Curtis, SW; Gerkowicz, SA; Spencer, JB; Terrell, ML; Jiang, VS; Marder, ME; Barr, DB; Marcus, M; Smith, AK. (2020). Examining Reproductive Health Outcomes in Females Exposed to Polychlorinated Biphenyl and Polybrominated Biphenyl. Sci Rep. 10.1038/s41598-020-60234-9.
Nelson, W; Wang, YX; Sakwari, G; Ding, YB. (2020). Review of the effects of perinatal exposure to endocrine-disrupting chemicals in animals and humans. In P de Voogt (Ed.), Reviews of environmental contamination and toxicology, vol 251 (pp. 131–184). New York, NY: Springer. 10.1007/398_2019_30.
Neugebauer, J; Wittsiepe, J; Kasper-Sonnenberg, M; Schöneck, N; Schölmerich, A; Wilhelm, M. (2015). The influence of low level pre- and perinatal exposure to PCDD/Fs, PCBs, and lead on attention performance and attention-related behavior among German school-aged children: Results from the Duisburg Birth Cohort Study. Int J Hyg Environ Health 218: 153–162. 10.1016/j.ijheh.2014.09.005.25456149
Newman, J; Aucompaugh, AG; Schell, LM; Denham, M; DeCaprio, A; Gallo, MV; Ravenscroft, J; Kao, C-C; Rougas, M; Dawn, D; Jacobs, AM; Tarbell, AM; Worswick, P; Akwesasne Task Force on the Environment. (2006). PCBs and cognitive functioning of Mohawk adolescents. Neurotoxicol Teratol 28: 439–445. 10.1016/j.ntt.2006.03.001.16809019
Newman, J; Behforooz, B; Khuzwayo, AG; Gallo, MV; Schell, LM; Akwesasne Task Force on the Environment. (2014). PCBs and ADHD in Mohawk adolescents. Neurotoxicol Teratol 42: 25–34. 10.1016/j.ntt.2014.01.005.24462617
Nguon, K; Baxter, MG; Sajdel-Sulkowska, EM. (2005a). Perinatal exposure to polychlorinated biphenyls differentially affects cerebellar development and motor functions in male and female rat neonates. Cerebellum 4: 112–122. 10.1080/14734220510007860.16035193
Nguon, K; Ladd, B; Baxter, MG; Sajdel-Sulkowska, EM. (2005b). Sexual dimorphism in cerebellar structure, function, and response to environmental perturbations [Review]. In Cl de Zeeuw; F Cicirata (Eds.), Creating coordination in the cerebellum (pp. 341–351). Amsterdam, Netherlands: Elsevier Science. 10.1016/S0079-6123(04)48027-3.
Nishida, N; Farmer, JD; Kodavanti, PRS; Tilson, HA; MacPhail, RC. (1997). Effects of acute and repeated exposures to Aroclor 1254 in adult rats: Motor activity and flavor aversion conditioning. Fundam Appl Toxicol 40: 68–74. 10.1006/faat.1997.2352.9398489
Niskar, A; Needham, LL; Rubin, C; Turner, WE; Martin, CA; Patterson, DG, Jr; Hasty, L; Wong, LY; Marcus, M. (2009). Serum dioxin, polychlorinated biphenyls, and endometriosis: A case-control study in Atlanta. Chemosphere 74: 944–949. 10.1016/j.chemosphere.2008.10.005.19027927
Nobili, V; Alisi, A; Panera, N; Agostoni, C. (2008). Low birth weight and catch-up-growth associated with metabolic syndrome: a ten year systematic review [Review]. Pediatr Endocrinol Rev 6: 241–247.19202511
Nowack, N; Wittsiepe, J; Kasper-Sönnenberg, M; Wilhelm, M; Scholmerich, A. (2015). Influence of low-level prenatal exposure to PCDD/FS and PCBs on empathizing, systemizing and autistic traits: Results from the Duisburg birth cohort study. PLoS ONE 10: e0129906. 10.1371/journal.pone.0129906.26066795
NRC (National Research Council). (1983). Risk assessment in the federal government: Managing the process. Washington, DC: National Academies Press. 10.17226/366.
Ochiai, S; Shimojo, N; Igoshi, Y; Watanabe, M; Matsuno, Y; Suzuki, S; Kohno, Y; Mori, C. (2014). A pilot study for foetal exposure to multiple persistent organic pollutants and the development of infant atopic dermatitis in modern Japanese society. Chemosphere 94: 48–52. 10.1016/j.chemosphere.2013.09.009.24080003
Oda, H; Yoshida, A. (1994). Effect of feeding xenobiotics on serum high density lipoprotein and apolipoprotein A-I in rats. Biosci Biotechnol Biochem 58: 1646–1651. 10.1271/bbb.58.1646.
Oishi, S; Morita, M; Fukuda, H. (1978). Comparative toxicity of polychlorinated biphenyls and dibenzofurans in rats. Toxicol Appl Pharmacol 43: 13–22. 10.1016/S0041-008X(78)80028-3.415381
Okeme, JO; Arrandale, VH. (2019). Electronic waste recycling: Occupational exposures and work-related health effects. Curr Environ Health Rep 6: 256–268. 10.1007/s40572-019-00255-3.31734812
Opal, SM. (2010). Endotoxins and other sepsis triggers. In C Ronco; P Piccinni; MH Rosner (Eds.), Endoxemia and endotoxin shock: Disease, diagnosis and therapy (pp. 14–24). Basel, Switzerland: Karger. 10.1159/000315915.
Oppi, S; Lüscher, TF; Stein, S. (2019). Mouse models for atherosclerosis research- Which is my line? [Review]. Front Cardiovasc Med 6: 46. 10.3389/fcvm.2019.00046.31032262
Orenstein, ST; Thurston, SW; Bellinger, DC; Schwartz, JD; Amarasiriwardena, CJ; Altshul, LM; Korrick, SA. (2014). Prenatal organochlorine and methylmercury exposure and memory and learning in school-age children in communities near the New Bedford Harbor Superfund site, Massachusetts. Environ Health Perspect 122: 1253–1259. 10.1289/ehp.1307804.25062363
Osterloh, J; Cone, J; Harrison, R; Wade, R; Becker, C. (1986). Pilot survey of urinary porphyrins from persons transiently exposed to a PCB transformer fire. J Toxicol Clin Toxicol 24: 533–544. 10.3109/15563658608995392.3106647
Osuna, CE; Grandjean, P; Weihe, P; El-Fawal, HA. (2014). Autoantibodies associated with prenatal and childhood exposure to environmental chemicals in Faroese children. Toxicol Sci 142: 158–166. 10.1093/toxsci/kfu163.25124724
Otake, T; Yoshinaga, J; Seki, Y; Matsumura, T; Watanabe, K; Ishijima, M; Kato, N. (2006). Retrospectivein utero exposure assessment of PCBs using preserved umbilical cords and its application to case-control comparison. Environ Health Prev Med 11: 65–68. 10.1007/BF02898144.21432364
Ouw, HK; Simpson, GR; Siyali, DS. (1976). Use and health effects of Aroclor 1242, a polychlorinated biphenyl, in an electrical industry. Arch Environ Health 31: 189–194.821401
Overmann, SR; Kostas, J; Wilson, LR; Shain, W; Bush, B. (1987). Neurobehavioral and somatic effects of perinatal PCB exposure in rats. Environ Res 44: 56–70. 10.1016/S0013-9351(87)80086-5 .3115773
Paliwoda, RE; Newbigging, AM; Wang, Z; Le, XC. (2016). Benefits and risks associated with consumption of Great Lakes fish containing omega-3 fatty acids and polychlorinated biphenyls (PCBs). J Environ Sci 41: 1–5. 10.1016/j.jes.2015.12.002.
Palkovičová Murínová, Ľ; Moleti, A; Sisto, R; Wimmerová, S; Jusko, TA; Tihányi, J; Jurečková, D; Kováč, J; Koštiaková, V; Drobná, B; Trnovec, T. (2016). PCB exposure and cochlear function at age 6 years. Environ Res 151: 428–435. 10.1016/j.envres.2016.08.017.27552711
Pan, W; Ye, X; Yin, S; Ma, X; Li, C; Zhou, J; Liu, W; Liu, J. (2019). Selected persistent organic pollutants associated with the risk of primary ovarian insufficiency in women. Environ Int 129: 51–58. 10.1016/j.envint.2019.05.023.31108393
Pantaleoni, GC; Fanini, D; Sponta, AM; Palumbo, G; Giorgi, R; Adams, PM. (1988). Effects of maternal exposure to polychlorobiphenyls (PCBs) on F1 generation behavior in the rat. Fundam Appl Toxicol 11: 440–449. 10.1016/0272-0590(88)90108-X.3146520
Papanikolaou, G; Pantopoulos, K. (2017). Systemic iron homeostasis and erythropoiesis. 69: 399–413. 10.1002/iub.1629.
Park, HY; Hertz-Picciotto, I; Petrik, J; Palkovicova, L; Kocan, A; Trnovec, T. (2008). Prenatal PCB exposure and thymus size at birth in neonates in eastern Slovakia. Environ Health Perspect 116: 104–109. 10.1289/ehp.9769.18197307
Park, HY; Hertz-Picciotto, I; Sovcikova, E; Kocan, A; Drobna, B; Trnovec, T. (2010). Neurodevelopmental toxicity of prenatal polychlorinated biphenyls (PCBs) by chemical structure and activity: A birth cohort study. Environ Health 9: 51. 10.1186/1476-069X-9-51.20731829
Park, HY; Park, JS; Sovcikova, E; Kocan, A; Linderholm, L; Bergman, A; Trnovec, T; Hertz-Picciotto, I. (2009). Exposure to hydroxylated polychlorinated biphenyls (OH-PCBs) in the prenatal period and subsequent neurodevelopment in eastern Slovakia. Environ Health Perspect 117: 1600–1606. 10.1289/ehp.0900611.20019912
Park, SH; Ha, EH; Hong, YS; Park, H. (2016). Serum Levels of Persistent Organic Pollutants and Insulin Secretion among Children Aged 7 to 9 Years: A Prospective Cohort Study. Environ Health Perspect 124: 1924–1930. 10.1289/EHP147.27266903
Parker-Lalomio, M; McCann, K; Piorkowski, J; Freels, S; Persky, VW. (2018). Prenatal exposure to polychlorinated biphenyls and asthma, eczema/hay fever, and frequent ear infections. J Asthma 55: 1105–1115. 10.1080/02770903.2017.1396470.29211547
Patandin, S; Lanting, CI; Mulder, PGH; Boersma, ER; Sauer, PJJ; Weisglas-Kuperus, N. (1999). Effects of environmental exposure to polychlorinated biphenyls and dioxins on cognitive abilities in Dutch children at 42 months of age. J Pediatr 134: 33–41. 10.1016/S0022–3476(99)70369–0.9880446
Patel, CJ; Cullen, MR; Ioannidis, JP; Butte, AJ. (2012). Systematic evaluation of environmental factors: persistent pollutants and nutrients correlated with serum lipid levels. Int J Epidemiol 41: 828–843. 10.1093/ije/dys003.22421054
Paul, R; Moltó, J; Ortuño, N; Romero, A; Bezos, C; Aizpurua, J; Gómez-Torres, MJ. (2017). Relationship between serum dioxin-like polychlorinated biphenyls and post-testicular maturation in human sperm. Reprod Toxicol 73: 312–321. 10.1016/j.reprotox.2017.07.004.28705580
Paunescu, AC; Ayotte, P; Dewailly, E; Dodin, S. (2013a). Dioxin-like compounds are not associated with bone strength measured by ultrasonography in Inuit women from Nunavik (Canada): results of a cross-sectional study. Int J Circumpolar Health 72. 10.3402/ijch.v72i0.20843.
Paunescu, AC; Dewailly, E; Dodin, S; Nieboer, E; Ayotte, P. (2013b). Dioxin-like compounds and bone quality in Cree women of Eastern James Bay (Canada): a cross-sectional study. Environ Health 12: 54. 10.1186/1476-069X-12-54.23816203
Pearson, BL; Bettis, JK; Meyza, KZ; Yamamoto, LY; Blanchard, DC; Blanchard, RJ. (2012). Absence of social conditioned place preference in BTBR T+tf/J mice: relevance for social motivation testing in rodent models of autism. Behav Brain Res 233: 99–104. 10.1016/j.bbr.2012.04.040.22562042
Penell, J; Lind, L; Salihovic, S; van Bavel, B; Lind, PM. (2014). Persistent organic pollutants are related to the change in circulating lipid levels during a 5 year follow-up. Environ Res 134: 190–197. 10.1016/j.envres.2014.08.005.25173051
Peper, M; Klett, M; Morgenstern, R. (2005). Neuropsychological effects of chronic low-dose exposure to polychlorinated biphenyls (PCBs): A cross-sectional study. Environ Health 4: 22. 10.1186/1476-069X-4-22.16236166
Pereira, C; Rao, CV. (2006). Combined and individual administration of diethyl phthalate and polychlorinated biphenyls and its toxicity in female Wistar rats. Environ Toxicol Pharmacol 21: 93–102. 10.1016/j.etap.2005.08.001.21783644
Persky, V; Piorkowski, J; Turyk, M; Freels, S; Chatterton, R, Jr; Dimos, J; Bradlow, HL; Chary, LK; Burse, V; Unterman, T; Sepkovic, D; McCann, K. (2011). Associations of polychlorinated biphenyl exposure and endogenous hormones with diabetes in post-menopausal women previously employed at a capacitor manufacturing plant. Environ Res 111: 817–824. 10.1016/j.envres.2011.05.012.21684538
Persky, V; Piorkowski, J; Turyk, M; Freels, S; Chatterton, R, Jr; Dimos, J; Bradlow, HL; Chary, LK; Burse, V; Unterman, T; Sepkovic, DW; McCann, K. (2012). Polychlorinated biphenyl exposure, diabetes and endogenous hormones: A cross-sectional study in men previously employed at a capacitor manufacturing plant. Environ Health 11: 57. 10.1186/1476-069X-11-57.22931295
Persky, V; Turyk, M; Anderson, HA; Hanrahan, LP; Falk, C; Steenport, DN; Chatterton, R, Jr; Freels, S; The Great Lakes Consortium. (2001). The effects of PCB exposure and fish consumption on endogenous hormones. Environ Health Perspect 109: 1275–1283. 10.1289/ehp.011091275.11748036
Petersen, MS; Halling, J; Bech, S; Wermuth, L; Weihe, P; Nielsen, F; Jørgensen, PJ; Budtz-Jørgensen, E; Grandjean, P. (2008). Impact of dietary exposure to food contaminants on the risk of Parkinson's disease. Neurotoxicology 29: 584–590. 10.1016/j.neuro.2008.03.001.18455239
Petersen, MS; Halling, J; Jørgensen, N; Nielsen, F; Grandjean, P; Jensen, TK; Weihe, P. (2018). Reproductive function in a population of young Faroese men with elevated exposure to polychlorinated biphenyls (PCBs) and perfluorinated alkylate substances (PFAS). Int J Environ Res Public Health 15: 1880. 10.3390/ijerph15091880.30200252
Petersen, MS; Halling, J; Weihe, P; Jensen, TK; Grandjean, P; Nielsen, F; Jørgensen, N. (2015). Spermatogenic capacity in fertile men with elevated exposure to polychlorinated biphenyls. Environ Res 138: 345–351. 10.1016/j.envres.2015.02.030.25766940
Petriello, MC; Brandon, JA; Hoffman, J; Wang, C; Tripathi, H; Abdel-Latif, A; Ye, X; Li, X; Yang, L; Lee, E; Soman, S; Barney, J; Wahlang, B; Hennig, B; Morris, AJ. (2018). Dioxin-like PCB 126 Increases Systemic Inflammation and Accelerates Atherosclerosis in Lean LDL Receptor-Deficient Mice. Toxicol Sci 162: 548–558. 10.1093/toxsci/kfx275.29216392
Petro, EM; Leroy, JL; Covaci, A; Fransen, E; De Neubourg, D; Dirtu, AC; De Pauw, I; Bols, PE. (2012). Endocrine-disrupting chemicals in human follicular fluid impair in vitro oocyte developmental competence. Hum Reprod 27: 1025–1033. 10.1093/humrep/der448.22267834
Petrosino, V; Motta, G; Tenore, G; Coletta, M; Guariglia, A; Testa, D. (2018). The role of heavy metals and polychlorinated biphenyls (PCBs) in the oncogenesis of head and neck tumors and thyroid diseases: a pilot study. Biometals 31: 285–295. 10.1007/s10534-018-0091-9.29520558
Pierce, CR; Kalivas, PW. (2007). Locomotor behavior. Curr Protoc Neurosci 40: 8.1.1–8.1.9. 10.1002/0471142301.ns0801s40.
Pillai, MR; Keylock, KT; Cromwell, HC; Meserve, LA. (2020). Exercise influences the impact of polychlorinated biphenyl exposure on immune function. PLoS ONE. 10.1371/journal.pone.0237705.
Pines, A; Cucos, S; Ever-Hadani, P; Melamed, E; Pollak, E; Zevin-Pines, R. (1986). Levels of some organochlorine residues in blood of patients with arteriosclerotic disease. Sci Total Environ 54: 135–155. 10.1016/0048-9697(86)90261–5.3101173
Platonow, NS; Meads, EB; Liptrap, RM; Lotz, F. (1976). Effects of some commercial preparations of polychlorinated biphenyls in growing piglets. Can J Comp Med 40: 421–428.826311
Ploteau, S; Antignac, JP; Volteau, C; Marchand, P; Vénisseau, A; Vacher, V; Le Bizec, B. (2016). Distribution of persistent organic pollutants in serum, omental, and parietal adipose tissue of French women with deep infiltrating endometriosis and circulating versus stored ratio as new marker of exposure. Environ Int 97: 125–136. 10.1016/j.envint.2016.08.011.27575367
Ploteau, S; Cano-Sancho, G; Volteau, C; Legrand, A; Vénisseau, A; Vacher, V; Marchand, P; Le Bizec, B; Antignac, JP. (2017). Associations between internal exposure levels of persistent organic pollutants in adipose tissue and deep infiltrating endometriosis with or without concurrent ovarian endometrioma. Environ Int 108: 195–203. 10.1016/j.envint.2017.08.019.28869876
Plusquellec, P; Muckle, G; Dewailly, E; Ayotte, P; Bégin, G; Desrosiers, C; Després, C; Saint-Amour, D; Poitras, K. (2010). The relation of environmental contaminants exposure to behavioral indicators in Inuit preschoolers in Arctic Quebec. Neurotoxicology 31: 17–25. 10.1016/j.neuro.2009.10.008.19854214
Poland, A; Glover, E; Kende, AS. (1976). Stereospecific, high affinity binding of 2,3,7,8-tetrachlorodibenzo-p-dioxin by hepatic cytosol: Evidence that the binding species is receptor for induction of aryl hydrocarbon hydroxylase. J Biol Chem 251: 4936–4946.956169
Pollack, AZ; Krall, JR; Kannan, K; Buck Louis, GM. (2021). Adipose to serum ratio and mixtures of persistent organic pollutants in relation to endometriosis: Findings from the ENDO Study. Environ Res 195: 110732. 10.1016/j.envres.2021.110732.33484721
Powers, BE; Poon, E; Sable, HJK; Schantz, SL. (2009). Developmental exposure to PCBs, MeHg, or both: Long-term effects on auditory function. Environ Health Perspect 117: 1101–1107. 10.1289/ehp.0800428.19654920
Powers, BE; Widholm, JJ; Lasky, RE; Schantz, SL. (2006). Auditory deficits in rats exposed to an environmental PCB mixture during development. Toxicol Sci 89: 415–422. 10.1093/toxsci/kfj051.16317017
Price, NH; Yates, WG; Allen, SD; Waters, SW. (1979). Toxicity Evaluation for Establishing IDLH Values (Final Report) TR 1518–005. (NIOSH/00091836). Cincinnati, OH: NIOSH. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB87229498.xhtml.
Prince, MM; Hein, MJ; Ruder, AM; Waters, MA; Laber, PA; Whelan, EA. (2006a). Update: cohort mortality study of workers highly exposed to polychlorinated biphenyls (PCBs) during the manufacture of electrical capacitors, 1940–1998. Environ Health 5: 13. 10.1186/1476-069x-5-13.16716225
Prince, MM; Ruder, AM; Hein, MJ; Waters, MA; Whelan, EA; Nilsen, N; Ward, EM; Schnorr, TM; Laber, PA; Davis-King, KE. (2006b). Mortality and exposure response among 14,458 electrical capacitor manufacturing workers exposed to polychlorinated biphenyls (PCBs). Environ Health Perspect 114: 1508–1514. 10.1289/ehp.9175.17035134
Provost, T; Kennedy, M; Castracane, VD; Meserve, L. (2007). The effects of polychlorinated biphenyl on circulating leptin and thyroid hormone status in Sprague-Dawley rats, Rattus norvegicus. Ohio J Sci 107: 19–22.
Przybyla, J; Houseman, EA; Smit, E; Kile, ML. (2017). A path analysis of multiple neurotoxic chemicals and cognitive functioning in older US adults (NHANES 1999–2002). Environ Health 16: 19. 10.1186/s12940-017-0227-3.28270159
Qin, Y; Leung, C; Leung, A; Wu, SC; Zheng, J; Wong, MH. (2010). Persistent organic pollutants and heavy metals in adipose tissues of patients with uterine leiomyomas and the association of these pollutants with seafood diet, BMI, and age. Environ Sci Pollut Res Int 17: 229–240. 10.1007/s11356-009-0251-0.
Raffetti, E; Donato, F; De Palma, G; Leonardi, L; Sileo, C; Magoni, M. (2020). Polychlorinated biphenyls (PCBs) and risk of dementia and Parkinson disease: A population-based cohort study in a North Italian highly polluted area. Chemosphere 261: 127522. 10.1016/j.chemosphere.2020.127522.32712378
Raffetti, E; Donato, F; Speziani, F; Scarcella, C; Gaia, A; Magoni, M. (2018). Polychlorinated biphenyls (PCBs) exposure and cardiovascular, endocrine and metabolic diseases: A population-based cohort study in a North Italian highly polluted area. Environ Int 120: 215–222. 10.1016/j.envint.2018.08.022.30103120
Rahman, ML; Zhang, C; Smarr, MM; Lee, S; Honda, M; Kannan, K; Tekola-Ayele, F; Buck Louis, GM. (2019). Persistent organic pollutants and gestational diabetes: A multi-center prospective cohort study of healthy US women. Environ Int 124: 249–258. 10.1016/j.envint.2019.01.027.30660025
Rantakokko, P; Männistö, V; Airaksinen, R; Koponen, J; Viluksela, M; Kiviranta, H; Pihlajamäki, J. (2015). Persistent organic pollutants and non-alcoholic fatty liver disease in morbidly obese patients: A cohort study. Environ Health 14: 79. 10.1186/s12940-015-0066-z.26420011
Raymond, MR; Christensen, KY; Thompson, BA; Anderson, HA. (2016). Associations between fish consumption and contaminant biomarkers with cardiovascular conditions among older male anglers in Wisconsin. J Occup Environ Med 58: 676–682. 10.1097/JOM.0000000000000757.27253229
Reichrtová, E; Ciznár, P; Prachar, V; Palkovicová, L; Veningerová, M. (1999). Cord serum immunoglobulin E related to the environmental contamination of human placentas with organochlorine compounds. Environ Health Perspect 107: 895–899. 10.1289/ehp.107-1566702.10544157
Reilly, MP; Weeks, CD; Crews, D; Gore, AC. (2018). Application of a novel social choice paradigm to assess effects of prenatal endocrine-disrupting chemical exposure in rats (Rattus norvegicus). 132: 253–267. 10.1037/com0000103.
Reilly, MP; Weeks, CD; Topper, VY; Thompson, LM; Crews, D; Gore, AC. (2015). The effects of prenatal PCBs on adult social behavior in rats. Horm Behav 73: 47–55. 10.1016/j.yhbeh.2015.06.002.26093262
Rennert, A; Wittsiepe, J; Kasper-Sonnenberg, M; Binder, G; Fürst, P; Cramer, C; Krämer, U; Wilhelm, M. (2012). Prenatal and early life exposure to polychlorinated dibenzo-p-dioxins, dibenzofurans and biphenyls may influence dehydroepiandrosterone sulfate levels at prepubertal age: results from the Duisburg birth cohort study. J Toxicol Environ Health A 75: 1232–1240. 10.1080/15287394.2012.709375.22994577
Ribas-Fitó, N; Sala, M; Cardo, E; Mazón, C; de Muga, ME; Verdú, A; Marco, E; Grimalt, JO; Sunyer, J. (2002). Association of hexachlorobenzene and other organochlorine compounds with anthropometric measures at birth. Pediatr Res 52: 163–167. 10.1203/00006450-200208000-00006.12149491
Ribas-Fitó, N; Sala, M; Cardo, E; Mazón, C; de Muga, ME; Verdú, A; Marco, E; Grimalt, JO; Sunyer, J. (2003). Organochlorine compounds and concentrations of thyroid stimulating hormone in newborns. Occup Environ Med 60: 301–303. 10.1136/oem.60.4.301.12660379
Rice, D; Barone, S, Jr. (2000). Critical periods of vulnerability for the developing nervous system: Evidence from humans and animal models [Review]. Environ Health Perspect 108: 511–533. 10.2307/3454543.10852851
Rice, DC. (1997). Effect of postnatal exposure to a PCB mixture in monkeys on multiple fixed interval-fixed ratio performance. Neurotoxicol Teratol 19: 429–434. 10.1016/S0892-0362(97)87364–3.9392778
Rice, DC. (1998). Effects of postnatal exposure of monkeys to a PCB mixture on spatial discrimination reversal and DRL performance. Neurotoxicol Teratol 20: 391–400. 10.1016/S0892-0362(97)00134–7.9697965
Rice, DC; Hayward, S. (1997). Effects of postnatal exposure to a PCB mixture in monkeys on nonspatial discrimination reversal and delayed alternation performance. Neurotoxicology 18: 479–494.9291496
Rice, DC; Hayward, S. (1999). Effects of postnatal exposure of monkeys to a PCB mixture on concurrent random interval-random interval and progressive ratio performance. Neurotoxicol Teratol 21: 47–58. 10.1016/S0892-0362(98)00032–4.10023801
Richthoff, J; Rylander, L; Jönsson, BA; Akesson, H; Hagmar, L; Nilsson-Ehle, P; Stridsberg, M; Giwercman, A. (2003). Serum levels of 2,2',4,4',5,5'-hexachlorobiphenyl (CB-153) in relation to markers of reproductive function in young males from the general Swedish population. Environ Health Perspect 111: 409–413. 10.1289/ehp.5767.12676591
Righter, HF; Booth, NH; Teske, RH. (1976). Acute effects of Aroclor 1254 on the feline cardiovascular system. Environ Res 11: 353–358. 10.1016/0013-9351(76)90097-9.820552
Rignell-Hydbom, A; Elfving, M; Ivarsson, SA; Lindh, C; Jönsson, BA; Olofsson, P; Rylander, L. (2010). A nested case-control study of intrauterine exposure to persistent organochlorine pollutants in relation to risk of type 1 diabetes. PLoS ONE 5: e11281. 10.1371/journal.pone.0011281.20585661
Rignell-Hydbom, A; Lidfeldt, J; Kiviranta, H; Rantakokko, P; Samsioe, G; Agardh, CD; Rylander, L. (2009a). Exposure to p,p'-DDE: a risk factor for type 2 diabetes. PLoS ONE 4: e7503. 10.1371/journal.pone.0007503.19838294
Rignell-Hydbom, A; Rylander, L; Elzanaty, S; Giwercman, A; Lindh, CH; Hagmar, L. (2005a). Exposure to persistent organochlorine pollutants and seminal levels of markers of epididymal and accessory sex gland functions in Swedish men. Hum Reprod 20: 1910–1914. 10.1093/humrep/deh856.15802324
Rignell-Hydbom, A; Rylander, L; Giwercman, A; Jónsson, BA; Lindh, C; Eleuteri, P; Rescia, M; Leter, G; Cordelli, E; Spano, M; Hagmar, L. (2005b). Exposure to PCBs and p,p'-DDE and human sperm chromatin integrity. Environ Health Perspect 113: 175–179. 10.1289/ehp.7252.15687046
Rignell-Hydbom, A; Rylander, L; Giwercman, A; Jónsson, BA; Nilsson-Ehle, P; Hagmar, L. (2004). Exposure to CB-153 and p,p'-DDE and male reproductive function. Hum Reprod 19: 2066–2075. 10.1093/humrep/deh362.15284211
Rignell-Hydbom, A; Skerfving, S; Lundh, T; Lindh, CH; Elmståhl, S; Bjellerup, P; Jünsson, BA; Strümberg, U; Akesson, A. (2009b). Exposure to cadmium and persistent organochlorine pollutants and its association with bone mineral density and markers of bone metabolism on postmenopausal women. Environ Res 109: 991–996. 10.1016/j.envres.2009.08.008.19733845
Rocha-Amador, D; Navarro, M; Trejo-Acevedo, A; Carrizales, L; Pérez-Maldonado, I; Díaz-Barriga, F; Calderón, J. (2009). Use of the Rey-Osterrieth Complex Figure Test for neurotoxicity evaluation of mixtures in children. Neurotoxicology 30: 1149–1154. 10.1016/j.neuro.2009.09.003.19770001
Rocheleau, CM; Bertke, SJ; Deddens, JA; Ruder, AM; Lawson, CC; Waters, MA; Hopf, NB; Riggs, MA; Whelan, EA. (2011). Maternal exposure to polychlorinated biphenyls and the secondary sex ratio: An occupational cohort study. Environ Health 10: 20. 10.1186/1476-069X-10-20.21418576
Roegge, CS; Seo, BW; Crofton, KM; Schantz, SL. (2000). Gestational-lactational exposure to Aroclor 1254 impairs radial-arm maze performance in male rats. Toxicol Sci 57: 121–130. 10.1093/toxsci/57.1.121.10966518
Roegge, CS; Wang, VC; Powers, BE; Klintsova, AY; Villareal, S; Greenough, WT; Schantz, SL. (2004). Motor impairment in rats exposed to PCBs and methylmercury during early development. Toxicol Sci 77: 315–324. 10.1093/toxsci/kfg252.14600290
Rogan, WJ; Gladen, BC. (1991). PCBs, DDE, and child development at 18 and 24 months. Ann Epidemiol 1: 407–413. 10.1016/1047-2797(91)90010-A.1669521
Rogan, WJ; Gladen, BC; McKinney, JD; Carreras, N; Hardy, P; Thullen, J; Tingelstad, J; Tully, M. (1987). Polychlorinated biphenyls (PCBs) and dichlorodiphenyl dichloroethene (DDE) in human milk: Effects on growth, morbidity, and duration of lactation. Am J Public Health 77: 1294–1297. 10.2105/AJPH.77.10.1294.3115123
Romeo, L; Catalani, S; Pasini, F; Bergonzi, R; Perbellini, L; Apostoli, P. (2009). Xenobiotic action on steroid hormone synthesis and sulfonation the example of lead and polychlorinated biphenyls. Int Arch Occup Environ Health 82: 557–564. 10.1007/s00420-008-0371-8.18925412
Rose, G. (1985). Sick individuals and sick populations. Int J Epidemiol 14: 32–38. 10.1093/ije/14.1.32.3872850
Rosin, PL; Martin, BR. (1981). Neurochemical and behavioral effects of polychlorinated biphenyls in mice. Neurotoxicology 2: 749–764.6123098
Roy, A; Perkins, NJ; Buck Louis, GM. (2012). Assessing Chemical Mixtures and Human Health: Use of Bayesian Belief Net Analysis. JEP 3: 462–468. 10.4236/jep.2012.36056.23125944
Rozati, R; Reddy, PP; Reddanna, P; Mujtaba, R. (2002). Role of environmental estrogens in the deterioration of male factor fertility. Fertil Steril 78: 1187–1194. 10.1016/S0015-0282(02)04389-3 .12477510
Roze, E; Meijer, L; Bakker, A; van Braeckel, KNJ, A; Sauer, PJJ; Bos, AF. (2009). Prenatal exposure to organohalogens, including brominated flame retardants, influences motor, cognitive, and behavioral performance at school age. Environ Health Perspect 117: 1953–1958. 10.1289/ehp.0901015.20049217
Rude, KM; Pusceddu, MM; Keogh, CE; Sladek, JA; Rabasa, G; Miller, EN; Sethi, S; Keil, KP; Pessah, IN; Lein, PJ; Gareau, MG. (2019). Developmental exposure to polychlorinated biphenyls (PCBs) in the maternal diet causes host-microbe defects in weanling offspring mice. Environ Pollut 253: 708–721. 10.1016/j.envpol.2019.07.066.31336350
Ruder, AM; Hein, MJ; Hopf, NB; Waters, MA. (2014). Mortality among 24,865 workers exposed to polychlorinated biphenyls (PCBs) in three electrical capacitor manufacturing plants: A ten-year update. Int J Hyg Environ Health 217: 176–187. 10.1016/j.ijheh.2013.04.006.23707056
Ruder, AM; Hein, MJ; Nilsen, N; Waters, MA; Laber, P; Davis-King, K; Prince, MM; Whelan, E. (2006). Mortality among workers exposed to polychlorinated biphenyls (PCBs) in an electrical capacitor manufacturing plant in Indiana: An update. Environ Health Perspect 114: 18–23. 10.1289/ehp.8253.16393652
Ruel, MVM; Bos, AF; Soechitram, SD; Meijer, L; Sauer, PJJ; Berghuis, SA. (2019). Prenatal exposure to organohalogen compounds and children's mental and motor development at 18 and 30 months of age. Neurotoxicology 72: 6–14. 10.1016/j.neuro.2019.01.003.30664974
Rusiecki, JA; Denic-Roberts, H; Byrne, C; Cash, J; Raines, CF; Brinton, LA; Zahm, SH; Mason, T; Bonner, MR; Blair, A; Hoover, R. (2020). Serum concentrations of DDE, PCBs, and other persistent organic pollutants and mammographic breast density in Triana, Alabama, a highly exposed population. Environ Res 182: 109068. 10.1016/j.envres.2019.109068.31918312
Rylander, C; Sandanger, TM; Nøst, TH; Breivik, K; Lund, E. (2015). Combining plasma measurements and mechanistic modeling to explore the effect of POPs on type 2 diabetes mellitus in Norwegian women. Environ Res 142: 365–373. 10.1016/j.envres.2015.07.002.26208316
Sable, HJK; Powers, BE; Wang, VC; Widholm, JJ; Schantz, SL. (2006). Alterations in DRH and DRL performance in rats developmentally exposed to an environmental PCB mixture. Neurotoxicol Teratol 28: 548–556. 10.1016/j.ntt.2006.06.005.16930942
Sager, DB. (1983). Effect of postnatal exposure to polychlorinated biphenyls on adult male reproductive function. Environ Res 31: 76–94. 10.1016/0013-9351(83)90063-4.6406218
Sagiv, SK; Kalkbrenner, AE; Bellinger, DC. (2015). Of decrements and disorders: assessing impairments in neurodevelopment in prospective studies of environmental toxicant exposures. Environ Health 14: 8. 10.1186/1476-069X-14-8.25609433
Sagiv, SK; Thurston, SW; Bellinger, DC; Tolbert, PE; Altshul, LM; Korrick, SA. (2010). Prenatal organochlorine exposure and behaviors associated with attention deficit hyperactivity disorder in school-aged children. Am J Epidemiol 171: 593–601. 10.1093/aje/kwp427.20106937
Saito, M; Ikegami, S; Aizawa, T; Innami, S. (1983a). Effect of the degradation of cytochrome P-450 heme by secobarbital on polychlorinated biphenyls (PCB)-induced hepatic vitamin A reduction and lipid peroxide formation in rats. J Nutr Sci Vitaminol 29: 467–480. 10.3177/jnsv.29.467.6417289
Saito, M; Ikegami, S; Nishide, E; Innami, S. (1983b). Relevances of mixed function oxidase system and ascorbic acid to the lipid peroxide formation in the liver of rats given polychlorinated biphenyls (PCB). Fukuoka Igaku Zasshi 74: 222–233.6411564
Sala, M; Sunyer, J; Herrero, C; To-Figueras, J; Grimalt, J. (2001). Association between serum concentrations of hexachlorobenzene and polychlorobiphenyls with thyroid hormone and liver enzymes in a sample of the general population. Occup Environ Med 58: 172–177. 10.1136/oem.58.3.172.11171930
Sánchez-Ferrer, ML; Mendiola, J; Hernández-Peñalver, Al; Corbalán-Biyang, S; Carmona-Barnosi, A; Prieto-Sánchez, MT; Nieto, A; Torres-Cantero, AM. (2017). Presence of polycystic ovary syndrome is associated with longer anogenital distance in adult Mediterranean women. Hum Reprod 32: 2315–2323. 10.1093/humrep/dex274.29025054
Sanders, OT; Kirkpatrick, RL. (1975). Effects of a polychlorinated biphenyl (PCB) on sleeping times, plasma corticosteroids, and testicular activity of white-footed mice. Environ Physiol Biochem 5: 308–313.811460
Sanders, OT; Kirkpatrick, RL. (1977). Reproductive characteristics and corticoid levels of female white-footed mice fed ad libitum and restricted diets containing a polychlorinated biphenyl. Environ Res 13: 358–363. 10.1016/0013-9351(77)90015–9.407075
Sanders, OT; Kirkpatrick, RL; Scanlon, PE. (1977). Polychlorinated biphenyls and nutritional restriction: Their effects and interactions on endocrine and reproductive characteristics of male white mice. Toxicol Appl Pharmacol 40: 91–98. 10.1016/0041-008X(77)90120-X.405757
Santiago-Rivera, AL; Morse, GS; Haase, RF; McCaffrey, RJ; Tarbell, A. (2007). Exposure to an environmental toxin, quality of life and psychological distress. J Environ Psychol 27: 33–43. 10.1016/j.jenvp.2006.12.004.
Schaeffer, E; Greim, H; Goessner, W. (1984). Pathology of chronic polychlorinated biphenyl (PCB) feeding in rats. Toxicol Appl Pharmacol 75: 278–288. 10.1016/0041-008X(84)90210-2.6433511
Schantz, SL; Gasior, DM; Polverejan, E; McCaffrey, RJ; Sweeney, AM; Humphrey, HEB; Gardiner, JC. (2001). Impairments of memory and learning in older adults exposed to polychlorinated biphenyls via consumption of Great Lakes fish. Environ Health Perspect 109: 605–611. 10.1289/ehp.01109605.
Schantz, SL; Levin, ED; Bowman, RE; Heironimus, MP; Laughlin, NK. (1989). Effects of perinatal PCB exposure on discrimination-reversal learning in monkeys. Neurotoxicol Teratol 11: 243–250. 10.1016/0892-0362(89)90066-4.2502707
Schell, LM; Gallo, MV; Deane, GD; Nelder, KR; DeCaprio, AP; Jacobs, A; Akwesasne Task Force on the Environment. (2014). Relationships of polychlorinated biphenyls and dichlorodiphenyldichloroethylene (p,p'-DDE) with testosterone levels in adolescent males. Environ Health Perspect 122: 304–309. 10.1289/ehp.1205984.24398050
Schell, LM; Gallo, MV; DeCaprio, AP; Hubicki, L; Denham, M; Ravenscroft, J; Akwesasne Task Force on the Environment. (2004). Thyroid function in relation to burden of PCBs, p,p'-DDE, HCB, mirex and lead among Akwesasne Mohawk youth: A preliminary study. Environ Toxicol Pharmacol 18: 91–99. 10.1016/j.etap.2004.01.010.21782738
Schell, LM; Gallo, MV; Ravenscroft, J; Decaprio, AP. (2009). Persistent organic pollutants and anti-thyroid peroxidase levels in Akwesasne Mohawk young adults. Environ Res 109: 86–92. 10.1016/j.envres.2008.08.015.18995849
Schmoldt, A; Altenähr, E; Grote, W; Dammann, HG; Sidau, B; Benthe, HF. (1977). Rat liver changes after subchronic exposition to polychlorinated biphenyls (PCB) of low chlorine content. Arch Toxicol 37: 203–217. 10.1007/BF00355489.409375
Schoenroth, L; Chan, S; Fritzler, M. (2004). Autoantibodies and levels of polychlorinated biphenyls in persons living near a hazardous waste treatment facility. J Investig Med 52: 170–176. 10.1136/ijm-52-03-31.
Sciome (Sciome, LLC.). (2023). SWIFT-Active Screener. Retrieved from https://www.sciome.com/swift-activescreener/
SCPOP (Stockholm Convention on Persistent Organic Pollutants). (2008). The 12 initial POPs under the Stockholm Convention. Available online at http://chm.pops.int/TheConvention/ThePOPs/The12lnitialPOPs/tabid/296/Default.aspx (accessed July 9, 2021).
Seegal, RF. (2011). PCBs alter dopamine mediated function in aging workers. (DAMD17-02-1-0173). Fort Detrick, MD: U.S. Army Medical Research and Materiel Command. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/ADA593238.xhtml.
Seegal, RF; Fitzgerald, EF; McCaffrey, RJ; Shrestha, S; Hills, EA; Wolff, MS; Haase, RF; Todd, AC; Parsons, PJ; Molho, ES; Higgins, DS; Factor, SA; Seibyl, JP. (2013). Tibial bone lead, but not serum polychlorinated biphenyl, concentrations are associated with neurocognitive deficits in former capacitor workers. J Occup Environ Med 55: 552–562. 10.1097/JOM.0b013e318285f3fd.23618890
Segre, M; Arena, SM; Greeley, EH; Melancon, MJ; Graham, DA; French, JB, Jr. (2002). Immunological and physiological effects of chronic exposure of Peromyscus leucopus to Aroclor 1254 at a concentration similar to that found at contaminated sites. Toxicology 174: 163–172. 10.1016/S0300-483X(02)00039–2.12007856
Selvakumar, K; Bavithra, S; Ganesh, L; Krishnamoorthy, G; Venkataraman, P; Arunakaran, J. (2013). Polychlorinated biphenyls induced oxidative stress mediated neurodegeneration in hippocampus and behavioral changes of adult rats: anxiolytic-like effects of quercetin. Toxicol Lett 222: 45–54. 10.1016/j.toxlet.2013.06.237.23831945
Seo, BW; Meserve, LA. (1995). Effects of maternal ingestion of Aroclor 1254 (PCB) on the developmental pattern of oxygen consumption and body temperature in neonatal rats. Bull Environ Contam Toxicol 55: 22–28. 10.1007/BF00212384.7663088
Serdar, B; Leblanc, WG; Norris, JM; Dickinson, LM. (2014). Potential effects of polychlorinated biphenyls (PCBs) and selected organochlorine pesticides (OCPs) on immune cells and blood biochemistry measures: a cross-sectional assessment of the NHANES 2003–2004 data. Environ Health 13: 114. 10.1186/1476-069X-13-114.25515064
Shapiro, GD; Dodds, L; Arbuckle, TE; Ashley-Martin, J; Ettinger, AS; Fisher, M; Taback, S; Bouchard, MF; Monnier, P; Dallaire, R; Morisset, AS; Fraser, W. (2016). Exposure to organophosphorus and organochlorine pesticides, perfluoroalkyl substances, and polychlorinated biphenyls in pregnancy and the association with impaired glucose tolerance and gestational diabetes mellitus: The MIREC Study. Environ Res 147: 71–81. 10.1016/j.envres.2016.01.040.26852007
Shi, H; Jan, J; Hardesty, JE; Falkner, KC; Prough, RA; Balamurugan, AN; Mokshagundam, SP; Chari, ST; Cave, MC. (2019). Polychlorinated biphenyl exposures differentially regulate hepatic metabolism and pancreatic function: Implications for nonalcoholic steatohepatitis and diabetes. Toxicol Appl Pharmacol 363: 22–33. 10.1016/j.taap.2018.10.011.30312631
Shigematsu, N; Ishimaru, S; Saito, R; Ikeda, T; Matsuba, K; Sugiyama, K; Masuda, Y. (1978). Respiratory involvement in polychlorinated biphenyls poisoning. Environ Res 16: 92–100. 10.1016/0013-9351(78)90146–9.98327
Siblerud, R; Mutter, J; Moore, E; Naumann, J; Walach, H. (2019). A hypothesis and evidence that mercury may be an etiological factor in Alzheimer's disease. Int J Environ Res Public Health 16: 5152. 10.3390/ijerph16245152.31861093
Sifakis, S; Androutsopoulos, VP; Tsatsakis, AM; Spandidos, DA. (2017). Human exposure to endocrine disrupting chemicals: effects on the male and female reproductive systems [Review]. Environ Toxicol Pharmacol 51: 56–70. 10.1016/j.etap.2017.02.024.28292651
Sinks, T; Smith, AB; Steele, G; Rinsky, R; Watkins, K. (1990). A retrospective cohort mortality study of workers at an electric capacitor plant utilizing polychlorinated biphenyls. In H Sakurai; I Okazaki; K Omae (Eds.), Occupational epidemiology (pp. 113–119). Bridgewater, NJ: Excerpta Medica.
Sinks, T; Steele, G; Smith, AB; Watkins, K; Shults, R. (1992a). Mortality among polychlorinated biphenyl exposed workers. Rev Epidemiol Sante Publique 40: S107.
Sinks, T; Steele, G; Smith, AB; Watkins, K; Shults, RA. (1992b). Mortality among workers exposed to polychlorinated biphenyls. Am J Epidemiol 136: 389–398.1415158
Sisto, R; Moleti, A; Palkovičová Murínová, L; Wimmerová, S; Lancz, K; Tihányi, J; Čonka, K; Šovčíková, E; Hertz-Picciotto, I; Jusko, TA; Trnovec, T. (2015). Environmental exposure to organochlorine pesticides and deficits in cochlear status in children. Environ Sci Pollut Res Int 22: 14570–14578. 10.1007/s11356-015-4690-5.25989860
Sjöberg Lind, Y; Lind, PM; Salihovic, S; van Bavel, B; Lind, L. (2013). Circulating levels of persistent organic pollutants (POPs) are associated with left ventricular systolic and diastolic dysfunction in the elderly. Environ Res 123: 39–45. 10.1016/j.envres.2013.02.007.23562393
Skakkebaek, NE; Rajpert-De Meyts, E; Main, KM. (2001). Testicular dysgenesis syndrome: an increasingly common developmental disorder with environmental aspects [Review]. Hum Reprod 16: 972–978.11331648
Skovgaard, AM; Houmann, T; Landorph, SL; Christiansen, E. (2004). Assessment and classification of psychopathology in epidemiological research of children 0–3 years of age: A review of the literature [Review]. Eur Child Adolesc Psychiatry 13: 337–346. 10.1007/s00787-004-0393-z.15619045
Small, CM; Manatunga, AK; Marcus, M. (2007). Validity of self-reported menstrual cycle length. Ann Epidemiol 17: 163–170. 10.1016/j.annepidem.2006.05.005.16882471
Smarr, MM; Sapra, KJ; Gemmill, A; Kahn, LG; Wise, LA; Lynch, CD; Factor-Litvak, P; Mumford, SL; Skakkebaek, NE; Slama, R; Lobdell, DT; Stanford, JB; Jensen, TK; Boyle, EH; Eisenberg, ML; Turek, PJ; Sundaram, R; Thoma, ME; Buck Louis, GM. (2017). Is human fecundity changing? A discussion of research and data gaps precluding us from having an answer. Hum Reprod 32: 499–504. 10.1093/humrep/dew361.28137753
Smit, LA; Lenters, V; Høyer, BB; Lindh, CH; Pedersen, HS; Liermontova, I; Jönsson, BA; Piersma, AH; Bonde, JP; Toft, G; Vermeulen, R; Heederik, D. (2015). Prenatal exposure to environmental chemical contaminants and asthma and eczema in school-age children. Allergy 70: 653–660. 10.1111/all.12605.25753462
Smith, AB; Schloemer, J; Lowry, LK; Smallwood, AW; Ligo, RN; Tanaka, S; Stringer, W; Jones, M; Hervin, R; Glueck, CJ. (1982). Metabolic and health consequences of occupational exposure to polychlorinated biphenyls. Br J Ind Med 39: 361–369. 10.1136/oem.39.4.361.6128023
Smith, PN; Lochmiller, RL; Qualls, CW, Jr; Lish, JW; McMurry, ST. (2003). Lymphoproliferative responses of splenocytes from wild cotton rats (Sigmodon hispidus) following acute exposure to Aroclor 1254. Bull Environ Contam Toxicol 70: 97–105. 10.1007/s00128-002-0161-z.12478430
Sovcfkova, E; Wimmerova, S; Strémy, M; Kotianová, J; Loffredo, CA; Murínová, LP; Chovancová, J; Čonka, K; Lancz, K; Trnovec, T. (2015). Simple reaction time in 8–9-year old children environmentally exposed to PCBs. Neurotoxicology 51: 138–144. 10.1016/j.neuro.2015.10.005.26480857
Spann, K; Snape, N; Baturcam, E; Fantino, E. (2016). The Impact of Early-Life Exposure to Air-borne Environmental Insults on the Function of the Airway Epithelium in Asthma [Review]. 82: 28–40. 10.1016/j.aogh.2016.01.007.
Spector, JT; De Roos, AJ; Ulrich, CM; Sheppard, L; Sjödin, A; Wener, MH; Wood, B; McTiernan, A. (2014). Plasma polychlorinated biphenyl concentrations and immune function in postmenopausal women. Environ Res 131: 174–180. 10.1016/j.envres.2014.03.011.24721136
Stachel, B; Dougherty, RC; Lahl, U; Schlösser, M; Zeschmar, B. (1989). Toxic environmental chemicals in human semen: Analytical method and case studies. Andrologia 21: 282–291. 10.1111/j.1439-0272.1989.tb02412.x.2774220
Staessen, JA; Nawrot, T; Den Hond, E; Thijs, L; Fagard, R; Hoppenbrouwers, K; Koppen, G; Nelen, V; Schoeters, G; Vanderschueren, D; Van Hecke, E; Verschaeve, L; Vlietinck, R; Roels, HA. (2001). Renal function, cytogenetic measurements, and sexual developments in adolescents in relation to environmental pollutants: A feasibility study of biomarkers. Lancet 357: 1660–1669. 10.1016/S0140-6736(00)04822–4.11425371
Stehr-Green, PA; Welty, E; Steele, G; Steinberg, K. (1986). Evaluation of potential health effects associated with serum polychlorinated biphenyl levels. Environ Health Perspect 70: 255–259.3104024
Steinberg, KK; Freni-Titulaer, LW; Rogers, TN; Burse, VW; Mueller, PW; Stehr, PA; Miller, DT; Steele, G. (1986). Effects of polychlorinated biphenyls and lipemia on serum analytes. J Toxicol Environ Health 19: 369–381. 10.1080/15287398609530935.3021964
Steinberg, RM; Juenger, TE; Gore, AC. (2007). The effects of prenatal PCBs on adult female paced mating reproductive behaviors in rats. Horm Behav 51: 364–372. 10.1016/j.yhbeh.2006.12.004.17274994
Steinberg, RM; Walker, DM; Juenger, TE; Woller, MJ; Gore, AC. (2008). Effects of perinatal polychlorinated biphenyls on adult female rat reproduction: development, reproductive physiology, and second generational effects. Biol Reprod 78: 1091–1101. 10.1095/biolreprod.107.067249.18305224
Stern, JH; Rutkowski, JM; Scherer, PE. (2016). Adiponectin, Leptin, and Fatty Acids in the Maintenance of Metabolic Homeostasis through Adipose Tissue Crosstalk. Cell Metab 23: 770–784. 10.1016/j.cmet.2016.04.011.27166942
Steuerwald, U; Weihe, P; Jörgensen, PJ; Bjerve, K; Brock, J; Heinzow, B; Budtz-Jörgensen, E; Grandjean, P. (2000). Maternal seafood diet, methylmercury exposure, and neonatal neurologic function. J Pediatr 136: 599–605. 10.1067/mpd.2000.102774.10802490
Stewart, P; Reihman, J; Gump, B; Lonky, E; Darvill, T; Pagano, J. (2005). Response inhibition at 8 and 9 1/2 years of age in children prenatally exposed to PCBs. Neurotoxicol Teratol 27: 771–780. 10.1016/j.ntt.2005.07.003.16198536
Stewart, PW; Lonky, E; Reihman, J; Pagano, J; Gump, BB; Darvill, T. (2008). The relationship between prenatal PCB exposure and intelligence (IQ) in 9-year-old children. Environ Health Perspect 116: 1416–1422. 10.1289/ehp.11058.18941588
Stewart, PW; Sargent, DM; Reihman, J; Gump, BB; Lonky, E; Darvill, T; Hicks, H; Pagano, J. (2006). Response inhibition during Differential Reinforcement of Low Rates (DRL) schedules may be sensitive to low-level polychlorinated biphenyl, methylmercury, and lead exposure in children. Environ Health Perspect 114: 1923–1929. 10.1289/ehp.9216.17185286
Stølevik, SB; Nygaard, UC; Namork, E; Haugen, M; Kvalem, HE; Meltzer, HM; Alexander, J; van Delft, JHM; van Loveren, H; Løvik, M; Granum, B. (2011). Prenatal exposure to polychlorinated biphenyls and dioxins is associated with increased risk of wheeze and infections in infants. Food Chem Toxicol 49: 1843–1848. 10.1016/j.fct.2011.05.002.21571030
Stølevik, SB; Nygaard, UC; Namork, E; Haugen, M; Meltzer, HM; Alexander, J; Knutsen, HK; Aaberge, I; Vainio, K; van Loveren, H; Løvik, M; Granum, B. (2013). Prenatal exposure to polychlorinated biphenyls and dioxins from the maternal diet may be associated with immunosuppressive effects that persist into early childhood. Food Chem Toxicol 51: 165–172. 10.1016/j.fct.2012.09.027.23036451
Størm, JE; Hart, JL; Smith, RF. (1981). Behavior of mice after pre- and postnatal exposure to Arochlor 1254. Neurobehav Toxicol Teratol 3: 5–9.
Street, JC; Sharma, RP. (1975). Alteration of induced cellular and humoral immune responses by pesticides and chemicals of environmental concern: Quantitative studies of immunosuppression by DDT, Aroclor 1254, carbaryl, carbofuran, and methylparathion. Toxicol Appl Pharmacol 32: 587–602. 10.1016/0041-008X(75)90123–4.50651
Strøm, M; Hansen, S; Olsen, SF; Haug, LS; Rantakokko, P; Kiviranta, H; Halldorsson, TI. (2014). Persistent organic pollutants measured in maternal serum and offspring neurodevelopmental outcomes--a prospective study with long-term follow-up. Environ Int 68: 41–48. 10.1016/j.envint.2014.03.002.24704638
Stubleski, J; Lind, L; Salihovic, S; Lind, PM; Kärrman, A. (2018). Longitudinal changes in persistent organic pollutants (POPs) from 2001 to 2009 in a sample of elderly Swedish men and women. Environ Res 165: 193–200. 10.1016/j.envres.2018.04.009.29715601
Su, FC; Goutman, SA; Chernyak, S; Mukherjee, B; Callaghan, BC; Batterman, S; Feldman, EL. (2016). Association of Environmental Toxins With Amyotrophic Lateral Sclerosis. JAMA Neurol 73: 803–811. 10.1001/jamaneurol.2016.0594.27159543
Su, PH; Chen, HY; Chen, SJ; Chen, JY; Liou, SH; Wang, SL. (2015). Thyroid and growth hormone concentrations in 8-year-old children exposed in utero to dioxins and polychlorinated biphenyls. J Toxicol Sci 40: 309–319. 10.2131/jts.40.309.25972192
Su, PH; Huang, PC; Lin, CY; Ying, TH; Chen, JY; Wang, SL. (2012). The effect of in utero exposure to dioxins and polychlorinated biphenyls on reproductive development in eight year-old children. Environ Int 39: 181–187. 10.1016/j.envint.2011.09.009.22208758
Suarez-Lopez, JR; Clemesha, CG; Porta, M; Gross, MD; Lee, DH. (2019). Organochlorine pesticides and polychlorinated biphenyls (PCBs) in early adulthood and blood lipids over a 23-year follow-up. Environ Toxicol Pharmacol 66: 24–35. 10.1016/j.etap.2018.12.018.30594847
Suarez-Lopez, JR; Lee, DH; Porta, M; Steffes, MW; Jacobs, DR. (2015). Persistent organic pollutants in young adults and changes in glucose related metabolism over a 23-year follow-up. Environ Res 137: 485–494. 10.1016/j.envres.2014.11.001.25706918
Sugawara, N; Nakai, K; Nakamura, T; Ohba, T; Suzuki, K; Kameo, S; Satoh, C; Satoh, H. (2006). Developmental and neurobehavioral effects of perinatal exposure to polychlorinated biphenyls in mice. Arch Toxicol 80: 286–292. 10.1007/s00204-005-0042-4.16244857
Sugawara, N; Ohba, T; Nakai, K; Kakita, A; Nakamura, T; Suzuki, K; Kameo, S; Shimada, M; Kurokawa, N; Satoh, C; Satoh, H. (2008). Effects of perinatal coexposure to methylmercury and polychlorinated biphenyls on neurobehavioral development in mice. Arch Toxicol 82: 387–397. 10.1007/s00204-007-0254-x.17992516
Sumathi, T; Asha, D; Nagarajan, G; Sreenivas, A; Nivedha, R. (2016). L-Theanine alleviates the neuropathological changes induced by PCB (Aroclor 1254) via inhibiting upregulation of inflammatory cytokines and oxidative stress in rat brain. Environ Toxicol Pharmacol 42: 99–117. 10.1016/j.etap.2016.01.008.26826962
Sunyer, J; Garcia-Esteban, R; Alvarez, M; Guxens, M; Goni, F; Basterrechea, M; Vrijheid, M; Guerra, S; Anto, JM. (2010). DDE in mothers' blood during pregnancy and lower respiratory tract infections in their infants. Epidemiology 21: 729–735. 10.1097/EDE.0b013e3181e5ea96.20616741
Svensson, BG; Hallberg, T; Nilsson, A; Schütz, A; Hagmar, L. (1994). Parameters of immunological competence in subjects with high consumption of fish contaminated with persistent organochlorine compounds. Int Arch Occup Environ Health 65: 351–358. 10.1007/BF00383243.8034358
Takamatsu, M; Oki, M; Maeda, K; Inoue, Y; Hirayama, H; Yoshizuka, K. (1984). PCBs in blood of workers exposed to PCBs and their health status. Am J Ind Med 5: 59–68. 10.1002/ajim.4700050107.6422750
Takser, L; Lafond, J; Mergler, D. (2006). Prolactin levels are positively correlated with polychlorinated biphenyls (PCB) in cord serum. Environ Toxicol 10: 213–220. 10.2495/ETOX060211.
Takser, L; Mergler, D; Baldwin, M; de Grosbois, S; Smargiassi, A; Lafond, J. (2005). Thyroid hormones in pregnancy in relation to environmental exposure to organochlorine compounds and mercury. Environ Health Perspect 113: 1039–1045. 10.1289/ehp.7685.16079076
Talcott, PA; Koller, LD. (1983). The effect of inorganic lead and/or a polychlorinated biphenyl on the developing immune system of mice. J Toxicol Environ Health 12: 337–352. 10.1080/15287398309530431.6418890
Talcott, PA; Koller, LD; Exon, JH. (1985). The effect of lead and polychlorinated biphenyl exposure on rat natural killer cell cytotoxicity. 7: 255–261. 10.1016/0192-0561(85)90034-7.
Tanaka, T; Morita, A; Kato, M; Hirai, T; Mizoue, T; Terauchi, Y; Watanabe, S; Noda, M; SCOP Study Group. (2011). Congener-specific polychlorinated biphenyls and the prevalence of diabetes in the Saku Control Obesity Program (SCOP). Endocr J 58: 589–596. 10.1507/endocri.K10E-361.21551956
Tang-Páronard, JL; Heitmann, BL; Jensen, TK; Vinggaard, AM; Madsbad, S; Steuerwald, U; Grandjean, P; Weihe, P; Nielsen, F; Andersen, HR. (2015). Prenatal exposure to persistent organochlorine pollutants is associated with high insulin levels in 5-year-old girls. Environ Res 142: 407–413. 10.1016/j.envres.2015.07.009.26232659
Tang, M; Yin, S; Zhang, J; Chen, K; Jin, M; Liu, W. (2018). Prenatal exposure to polychlorinated biphenyl and umbilical cord hormones and birth outcomes in an island population. Environ Pollut 237: 581–591. 10.1016/j.envpol.2018.02.044.29525625
Tanner, EM; Bloom, MS; Kannan, K; Lynch, J; Wang, W; Yucel, R; Fitzgerald, EF. (2020). A longitudinal study of polychlorinated biphenyls and neuropsychological function among older adults from New York State. Int J Hyg Environ Health 223: 1–9. 10.1016/j.ijheh.2019.10.012.31706927
Tatsuta, N; Nakai, K; Murata, K; Suzuki, K; Iwai-Shimada, M; Yaginuma-Sakurai, K; Kurokawa, N; Nakamura, T; Hosokawa, T; Satoh, H. (2012). Prenatal exposures to environmental chemicals and birth order as risk factors for child behavior problems. Environ Res 114: 47–52. 10.1016/j.envres.2012.02.001.22421256
Taylor, MM; Crofton, KM; MacPhail, RC. (2002). Schedule-controlled behavior in rats exposed perinatally to the PCB mixture Aroclor 1254. Neurotoxicol Teratol 24: 511–518.12127897
Taylor, PR; Lawrence, CE; Hwang, HL; Paulson, AS. (1984). Polychlorinated biphenyls: Influence on birthweight and gestation. Am J Public Health 74: 1153–1154. 10.2105/ajph.74.10.1153.6433730
Taylor, PR; Stelma, JM; Lawrence, CE. (1989). The relation of polychlorinated biphenyls to birth weight and gestational age in the offspring of occupationally exposed mothers. Am J Epidemiol 129: 395–406.2492144
Tesch, GH. (2010). Review: Serum and urine biomarkers of kidney disease: A pathophysiological perspective [Review]. Nephrology 15: 609–616. 10.1111/j.1440-1797.2010.01361.x.20883281
Tewari, N; Kalkunte, S; Murray, DW; Sharma, S. (2009). The water channel aquaporin 1 is a novel molecular target of polychlorinated biphenyls for in utero anomalies. J Biol Chem 284: 15224–15232. 10.1074/jbc.M808892200.19332547
Thayer, KA; Shaffer, RM; Angrish, M; Arzuaga, X; Carlson, LM; Davis, A; Dishaw, L; Druwe, I; Gibbons, C; Glenn, B; Jones, R; Kaiser, JP; Keshava, C; Keshava, N; Kraft, A; Lizarraga, L; Markey, K; Persad, A; Radke, EG; ... Yost, E. (2022). Use of systematic evidence maps within the US environmental protection agency (EPA) integrated risk information system (IRIS) program: Advancements to date and looking ahead [Comment]. Environ Int 169: 107363. 10.1016/j.envint.2022.107363.36057470
Thomas, PT; Hinsdill, RD. (1978). Effect of polychlorinated biphenyls on the immune responses of rhesus monkeys and mice. Toxicol Appl Pharmacol 44: 41–51. 10.1016/0041-008X(78)90282-X.79241
Thomas, PT; Hinsdill, RD. (1980). Perinatal PCB exposure and its effect on the immune system of young rabbits. Drug Chem Toxicol 3: 173–184. 10.3109/01480548009108281.6785064
Tian, YH; Hwan Kim, S; Lee, SY; Jang, CG. (2011). Lactational and postnatal exposure to polychlorinated biphenyls induces sex-specific anxiolytic behavior and cognitive deficit in mice offspring. Synapse 65: 1032–1041. 10.1002/syn.20934.21425352
Timmermann, CAG; Pedersen, HS; Weihe, P; Bjerregaard, P; Nielsen, F; Heilmann, C; Grandjean, P. (2021). Concentrations of tetanus and diphtheria antibodies in vaccinated Greenlandic children aged 7–12 years exposed to marine pollutants, a cross sectional study. Environ Res 203: 111712. 10.1016/j.envres.2021.111712.34343554
Toft, G; Axmon, A; Giwercman, A; Thulstrup, AM; Rignell-Hydbom, A; Pedersen, HS; Ludwicki, JK; Zvyezday, V; Zinchuk, A; Spano, M; Manicardi, GC; Bonefeld-Jörgensen, EC; Hagmar, L; Bonde, JP; INUENDO. (2005). Fertility in four regions spanning large contrasts in serum levels of widespread persistent organochlorines: A cross-sectional study. Environ Health 4: 26. 10.1186/1476-069X-4-26.16280075
Toft, G; Rignell-Hydbom, A; Tyrkiel, E; Shvets, M; Giwercman, A; Lindh, CH; Pedersen, HS; Ludwicki, JK; Lesovoy, V; Hagmar, L; Spanó, M; Manicardi, GC; Bonefeld-Jorgensen, EC; Thulstrup, AM; Bonde, JP. (2006). Semen quality and exposure to persistent organochlorine pollutants. Epidemiology 17: 450–458. 10.1097/01.ede.0000221769.41028.d2.16755259
Tokunaga, S; Kataoka, K. (2001). Association between blood concentration of polychlorinated biphenyls and manifestations of symptoms and signs in chronic "Yusho" patients from 1986 to 1997. Fukuoka Igaku Zasshi 92: 122–133.11452509
Tokunaga, S; Kataoka, K. (2003). A longitudinal analysis on the association of serum lipids and lipoproteins concentrations with blood polychlorinated biphenyls level in chronic "Yusho" patients. Fukuoka Igaku Zasshi 94: 110–117.12872711
Topper, VY; Reilly, MP; Wagner, LM; Thompson, LM; Gillette, R; Crews, D; Gore, AC. (2019). Social and neuromolecular phenotypes are programmed by prenatal exposures to endocrine-disrupting chemicals. Mol Cell Endocrinol 479: 133–146. 10.1016/j.mce.2018.09.010.30287398
Trabert, B; Chen, Z; Kannan, K; Peterson, CM; Pollack, AZ; Sun, L; Buck Louis, GM. (2015). Persistent organic pollutants (POPs) and fibroids: results from the ENDO study. J Expo Sci Environ Epidemiol 25: 278–285. 10.1038/jes.2014.31.24802554
Triplett, DA. (2000). Coagulation and bleeding disorders: review and update. Clin Chem 46: 1260–1269.10926920
Trnovec, T; Jusko, TA; Šovčíková, E; Lancz, K; Chovancová, J; Patayová, H; Palkovičová, L; Drobná, B; Langer, P; Van den Berg, M; Dedik, L; Wimmerová, S. (2013). Relative effect potency estimates of dioxin-like activity for dioxins, furans, and dioxin-like PCBs in adults based on two thyroid outcomes. Environ Health Perspect 121: 886–892. 10.1289/ehp.1205739.23665575
Trnovec, T; Šovčíková, E; Hust'ák, M; Wimmerova, S; Kočan, A; Jurečková, D; Langer, P; Palkoviíová, L; Drobná, B. (2008). Exposure to polychlorinated biphenyls and hearing impairment in children. Environ Toxicol Pharmacol 25: 183–187. 10.1016/j.etap.2007.10.030.21783857
Trnovec, T; Šovčíková, E; Pavlovcinová, G; Jakubíková, J; Jusko, TA; Husták, M; Jurecková, D; Palkovicová, L; Kocan, A; Drobná, B; Lancz, K; Wimmerová, S. (2010). Serum PCB concentrations and cochlear function in 12-year-old children. Environ Sci Technol 44: 2884–2889. 10.1021/es901918h.20384380
Truelove, JF; Tanner, JR; Langlois, IA; Stapley, RA; Arnold, DL; Mes, JC. (1990). Effect of polychlorinated biphenyls on several endocrine reproductive parameters in the female rhesus monkey. Arch Environ Contam Toxicol 19: 939–943. 10.1007/BF01055065.2124092
Tryphonas, H; Hayward, S; O'Grady, L; Loo, JCK; Arnold, DL; Bryce, F; Zawidzka, ZZ. (1989). Immunotoxicity studies of PCB (Aroclor 1254) in the adult rhesus (Macaca mulatta) monkey--Preliminary report. International Journal of Immunopharmacology 11: 199–206. 10.1016/0192-0561(89)90072–6.2495254
Tryphonas, H; Luster, MI; Schiffman, G; Dawson, LL; Hodgen, M; Germolec, D; Hayward, S; Bryce, F; Loo, JCK; Mandy, F; Arnold, DL. (1991). Effect of chronic exposure of PCB (Aroclor 1254) on specific and nonspecific immune parameters in the rhesus (Macaca mulatta) monkey. Fundam Appl Toxicol 16: 773–786. 10.1093/toxsci/16.4.773.1884915
Tsuji, M; Vogel, CFA; Koriyama, C; Akiba, S; Katoh, T; Kawamoto, T; Matsumura, F. (2012). Association of serum levels of polychlorinated biphenyls with IL-8 mRNA expression in blood samples from asthmatic and non-asthmatic Japanese children. Chemosphere 87: 1228–1234. 10.1016/j.chemosphere.2012.01.022.22326254
Tsukimori, K; Tokunaga, S; Shibata, S; Uchi, H; Nakayama, D; Ishimaru, T; Nakano, H; Wake, N; Yoshimura, T; Furue, M. (2008). Long-term effects of polychlorinated biphenyls and dioxins on pregnancy outcomes in women affected by the Yusho incident. Environ Health Perspect 116: 626–630. 10.1289/ehp.10686.18470296
Turyk, M; Anderson, H; Knobeloch, L; Imm, P; Persky, V. (2009). Organochlorine exposure and incidence of diabetes in a cohort of Great Lakes sport fish consumers. Environ Health Perspect 117: 1076–1082. 10.1289/ehp.0800281.19654916
Turyk, ME; Bhavsar, SP; Bowerman, W; Boysen, E; Clark, M; Diamond, M; Mergler, D; Pantazopoulos, P; Schantz, S; Carpenter, DO. (2012). Risks and benefits of consumption of Great Lakes fish [Review]. Environ Health Perspect 120: 11–18. 10.1289/ehp.1003396.21947562
U.S. EPA (U.S. Environmental Protection Agency). (1979). EPA bans PCB manufacture; phases out uses (EPA press release - April 19, 1979). Available online at https://archive.epa.gov/epa/aboutepa/epa-bans-pcb-manufacture-phases-out-uses.html (accessed July 9, 2021).
U.S. EPA (U.S. Environmental Protection Agency). (1991). Guidelines for developmental toxicity risk assessment. Fed Reg 56: 63798–63826.
U.S. EPA (U.S. Environmental Protection Agency). (1993). IRIS chemical assessment summary for Aroclor 1016 (CASRN 12674–11-2). https://cfpub.epa.gov/ncea/iris2/chemicalLanding.cfm?substancenmbr=462.
U.S. EPA (U.S. Environmental Protection Agency). (1994). IRIS chemical assessment summary for Aroclor 1248 (CASRN 12672–29-6). https://cfpub.epa.gov/ncea/iris2/chemicalLanding.cfm?substancenmbr=649.
U.S. EPA (U.S. Environmental Protection Agency). (1996). PCBs: Cancer dose-response assessment and application to environmental mixtures [EPA Report]. (EPA/600/P-96/001F). Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development, National Center for Environmental Assessment. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=300028X3.txt.
U.S. EPA (U.S. Environmental Protection Agency). (2012). Polychlorinated biphenyls (PCBs) in school buildings: Sources, environmental levels, and exposures [EPA Report]. (EPA/600/R-12/051). https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=P100FK2V.txt.
U.S. EPA (U.S. Environmental Protection Agency). (2015). Scoping and problem formulation for the toxicological review of polychlorinated biphenyls (PCBS): Effects other than cancer (Draft) [EPA Report]. (EPA/635/R-14/198). Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development, National Center for Environmental Assessment. https://cfpub.epa.gov/ncea/iris_drafts/recordisplay.cfm?deid=309645.
U.S. EPA (U.S. Environmental Protection Agency). (2019). Systematic review protocol for the polychlorinated biphenyls (PCBs) noncancer IRIS assessment (preliminary assessment materials) [EPA Report]. (EPA/635/R-19/201). Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development, Center for Public Health and Environmental Assessment, Integrated Risk Information System. https://cfpub.epa.gov/ncea/iris_drafts/recordisplay.cfm?deid=237359.
U.S. EPA (U.S. Environmental Protection Agency). (2022). ORD staff handbook for developing IRIS assessments [EPA Report]. (EPA 600/R-22/268). Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development, Center for Public Health and Environmental Assessment. https://cfpub.epa.gov/ncea/iris_drafts/recordisplay.cfm?deid=356370.
Uemura, H; Arisawa, K; Hiyoshi, M; Kitayama, A; Takami, H; Sawachika, F; Dakeshita, S; Nii, K; Satoh, H; Sumiyoshi, Y; Morinaga, K; Kodama, K; Suzuki, TI; Nagai, M; Suzuki, T. (2009). Prevalence of metabolic syndrome associated with body burden levels of dioxin and related compounds among Japan's general population. Environ Health Perspect 117: 568–573. 10.1289/ehp.0800012.19440495
Ukropec, J; Radikova, Z; Huckova, M; Koska, J; Kocan, A; Sebokova, E; Drobna, B; Trnovec, T; Susienkova, K; Labudova, V; Gasperikova, D; Langer, P; Klimes, I. (2010). High prevalence of prediabetes and diabetes in a population exposed to high levels of an organochlorine cocktail. Diabetologia 53: 899–906. 10.1007/s00125-010-1683-2.20182860
Vafeiadi, M; Georgiou, V; Chalkiadaki, G; Rantakokko, P; Kiviranta, H; Karachaliou, M; Fthenou, E; Venihaki, M; Sarri, K; Vassilaki, M; Kyrtopoulos, SA; Oken, E; Kogevinas, M; Chatzi, L. (2015). Association of Prenatal Exposure to Persistent Organic Pollutants with Obesity and Cardiometabolic Traits in Early Childhood: The Rhea Mother-Child Cohort (Crete, Greece). Environ Health Perspect 123: 1015–1021. 10.1289/ehp.1409062.25910281
Vafeiadi, M; Roumeliotaki, T; Chalkiadaki, G; Rantakokko, P; Kiviranta, H; Fthenou, E; Kyrtopoulos, SA; Kogevinas, M; Chatzi, L. (2017). Persistent organic pollutants in early pregnancy and risk of gestational diabetes mellitus. Environ Int 98: 89–95. 10.1016/j.envint.2016.10.005.27743729
Vagi, SJ; Azziz-Baumgartner, E; Sjödin, A; Calafat, AM; Dumesic, D; Gonzalez, L; Kato, K; Silva, MJ; Ye, X; Azziz, R. (2014). Exploring the potential association between brominated diphenyl ethers, polychlorinated biphenyls, organochlorine pesticides, perfluorinated compounds, phthalates, and bisphenol a in polycystic ovary syndrome: a case-control study. BMC Endocrine Disorders 14: 86. 10.1186/1472-6823-14-86.25348326
Valvi, D; Oulhote, Y; Weihe, P; Dalgård, C; Bjerve, KS; Steuerwald, U; Grandjean, P. (2017). Gestational diabetes and offspring birth size at elevated environmental pollutant exposures. Environ Int 107: 205–215. 10.1016/j.envint.2017.07.016.28753482
van Batenburg-Eddes, T; de Groot, L; Steegers, EA; Hofman, A; Jaddoe, VW; Verhulst, FC; Tiemeier, H. (2010). Fetal programming of infant neuromotor development: the generation R study. Pediatr Res 67: 132–137. 10.1203/PDR.0b013e3181c2dc76.
van den Berg, M; Birnbaum, LS; Denison, M; De Vito, M; Farland, W; Feeley, M; Fiedler, H; Hakansson, H; Hanberg, A; Haws, L; Rose, M; Safe, S; Schrenk, D; Tohyama, C; Tritscher, A; Tuomisto, J; Tysklind, M; Walker, N; Peterson, RE. (2006). The 2005 World Health Organization reevaluation of human and mammalian toxic equivalency factors for dioxins and dioxin-like compounds [Review]. Toxicol Sci 93: 223–241. 10.1093/toxsci/kfl055.16829543
van den Berg, M; Kypke, K; Kotz, A; Tritscher, A; Lee, SY; Magulova, K; Fiedler, H; Malisch, R. (2017). WHO/UNEP global surveys of PCDDs, PCDFs, PCBs and DDTs in human milk and benefit-risk evaluation of breastfeeding [Review]. Arch Toxicol 91: 83–96. 10.1007/s00204-016-1802-z.27438348
Van Den Heuvel, RL; Koppen, G; Staessen, JA; Den Hond, E; Verheyen, G; Nawrot, TS; Roels, HA; Vlietinck, R; Schoeters, GER. (2002). Immunologic biomarkers in relation to exposure markers of PCBs and dioxins in Flemish adolescents (Belgium). Environ Health Perspect 110: 595–600. 10.1289/ehp.02110595.12055051
Van Larebeke, N; Sioen, I; Hond, ED; Nelen, V; Van de Mieroop, E; Nawrot, T; Bruckers, L; Schoeters, G; Baeyens, W. (2015). Internal exposure to organochlorine pollutants and cadmium and self-reported health status: a prospective study. Int J Hyg Environ Health 218: 232–245. 10.1016/j.ijheh.2014.11.002.25547368
van Wijngaarden, E; Savitz, DA; Kleckner, RC; Kavet, R; Loomis, D. (2001). Mortality patterns by occupation in a cohort of electric utility workers. Am J Ind Med 40: 667–673. 10.1002/ajim.10015.11757043
Varghese, A; Cawley, M; Hong, T. (2018). Supervised clustering for automated document classification and prioritization: A case study using toxicological abstracts. Environ Syst Decis 38: 398–414. 10.1007/s10669-017-9670-5.
Varghese, A; Hong, T; Hunter, C; Agyeman-Badu, G; Cawley, M. (2019). Active learning in automated text classification: a case study exploring bias in predicted model performance metrics. Environ Syst Decis 39: 1–12. 10.1007/s10669019-09717-3.
Vasiliu, O; Muttineni, J; Karmaus, W. (2004). In utero exposure to organochlorines and age at menarche. Hum Reprod 19: 1506–1512. 10.1093/humrep/deh292.15131079
Velasquez, MT; Kimmel, PL; Michaelis, OE. (1990). Animal models of spontaneous diabetic kidney disease [Review]. FASEB J 4: 2850–2859. 10.1096/fasebj.4.11.2199283.2199283
Vermeir, G; Viaene, M; Staessen, J; Den Hond, E; Roels, HA. (2005). Neurobehavioural investigations in adolescents exposed to environmental pollutants. Environ Toxicol Pharmacol 19: 707–713. 10.1016/j.etap.2004.12.041.21783546
Vested, A; Ramlau-Hansen, CH; Olsen, SF; Bonde, JP; Stovring, H; Kristensen, SL; Halldorsson, TI; Rantakokko, P; Kiviranta, H; Ernst, EH; Toft, G. (2014). In utero exposure to persistent organochlorine pollutants and reproductive health in the human male. Reproduction 148: 635–646. 10.1530/REP-13-0488.25190505
Viigimaa, M; Vlachopoulos, C; Doumas, M; Wolf, J; Imprialos, K; Terentes-Printzios, D; Ioakeimidis, N; Kotsar, A; Kiitam, U; Stavropoulos, K; Narkiewicz, K; Manolis, A; Jelakovic, B; Lovic, D; Kreutz, R; Tsioufis, K; Mancia, G. (2020). Update of the position paper on arterial hypertension and erectile dysfunction. J Hypertens 38: 1220–1234. 10.1097/HJH.0000000000002382.32073535
Vinceti, M; Violi, F; Tzatzarakis, M; Mandrioli, J; Malagoli, C; Hatch, EE; Fini, N; Fasano, A; Rakitskii, VN; Kalantzi, OI; Tsatsakis, A. (2017). Pesticides, polychlorinated biphenyls and polycyclic aromatic hydrocarbons in cerebrospinal fluid of amyotrophic lateral sclerosis patients: a case-control study. Environ Res 155: 261–267. 10.1016/j.envres.2017.02.025.28242563
Vitku, J; Heracek, J; Sosvorova, L; Hampl, R; Chlupacova, T; Hill, M; Sobotka, V; Bicikova, M; Starka, L. (2016). Associations of bisphenol A and polychlorinated biphenyls with spermatogenesis and steroidogenesis in two biological fluids from men attending an infertility clinic. Environ Int 89-90: 166–173. 10.1016/j.envint.2016.01.021.
Vogel-Ciernia, A; Wood, MA. (2014). Examining object location and object recognition memory in mice. Curr Protoc Neurosci 69: 8.31.31–38.31.17. 10.1002/0471142301.ns0831s69.
Vorkamp, K. (2015). An overlooked environmental issue? A review of the inadvertent formation of PCB-11 and other PCB congeners and their occurrence in consumer products and in the environment [Review]. Sci Total Environ 541: 1463–1476. 10.1016/j.scitotenv.2015.10.019.26490526
Vos, JG; Beems, RB. (1971). Dermal toxicity studies of technical polychlorinated biphenyls and fractions thereof in rabbits. Toxicol Appl Pharmacol 19: 617–633. 10.1016/0041-008X(71)90294–8.5132032
Vos, JG; de Roij, T. (1972). Immunosuppressive activity of a polychlorinated diphenyl preparation on the humoral immune response in guinea pigs. Toxicol Appl Pharmacol 21: 549–555. 10.1016/0041-008X(72)90011–7.4114810
Vos, JG; Notenboom-Ram, E. (1972). Comparative toxicity study of 2,4,5,2',4',5'-hexachlorobiphenyl and a polychlorinated biphenyl mixture in rabbits. Toxicol Appl Pharmacol 23: 563–578. 10.1016/0041-008X(72)90097-X.4630164
Vos, JG; Van Driel-Grootenhuis, L. (1972). PCB-induced suppression of the humoral and cell-mediated immunity in guinea pigs. Sci Total Environ 1: 289–302. 10.1016/0048-9697(72)90024–1.4633048
Vreugdenhil, HJ; Lanting, CI; Mulder, PGH; Boersma, ER; Weisglas-Kuperus, N. (2002). Effects of prenatal PCB and dioxin background exposure on cognitive and motor abilities in Dutch children at school age. J Pediatr 140: 48–56. 10.1067/mpd.2002.119625.11815763
Vreugdenhil, HJ; Mulder, PGH; Emmen, HH; Weisglas-Kuperus, N. (2004a). Effects of perinatal exposure to PCBs on neuropsychological functions in the Rotterdam cohort at 9 years of age. Neuropsychology 18: 185–193. 10.1037/0894-4105.18.1.185.14744201
Vreugdenhil, HJ; Van Zanten, GA; Brocaar, MP; Mulder, PG; Weisglas-Kuperus, N. (2004b). Prenatal exposure to polychlorinated biphenyls and breastfeeding: opposing effects on auditory P300 latencies in 9-year-old Dutch children. Dev Med Child Neurol 46: 398–405. 10.1017/S0012162204000647.15174531
Wahlang, B; Appana, S; Falkner, KC; McClain, CJ; Brock, G; Cave, MC. (2020). Insecticide and metal exposures are associated with a surrogate biomarker for non-alcoholic fatty liver disease in the National Health and Nutrition Examination Survey 2003–2004. Environ Sci Pollut Res Int 27: 6476–6487. 10.1007/s11356-019-07066-x.31873887
Wahlang, B; Jin, J; Hardesty, JE; Head, KZ; Shi, H; Falkner, KC; Prough, RA; Klinge, CM; Cave, MC. (2019). Identifying sex differences arising from polychlorinated biphenyl exposures in toxicant-associated liver disease. Food Chem Toxicol 129: 64–76. 10.1016/j.fct.2019.04.007.31026535
Wahlang, B; Perkins, JT; Petriello, MC; Hoffman, JB; Strömberg, AJ; Hennig, B. (2017). A compromised liver alters polychlorinated biphenyl-mediated toxicity. Toxicology 380: 11–22. 10.1016/j.tox.2017.02.001.28163111
Wahlang, B; Prough, RA; Falkner, KC; Hardesty, JE; Song, M; Clair, HB; Clark, BJ; States, JC; Arteel, GE; Cave, MC. (2016). Polychlorinated biphenyl-xenobiotic nuclear receptor interactions regulate energy metabolism, behavior, and inflammation in non-alcoholic-steatohepatitis. Toxicol Sci 149: 396–410. 10.1093/toxsci/kfv250.26612838
Wahlang, B; Song, M; Beier, JI; Cameron Falkner, K; Al-Eryani, L; Clair, HB; Prough, RA; Osborne, TS; Malarkey, DE; States, JC; Cave, MC. (2014). Evaluation of Aroclor 1260 exposure in a mouse model of diet-induced obesity and non-alcoholic fatty liver disease. Toxicol Appl Pharmacol 279: 380–390. 10.1016/j.taap.2014.06.019.24998970
Wahlström, E; Ollerstam, A; Sundius, L; Zhang, H. (2013). Use of lung weight as biomarker for assessment of lung toxicity in rat inhalation studies. Toxicol Pathol 41: 902–912. 10.1177/0192623312470763.23319420
Walker, DM; Goetz, BM; Gore, AC. (2014). Dynamic postnatal developmental and sex-specific neuroendocrine effects of prenatal PCBs in rats. Mol Endocrinol 28: 99–115. 10.1210/me.2013-1270.24284824
Walkowiak, J; Wiener, JA; Fastabend, A; Heinzow, B; Krämer, U; Schmidt, E; Steingrüber, HJ; Wundram, S; Winneke, G. (2001). Environmental exposure to polychlorinated biphenyls and quality of the home environment: Effects on psychodevelopment in early childhood. Lancet 358: 1602–1607. 10.1016/S0140-6736(01)06654–5.11716887
Wallin, E; Rylander, L; Jönssson, BA; Lundh, T; Isaksson, A; Hagmar, L. (2005). Exposure to CB-153 and p,p'-DDE and bone mineral density and bone metabolism markers in middle-aged and elderly men and women. Osteoporos Int 16: 2085–2094. 10.1007/s00198-005-2004-3.16234998
Wang, BL; Pang, ST; Sun, JP; Zhang, XL; Li, XL; Sun, YG; Lu, XM; Zhang, Q. (2015). Levels of polychlorinated biphenyls in settled house dust from urban dwellings in China and their neurodevelopmental effects on preschool-aged children. Sci Total Environ 505: 402–408. 10.1016/j.scitotenv.2014.10.026.25461042
Wang, SL; Chen, TT; Hsu, JF; Hsu, CC; Chang, LW; Ryan, JJ; Guo, YL; Lambert, GH. (2003). Neonatal and childhood teeth in relation to perinatal exposure to polychlorinated biphenyls and dibenzofurans: Observations of the Yucheng children in Taiwan. Environ Res 93: 131–137. 10.1016/S0013-9351(03)00040–9.12963397
Wang, SL; Su, PH; Jong, SB; Guo, YL; Chou, WL; Päpke, O. (2005). In utero exposure to dioxins and polychlorinated biphenyls and its relations to thyroid function and growth hormone in newborns. Environ Health Perspect 113: 1645–1650. 10.1289/ehp.7994.16263525
Wang, Y; Lu, C; Sheng, Z; Liu, G; Fu, Z; Zhu, B; Peng, S. (2011). Enhanced hepatotoxicity induced by repeated exposure to polychlorinated biphenyls and 2,3,7,8-tetrachlorodibenzo-p-dioxin in combination in male rats. J Environ Sci 23: 119–124. 10.1016/S1001-0742(10)60382-8.
Warembourg, C; Debost-Legrand, A; Bonvallot, N; Massart, C; Garlantézec, R; Monfort, C; Gaudreau, E; Chevrier, C; Cordier, S. (2015). Exposure of pregnant women to persistent organic pollutants and cord sex hormone levels. Hum Reprod 31: 190–198. 10.1093/humrep/dev260.26493407
Warembourg, C; Maitre, L; Tamayo-Uria, I; Fossati, S; Roumeliotaki, T; Aasvang, GM; Andrusaityte, S; Casas, M; Cequier, E; Chatzi, L; Dedele, A; Gonzalez, JR; Grazuleviciene, R; Haug, LS; Hernandez-Ferrer, C; Heude, B; Karachaliou, M; Krog, NH; Mceachan, R; ... Basagana, X. (2019). Early-life environmental exposures and blood pressure in children. J Am Coll Cardiol 74: 1317–1328. 10.1016/j.jacc.2019.06.069.31488269
Wassermann, M; Ron, M; Bercovici, B; Wassermann, D; Cucos, S; Pines, A. (1982). Premature delivery and organochlorine compounds: Polychlorinated biphenyls and some organochlorine insecticides. Environ Res 28: 106–112. 10.1016/0013-9351(82)90158-X.6179776
Watanabe, M; Sugahara, T. (1981). Experimental formation of cleft palate in mice with polychlorinated biphenyls (PCB). Toxicology 19: 49–53.6784272
Wei, T; Ping, CJ; Chen, YY; Hua, WW. (2015). Assessing Adverse Effects of Aroclor 1254 on perinatally Exposed Rat Offspring [Letter]. Biomed Environ Sci 28: 687–690. 10.3967/bes2015.097.26464258
Weisglas-Kuperus, N; Patandin, S; Berbers, GAM; Sas, TCJ; Mulder, PGH; Sauer, PJJ; Hooijkaas, H. (2000). Immunologic effects of background exposure to polychlorinated biphenyls and dioxins in Dutch preschool children. Environ Health Perspect 108: 1203–1207.11133402
Weisglas-Kuperus, N; Sas, TCJ; Koopman-Esseboom, C; van der Zwan, CW; De Ridder, MAJ; Beishuizen, A; Hooijkaas, H; Sauer, PJJ. (1995). Immunologic effects of background prenatal and postnatal exposure to dioxins and polychlorinated biphenyls in Dutch infants. Pediatr Res 38: 404–410. 10.1203/00006450-199509000-00022.7494667
Weisglas-Kuperus, N; Vreugdenhil, HJI; Mulder, PGH. (2004). Immunological effects of environmental exposure to polychlorinated biphenyls and dioxins in Dutch school children. Toxicol Lett 149: 281–285. 10.1016/j.toxlet.2003.12.039.15093274
Weiss, B. (2010). Lead, manganese, and methylmercury as risk factors for neurobehavioral impairment in advanced age. International Journal of Alzheimer's Disease 2011: 607543. 10.4061/2011/607543.
Weiss, J; Wallin, E; Axmon, A; Jönsson, BA; Akesson, H; Janák, K; Hagmar, L; Bergman, A. (2006). Hydroxy-PCBs, PBDEs, and HBCDDs in serum from an elderly population of Swedish fishermen's wives and associations with bone density. Environ Sci Technol 40: 6282–6289. 10.1021/es0610941.17120554
Weisskopf, MG; Knekt, P; O'Reilly, EJ; Lyytinen, J; Reunanen, A; Laden, F; Altshul, L; Ascherio, A. (2012). Polychlorinated biphenyls in prospectively collected serum and Parkinson's disease risk. Mov Disord 27: 1659–1665. 10.1002/mds.25217.23044514
Weitekamp, CA; Phillips, LJ; Carlson, LM; Deluca, NM; Hubal, EAC; Lehmann, GM. (2021). A state-of-the-science review of polychlorinated biphenyl exposures at background levels: Relative contributions of exposure routes. Sci Total Environ 776: 145912. 10.1016/j.scitotenv.2021.145912.36590071
Welsch, F. (1985). Effects of acute or chronic polychlorinated biphenyl ingestion on maternal metabolic homeostasis and on the manifestations of embryotoxicity caused by cyclophosphamide in mice. Arch Toxicol 57: 104–113. 10.1007/BF00343119.3927875
Wenk, GL. (2004). Assessment of spatial memory using the radial arm maze and Morris water maze. Curr Protoc Neurosci Chapter 8: Unit 8.5A. 10.1002/0471142301.ns0805as26.
Wesselink, AK; Claus Henn, B; Fruh, V; Orta, OR; Weuve, J; Hauser, R; Williams, PL; McClean, MD; Sjodin, A; Bethea, TN; Brasky, TM; Baird, DD; Wise, LA. (2021). A prospective ultrasound study of plasma polychlorinated biphenyl concentrations and incidence of uterine leiomyomata. Epidemiology 32: 259–267. 10.1097/EDE.0000000000001320.33427764
Whitcomb, BW; Schisterman, EF; Buck, GM; Weiner, JM; Greizerstein, H; Kostyniak, PJ. (2005). Relative concentrations of organochlorines in adipose tissue and serum among reproductive age women. Environ Toxicol Pharmacol 19: 203–213. 10.1016/j.etap.2004.04.009.21783478
White, RF; Campbell, R; Echeverria, D; Knox, SS; Janulewicz, P. (2009). Assessment of neuropsychological trajectories in longitudinal population-based studies of children. J Epidemiol Community Health 63: i15–i26. 10.1136/jech.2007.071530.19098136
White, RF; Palumbo, CL; Yurgelun-Todd, DA; Heaton, KJ; Weihe, P; Debes, F; Grandjean, P. (2011). Functional MRI approach to developmental methylmercury and polychlorinated biphenyl neurotoxicity. Neurotoxicology 32: 975–980. 10.1016/j.neuro.2011.04.001.21545807
Widholm, JJ; Clarkson, GB; Strupp, BJ; Crofton, KM; Seegal, RF; Schantz, SL. (2001). Spatial reversal learning in Aroclor 1254-exposed rats: Sex-specific deficits in associative ability and inhibitory control. Toxicol Appl Pharmacol 174: 188–198. 10.1006/taap.2001.9199.11446834
Widholm, JJ; Villareal, S; Seegal, RF; Schantz, SL. (2004). Spatial alternation deficits following developmental exposure to Aroclor 1254 and/or methylmercury in rats. Toxicol Sci 82: 577–589. 10.1093/toxsci/kfh290.15456922
Wilhelm, M; Ranft, U; Krämer, U; Wittsiepe, J; Lemm, F; Fürst, P; Eberwein, G; Winneke, G. (2008a). Lack of neurodevelopmental adversity by prenatal exposure of infants to current lowered PCB levels: Comparison of two German birth cohort studies. J Toxicol Environ Health A 71: 700–702. 10.1080/15287390801984904.18569566
Wilhelm, M; Wittsiepe, J; Lemm, F; Ranft, U; Krämer, U; Fürst, P; Röseler, SC; Greshake, M; Imöhl, M; Eberwein, G; Rauchfuss, K; Kraft, M; Winneke, G. (2008b). The Duisburg birth cohort study: Influence of the prenatal exposure to PCDD/Fs and dioxin-like PCBs on thyroid hormone status in newborns and neurodevelopment of infants until the age of 24 months [Review]. Mutat Res 659: 83–92. 10.1016/j.mrrev.2007.11.002.18093869
Willett, LB; Liu, TT; Durst, HI; Smith, KL; Redman, DR. (1987). Health and productivity of dairy cows fed polychlorinated biphenyls. Fundam Appl Toxicol 9: 60–68. 10.1093/toxsci/9.1.60.3114032
Windham, GC; Lee, D; Mitchell, P; Anderson, M; Petreas, M; Lasley, B. (2005). Exposure to organochlorine compounds and effects on ovarian function. Epidemiology 16: 182–190. 10.1097/01.ede.0000152527.24339.17.15703532
Windham, GC; Pinney, SM; Voss, RW; Sjodin, A; Biro, FM; Greenspan, LC; Stewart, S; Hiatt, RA; Kushi, LH. (2015). Brominated flame retardants and other persistent organohalogenated compounds in relation to timing of puberty in a longitudinal study of girls. Environ Health Perspect 123: 1046–1052. 10.1289/ehp.1408778.25956003
Winneke, G; Bucholski, A; Heinzow, B; Krämer, U; Schmidt, E; Walkowiak, J; Wiener, JA; Steingrüber, HJ. (1998). Developmental neurotoxicity of polychlorinated biphenyls (PCBS): Cognitive and psychomotor functions in 7-month old children. Toxicol Lett 102-103: 423–428. 10.1016/S0378-4274(98)00334-8.10022290
Winneke, G; Krämer, U; Sucker, K; Walkowiak, J; Fastabend, A; Heinzow, B; Steingrüber, HJ. (2005). PCB-related neurodevelopmental deficit may be transient: Follow-up of a cohort at 6 years of age. Environ Toxicol Pharmacol 19: 701–706. 10.1016/j.etap.2004.12.040.21783545
Winslow, JT. (2003). Mouse social recognition and preference. Curr Protoc Neurosci 22: 8.16.11-18.16.16. 10.1002/0471142301.ns0816s22.
Wojtyniak, BJ; Rabczenko, D; Jönsson, BA; Zvezday, V; Pedersen, HS; Rylander, L; Toft, G; Ludwicki, JK; Góralczyk, K; Lesovaya, A; Hagmar, L; Bonde, JP; Group, IR. (2010). Association of maternal serum concentrations of 2,2', 4,4'5,5'-hexachlorobiphenyl (CB-153) and l,l-dichloro-2,2-bis (p-chlorophenyl)-ethylene (p,p'-DDE) levels with birth weight, gestational age and preterm births in Inuit and European populations. Environ Health 9: 56. 10.1186/1476-069X-9-56.20819217
Wolff, MS. (1985). Occupational exposure to polychiorinated biphenyls (PCBs). Environ Health Perspect 60: 133–138. 10.2307/3429954.3928344
Wolff, MS; Britton, JA; Boguski, L; Hochman, S; Maloney, N; Serra, N; Liu, ZS; Berkowitz, G; Larson, S; Forman, J. (2008). Environmental exposures and puberty in inner-city girls. Environ Res 107: 393–400. 10.1016/j.envres.2008.03.006.18479682
Wu, K; Xu, X; Liu, J; Guo, Y; Huo, X. (2011). In utero exposure to polychlorinated biphenyls and reduced neonatal physiological development from Guiyu, China. Ecotoxicol Environ Saf 74: 2141–2147. 10.1016/j.ecoenv.2011.07.038.21851983
Wu, YC; Hsieh, RP; Lu, YC. (1984a). Altered distribution of lymphocyte subpopulations and augmentation of lymphocyte proliferation in chronic PCB poisoned patients. Zhonghua Weishengwuxue he Mianyixue Zazhi 17: 177–187.
Wu, YC; Lü, YC; Kao, HY; Pan, CC; Lin, RY. (1984b). Cell-mediated immunity in patients with polychlorinated biphenyl poisoning. Taiwan Yi Xue Hui Za Zhi 83: 419–429.6432941
Xi, Z; Fang, L; Xu, J; Li, B; Zuo, Z; Lv, L; Wang, C. (2019). Exposure to Aroclor 1254 persistently suppresses the functions of pancreatic β-cells and deteriorates glucose homeostasis in male mice. Environ Pollut 249: 822–830. 10.1016/j.envpol.2019.03.101.30953944
Xu, P; Lou, X; Ding, G; Shen, H; Wu, L; Chen, Z; Han, J; Han, G; Wang, X. (2014). Association of PCB, PBDE and PCDD/F body burdens with hormone levels for children in an e-waste dismantling area of Zhejiang Province, China. Sci Total Environ 499: 55–61. 10.1016/j.scitotenv.2014.08.057.25173862
Yakushiji, T; Watanabe, I; Kuwabara, K; Tanaka, R; Kashimoto, T; Kunita, N; Hara, I. (1984). Postnatal transfer of PCBs from exposed mothers to their babies: Influence of breast-feeding. Arch Environ Health 39: 368–375. 10.1080/00039896.1984.10545866.6439130
Yang, CY; Wang, YJ; Chen, PC; Tsai, SJ; Guo, YL. (2008). Exposure to a mixture of polychlorinated biphenyls and polychlorinated dibenzofurans resulted in a prolonged time to pregnancy in women. Environ Health Perspect 116: 599–604. 10.1289/ehp.10715.18470317
Yang, D; Kim, KH; Phimister, A; Bachstetter, AD; Ward, TR; Stackman, RW; Mervis, RF; Wisniewski, AB; Klein, SL; Kodavanti, PRS; Anderson, KA; Wayman, G; Pessah, IN; Lein, PJ. (2009). Developmental exposure to polychlorinated biphenyls interferes with experience-dependent dendritic plasticity and ryanodine receptor expression in weanling rats. Environ Health Perspect 117: 426–435. 10.1289/ehp.11771.19337518
Yang, M; Silverman, JL; Crawley, JN. (2011). Automated three-chambered social approach task for mice. Curr Protoc Neurosci 56: 8.26.21–28.26.16. 10.1002/0471142301.ns0826s56.
Yang, Q; Zhao, Y; Qiu, X; Zhang, C; Li, R; Qiao, J. (2015). Association of serum levels of typical organic pollutants with polycystic ovary syndrome (PCOS): A case-control study. Hum Reprod 30: 1964–1973. 10.1093/humrep/dev123.26040477
Yoshimura, T; Nakano, J; Okita, M; Kikuchi, Y; Kitamura, T; Ishikawa, T. (2005). Complete blood cell counts and blood chemistry in Yusho. J Dermatol Sci 1: S45–S55. 10.1016/j.descs.2005.03.008.
Younglai, E; Foster, W; Hughes, E; Trim, K; Jarrell, J. (2002). Levels of environmental contaminants in human follicular fluid, serum, and seminal plasma of couples undergoing in vitro fertilization. Arch Environ Contam Toxicol 43: 121–126. 10.1007/s00244-001-0048-8.12045882
Yu, ML; Hsin, JW; Hsu, CC; Chan, WC; Guo, YL. (1998). The immunologic evaluation of the Yucheng children. Chemosphere 37: 1855–1865. 10.1016/S0045-6535(98)00251-3.9828314
Yu, ML; Hsu, CC; Gladen, BC; Rogan, WJ. (1991). In utero PCB/PCDF exposure: Relation of developmental delay to dysmorphology and dose. Neurotoxicol Teratol 13: 195–202. 10.1016/0892–0362(91)90011-K.1710764
Zahalka, EA; Ellis, DH; Goldey, ES; Stanton, ME; Lau, C. (2001). Perinatal exposure to polychlorinated biphenyls Aroclor 1016 or 1254 did not alter brain catecholamines nor delayed alternation performance in Long-Evans rats. Brain Res Bull 55: 487–500. 10.1016/S0361-9230(01)00548–2.11543949
Zani, C; Magoni, M; Speziani, F; Leonardi, L; Orizio, G; Scarcella, C; Gaia, A; Donato, F. (2019). Polychlorinated biphenyl serum levels, thyroid hormones and endocrine and metabolic diseases in people living in a highly polluted area in North Italy: A population-based study. Heliyon 5: e01870. 10.1016/j.heliyon.2019.e01870.31194120
Zepp, RL, Jr.; Kirkpatrick, RL. (1976). Reproduction in cottontails fed diets containing a PCB. J Wildl Manag 40: 491–495. 10.2307/3799952.
Zhang, H; Yolton, K; Webster, GM; Sjödin, A; Calafat, AM; Dietrich, KN; Xu, Y; Xie, C; Braun, JM; Lanphear, BP; Chen, A. (2016). Prenatal PBDE and PCB Exposures and Reading, Cognition, and Externalizing Behavior in Children. Environ Health Perspect 125: 746–752. 10.1289/EHP478.27385187
Zhang, L; Liu, X; Meng, G; Chi, M; Li, J; Yin, S; Zhao, Y; Wu, Y. (2018). Non-dioxin-like polychlorinated biphenyls in early pregnancy and risk of gestational diabetes mellitus. Environ Int 115: 127–132. 10.1016/j.envint.2018.03.012.29558635
Zhang, W; Chen, Z; Liu, A; Buck Louis, GM. (2019). A weighted kernel machine regression approach to environmental pollutants and infertility. Stat Med 38: 809–827. 10.1002/sim.8003.30328128
Zhang, X; Kramer, MS. (2009). Variations in mortality and morbidity by gestational age among infants born at term. J Pediatr 154: 358–362.e351. 10.1016/j.jpeds.2008.09.013.18950794
Zhao, S; Jones, KC; Li, J; Sweetman, AJ; Liu, X; Xu, Y; Wang, Y; Lin, T; Mao, S; Li, K; Tang, J; Zhang, G. (2020a). Evidence for major contributions of unintentionally produced PCBs in the air of China: Implications for the national source inventory. Environ Sci Technol 54: 2163–2171. 10.1021/acs.est.9b06051.31851493
Zhao, YH; Qu, H; Wang, YH; Xiao, WL; Zhang, Y; Shi, DZ. (2020b). Small rodent models of atherosclerosis [Review]. Biomed Pharmacother 129: 110426. 10.1016/j.biopha.2020.110426.32574973
Zhou, H; Qin, G; Longnecker, MP. (2011a). A Partial Linear Model in the Outcome-Dependent Sampling Setting to Evaluate the Effect of Prenatal PCB Exposure on Cognitive Function in Children. Biometrics 67: 876–885. DOI: 10.1111/j.15410420.2010.01500.x.21039397
Zhou, H; You, J; Qin, G; Longnecker, MP. (2011b). A partially linear regression model for data from an outcome-dependent sampling design. J R Stat Soc Ser C Appl Stat 60: 559–574. 10.1111/j.1467-9876.2010.00756.x.
Zinkl, JG. (1977). Skin and liver lesions in rats fed a polychlorinated biphenyl mixture. Arch Environ Contam Toxicol 5: 217–228. 10.1007/BF02220905.74241
Zipse, LR; Brandling-Bennett, EM; Clark, AS. (2000). Paced mating behavior in the naturally cycling and the hormone-treated female rat. Physiol Behav 70: 205–209. 10.1016/s0031-9384(00)00242–0.10978497