# EXECUTIVE SUMMARY

Assessing health outcomes associated with exposure to polychlorinated biphenyls (PCBs) is important given their persistent and ubiquitous nature. PCBs are classified as a Group 1 carcinogen, but the full range of noncancer health effects that could result from exposure to PCBs has not been systematically summarized and evaluated. This review compiles and organizes human and other mammalian studies of noncancer health endpoints measured with exposure to PCB mixtures to identify areas of robust research, as well as areas of uncertainty and research needs.

A protocol was developed that describes the systematic review methods, including the literature search strategy and the Populations, Exposures, Comparators, and Outcomes (PECO) criteria used to facilitate subsequent screening and categorization of literature into a systematic evidence map of PCB exposure and noncancer health endpoints across 15 organs/systems. A comprehensive literature search yielded 62,599 records. After a prioritization step that included machine learning and natural language processing, 17,037 studies were manually screened at the title and abstract level. An additional 900 studies identified by experts or supplemental searches were also included, for a total of 17,937 studies reviewed. After full-text screening of 3,889 references, 1,586 studies met PECO and were included in the database. Relevant study details such as the PCB congeners measured or administered, organs/systems and endpoints assessed, exposure duration, and species were extracted into literature summary tables. Summary data are available online as interactive visuals with downloadable metadata.

We identified 637 mammalian toxicological studies evaluating endpoints in a variety of species exposed for different durations and at different life stages and 953 epidemiological studies conducted among diverse populations. Although human and other mammalian data are abundant for some organs/systems (e.g., hepatobiliary, nervous system, and reproductive), other endpoints of great public interest (e.g., cardiovascular disease, autism) have not been extensively studied in the context of exposure to PCB mixtures. Furthermore, despite many years of research, sparse data exist for inhalation and dermal exposures, which are highly relevant human exposure routes. Robust research is available to inform PCB hazard assessments for most organs/systems, but the amount of data to inform associations with specific endpoints differs. This evidence map provides a foundation for future systematic reviews and noncancer hazard assessments of PCB mixtures and for strategic planning of research to address areas of greater uncertainty.