# AUTHOR | CONTRIBUTORS | REVIEWERS

## Authors

Laura M. Carlson, PhD. (Lead Author) | Office of Research and Development, Center for Public Health and Environmental Assessment (CPHEA)
Krista Christensen, Ph.D. (Lead Author) | Office of Research and Development, Center for Public Health and Environmental Assessment (CPHEA)
Geniece M. Lehmann, Ph.D. (Lead Author) | Office of Research and Development, Center for Public Health and Environmental Assessment (CPHEA)
Xabier Arzuaga, Ph.D.
Evan Coffman, Ph.D.
Rachel M. Shaffer, Ph.D.
Erin E. Yost, Ph.D.

## Contributors

Robyn Blain | ICF, Reston, VA
Michael S. Bloom | George Mason University, Fairfax, VA
Pam Factor-Litvak | Mailman School of Public Health, Columbia University, New York, NY
Brandall Ingle | ICF, Reston, VA
Todd A. Jusko | University of Rochester School of Medicine and Dentistry, Rochester, NY
Aileen F. Keating | Department of Animal Science, Iowa State University, Ames, IA
Carolyn R. Klocke | Department of Molecular Biosciences, University of California, Davis School of Veterinary Medicine, Davis, CA
Pamela J. Lein | Department of Molecular Biosciences, University of California, Davis School of Veterinary Medicine, Davis, CA
Cynthia Lin | ICF, Reston, VA
John D. Meeker | University of Michigan, Ann Arbor, MI
Pradeep Rajan | Pradeep Rajan LLC, Chapel Hill, NC
Larry Robertson | University of Iowa, Iowa City, IA
Sharon K. Sagiv | Center for Environmental Research and Children’s Health (CERCH), School of Public Health, University of California, Berkeley, CA
Alexander Sergeev | Ohio Universitv, Athens, OH
Kelly Shipkowski | ICF, Reston, VA
Raquel A. Silva | ICF, Reston, VA
Samantha Snow | ICF, Reston, VA
Michal Toborek | University of Miami, Miami, FL
Joanne Trgovcich | ICF, Reston, VA

## Executive Direction

Wayne Cascio, M.D (CPHEA Director) | Office of Research and Development, Center for Public Health and Environmental Assessment (CPHEA)
V. Kay Holt, M.S. (CPHEA Deputy Director) | Office of Research and Development, Center for Public Health and Environmental Assessment (CPHEA)
Samantha Jones, Ph.D. (CPHEA Associate Director) | Office of Research and Development, Center for Public Health and Environmental Assessment (CPHEA)
Kristina Thayer, Ph.D. (CPAD Director)
Steve Dutton, Ph.D. (HEEAD Director)
Andrew Kraft, Ph.D. (CPAD Associate Director)
Ravi Subramaniam, Ph.D. (Acting CPAD Senior Advisor)
Paul White, Ph.D. (CPAD Senior Science Advisor)
Andrew Hotchkiss, Ph.D. (Branch Chief)
Janice Lee, Ph.D. (Branch Chief)
Elizabeth Radke-Farabaugh, Ph.D. (Branch Chief)
Viktor Morozov, Ph.D. (Branch Chief)
Garland Waleko, M.S. (Acting Branch Chief)

## Production Team

Ryan Jones (HERO Technical Lead) | Office of Research and Development, Center for Public Health and Environmental Assessment (CPHEA)
Andrew Shapiro (HAWC Technical Lead) | Office of Research and Development, Center for Public Health and Environmental Assessment (CPHEA)
Dahnish Shams (Project Management Team) | Office of Research and Development, Center for Public Health and Environmental Assessment (CPHEA)
Avanti Shirke (Project Management Team)
Jessica Soto-Hernandez (Project Management Team)
Vicki Soto (Project Management Team)
Shane Thacker (HERO Lead Developer)
Sean Watford (HERO/HAWC Team)

## Reviewers

This report was peer reviewed by independent, expert scientists external to EPA convened by Versar under contract EP-C-17-023 (Order No. 68HERH21F0354).
Andreas Kortenkamp, Ph.D. | Brunel University, London United Kingdom
John C. Lipscomb, Ph.D. DABT, FATS | CTEH, LLC, North Little Rock, AR
Cynthia V. Rider, Ph.D. | Division of National Toxicology Program, National Institute of Environmental Health Sciences, Durham, NC, USA
Questions regarding the content of this report should be directed to the EPA Office of Research and Development (ORD) Center for Public Health and Environmental Assessment (CPHEA) website at https://ecomments.epa.gov/