# 4 CONCLUSIONS

In this review, over 1,500 studies of humans and other mammals exposed to PCB mixtures were mapped to 15 organs/systems. We identified 637 mammalian toxicological studies evaluating endpoints in a variety of species exposed for different durations and at different life stages and 953 epidemiological studies conducted using diverse populations and methods. Although human and other mammalian data are abundant for some organs/systems (e.g., hepatobiliary, nervous system, and reproductive), some endpoints of great public interest (e.g., cardiovascular disease, autism) have not been extensively studied in the context of PCB mixture exposure (see Table 3^1^).

Table 3 provides a high-level summary of the endpoints in each organ/system that were evaluated in human studies, along with preliminary assessments of the informativeness of each database that consider the availability of both human and other mammalian studies. More informative databases are more likely to support conclusive systematic reviews, while less informative databases could be used to identify important topics for future research. Endpoints identified as having low specificity might be most useful when evaluated in combination with other, more informative measures. The anthropocentric focus of Table 3 was chosen for simplicity and because endpoints grounded in strong human and other mammalian data provide the most informative basis for hazard identification. However, endpoints evaluated only in animals can and often do provide sufficient evidence to support the identification of hazards and analysis of dose-response relationships critical for risk assessment (U.S. EPA, 2022). Notably, sparse data exist for inhalation and dermal exposures in both humans and other mammals, representing important areas of uncertainty that would benefit from further research, especially because these are highly relevant human exposure routes.

There are several considerations that are important for interpreting this work. First, it relies on publicly accessible published data. Supplemental search strategies (e.g., searching reference lists of reviews, citation mapping, gray literature searches) were not extensively applied, but technical experts did identify a few additional references for screening (n = 25). Historically, scientific journals have often enforced publication length restrictions, sometimes leading to incomplete reporting of study results. Potential selective reporting, where authors fail to mention they conducted an evaluation or fail to report the results of an evaluation, is a factor to consider at the study evaluation step of a full systematic review. Furthermore, journals have been somewhat reluctant to publish reports with primarily null results (Mlinarić et al., 2017), and some work might not have been published on the basis of decisions made by study sponsors or other factors (Bero et al., 2016). Publication bias exists when the reasons behind a failure to publish are associated with the direction or magnitude of the effects observed (Dwan et al., 2013; Dwan et al., 2008). Our analysis of the PCB database included only published reports and did not address the potential for publication bias. Future systematic reviews stemming from this work could consider using statistical approaches to assess publication bias for studies of health endpoints and exposure to PCB mixtures (Dalton et al., 2016). Another caveat is that this evidence map is based only on full-text screening and preliminary data extraction. Future analyses could include study evaluation and full extraction of the data from subsets of studies relevant for specific research questions. These additional review steps are needed to develop strong conclusions linking PCB exposure with potential health effects. For example, full data extraction would be required to examine the magnitude of exposure in animal studies relative to anticipated human exposures, which is an important consideration for both hazard identification and dose-response assessment. Of note, another challenge in conducting systematic reviews of large complex databases involves the use of multiple systematic review tools, continual duplicate removal, and an ever-increasing literature base as new studies are published each year.

The primary goal of this evidence map was to use systematic review methods to identify, summarize, organize, and disseminate data relevant for characterizing potential human health concerns from exposure to PCB mixtures. As an important part of this effort, we developed interactive figures to help readers explore the available literature, including the ability to create lists of references with customized combinations of study design features based on the specific interests of the individual user. By sharing information from this SEM in this way, we hope to provide a valuable tool that will both support future risk assessment work and highlight areas of uncertainty that can be prioritized in future research to advance our understanding of PCB mixtures and their potential effects on health.

Table 3 Overview of the databases available for selected endpoint categories by organ/system

Organ/system | More informative endpoint categories | Less informative endpoint categories | Notes
Cardiovascular | Blood pressure/Hypertension; IHD (including myocardial infarction); Cerebrovascular disease (including stroke) | More data needed:; Atherosclerosis and other vascular diseases; Heart failure; Fetal heart rate; Low specificity or sensitivity:; Cardiovascular disease (NOS); Subjective complaints | Cholesterol/triglyceride levels were classified as hepatobiliary endpoints (Section 3.3.7)
Dermal | Acne/Chloracne; Abnormal pigmentation; Dermal irritation (including eczema); Hyperkeratosis; Nail deformities | More data needed:; Periodontal disease (including gingival swelling/recession); Scar formation; Low specificity or sensitivity:; “Skin problems” | Most human studies evaluated endpoints at high PCB exposure levels; Atopic eczema was classified as an immune endpoint (Section 3.3.8); dental abnormalities were classified as musculoskeletal endpoints (Section 3.3.10)
Developmental | Weight and size (early life) | More data needed:; Miscarriage/stillbirth; Birth defects; Low specificity or sensitivity:; Placental weight/histology | Measures of gestation length, pubertal development, and endpoints associated with testicular dysgenesis syndrome were classified as reproductive endpoints (Section 3.3.10)
Endocrine | Thyroid function | More data needed:; Thyroid disease; Adrenal gland function; Other endocrine organs and hormones (including parathyroid endpoints) | Sex hormone levels were classified as reproductive endpoints (Section 3.3.13); insulin levels were classified as metabolic endpoints (Section 3.3.9
Gastrointestinal | (none) | More data needed:; Gastric ulcer; Colorectal polyps; Abdominal ultrasonography; Low specificity or sensitivity:; Abdominal pain; Nausea/vomiting; Changes in bowel habits; Bloating; Indigestion; Loss of appetite | Database limited for hazard assessment
Hematopoietic | WBC counts; Red blood cell counts/Hemoglobin | More data needed:; Anemia; Clotting function; Platelet counts; Low specificity or sensitivity:; Blood disease mortality | Measures of WBC function were classified as immune endpoints (Section 3.3.8)
Hepatobiliary | Liver disease (including cirrhosis and steatosis); Serum biomarkers of liver function; Cholesterol/Triglyceride levels; Liver enzyme induction | More data needed:; Porphyria; Gallbladder and biliary endpoints; Low specificity or sensitivity:; Hepatomegaly
Immune | Immune suppression (including susceptibility to infection, antigen-specific antibody responses, WBC function, DTH); Atopy (including allergies/asthma) | More data needed:; Autoimmunity (especially autoimmune disease incidence); Low specificity or sensitivity:; Nonspecific immunoglobulin levels; WBC counts; Immune organ size/weight | WBC counts were classified primarily as hematopoietic endpoints (Section 3.3.6)
Metabolic | Glucose homeostasis (including IR, IGT/prediabetes, Type 2 diabetes mellitus, gestational diabetes) | More data needed:; Metabolic rate; Low specificity or sensitivity:; Metabolic syndrome; Diabetes mellitus (NOS); Overweight/obesity | Cholesterol/triglyceride levels were classified as hepatobiliary endpoints (Section 3.3.7); Type 1 Diabetes was classified as an immune endpoint (Section 3.3.8); diabetic nephropathy was classified as a urinary system endpoint (Section 3.3.15)
Musculoskeletal | Bone density/strength; Dental abnormalities (including enamel defects and dental caries) | More data needed:; Arthritis; Low specificity or sensitivity:; Musculoskeletal complaints (including muscle/joint pain, muscle weakness) | Most human studies evaluated endpoints at high PCB exposure levels, especially in fish-consuming populations; Rheumatoid arthritis was also classified as an immune endpoint (Section 3.3.8)
Nervous System | Cognitive function; Attention, impulse control, externalizing and internalizing behaviors; Executive function; Motor function/development; Following developmental exposures:; Social cognition and behavior; Auditory function | More data needed:; Brain aging disorders; Visual function; Olfactory function; Neurophysiology/neuroimaging; Following exposures during adulthood:; Social cognition and behavior; Auditory function; Low specificity or sensitivity:; Dizziness; Headache; Fatigue/level of consciousness; Neurological condition; Neurological disease mortality; Peripheral sensation or pain; Play behavior; Sleep problems
Ocular | Ocular swelling and irritation (including periorbital edema, ocular discharge, Meibomian gland enlargement, conjunctivitis) | | Most human studies evaluated endpoints at high PCB exposure levels; Infectious forms of conjunctivitis were classified as immune endpoints (Section 3.3.8)
Reproductive | Sex hormone levels; Fertility; Sperm/semen parameters; Gestation length (including preterm birth); Endometriosis; Pubertal development; Endpoints associated with testicular dysgenesis syndrome (including anogenital distance, hypospadias, cryptorchidism, sex ratio) | More data needed:; Gynecological disorders other than endometriosis; Pregnancy-related disorders (including preeclampsia); Menstrual cycle characteristics; Ovulation; Reproductive aging; Low specificity or sensitivity:; Erectile dysfunction | Measures of birth defects, miscarriage/stillbirth, and placental health were classified as developmental endpoints (Section 3.3.3)
Respiratory | Pulmonary health and function (including chest radiography, spirometry, respiratory sounds, sputum analysis) | Low specificity or sensitivity:; Respiratory disease mortality; Respiratory illness history; Respiratory symptoms (e.g., shortness of breath, cough/sputum, chest tightness) | Most human studies evaluated endpoints at high PCB exposure levels; Asthma and infectious respiratory diseases were classified as immune endpoints (Section 3.3.8)
Urinary System | Biomarkers of renal function (including markers measured in serum or urine) | More data needed:; Kidney disease/renal failure (including diabetic nephropathy); Urinary system components other than the kidneys; Low specificity or sensitivity:; Urinary system mortality (NOS)

DTH = delayed type hypersensitivity; IGT = impaired glucose tolerance; IR = insulin resistance; IHD = ischemic heart disease; NOS = not otherwise specified; PCB = polychlorinated biphenyl; WBC = white blood cell.

1 This table provides an overview of the available data relevant for evaluating select endpoints within each organ/system, with a focus on endpoints evaluated in human studies. Preliminary assessments of the potential informativeness of each database are included, with availability of evidence from nonhuman mammalian studies contributing to those assessments. Endpoints measured only in nonhuman mammalian models are not included in this table to reduce the complexity of the analysis and to focus on the endpoints with the most direct human relevance.