# 2 METHODS

## 2.1 LITERATURE SEARCH

A protocol was developed that describes the literature search strategy and PECO criteria used to facilitate subsequent screening and categorization of literature into a SEM of PCB exposure and noncancer health endpoints (U.S. EPA, 2019). The protocol was registered in 2019 via Zenodo (https://doi.org/10.5281/zenodo.3585771). Peer-reviewed literature was identified by searching PubMed (National Library of Medicine), Web of Science (Clarivate Analytics), and, prior to 2019, Toxline (National Library of Medicine). The literature search strategy relied on terms describing PCB mixtures and individual congeners (e.g., "polychlorinated biphenyls," "Aroclor," "PCB," "tetrachlorobiphenyl") to gather information on exposure to the chemicals of interest. Additional exposure terms were used to identify studies not indexed by the chemical name (e.g., "capacitor manufacturing workers," "Yu-Cheng," "New York State Angler Cohort"). These search terms were intentionally broad and did not prioritize studies in which exposure was quantified for individual participants; this was considered during screening of the literature. The detailed search strategies are presented in Table S1A, and a summary of search results is provided in Table S1B in Supplementary File 1. A list of all references retrieved through the literature searches is provided in Supplementary File 2, and search results by year are provided in Supplementary Files 3–9. The original search, conducted in 2015, was not restricted by publication date or language (Supplementary File 3). Literature search updates were conducted yearly through September 1, 2021 and were restricted to the 12-month period since the original search or the most recent update (Supplementary Files 4–9). Each annual search update utilized the same search terms. Records identified through the original literature search were prioritized electronically as described below. Reference lists of health assessments published by federal, state, and international health agencies were searched to identify seed references (described below), but additional supplemental search strategies (e.g., citation mapping) were not applied. Twenty-five references were identified through recommendation by technical experts (see Table S1C).

## 2.2 ELECTRONIC APPROACHES USED TO REFINE A LARGE DATABASE

Screening a large number of candidate studies for inclusion is time-consuming when conducted manually by human reviewers. Automation tools are available to reduce the human effort needed for screening. For this review, natural language processing (NLP) and machine learning (ML) techniques were employed to identify the most relevant literature for manual screening. Studies were prioritized using DoCTER, a Document Classification and Topic Extraction Resource (Varghese et al., 2018). Details of the NLP and ML methods are described elsewhere (Varghese et al., 2019; Varghese et al., 2018). Briefly, 483 studies selected as having met the PECO criteria for inclusion in this review (see Table 1) were designated as seed references (provided in Table S1D). Seed references are a set of relevant documents that are labeled and included in the larger collection of unclassified documents. Seed references function as tracers in the document prioritization process, helping identify documents with similar content. For this review, seed references were identified during problem formulation (U.S. EPA, 2015), which was largely on the basis of a survey of references cited in health assessments published by federal, state, and international health agencies, most notably ATSDR (2000). Seed studies were included in the corpus of references identified by keyword searches and used to prioritize studies using an ML method called supervised clustering. In Phase 1 of a two-phased prioritization approach, titles and abstracts of all references identified by keyword searches, along with the seed references, were represented as a mathematical matrix using an NLP transformation and then organized into groups of references with semantic similarity (i.e., "clusters") using algorithms as depicted in Figure 1A. Two clustering algorithms (k-means, nonnegative matrix factorization) were applied using cluster sizes of 10, 20, or 30 references for a total of 6 different clustering approaches. Reference clusters that included seed references were identified as illustrated in Figure 1B.

Figure 1 Illustration of electronic prioritization approaches

1A. Schematic illustration of electronic prioritization of literature depicting references clustered by similarity using natural language processing. 1B. Illustration depicting clusters containing relevant seed references (circled blue clusters). Clusters were ranked by the number of seed studies included. 1C. Visualization of identified clusters. Clusters were organized into groups (A–F) on the basis of the number of approaches that identified the cluster such that Group A contains clusters that include seed references identified by six approaches and Group F contains clusters that include seed references identified by a single approach. All references in the top four groups (A–D) were manually screened for inclusion based on PECO criteria. Low scoring groups (E, F) were subjected to additional machine learning approaches to capture relevant references for manual screening.

Figure 1. Illustration of electronic prioritization approaches.

In each of these six approaches, clusters were ranked in decreasing order of the number of seed studies included in the cluster, and clusters were accepted in order until 90% of the total set of seed studies was captured. A 90% threshold was selected because it provided an optimal balance between the statistical measures of recall (fraction of relevant studies retrieved) and precision (fraction of relevant studies among the retrieved studies) (Varghese et al., 2018). Higher thresholds would have resulted in diminished precision and a considerably higher manual screening burden given the size of the original literature database. This method was repeated for all six clustering approaches; thus, a given study could have appeared in one of the accepted clusters (and thus appear with the greatest fraction of the seed studies) in anywhere from zero to six of the approaches. Clusters containing seed references were grouped by the number of approaches in which they were identified (Groups A–F, Figure 1C). Studies that appeared in groups A–D (representing 6, 5, 4, or 3 approaches, Figure 1C) were subjected to manual title and abstract-level screening, as described in Section 2.3.1. Screened studies from Phase 1 were used to train the ML model in Phase 2.

In Phase 2, a supervised ML algorithm (support vector machines; (Varghese et al., 2018)) was used to predict relevance for those studies in the remaining groups of clusters that appeared in one or two approaches (groups E and F, Figure 1C). Also included in this approach was one group of studies excluded from initial clustering until abstracts were recovered and a second group of studies with titles only. The training data set for this secondary analysis is distinct from the seed references mentioned above and included all studies manually screened in Phase 1; the training data set for supervised ML thus included examples of studies that met PECO and those that did not. Studies predicted to be relevant in Phase 2 by the supervised ML algorithm were subjected to manual title and abstract-level screening. Details of the DoCTER prioritization strategy are presented in Table S1E, and a list of studies prioritized using DoCTER supervised clustering and ML approaches is provided in Table S1F.

Because fewer references were identified in yearly search updates, alternative approaches were used to prioritize the literature for screening (summarized in Figure 2). References identified in 2016 were directly subjected to manual screening without electronic prioritization. References identified after August 2016 were prioritized using SWIFT-Active Screener (Sciome, 2023), a web-based software application integrated with electronic prioritization using ML and statistical approaches. For each literature update, manually reviewed studies were used to train the model, which is updated iteratively, thus reducing manual screening efforts (Howard et al., 2020).

Figure 2 Chronology of prioritization approaches applied to PCB literature search results

The initial 2015 literature search used DoCTER, an electronic prioritization approach described in Section 2.2 and in ICF (2021). The literature updates from 2017–2021 utilized SWIFT-Active Screener, another electronic prioritization program fully described in Sciome (2023).

Figure 2, showing initial literature search and updates (results of).

## 2.3 LITERATURE SCREENING

### 2.3.1 Title and Abstract Screening of the Literature

Prioritized records were combined with smaller groups of records, including seed references, records identified through literature search updates, and references suggested by technical experts, into a single database. The literature was then manually screened in two steps to determine whether individual studies should be included or excluded as a primary source of health endpoint data based on PECO criteria shown in Table 1. Step 1 consisted of title and abstract screening, while Step 2 involved full-text screening (Section 2.3.2).

In Step 1, two trained screeners independently conducted a manual title and abstract review using structured forms developed in DRAGON (a modular database with integrated screening and literature evaluation tools developed for systematic review) (ICF, 2018) to identify records that appeared to meet the PECO criteria. For citations with no abstract, articles were screened based on title relevance. Screening conflicts were resolved by a third reviewer. Each study was categorized to one of the following bins: "Relevant to Hazard Identification in Humans”, "Relevant to Hazard Identification in Animals" (nonhuman mammals only), "Potentially Relevant Supplemental Material", or "Not Relevant". Identification of studies "Relevant to Hazard Identification in Humans" or "Relevant to Hazard Identification in Animals" was based on the species of the population(s) exposed to PCBs. Studies identified as "Not Relevant" did not meet PECO. "Potentially Relevant Supplemental Material" included toxicokinetic studies, studies describing pharmacokinetic models for PCB congeners and mixtures, and mechanistic studies. Additional records tracked as "Potentially Relevant Supplemental Material" included conference abstracts, secondary data sources (e.g., reviews, agency assessments), non-English-language studies, exposure studies unrelated to health endpoints, and human case reports or case series. The tags used for study categorization are summarized in Tables S1G, S1H, and S1I. Categories of "Potentially Relevant Supplemental Material" are shown in Table S1I.

References retrieved through August 2016 were screened and tagged using DRAGON. Screening decisions and study metadata recorded in DRAGON (v. 03-25-2016) were recently moved to a second generation, web-based systematic review platform rebranded as litstream™ (ICF, 2021). References identified in search updates after August 2016 were screened in SWIFT-Active Screener until the software indicated a likelihood of 95% that all relevant studies had been captured. This threshold is comparable to human error rates (Bannach-Brown et al., 2018; Howard et al., 2016; Cohen et al., 2006) and is used as a metric to evaluate ML performance. A summary of literature prioritized using SWIFT-Active Screener is provided in Table S1J.

To validate the application of clustering and ML algorithms, a subset of nonprioritized studies was also randomly selected for manual title and abstract-level review.

### 2.3.2 Full-Text Screening of the Literature

Records not excluded or considered "Potentially Relevant Supplemental Material" based on the title and abstract advanced to full-text manual review using litstream. Full-text copies of these potentially relevant records were retrieved and independently assessed by two screeners to confirm eligibility according to the PECO criteria. Screening conflicts were resolved by a third reviewer. Seed references, which had been identified as meeting PECO during problem formulation (U.S. EPA, 2015) were also included in the full-text screen to categorize these records.

In addition to confirming that studies met PECO criteria, the health endpoints investigated in each study were identified using structured forms in litstream. Health endpoints were organized into the following categories based on Thayer et al. (2022): Cardiovascular, Dermal, Developmental, Endocrine, Gastrointestinal, Hematopoietic, Hepatobiliary, Immune System, Metabolic, Musculoskeletal, Nervous System, Ocular, Reproductive, Respiratory, and Urinary System. These organ/system categories were chosen because of their potential to include specific noncancer health endpoints that could be affected by PCB exposure at levels relevant to those experienced in the general population. Assignment of specific endpoints into each of the organs/systems was made by one or more coauthors based on their primary areas of expertise. Some studies evaluated multiple endpoints and so were assigned to multiple organs/systems. We recognize that there is crosstalk among many physiological systems, which can complicate the categorization of endpoints; specific information on which endpoints are included in each organ/system is provided in Section 3.3. Studies focused entirely on cancer or frank toxicity, including mortality of unknown cause, and wasting, although not the focus of this review, were considered "Potentially Relevant Supplemental Material". Humans tend to be exposed to complex PCB mixtures that contain many congeners of varied toxic potency and potential modes of action (U.S. EPA, 2015). Since the focus of this review is on studies of mixtures that better reflect a typical human exposure scenario, toxicological studies in which mammals were exposed only to individual PCB congeners or to mixtures comprising fewer than four congeners were considered "Potentially Relevant Supplemental Material".

Based on the results for the full-text review, summary-level, sortable lists of relevant literature were created for human and animal (nonhuman mammalian) studies for each organ/system. Fundamental study design information (e.g., study population, exposure assessment/design, PCB mixtures administered in nonhuman mammalian studies, health endpoints evaluated) was extracted for each study in Microsoft Excel by one individual and independently reviewed by at least one additional individual.