# 1 INTRODUCTION

Polychlorinated biphenyls (PCBs) are halogenated organic pollutants consisting of 209 congeners varying in the number and position of chlorine atoms substituted on biphenyl rings. PCBs were produced as technical mixtures (e.g., Aroclors) containing numerous individual congeners. Mixtures of these congeners were used as dielectric fluids in capacitors and transformers, as lubricants, and as additives in a variety of other products, including paints and caulk. PCB production was banned in the United States in 1979 (U.S. EPA, 1979) and in most of the world by the time the Stockholm Convention was adopted in 2001 (SCPOP, 2008). Even so, because of their widespread use, disposal, and resistance to degradation, these chemicals are pervasive in the environment and biota.

Humans are exposed to PCBs throughout their lifetimes, including prenatally and during the early postnatal period through breastfeeding (van den Berg et al., 2017), with continuing exposure through multiple routes including diet and inhalation (Weitekamp et al., 2021). Occupational exposure historically occurred during production or use of PCBs and PCB containing products (Wolff, 1985), and may still occur, for example through maintenance, repair, or recycling of old PCB containing products or disturbance of construction materials containing PCBs (Okeme and Arrandale, 2019; Herrick et al., 2007). The general population can be exposed to PCBs by ingesting contaminated food (especially fish from contaminated waters), and by inhaling contaminated air, in both indoor and outdoor settings, especially at locations which still use electrical equipment and/or building and construction products containing PCBs. The issue of potential inhalation exposure to PCBs in contaminated buildings, including some schools, is an environmental health topic that has received much attention from the US Environmental Protection Agency (U.S. EPA, 2019, 2015, 2012).

The PCB mixtures associated with each exposure pathway differ from each other and from the original technical mixtures due to differential degradation of the individual congeners in the environment over time, variable partitioning of PCB congeners in environmental compartments, and differences in toxicokinetics. Another factor contributing to differences between modern environmental PCB mixtures and technical mixtures is the ongoing, inadvertent PCB production that occurs during certain manufacturing processes, such as pigment production (Zhao et al., 2020a; Vorkamp, 2015; Hu and Hornbuckle, 2010). Therefore, humans are exposed to different environmental mixtures of PCBs from different sources (Ampleman et al., 2015; Hornbuckle and Robertson, 2010) that have distinct congener compositions from the original produced mixtures. Furthermore, the composition of an exogenous environmental PCB mixture is subject to change after uptake into the human body as different congeners are metabolized and eliminated at different rates. Consequently, relating measures of PCB congeners in biological matrices to their corresponding environmental source mixtures can be challenging, which complicates traditional risk assessment (Christensen et al., 2021).

Associations between PCB exposure and cancer and noncancer health endpoints have been reported in both human epidemiological and experimental animal studies (IARC, 2015; ATSDR, 2000). Of the 209 congeners, approximately 12 are considered “dioxin like,” meaning that they bind to the aryl hydrocarbon receptor (AhR) and can interact with biological systems through the same mode of action as 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) (van den Berg et al., 2006; Poland et al., 1976). The remaining "nondioxin-like" congeners have also been reported to be associated with health endpoints; however, the specific hazards, dose-response relationships, and modes of action are variable and not as clearly understood for these PCBs. National and international health agencies have assessed PCB toxicity, including cancer (IARC, 2015; U.S. EPA, 1996) and noncancer endpoints (ATSDR, 2000; U.S. EPA, 1994, 1993). The International Agency for Research on Cancer (IARC) has classified PCBs as Group 1 carcinogens (IARC, 2015). However, the most comprehensive review of the potential effects of PCB exposure to date was conducted by the Agency for Toxic Substances and Disease Registry (ATSDR) (ATSDR, 2011, 2000). These reviews identified several noncancer outcomes sensitive to PCB exposure, including dermal, ocular, immune, thyroid, liver, reproductive, developmental, and neurodevelopmental effects (ATSDR, 2000). New research since ATSDR’s assessments suggests the potential for additional health hazards, notably metabolic and cardiovascular effects. Furthermore, the full database of PCB literature has not previously been reviewed using systematic methods with the intent to identify most of the available data informing potential noncancer health hazards of exposure to PCB mixtures.

Systematic evidence maps (SEMs) are a useful tool to gain appreciation for the size and content of a literature database (Thayer et al., 2022). SEMs are used as analysis tools, which "do not seek to synthesize evidence but instead to catalog it, utilizing systematic search and selection strategies to produce searchable databases of studies along with detailed descriptive information" (Elsevier, 2017). In this approach, systematic review methods are used, including a targeted search of the literature guided by Populations, Exposures, Comparators, and Outcomes (PECO) criteria (see Table 1) and subsequent study categorization and development of visualizations to "map" the contents of the database. The resulting map can be used to evaluate the data available to inform specific questions that could be of interest for future systematic reviews.

Table 1 Populations, exposures, comparators, outcomes (PECO) criteria^a^

PECO element | Description of Studies Included
[underlined: P]opulations | [underlined: Human]: Adults and/or children with exposure to PCBs at any life stage.; [underlined: Animal]: Nonhuman mammalian animal species (whole organism) exposed during any life stage (during any period from in utero through adulthood). Studies including evaluations of transgenic animals only (i.e., with no evaluations of exposure-response relationships in wild-type animals) were considered “Potentially Relevant Supplemental Material.”
[underlined: E]xposures | [underlined: Human]: Any exposure to PCBs (in vivo) as determined by controlled exposure, measured PCB concentration in contact medium (e.g., food, air, dust), biomarkers of exposure (e.g., serum PCB levels), or occupation in a job involving exposure to PCBs (e.g., electric capacitor manufacturing). The following exposure assessment methods/exposure contexts were considered “Potentially Relevant Supplemental Material” in the absence of biomarker measurements or estimates derived using scientifically sound methods: Yusho/Yu-Cheng patient status; consumption of fish (or marine mammals or other wildlife); and residential proximity to a PCB-contaminated site.; [underlined: Animal:] One or more oral (gavage, diet, drinking water, intragastric), inhalation (aerosol, vapor, or particle; whole-body or nose-only), dermal (occlusive, semiocclusive, nonocclusive), or injected (intravenous, subcutaneous, intraperitoneal) treatment(s) with any clearly quantified dosage of PCB congeners or PCB mixtures administered to a whole animal (in vivo).; Studies were considered “Potentially Relevant Supplemental Material” if they used only routes of administration not listed above (e.g., intratracheal instillation, intracisternal injection) or evaluated only combinations of PCBs with other exposures (e.g., metals).
[underlined: C]omparators | [underlined: Human]: A referent or comparison population that is unexposed or exposed at lower levels of PCBs, or exposed to PCBs for shorter periods of time, or cases versus controls, or a repeated measures design. However, worker surveillance studies are considered to meet PECO criteria even if no statistical analysis using a referent group is presented. Case reports and case series were considered “Potentially Relevant Supplemental Material.”; [underlined: Animal]: A concurrent control group exposed to vehicle-only treatment or untreated control.
[underlined: O]utcomes | [underlined: Human]: Any examination of survival, body weight, or development, or of the structure or function of dermatological, cardiovascular, endocrine, gastrointestinal, hematological, hepatobiliary, immune, nervous, ocular, musculoskeletal, urinary, respiratory, or reproductive cells, tissues, or systems.; [underlined: Animal]: Any examination of survival, body weight, or development, or of the structure or function of dermatological, cardiovascular, endocrine, gastrointestinal, hematological, hepatobiliary, immune, nervous, ocular, musculoskeletal, urinary, respiratory, or reproductive cells, tissues, or systems.; In general, endpoints related to clinical diagnostic criteria, disease outcomes, histopathological examination, or other apical/phenotypic outcomes are considered to meet PECO criteria and are prioritized for evidence synthesis while endpoints such as observations of cellular structure, gene expression, cell signaling, or other similar biochemical measures are considered “Potentially Relevant Supplemental Material.”

a PECO criteria are based on those presented in U.S. EPA (2019).

This evidence map’s main objective is to summarize available noncancer health endpoint data for mammalian toxicological and human epidemiological studies of exposures to PCB mixtures. By identifying health endpoints with databases sufficient to support evaluations of coherence across evidence streams (i.e., from studies in humans and nonhuman mammals) and across biologically related endpoints (e.g., endpoints linked through a common adverse outcome pathway), we can highlight the databases with the highest likelihood of supporting an analysis of causal relationships with exposure to PCB mixtures for future systematic reviews. Conversely, by identifying areas with poorer databases, this evidence map can also be used to inform future research efforts on topics that have been insufficiently studied.