# APPENDIX A QUALITY ASSURANCE FOR A SYSTEMATIC EVIDENCE MAP FOR POLYCHLORINATED BIPHENYL (PCB) MIXTURES: EVALUATION OF NONCANCER HEALTH ENDPOINTS AND EXPOSURES

This product is prepared under the auspices of the U.S. Environmental Protection Agency (EPA) within the Office of Research and Development (ORD) in the Center for Public Health and Environmental Assessment (CPHEA). EPA has an agency-wide quality assurance (QA) policy that is outlined in the EPA Quality Manual for Environmental Programs (see CIO 2105-P-01.1 (https://www.epa.gov/irmpoli8/environmental-information-quality-procedure)) and follows the specifications outlined in EPA Order CIO 2105.1 (https://www.epa.gov/irmpoli8/environmental-information-policy-procedures-and-standards).

As required by CIO 2105.1, ORD maintains a Quality Management Program, which is documented in an internal Quality Management Plan (QMP), The latest version was developed in 2013 using Guidance for Developing Quality Systems for Environmental Programs (QA/G-1) (https://www.epa.gov/quality/guidance-developing-quality-systems-environmental-programs-epa-qag-1). A National Center for Environmental Assessment (NCEA)/CPHEA-specific QMP was also developed in 2013 as an appendix to the ORD QMP. QA for products developed within CPHEA is managed under the ORD QMP and applicable appendices.

This work was conducted under the U.S. EPA Quality Assurance program to ensure data are of known and acceptable quality to support their intended use. Surveillance of the work by the lead authors and programmatic scientific leads ensured adherence to QA processes and criteria, as well as quick and effective resolution of any problems. The QA manager, lead authors, and programmatic scientific leads have determined under the QA program that this work meets all U.S. EPA quality requirements. This report was written with guidance from the CPHEA Quality Assurance Project Plans (QAPPs; see table below). As part of the QA system, a quality product review is conducted prior to management clearance. A Technical Systems Audit may be performed at the discretion of the QA staff. This project underwent three quality audits in 2020, 2021, and 2022, with no major findings. The report was subject to internal peer review by two CPHEA scientists and an independent external peer review by three scientific experts. The reviews focused on whether all studies were correctly selected, interpreted, and adequately described for the purposes of this report. The reviews also covered quantitative and qualitative aspects of the report and addressed whether uncertainties were adequately characterized.

Title | Document number | Latest approval date
Program Quality Assurance Project Plan (PQAPP) for the Integrated Risk Information System (IRIS) Program | L-CPAD-0030729-QP-1-5 | June 2022
Quality Assurance Project Plan (QAPP) General Support of CPHEA Human Health Assessment Activities | L-CPAD-0031961-QP-1-2 | May 2022
Quality Assurance Project Plan (QAPP) Support for the IRIS Toxicological Review of Polychlorinated Biphenyls (PCBs); Effects Other Than Cancer | L-CPAD-0031956-QP-1-2 | July 2021