# Acknowledgments

The authors would like to thank MaryJane Selgrade for preliminary review of studies related to immune and hematopoietic health endpoints and Francesca Branch and Catheryne Chiang for internal review of the draft report, and Jessica Soto-Hernandez for document production and publishing. The authors would also like to thank the following ICF staff for assistance in (1) literature searching, literature prioritization, and database support (Steven Black, Michelle Cawley, Grace Cooney, Tom Feiler, Jeremy Frye, Kaitlin Geary, Pam Hartman, Cara Henning, Josiah McCoy, Rachel McGill, Kristen McKinley, Alicia Murphy, Blake Reilly, Delaney Reilly, Nicole Vetter, Arun Varghese, Ashley Williams, River Williams); (2) creating Tableau visualizations (Courtney Lemeris); (3) screening studies (Carlye Austin, Steven Black, Natalie Blanton, Canden Byrd, Kathleen Clark, Tyler Cromer, Ryan Cronk, Jon Davis, Katie Duke, Sorina Eftim, Anna Engstrom, Susan Goldhaber, Ali Goldstone, Lindsey Green, Kate Helmick, Angela Hensel, Chelsea Hunter, Audrey Ichida, Allison Killius, Alex Kliminsky, Gillian Laidlaw, Ellen Lee, Camryn Leib, Jessica Levasseur, Alex Lindahl, Yi Lu, Kristen Magnuson, Maureen Malloy, Sophie McComb, Rachel McGill, Emma Meyer, Devon Morgan, Revathi Muralidharan, Alicia Murphy, Ed Murray, Sean Robins, Johanna Rochester, Amanda Ross, Pam Ross, Alessandria Schumacher, Kendall Scott, Jennifer Seed, Karen Setty, Codi Sharp, Robert Shin, Catherine Smith, Parnian Soleymani, Deshira Wallace, Jared Wang, Ashley Williams, River Williams, Jennifer Yourkavitch, Maricruz Zarco); and (4) technical editing (Tara Hamilton, Penelope Keller, Whitney Mitchell).