# ABBREVIATIONS

ACTH: adrenocorticotropic hormone
ALT: alanine aminotransferase
AOP: adverse outcome pathway
AhR: aryl hydrocarbon receptor
AST: aspartate aminotransferase
ATSDR: Agency for Toxic Substances and Disease Registry
BUN: blood urea nitrogen
BW: body weight
CASRN: Chemical Abstracts Service registry number
CERCH: Center for Environmental Research and Children’s Health
CNS: central nervous system
CPAD: Chemical and Pollutant Assessment Division
CPHEA: Center for Public Health and Environmental Assessment
CYP450: cytochrome P450 CYP1A2
DoCTER: Document Classification and Topic Extraction Resource
EPA: Environmental Protection Agency
EPM: elevated plus maze
EZM: elevated zero maze
FVC: forced vital capacity
FEV1: forceful exhalation
GGT: gamma-glutamyltransferase
GSH: glutathione
HAWC: Health Assessment Workspace Collaborative
HDL: low high-density lipoprotein
HERO: Health and Environmental Research Online
HF: heart failure
HPA: hypothalamus-pituitary-adrenal
HPT: hypothalamus-pituitary-thyroid
IGT: impaired glucose tolerance
i.p.: intraperitoneal
IR: insulin resistance
i.v.: intravenous
IARC: International Agency for Research on Cancer
IHD: ischemic heart disease
IRIS: Integrated Risk Information System
MCH: mean corpuscular hemoglobin
MCV: mean corpuscular volume
ML: machine learning
MetS: metabolic syndrome
MOA: mode of action
MI: myocardial infarction
NCI: National Cancer Institute
NHANES: National Health and Nutrition Examination Survey
NK: natural killer cells
NLP: natural language processing
NTP: National Toxicology Program
ORD: Office of Research and Development
OW/OB: overweight/obesity
PCBs: polychlorinated biphenyls
PCDFs: polychlorinated dibenzofurans
PECO: populations, exposures, comparators, and outcomes
PK: pharmacokinetic
QA: Quality Assurance
QAPP: Quality Assurance Project Plan
RBCs: red blood cells
SD: standard deviation
SE: standard error
SEMs: systematic evidence maps
SGOT: serum glutamic oxaloacetic transaminase, also known as AST
SGPT: serum glutamic pyruvic transaminase, also known as ALT
TCDD: 2,3,7,8-tetrachlorodibenzo-p-dioxin
TK: toxicokinetics
TSCATS: Toxic Substances Control Act Test Submissions
TSH: thyroid stimulating hormone
T4: thyroxine
T3: triiodothyronine
WOS: Web of Science