# References

Aaron, CP; Chervona, Y; Kawut, SM; Diez Roux, AV; Shen, M; Bluemke, DA; Van Hee, VC; Kaufman, JD; Barr, RG. (2016). Particulate matter exposure and cardiopulmonary differences in the multi-ethnic study of atherosclerosis. Environ Health Perspect 124: 1166–1173. 10.1289/ehp.1409451 26859533
Abt (Abt Associates Inc). (2001). Assessing public opinions on visibility impairment due to air pollution: Summary report. Research Triangle Park, NC: U.S. Environmental Protection Agency.
Adar, SD; Filigrana, PA; Clements, N; Peel, JL. (2014). Ambient coarse particulate matter and human health: A systematic review and meta-analysis [Review]. Curr Environ Health Rep 1: 258–274. 10.1007/s40572-014-0022-z 25152864
ADEQ (Arizona Department of Environmental Quality). (2003). Final report-recommendation for a Phoenix area visibility index. Phoenix, Arizona.
Adhikari, A; Yin, J. (2020). Short-Term Effects of Ambient Ozone, PM2.5, and Meteorological Factors on COVID-19 Confirmed Cases and Deaths in Queens, New York. Int J Environ Res Public Health 17. 10.3390/ijerph17114047
Al-Hamdan, MZ; Crosson, WL; Economou, SA; Estes, MG, Jr; Estes, S; Hemmings, SN; Kent, ST; Puckett, M; Quattrochi, DA; Rickman, DL; Wade, GM; McClure, LA. (2014). Environmental public health applications using remotely sensed data. Geocarto International 29: 85–98. 10.1080/10106049.2012.715209 24910505
Atkinson, RW; Kang, S; Anderson, HR; Mills, IC; Walton, HA. (2014). Epidemiological time series studies of PM2.5 and daily mortality and hospital admissions: a systematic review and meta-analysis [Review]. Thorax 69: 660–665. 10.1136/thoraxjnl-2013-204492 24706041
Awad, YA; Di, Q; Wang, Y; Choirat, C; Coull, BA; Zanobetti, A; Schwartz, J. (2019). Change in PM2.5 exposure and mortality among Medicare recipients: Combining a semi-randomized approach and inverse probability weights in a low exposure population. Environmental Epidemiology 3: e054. 10.1097/EE9.0000000000000054 31538135
Bai, L; Shin, S; Burnett, RT; Kwong, JC; Hystad, P; van Donkelaar, A; Goldberg, MS; Lavigne, E; Copes, R; Martin, RV; Kopp, A; Chen, H. (2019). Exposure to ambient air pollution and the incidence of congestive heart failure and acute myocardial infarction: A population-based study of 5.1 million Canadian adults living in Ontario. Environ Int 132: 105004. 10.1016/j.envint.2019.105004 31387019
Barnett, AG; Williams, GM; Schwartz, J; Best, TL; Neller, AH; Petroeschevsky, AL; Simpson, RW. (2006). The effects of air pollution on hospitalizations for cardiovascular disease in elderly people in Australian and New Zealand cities. Environ Health Perspect 114: 1018–1023. 10.1289/ehp.8674 16835053
Baxter, LK; Crooks, JL; Sacks, JD. (2017). Influence of exposure differences on city-to-city heterogeneity in PM2.5-mortality associations in US cities. Environ Health 16: 1. 10.1186/s12940-016-0208-y 28049482
Baxter, LK; Dionisio, K; Pradeep, P; Rappazzo, K; Neas, L. (2019). Human exposure factors as potential determinants of the heterogeneity in city-specific associations between PM2.5 and mortality. J Expo Sci Environ Epidemiol 29: 557–567. 10.1038/s41370-018-0080-7 30310133
Baxter, LK; Sacks, JD. (2014). Clustering cities with similar fine particulate matter exposure characteristics based on residential infiltration and in-vehicle commuting factors. Sci Total Environ 470–471: 631–638. 10.1016/j.scitotenv.2013.10.019
Bell, ML; Ebisu, K; Peng, RD; Walker, J; Samet, JM; Zeger, SL; Dominic, F. (2008). Seasonal and regional short-term effects of fine particles on hospital admissions in 202 U.S. counties, 1999-2005. Am J Epidemiol 168: 1301–1310. 10.1093/aje/kwn252 18854492
Bennett, JE; Tamura-Wicks, H; Parks, RM; Burnett, RT; Pope, CA; Bechle, MJ; Marshall, JD; Danaei, G; Ezzati, M. (2019). Particulate matter air pollution and national and county life expectancy loss in the USA: A spatiotemporal analysis. PLoS Med 16: e1002856. 10.1371/journal.pmed.1002856 31335874
Berrocal, VJ; Gelfand, AE; Holland, DM. (2010a). A bivariate space-time downscaler under space and time misalignment. Ann Appl Stat 4: 1942–1975. 10.1214/10-AOAS351 21853015
Berrocal, VJ; Gelfand, AE; Holland, DM. (2010b). A spatio-temporal downscaler for output from numerical models. J Agric Biol Environ Stat 15: 176–197. 10.1007/s13253-009-0004-z 21113385
Berrocal, VJ; Gelfand, AE; Holland, DM. (2012). Space-time data fusion under error in computer model output: An application to modeling air quality. Biometrics 68: 837–848. 10.1111/j.1541-0420.2011.01725.x 22211949
Bertazzon, S; Johnson, M; Eccles, K; Kaplan, GG. (2015). Accounting for spatial effects in land use regression for urban air pollution modeling. Spat Spatio-temporal Epidemiol 14–15: 9–21. 10.1016/j.sste.2015.06.002
Bevan, GH; Freedman, DA; Lee, EK; Rajagopalan, S; Al-Kindi, SG. (2021). Association between ambient air pollution and county-level cardiovascular mortality in the United States by social deprivation index. Am Heart J 235: 125–131. 10.1016/j.ahj.2021.02.005 33592167
Beyersdorf, AJ; Ziemba, LD; Chen, G; Corr, CA; Crawford, JH; Diskin, GS; Moore, RH; Thornhill, KL; Winstead, EL; Anderson, BE. (2016). The impacts of aerosol loading, composition, and water uptake on aerosol extinction variability in the Baltimore-Washington, DC region. Atmos Chem Phys 16: 1003–1015. 10.5194/acp-16-1003-2016
Bourdrel, T; Annesi-Maesano, I; Alahmad, B; Maesano, CN; Bind, MA. (2021). The impact of outdoor air pollution on COVID-19: a review of evidence from in vitro, animal, and human studies [Review]. 30. 10.1183/16000617.0242-2020
Boys, BL; Martin, RV; van Donkelaar, A; MacDonell, RJ; Hsu, NC; Cooper, MJ; Yantosca, RM; Lu, Z; Streets, DG; Zhang, Q; Wang, SW. (2014). Fifteen-year global time series of satellite-derived fine particulate matter. Environ Sci Technol 48: 11109–11118. 10.1021/es502113p 25184953
Brauer, M; Brook, JR; Christidis, T; Chu, Y; Crouse, DL; Erickson, A; Hystad, P; Li, C; Martin, RV; Meng, J; Pappin, AJ; Pinault, LL; Tjepkema, M; van Donkelaar, A; Weichenthal, S; Burnett, RT. (2019). Mortality-air pollution associations in low-exposure environments (MAPLE): Phase 1 (pp. 1–87). Boston, MA: Health Effects Institute.
Cakmak, S; Hebbern, C; Pinault, L; Lavigne, E; Vanos, J; Crouse, DL; Tjepkema, M. (2018). Associations between long-term PM2.5 and ozone exposure and mortality in the Canadian Census Health and Environment Cohort (CANCHEC), by spatial synoptic classification zone. Environ Int 111: 200–211. 10.1016/j.envint.2017.11.030 29227849
Chakrabarty, RK; Beeler, P; Liu, P; Goswami, S; Harvey, RD; Pervez, S; van Donkelaar, A; Martin, RV. (2021). Ambient PM2.5 exposure and rapid spread of COVID-19 in the United States. Sci Total Environ 760: 143391. 10.1016/j.scitotenv.2020.143391 33250247
Chen, H; Zhang, ZL; van Donkelaar, A; Bai, L; Martin, RV; Lavigne, E; Kwong, JC; Burnett, RT. (2020). Understanding the Joint Impacts of Fine Particulate Matter Concentration and Composition on the Incidence and Mortality of Cardiovascular Disease: A Component-Adjusted Approach. Environ Sci Technol 54: 4388–4399. 10.1021/acs.est.9b06861 32101425
Chi, GC; Hajat, A; Bird, CE; Cullen, MR; Griffin, BA; Miller, KA; Shih, RA; Stefanick, ML; Vedal, S; Whitsel, EA; Kaufman, JD. (2016). Individual and neighborhood socioeconomic status and the association between air pollution and cardiovascular disease. Environ Health Perspect 124: 1840–1847. 10.1289/EHP199 27138533
Chow, JC; Chen, LWA; Wang, X; Green, MC; Watson, JG. (2021). Improved estimation of PM2.5 brown carbon contributions to filter light attenuation. Particuology 56: 1–9. 10.1016/j.partic.2021.01.001
Christidis, T; Erickson, AC; Pappin, AJ; Crouse, DL; Pinault, LL; Weichenthal, SA; Brook, JR; van Donkelaar, A; Hystad, P; Martin, RV; Tjepkema, M; Burnett, RT; Brauer, M. (2019). Low concentrations of fine particle air pollution and mortality in the Canadian Community Health Survey cohort. Environ Health 18: 84. 10.1186/s12940-019-0518-y 31601202
Corrigan, AE; Becker, MM; Neas, LM; Cascio, WE; Rappold, AG. (2018). Fine particulate matters: The impact of air quality standards on cardiovascular mortality. Environ Res 161: 364–369. 10.1016/j.envres.2017.11.025 29195185
Crouse, D; Philip, S; van Donkelaar, A; Martin, RV; Jessiman, B; Peters, PA; Weichenthal, S; Brook, J. R.; Hubbell, B; Burnett, RT. (2016). A new method to jointly estimate the mortality risk of long-term exposure to fine particulate matter and its components. Sci Rep 6: 18916. 10.1038/srep18916 26732864
Crouse, DL; Erickson, AC; Christidis, T; Pinault, L; van Donkelaar, A; Li, C; Meng, J; Martin, RV; Tjepkema, M; Hystad, P; Burnett, R; Pappin, A; Brauer, M; Weichenthal, S. (2020). Evaluating the sensitivity of pm2.5-mortality associations to the spatial and temporal scale of exposure assessment. Epidemiology 31: 168–176. 10.1097/EDE.0000000000001136 31693516
Crouse, DL; Peters, PA; Hystad, P; Brook, JR; van Donkelaar, A; Martin, RV; Villeneuve, PJ; Jerrett, M; Goldberg, MS; Pope, CA; Brauer, M; Brook, RD; Robichaud, A; Menard, R; Burnett, RT. (2015). Ambient PM 2.5, O 3, and NO 2 exposures and associations with mortality over 16 years of follow-up in the Canadian Census Health and Environment Cohort (CanCHEC). Environ Health Perspect 123: 1180–1186. 10.1289/ehp.1409276 26528712
Crouse, DL; Peters, PA; van Donkelaar, A; Goldberg, MS; Villeneuve, PJ; Brion, O; Khan, S; Atari, DO; Jerrett, M; Pope, CA; Brauer, M; Brook, JR; Martin, RV; Stieb, D; Burnett, RT. (2012). Risk of nonaccidental and cardiovascular mortality in relation to long-term exposure to low concentrations of fine particulate matter: a Canadian national-level cohort study. Environ Health Perspect 120: 708–714. 10.1289/ehp.1104049 22313724
Crouse, DL; Pinault, L; Balram, A; Brauer, M; Burnett, RT; Martin, RV; van Donkelaar, A; Villeneuve, PJ; Weichenthal, S. (2019). Complex relationships between greenness, air pollution, and mortality in a population-based Canadian cohort. Environ Int 128: 292–300. 10.1016/j.envint.2019.04.047 31075749
Dai, L; Zanobetti, A; Koutrakis, P; Schwartz, JD. (2014). Associations of fine particulate matter species with mortality in the United States: a multicity time-series analysis. Environ Health Perspect 122: 837–842. 10.1289/ehp.1307568 24800826
Danesh Yazdi, M; Wang, Y; Di, Q; Wei, YG; Requia, WJ; Shi, LH; Sabath, MB; Dominici, F; Coull, BA; Evans, JS; Koutrakis, P; Schwartz, JD. (2021). Long-term association of air pollution and hospital admissions among Medicare participants using a doubly robust additive model. Circulation 143: 1584–1596. 10.1161/CIRCULATIONAHA.120.050252 33611922
Danesh Yazdi, M; Wang, Y; Di, Q; Zanobetti, A; Schwartz, J. (2019). Long-term exposure to PM2.5 and ozone and hospital admissions of Medicare participants in the Southeast USA. Environ Int 130: 104879. 10.1016/j.envint.2019.05.073 31238267
deSouza, P; Braun, D; Parks, RM; Schwartz, J; Dominici, F; Kioumourtzoglou, MA. (2021). Nationwide Study of Short-term Exposure to Fine Particulate Matter and Cardiovascular Hospitalizations Among Medicaid Enrollees. Epidemiology 32: 6–13. 10.1097/EDE.0000000000001265 33009251
Di, Q; Amini, H; Shi, L; Kloog, I; Silvern, R; Kelly, J; Sabath, MB; Choirat, C; Koutrakis, P; Lyapustin, A; Wang, Y; Mickley, LJ; Schwartz, J. (2019). An ensemble-based model of PM2.5 concentration across the contiguous United States with high spatiotemporal resolution. Environ Int 130: 104909. 10.1016/j.envint.2019.104909 31272018
Di, Q; Dai, L; Wang, Y; Zanobetti, A; Choirat, C; Schwartz, JD; Dominici, F. (2017a). Association of short-term exposure to air pollution with mortality in older adults. JAMA 318: 2446–2456. 10.1001/jama.2017.17923 29279932
Di, Q; Kloog, I; Koutrakis, P; Lyapustin, A; Wang, Y; Schwartz, J. (2016). Assessing PM2.5 exposures with high spatiotemporal resolution across the Continental United States. Environ Sci Technol 50: 4712–4721. 10.1021/acs.est.5b06121 27023334
Di, Q; Wang, Y; Zanobetti, A; Wang, Y; Koutrakis, P; Choirat, C; Dominici, F; Schwartz, JD. (2017b). Air pollution and mortality in the Medicare population. N Engl J Med 376: 2513–2522. 10.1056/NEJMoa1702747 28657878
Dominici, F; Peng, RD; Bell, ML; Pham, L; McDermott, A; Zeger, SL; Samet, JL. (2006). Fine particulate air pollution and hospital admission for cardiovascular and respiratory diseases. JAMA 295: 1127–1134. 10.1001/jama.295.10.1127 16522832
Dominici, F; Schwartz, J; Di, Q; Braun, D; Choirat, C; Zanobetti, A. (2019). Assessing adverse health effects of long-term exposure to low levels of ambient air pollution: Phase 1. Boston, MA: Health Effects Institute. https://www.healtheffects.org/system/files/dominici-rr-200-report.pdf
Dorans, KS; Wilker, EH; Li, W; Rice, MB; Ljungman, PL; Schwartz, J; Coull, BA; Kloog, I; Koutrakis, P; D’Agostino, RB; Massaro, JM; Hoffmann, U; O’Donnell, CJ; Mittleman, MA. (2016). Residential proximity to major roads, exposure to fine particulate matter, and coronary artery calcium: The Framingham Heart Study. Arterioscler Thromb Vasc Biol 36: 1679–1685. 10.1161/ATVBAHA.116.307141 27312220
Duan, C; Talbott, E; Brooks, M; Park, SK; Broadwin, R; Matthews, K; Barinas-Mitchell, E. (2019a). Five-year exposure to PM2.5 and ozone and subclinical atherosclerosis in late midlife women: The Study of Women’s Health Across the Nation. Int J Hyg Environ Health 222: 168–176. 10.1016/j.ijheh.2018.09.001 30236459
Duan, C; Talbott, EO; Broadwin, R; Brooks, M; Matthews, K; Barinas-Mitchell, E. (2019b). Residential exposure to PM2.5 and ozone and progression of subclinical atherosclerosis among women transitioning through menopause: The study of women’s health across the nation. J Womens Health 28: 802–811. 10.1089/jwh.2018.7182
Elliott, EG; Laden, F; James, P; Rimm, EB; Rexrode, KM; Hart, JE. (2020). Interaction between Long-Term Exposure to Fine Particulate Matter and Physical Activity, and Risk of Cardiovascular Disease and Overall Mortality in US Women. Environ Health Perspect 128: 127012. 10.1289/EHP7402 33356515
Ely, DW; Leary, JT; Stewart, TR; Ross, DM. (1991). The establishment of the Denver Visibility Standard. Denver, Colorado: Colorado Department of Health.
EPA Press Office (U.S. Environmental Protection Agency Press Office). (2021). EPA to reexamine health standards for harmful soot that previous administration left unchanged. Available online at https://www.epa.gov/newsreleases/epa-reexamine-health-standards-harmful-soot-previous-administration-left-unchanged
Erickson, AC; Brauer, M; Christidis, T; Pinault, L; Crouse, DL; van Donkelaar, A; Weichenthal, S; Pappin, A; Tjepkema, M; Martin, RV; Brook, JR; Hystad, P; Burnett, RT. (2019). Evaluation of a method to indirectly adjust for unmeasured covariates in the association between fine particulate matter and mortality. Environ Res 175: 108–116. 10.1016/j.envres.2019.05.010 31108354
Erickson, AC; Christidis, T; Pappin, A; Brook, JR; Crouse, DL; Hystad, P; Li, C; Martin, RV; Meng, J; Pinault, L; von Donkelaar, A; Weichenthal, S; Tjepkema, M; Burnett, RT; Brauer, M. (2020). Disease assimilation: The mortality impacts of fine particulate matter on immigrants to Canada. Health Rep 31: 14–26. 10.25318/82-003-x202000300002-eng
Erqou, S; Clougherty, JE; Olafiranye, O; Magnani, JW; Aiyer, A; Tripathy, S; Kinnee, E; Kip, KE; Reis, SE. (2018). Particulate matter air pollution and racial differences in cardiovascular disease risk. Arterioscler Thromb Vasc Biol 38: 935–942. 10.1161/ATVBAHA.117.310305 29545240
Eum, K; Suh, HH; Pun, V; Manjourides, J. (2018). Impact of long-term temporal trends in fine particulate matter (PM2.5) on association of annual PM2.5 exposure and mortality: an analysis of over 20 million Medicare beneficiaries. Environmental Epidemiology 2: e009. 10.1097/EE9.0000000000000009 34622119
Evans, KA; Hopke, PK; Utell, MJ; Kane, C; Thurston, SW; Ling, FS; Chalupa, D; Rich, DQ. (2017). Triggering of ST-elevation myocardial infarction by ambient wood smoke and other particulate and gaseous pollutants. J Expo Sci Environ Epidemiol 27: 198–206. 10.1038/jes.2016.15 27072425
Fan, M; Wang, Y. (2020). The impact of PM2.5 on mortality in older adults: evidence from retirement of coal-fired power plants in the United States. Environ Health 19: 28. 10.1186/s12940-020-00573-2 32126999
Fisher, JA; Puett, RC; Laden, F; Wellenius, GA; Sapkota, A; Liao, D; Yanosky, JD; Carter-Pokras, O; He, X; Hart, JE. (2019). Case-crossover analysis of short-term particulate matter exposures and stroke in the health professionals follow-up study. Environ Int 124: 153–160. 10.1016/j.envint.2018.12.044 30641259
Franklin, M; Koutrakis, P; Schwartz, J. (2008). The role of particle composition on the association between PM2.5 and mortality. Epidemiology 19: 680–689. 10.1097/EDE.0b013e3181812bb7 18714438
Friberg, MD; Kahn, RA; Holmes, HA; Chang, HH; Sarnat, SE; Tolbert, PE; Russell, AG; Mulholland, JA. (2017). Daily ambient air pollution metrics for five cities: Evaluation of data-fusion-based estimates and uncertainties. Atmos Environ 158: 36–50. 10.1016/j.atmosenv.2017.03.022
Friberg, MD; Zhai, X; Holmes, HA; Chang, HH; Strickland, MJ; Sarnat, SE; Tolbert, PE; Russell, AG; Mulholland, JA. (2016). Method for fusing observational data and chemical transport model simulations to estimate spatiotemporally resolved ambient air pollution - Supplemental material [Supplemental Data]. Environ Sci Technol 50.
Gan, WQ; Allen, RW; Brauer, M; Davies, HW; Mancini, GB; Lear, SA. (2014). Long-term exposure to traffic-related air pollution and progression of carotid artery atherosclerosis: a prospective cohort study. BMJ Open 4: e004743. 10.1136/bmjopen-2013-004743
Gardner, B; Ling, F; Hopke, PK; Frampton, MW; Utell, MJ; Zareba, W; Cameron, SJ; Chalupa, D; Kane, C; Kulandhaisamy, S; Topf, MC; Rich, DQ. (2014). Ambient fine particulate air pollution triggers ST-elevation myocardial infarction, but not non-ST elevation myocardial infarction: A case-crossover study. Part Fibre Toxicol 11: 1. 10.1186/1743-8977-11-1 24382024
Goldberger, JJ; Cain, ME; Hohnloser, SH; Kadish, AH; Knight, BP; Lauer, MS; Maron, BJ; Page, RL; Passman, RS; Siscovick, D; Stevenson, WG; Zipes, DP. (2008). American Heart Association/American College of Cardiology Foundation/Heart Rhythm Society Scientific Statement on Noninvasive Risk Stratification Techniques for Identifying Patients at Risk for Sudden Cardiac Death. A scientific statement from the American Heart Association Council on Clinical Cardiology Committee on Electrocardiography and Arrhythmias and Council on Epidemiology and Prevention. J Am Coll Cardiol 52: 1179–1199. 10.1016/j.jacc.2008.05.003 18804749
Gordon, TD; Prenni, AJ; Renfro, J. R.; Mcclure, E; Hicks, B; Onasch, TB; Freedman, A; Mcmeeking, GR; Chen, P. (2018). Open-path, closed-path, and reconstructed aerosol extinction at a rural site. J Air Waste Manag Assoc 68: 824–835. 10.1080/10962247.2018.1452801 29630469
Green, R; Broadwin, R; Malig, B; Basu, R; Gold, EB; Qi, L; Sternfeld, B; Bromberger, JT; Greendale, GA; Kravitz, HM; Tomey, K; Matthews, K; Derby, C; Jackson, EA; Green, R; Ostro, B. (2016). Long-and short-term exposure to air pollution and inflammatory/hemostatic markers in midlife women. Epidemiology 27: 211–220. https://journals.lww.com/epidem/Fulltext/2016/03000/Long__and_Short_term_Exposure_to_Air_Pollution_and.8.aspx 26600256
Greven, S; Dominici, F; Zeger, S. (2011). An Approach to the Estimation of Chronic Air Pollution Effects Using Spatio-Temporal Information. J Am Stat Assoc 106: 396–406. 10.1198/jasa.2011.ap09392 28751799
Han, I; Guo, YC; Afshar, M; Stock, TH; Symanski, E. (2017). Comparison of trace elements in size-fractionated particles in two communities with contrasting socioeconomic status in Houston, TX. Environ Monit Assess 189: 67. 10.1007/s10661-017-5780-2 28110452
Hand, J; Copeland, S; Day, D; Dillner, A; Indresand, H; Malm, W; McDade, C; Moore, C, Jr; Pitchford, M; Schichtel, B. (2011). IMPROVE (Interagency Monitoring of Protected Visual Environments): Spatial and seasonal patterns and temporal variability of haze and its constituents in the United States. Fort Collins, Co: Colorado State University, Cooperative Institute for Research in the Atmosphere. http://vista.cira.colostate.edu/Improve/spatial-and-seasonal-patterns-and-temporal-variability-of-haze-and-its-constituents-in-the-united-states-report-v-june-2011/
Hand, JL; Prenni, AJ; Copeland, S; Schichtel, BA; Malm, WC. (2020). Thirty years of the Clean Air Act Amendments: Impacts on haze in remote regions of the United States (1990-2018). Atmos Environ 243: 117865. 10.1016/j.atmosenv.2020.117865
Hart, JE; Liao, X; Hong, B; Puett, RC; Yanosky, JD; Suh, H; Kioumourtzoglou, MA; Spiegelman, D; Laden, F. (2015a). The association of long-term exposure to PM2.5 on all-cause mortality in the Nurses’ Health Study and the impact of measurement-error correction. Environ Health 14: 38. 10.1186/s12940-015-0027-6 25926123
Hart, JE; Puett, RC; Rexrode, KM; Albert, CM; Laden, F. (2015b). Effect modification of long-term air pollution exposures and the risk of incident cardiovascular disease in US women. J Am Heart Assoc 4. 10.1161/JAHA.115.002301
Hartiala, J; Breton, CV; Tang, WH; Lurmann, F; Hazen, SL; Gilliland, FD; Allayee, H. (2016). Ambient air pollution is associated with the severity of coronary atherosclerosis and incident myocardial infarction in patients undergoing elective cardiac evaluation. J Am Heart Assoc 5. 10.1161/JAHA.116.003947
Hayes, RB; Lim, C; Zhang, YL; Cromar, K; Shao, YZ; Reynolds, HR; Silverman, DT; Jones, RR; Park, Y; Jerrett, M; Ahn, J; Thurston, GD. (2020). PM2.5 air pollution and cause-specific cardiovascular disease mortality. Int J Epidemiol 49: 25–35. 10.1093/ije/dyz114 31289812
Hemmingsen, JG; Jantzen, K; Møller, P; Loft, S. (2015a). No oxidative stress or DNA damage in peripheral blood mononuclear cells after exposure to particles from urban street air in overweight elderly. Mutagenesis 30: 635–642. 10.1093/mutage/gev027 25904586
Hemmingsen, JG; Rissler, J; Lykkesfeldt, J; Sallsten, G; Kristiansen, J; Møller, P; Loft, S. (2015b). Controlled exposure to particulate matter from urban street air is associated with decreased vasodilation and heart rate variability in overweight and older adults. Part Fibre Toxicol 12: 6. 10.1186/s12989-015-0081-9 25890359
Henneman, LRF; Choirat, C; Zigler, ACM. (2019). Accountability assessment of health improvements in the United States associated with reduced coal emissions between 2005 and 2012. Epidemiology 30: 477–485. 10.1097/EDE.0000000000001024 31162280
Higbee, JD; Lefler, JS; Burnett, RT; Ezzati, M; Marshall, JD; Kim, SY; Bechle, M; Robinson, AL; Pope, CA. (2020). Estimating long-term pollution exposure effects through inverse probability weighting methods with Cox proportional hazards models. Environmental Epidemiology 4: e085. 10.1097/EE9.0000000000000085 32656485
Higgins, JP. (2008). Commentary: Heterogeneity in meta-analysis should be expected and appropriately quantified [Comment]. Int J Epidemiol 37: 1158–1160. 10.1093/ije/dyn204 18832388
Honda, T; Eliot, MN; Eaton, CB; Whitsel, E; Stewart, JD; Mu, L; Suh, H; Szpiro, A; Kaufman, JD; Vedal, S; Wellenius, GA. (2017). Long-term exposure to residential ambient fine and coarse particulate matter and incident hypertension in post-menopausal women. Environ Int 105: 79–85. 10.1016/j.envint.2017.05.009 28521192
Host, S; Larrieu, S; Pascal, L; Blanchard, M; Declercq, C; Fabre, P; Jusot, JF; Chardon, B; Le Tertre, A; Wagner, V; Prouvost, H; Lefranc, A. (2008). Short-term associations between fine and coarse particles and hospital admissions for cardiorespiratory diseases in six French cities. Occup Environ Med 65: 544–551. 10.1136/oem.2007.036194 18056749
Janes, H; Dominici, F; Zeger, SL. (2007). Trends in air pollution and mortality: an approach to the assessment of unmeasured confounding. Epidemiology 18: 416–423. 10.1097/EDE.0b013e31806462e9 17568215
Janssen, NAH; Fischer, P; Marra, M; Ameling, C; Cassee, FR. (2013). Short-term effects of PM2.5, PM10 and PM2.5-10 on daily mortality in the Netherlands. Sci Total Environ 463: 20–26. 10.1016/j.scitotenv.2013.05.062 23787105
Jerrett, M; Turner, MC; Beckerman, BS; Pope, CA; van Donkelaar, A; Martin, RV; Serre, M; Crouse, D; Gapstur, SM; Krewski, D; Diver, WR; Coogan, PF; Thurston, GD; Burnett, RT. (2016). Comparing the health effects of ambient particulate matter estimated using ground-based versus remote sensing exposure estimates. Environ Health Perspect 125: 552–559. 10.1289/EHP575 27611476
Jorgenson, AK; Hill, TD; Clark, B; Thombs, RP; Ore, P; Balistreri, KS; Givens, JE. (2020). Power, proximity, and physiology: does income inequality and racial composition amplify the impacts of air pollution on life expectancy in the United States? Environ Res Lett 15: 024013. 10.1088/1748-9326/ab6789
Juarez, PD; Tabatabai, M; Valdez, RB; Hood, DB; Im, W; Mouton, C; Colen, C; Al-Hamdan, MZ; Matthews-Juarez, P; Lichtveld, MY; Sarpong, D; Ramesh, A; Langston, MA; Rogers, GL; Phillips, CA; Reichard, JF; Donneyong, MM; Blot, W. (2020). The effects of social, personal, and behavioral risk factors and PM2.5 on cardio-metabolic disparities in a cohort of community health center patients. Int J Environ Res Public Health 17: 3561. 10.3390/ijerph17103561 32438697
Kannel, WB; Abbott, RD; Savage, DD; McNamara, PM. (1983). Coronary heart disease and atrial fibrillation: the Framingham Study. Am Heart J 106: 389–396.6869222
Kaufman, JP; Adar, SD; Barr, RG; Budoff, M; Burke, GL; Curl, CL; Diez Roux, AV; Gassett, AJ; Jacobs, DR, Jr; Kronmal, R; Larson, TV; Navas-Acien, A; Olives, C; Sampson, PD; Sheppard, L; Siscovick, DS; Stein, JH; Szpiro, AA; Watson, KE. (2016). Association between air pollution and coronary artery calcification within six metropolitan areas in the USA (the Multi-Ethnic Study of Atherosclerosis and Air Pollution): a longitudinal cohort study. Lancet 388: 696–704. 10.1016/S0140-6736(16)00378-0 27233746
Keller, JP; Larson, TV; Austin, E; Barr, RG; Sheppard, L; Vedal, S; Kaufman, JD; Szpiro, AA. (2018). Pollutant composition modification of the effect of air pollution on progression of coronary artery calcium: the Multi-Ethnic Study of Atherosclerosis. Environmental Epidemiology 2. 10.1097/EE9.0000000000000024
Keller, JP; Olives, C; Kim, SY; Sheppard, L; Sampson, PD; Szpiro, AA; Oron, AP; Lindström, J; Vedal, S; Kaufman, JD. (2015). A unified spatiotemporal modeling approach for predicting concentrations of multiple air pollutants in the multi-ethnic study of atherosclerosis and air pollution. Environ Health Perspect 123: 301–309. 10.1289/ehp.1408145 25398188
Kelly, JT; Jang, C; Timin, B; Di, Q; Schwartz, J; Liu, Y; van Donkelaar, A; Martin, RV; Berrocal, V; Bell, ML. (2020). Examining PM2.5 concentrations and exposure using multiple models. Environ Res 196: 110432. 10.1016/j.envres.2020.110432 33166538
Kim, SY; Bechle, M; Hankey, S; Sheppard, L; Szpiro, AA; Marshall, JD. (2020). Concentrations of criteria pollutants in the contiguous U.S., 1979 - 2015: Role of prediction model parsimony in integrated empirical geographic regression. PLoS ONE 15: e0228535. 10.1371/journal.pone.0228535 32069301
Kim, SY; Olives, C; Sheppard, L; Sampson, PD; Larson, TV; Keller, JP; Kaufman, JD. (2017). Historical Prediction Modeling Approach for Estimating Long-Term Concentrations of PM2.5 in Cohort Studies before the 1999 Implementation of Widespread Monitoring. Environ Health Perspect 125: 38–46. 10.1289/EHP131 27340825
Kleinman, L; Sedlacek, AJ, III; Adachi, K; Buseck, PR; Collier, S; Dubey, MK; Hodshire, AL; Lewis, E; Onasch, TB; Pierce, JR; Shilling, J; Springston, SR; Wang, J; Zhang, Q; Zhou, S; Yokelson, RJ. (2020). Rapid evolution of aerosol particles and their optical properties downwind of wildfires in the western US. Atmos Chem Phys 20: 13319–13341. 10.5194/acp-20-13319-2020
Kloog, I; Nordio, F; Zanobetti, A; Coull, BA; Koutrakis, P; Schwartz, JD. (2014). Short term effects of particle exposure on hospital admissions in the Mid-Atlantic states: a population estimate. PLoS ONE 9: e88578. 10.1371/journal.pone.0088578 24516670
Kloog, I; Ridgway, B; Koutrakis, P; Coull, BA; Schwartz, JD. (2013). Long- and short-term exposure to PM2.5 and mortality: Using novel exposure models. Epidemiology 24: 555–561. 10.1097/EDE.0b013e318294beaa 23676266
Koton, S; Molshatzki, N; Yuval, N; Myers, V; Broday, DM; Drory, Y; Steinberg, DM; Gerber, Y. (2013). Cumulative exposure to particulate matter air pollution and long-term post-myocardial infarction outcomes. Prev Med 57: 339–344. 10.1016/j.ypmed.2013.06.009 23777671
Krall, JR; Chang, HH; Waller, LA; Mulholland, JA; Winquist, A; Talbott, EO; Rager, JR; Tolbert, PE; Sarnat, SE. (2018). A multicity study of air pollution and cardiorespiratory emergency department visits: Comparing approaches for combining estimates across cities. Environ Int 120: 312–320. 10.1016/j.envint.2018.07.033 30107292
Künzli, N; Jerrett, M; Garcia-Esteban, R; Basagaña, X; Beckermann, B; Gilliland, F; Medina, M; Peters, J; Hodis, HN; Mack, WJ. (2010). Ambient air pollution and the progression of atherosclerosis in adults. PLoS ONE 5: e9096. 10.1371/journal.pone.0009096 20161713
Laing, JR; Jaffe, DA; Hee, JR. (2016). Physical and optical properties of aged biomass burning aerosol from wildfires in Siberia and the Western USA at the Mt. Bachelor Observatory. Atmos Chem Phys 16: 15185–15197. 10.5194/acp-16-15185-2016
Lambert, A; Hallar, AG; Garcia, M; Strong, C; Andrews, E; Hand, JL. (2020). Dust impacts of rapid agricultural expansion on the great plains. Geophys Res Lett 47: e2020GL090347. 10.1029/2020GL090347
Lanzinger, S; Schneider, A; Breitner, S; Stafoggia, M; Erzen, I; Dostal, M; Pastorkova, A; Bastian, S; Cyrys, J; Zscheppang, A; Kolodnitska, T; Peters, A. (2016). Associations between ultrafine and fine particles and mortality in five central European cities - Results from the UFIREG study. Environ Int 88: 44–52. 10.1016/j.envint.2015.12.006 26708280
Laupacis, A; Boysen, G; Connolly, S. (1994). Risk factors for stroke and efficacy of antithrombotic therapy in atrial fibrillation: Analysis of pooled data from five randomized controlled trials. Arch Intern Med 154: 1449–1457.8018000
Lavigne, E; Burnett, RT; Weichenthal, S. (2018). Association of short-term exposure to fine particulate air pollution and mortality: effect modification by oxidant gases. Sci Rep 8: 16097. 10.1038/s41598-018-34599-x 30382168
Lee, HJ. (2019). Benefits of High Resolution PM2.5 Prediction using Satellite MAIAC AOD and Land Use Regression for Exposure Assessment: California Examples. Environ Sci Technol 53: 12774–12783. 10.1021/acs.est.9b03799 31566957
Lee, HJ; Park, HY. (2020). Prioritizing the control of emission sources to mitigate PM2.5 disparity in California. Atmos Environ 224. 10.1016/j.atmosenv.2020.117316
Lee, M; Koutrakis, P; Coull, B; Kloog, I; Schwartz, J. (2015). Acute effect of fine particulate matter on mortality in three Southeastern states from 2007-2011. J Expo Sci Environ Epidemiol 26: 173–179. 10.1038/jes.2015.47 26306925
Lefler, JS; Higbee, JD; Burnett, RT; Ezzati, M; Coleman, NC; Mann, DD; Marshall, JD; Bechle, M; Wang, Y; Robinson, AL; Arden Pope, C. (2019). Air pollution and mortality in a large, representative U.S. cohort: multiple-pollutant analyses, and spatial and temporal decompositions. Environ Health 18: 101. 10.1186/s12940-019-0544-9 31752939
Leiser, CL; Smith, KR; Vanderslice, JA; Glotzbach, JP; Farrell, TW; Hanson, HA. (2019). Evaluation of the Sex-and-Age-Specific Effects of PM2.5 on Hospital Readmission in the Presence of the Competing Risk of Mortality in the Medicare Population of Utah 1999-2009. J Clin Med 8: 2114. 10.3390/jcm8122114 31810253
Lepeule, J; Laden, F; Dockery, D; Schwartz, J. (2012). Chronic exposure to fine particles and mortality: an extended follow-up of the Harvard Six Cities study from 1974 to 2009. Environ Health Perspect 120: 965–970. 10.1289/ehp.1104660 22456598
Liang, D; Shi, L; Zhao, J; Liu, P; Sarnat, JA; Gao, S; Schwartz, J; Liu, Y; Ebeit, ST; Scovronick, N; Chang, HH. (2020). Urban air pollution may enhance COVID-19 case-fatality and mortality rates in the United States. Innovation (N Y) 1: 100047. 10.1016/j.xinn.2020.100047
Liao, D; Peuquet, DJ; Duan, Y; Whitsel, EA; Dou, J; Smith, RL; Lin, HM; Chen, JC; Heiss, G. (2006). GIS approaches for the estimation of residential-level ambient PM concentrations. Environ Health Perspect 114: 1374–1380. 10.1289/ehp.9169 16966091
Liao, D; Whitsel, EA; Duan, Y; Lin, HM; Quibrera, PM; Smith, R; Peuquet, DJ; Prineas, RJ; Zhang, ZM; Anderson, G. (2009). Ambient particulate air pollution and ectopy-the environmental epidemiology of arrhythmogenesis in Women’s Health Initiative Study, 1999-2004. J Toxicol Environ Health A 72: 30–38. 10.1080/15287390802445483 18979352
Liévanos, RS. (2019). Racialized Structural Vulnerability: Neighborhood Racial Composition, Concentrated Disadvantage, and Fine Particulate Matter in California. Int J Environ Res Public Health 16: 3196. 10.3390/ijerph16173196 31480556
Lim, CC; Hayes, RB; Ahn, J; Shao, Y; Silverman, DT; Jones, RR; Garcia, C; Thurston, GD. (2018). Association between long-term exposure to ambient air pollution and diabetes mortality in the US. Environ Res 165: 330–336. 10.1016/j.envres.2018.04.011 29778967
Lipfert, FW; Wyzga, RE. (2020). Environmental predictors of survival in a cohort of U.S. military veterans: A multi-level spatio-temporal analysis stratified by race. Environ Res 183: 108842. 10.1016/j.envres.2019.108842 31818475
Lippmann, M; Chen, LC; Gordon, T; Ito, K; Thurston, GD. (2013a). National Particle Component Toxicity (NPACT) Initiative: Integrated epidemiologic and toxicologic studies of the health effects of particulate matter components [HEI]. (177). Boston, MA: Health Effects Institute. https://www.healtheffects.org/system/files/RR177-Lippmann.pdf
Lippmann, M; Chen, LC; Gordon, T; Ito, K; Thurston, GD. (2013b). National Particle Component Toxicity (NPACT) Initiative: Integrated epidemiologic and toxicologic studies of the health effects of particulate matter components: Investigators’ Report [HEI] (pp. 5–13). (177). Boston, MA: Health Effects Institute.
Lipsett, MJ; Ostro, BD; Reynolds, P; Goldberg, D; Hertz, A; Jerrett, M; Smith, DF; Garcia, C; Chang, ET; Bernstein, L. (2011). Long-term exposure to air pollution and cardiorespiratory disease in the California teachers study cohort. Am J Respir Crit Care Med 184: 828–835. 10.1164/rccm.201012-2082OC 21700913
Liu, C; Chen, R; Sera, F; Vicedo-Cabrera, AM; Guo, Y; Tong, S; Coelho, M; Saldiva, PHN; Lavigne, E; Matus, P; Valdes Ortega, N; Osorio Garcia, S; Pascal, M; Stafoggia, M; Scortichini, M; Hashizume, M; Honda, Y; Hurtado-Díaz, M; Cruz, J; Nunes, B; Teixeira, JP; Kim, H; Tobias, A; Íñiguez, C; Forsberg, B; Åström, C; Ragettli, MS; Guo, YL; Chen, BY; Bell, ML; Wright, CY; Scovronick, N; Garland, RM; Milojevic, A; Kyselý, J; Urban, A; Orru, H; Indermitte, E; Jaakkola, JJK; Ryti, NRI; Katsouyanni, K; Analitis, A; Zanobetti, A; Schwartz, J; Chen, J; Wu, T; Cohen, A; Gasparrini, A; Kan, H. (2019). Ambient Particulate Air Pollution and Daily Mortality in 652 Cities. N Engl J Med 381: 705–715. 10.1056/NEJMoa1817364 31433918
Liu, X; Bertazzon, S; Villeneuve, PJ; Johnson, M; Stieb, D; Coward, S; Tanyingoh, D; Windsor, JW; Underwood, F; Hill, MD; Rabi, D; Ghali, WA; Wilton, SB; James, MT; Graham, M; Mcmurtry, MS; Kaplan, GG. (2020). Temporal and spatial effect of air pollution on hospital admissions for myocardial infarction: a case-crossover study. CMAJ Open 8: E619–E626. 10.9778/cmajo.20190160
Loop, MS; McClure, LA; Levitan, EB; Al-Hamdan, MZ; Crosson, WL; Safford, MM. (2018). Fine particulate matter and incident coronary heart disease in the REGARDS cohort. Am Heart J 197: 94–102. 10.1016/j.ahj.2017.11.007 29447790
Lowenthal, DH; Kumar, N. (2016). Evaluation of the IMPROVE Equation for estimating aerosol light extinction. J Air Waste Manag Assoc 66: 726–737. 10.1080/10962247.2016.1178187 27104488
Luben, TJ; Buckley, BJ; Patel, MM; Stevens, T; Coffman, E; Rappazzo, KM; Owens, EO; Hines, EP; Moore, D; Painter, K; Jones, R; Datko-Williams, L; Wilkie, AA; Madden, M; Richmond-Bryant, J. (2018). A cross-disciplinary evaluation of evidence for multipollutant effects on cardiovascular disease [Review]. Environ Res 161: 144–152. 10.1016/j.envres.2017.11.008 29145006
Malik, AO; Jones, PG; Chan, PS; Peri-Okonny, PA; Hejjaji, V; Spertus, JA. (2019). Association of long-term exposure to particulate matter and ozone with health status and mortality in patients after myocardial infarction. Circulation Cardiovascular Quality and Outcomes 12: e005598. 10.1161/CIRCOUTCOMES.119.005598 30950650
Malm, W; Cismoski, S; Prenni, A; Peters, M. (2018). Use of cameras for monitoring visibility impairment. Atmos Environ 175: 167–183. 10.1016/j.atmosenv.2017.12.005
Malm, W; Kelley, K; Molenar, J; Daniel, T. (1981). Human perception of visual air quality (uniform haze). Atmos Environ 15: 1875–1890.
Malm, WC. (2016). Visibility: The seeing of near and distant landscape features (First ed.). Amsterdam, the Netherlands: Elsevier. http://store.elsevier.com/Visibility/William-Malm/isbn-9780128044506/
Malm, WC; Schichtel, B; Molenar, J; Prenni, A; Peters, M. (2019). Which visibility indicators best represent a population’s preference for a level of visual air quality? J Air Waste Manag Assoc 69: 145–161. 10.1080/10962247.2018.1506370 30067459
Malm, WC; Sisler, JF; Huffman, D; Eldred, RA; Cahill, TA. (1994). Spatial and seasonal trends in particle concentration and optical extinction in the United States. J Geophys Res 99: 1347–1370. 10.1029/93JD02916
McClure, LA; Loop, MS; Crosson, W; Kleindorfer, D; Kissela, B; Al-Hamdan, M. (2017). Fine particulate matter (pm2.5) and the risk of stroke in the REGARDS cohort. J Stroke Cerebrovasc Dis 26: 1739–1744. 10.1016/j.jstrokecerebrovasdis.2017.03.041 28456465
Mendy, A; Wu, X; Keller, JL; Fassler, CS; Apewokin, S; Mersha, TB; Xie, C; Pinney, SM. (2021). Long-term exposure to fine particulate matter and hospitalization in COVID-19 patients. Respir Med 178: 106313. 10.1016/j.rmed.2021.106313 33550152
Meng, J; Li, C; Martin, RV; van Donkelaar, A; Hystad, P; Brauer, M. (2019). Estimated Long-Term (1981-2016) Concentrations of Ambient Fine Particulate Matter across North America from Chemical Transport Modeling, Satellite Remote Sensing, and Ground-Based Measurements. Environ Sci Technol 53: 5071–5079. 10.1021/acs.est.8b06875 30995030
Mikati, I; Benson, AF; Luben, TJ; Sacks, JD; Richmond-Bryant, J. (2018). Disparities in distribution of particulate matter emission sources by race and poverty status. Am J Public Health 2018: e1–e6. 10.2105/AJPH.2017.304297
Miller, KA; Siscovick, DS; Sheppard, L; Shepherd, K; Sullivan, JH; Anderson, GL; Kaufman, JD. (2007). Longterm exposure to air pollution and incidence of cardiovascular events in women. N Engl J Med 356: 447–458. 10.1056/NEJMoa054409 17267905
NAPCA (National Air Pollution Control Administration). (1969). Air quality criteria for particulate matter. Washington, DC.
Nasari, MM; Szyszkowicz, M; Chen, H; Crouse, D; Turner, MC; Jerrett, M; Pope, CA; Hubbell, B; Fann, N; Cohen, A; Gapstur, SM; Diver, WR; Stieb, D; Forouzanfar, MH; Kim, SY; Olives, C; Krewski, D; Burnett, RT. (2016). A class of non-linear exposure-response models suitable for health impact assessment applicable to large cohort studies of ambient air pollution. Air Qual Atmos Health 9: 961–972. 10.1007/s11869-016-0398-z 27867428
NHLBI (National Institutes of Health, National Heart Lung and Blood Institute). (2017). NHLBI fact book, fiscal year 2012: Disease statistics. Available online at https://web.archive.org/web/20170711012213/http://www.nhlbi.nih.gov/about/documents/factbook/2012/chapter4 (accessed August 23, 2017).
NYC (City of New York). (2022). COVID-19 Data. Trends and totals. Available online at https://www1.nyc.gov/site/doh/covid/covid-19-data-totals.page
Ostro, B; Malig, B; Broadwin, R; Basu, R; Gold, EB; Bromberger, JT; Derby, C; Feinstein, S; Greendale, GA; Jackson, EA; Kravitz, HM; Matthews, KA; Sternfeld, B; Tomey, K; Green, RR; Green, R. (2014). Chronic PM2.5 exposure and inflammation: Determining sensitive subgroups in mid-life women. Environ Res 132: 168–175. 10.1016/j.envres.2014.03.042 24792413
Pappin, AJ; Christidis, T; Pinault, LL; Crouse, DL; Brook, JR; Erickson, A; Hystad, P; Li, C; Martin, RV; Meng, J; Weichenthal, S; van Donkelaar, A; Tjepkema, M; Brauer, M; Burnett, RT. (2019). Examining the Shape of the Association between Low Levels of Fine Particulate Matter and Mortality across Three Cycles of the Canadian Census Health and Environment Cohort. Environ Health Perspect 127: 107008. 10.1289/EHP5204 31638837
Parker, JD; Kravets, N; Vaidyanathan, A. (2018). Particulate matter air pollution exposure and heart disease mortality risks by race and ethnicity in the United States: 1997-2009 NHIS with mortality followup through 2011. Circulation 137: 1688–1697. 10.1161/CIRCULATIONAHA.117.029376 29237717
Pascal, M; Falq, G; Wagner, V; Chatignoux, E; Corso, M; Blanchard, M; Host, S; Pascal, L; Larrieu, S. (2014). Short-term impacts of particulate matter (PM10, PM10-2.5, PM2.5) on mortality in nine French cities. Atmos Environ 95: 175–184. 10.1016/j.atmosenv.2014.06.030
Peterson, GCL; Hogrefe, C; Corrigan, AE; Neas, LM; Mathur, R; Rappold, AG. (2020). Impact of Reductions in Emissions from Major Source Sectors on Fine Particulate Matter-Related Cardiovascular Mortality. Environ Health Perspect 128: 17005. 10.1289/EHP5692 31909652
Pinault, L; Brauer, M; Crouse, DL; Weichenthal, S; Erickson, A; van Donkelaar, A; Martin, RV; Charbonneau, S; Hystad, P; Brook, JR; Tjepkema, M; Christidis, T; Ménard, R; Robichaud, A; Burnett, RT. (2018). Diabetes status and susceptibility to the effects of pm2.5 exposure on cardiovascular mortality in a national Canadian cohort. Epidemiology 29: 784–794. 10.1097/EDE.0000000000000908 30074537
Pinault, L; Tjepkema, M; Crouse, DL; Weichenthal, S; van Donkelaar, A; Martin, RV; Brauer, M; Chen, H; Burnett, RT. (2016). Risk estimates of mortality attributed to low concentrations of ambient fine particulate matter in the Canadian community health survey cohort. Environ Health 15: 18. 10.1186/s12940-016-0111-6 26864652
Pinault, LL; Weichenthal, S; Crouse, DL; Brauer, M; Erickson, A; Donkelaar, AV; Martin, RV; Hystad, P; Chen, H; Finès, P; Brook, JR; Tjepkema, M; Burnett, RT. (2017). Associations between fine particulate matter and mortality in the 2001 Canadian Census Health and Environment Cohort. Environ Res 159: 406–415. 10.1016/j.envres.2017.08.037 28850858
Pitchford, M; Maim, W; Schichtel, B; Kumar, N; Lowenthal, D; Hand, J. (2007). Revised algorithm for estimating light extinction from IMPROVE particle speciation data. J Air Waste Manag Assoc 57: 1326–1336.18069456
Pope, CA, III; Thun, MJ; Namboodiri, MM; Dockery, DW; Evans, JS; Speizer, FE; Heath, CW, Jr. (1995). Particulate air pollution as a predictor of mortality in a prospective study of U.S. adults. Am J Respir Crit Care Med 151: 669–674. 10.1164/ajrccm/151.3_Pt_1.669 7881654
Pope, CA; Lefler, JS; Ezzati, M; Higbee, JD; Marshall, JD; Kim, SY; Bechle, M; Gilliat, KS; Vernon, SE; Robinson, AL; Burnett, RT. (2019). Mortality Risk and Fine Particulate Air Pollution in a Large, Representative Cohort of U.S. Adults. Environ Health Perspect 127: 77007. 10.1289/EHP4438 31339350
Pope, CA; Turner, MC; Burnett, R; Jerrett, M; Gapstur, SM; Diver, WR; Krewski, D; Brook, RD. (2014). Relationships between fine particulate air pollution, cardiometabolic disorders and cardiovascular mortality. Circ Res 116: 108–U258. 10.1161/CIRCRESAHA.116.305060 25348167
Prenni, AJ; Hand, JL; Malm, WC; Copeland, S; Luo, G; Yu, F; Taylor, N; Russell, LM; Schichtel, BA. (2019). An examination of the algorithm for estimating light extinction from IMPROVE particle speciation data. Atmos Environ 214. 10.1016/j.atmosenv.2019.116880
Pryor, SC. (1996). Assessing public perception of visibility for standard setting exercises. Atmos Environ 30: 2705–2716. 10.1016/1352-2310(95)00365-7
Prystowsky, EN; Benson, DW, Jr; Fuster, V; Hart, RG; Kay, GN; Myerburg, RJ; Naccarelli, GV; Wyse, DG. (1996). Management of patients with atrial fibrillation. A Statement for Healthcare Professionals. From the Subcommittee on Electrocardiography and Electrophysiology, American Heart Association. Circulation 93: 1262–1277.8653857
Pun, VC; Kazemiparkouhi, F; Manjourides, J; Suh, HH. (2017). Long-term PM2.5 exposures and respiratory, cancer and cardiovascular mortality in American older adults. Am J Epidemiol 186: 961–969. 10.1093/aje/kwx166 28541385
Qiu, X; Wei, Y; Wang, Y; Di, Q; Sofer, T; Awad, YA; Schwartz, J. (2020). Inverse probability weighted distributed lag effects of short-term exposure to PM2.5 and ozone on CVD hospitalizations in New England Medicare participants - Exploring the causal effects. Environ Res 182: 109095. 10.1016/j.envres.2019.109095 31927244
Rappazzo, KM; Joodi, G; Hoffman, SR; Pursell, IW; Mounsey, JP; Cascio, WE; Simpson, RJ. (2019). A case-crossover analysis of the relationship of air pollution with out-of-hospital sudden unexpected death in Wake County, North Carolina (2013-2015). Sci Total Environ 694: 133744. 10.1016/j.scitotenv.2019.133744 31756798
Rhinehart, ZJ; Kinnee, E; Essien, UR; Saul, M; Guhl, E; Clougherty, JE; Magnani, JW. (2020). Association of fine particulate matter and risk of stroke in patients with atrial fibrillation. JAMA Netw Open 3: e2011760. 10.1001/jamanetworkopen.2020.11760 32930777
Richmond-Bryant, J; Mikati, I; Benson, AF; Luben, TJ; Sacks, JD. (2020). Disparities in distribution of particulate matter emissions from US coal-fired power plants by race and poverty status after accounting for reductions in operations between 2015 and 2017. Am J Public Health 110: 655–661. 10.2105/AJPH.2019.305558 32191524
Rosofsky, A; Levy, JI; Zanobetti, A; Janulewicz, P; Fabian, MP. (2018). Temporal trends in air pollution exposure inequality in Massachusetts. Environ Res 161: 76–86. 10.1016/j.envres.2017.10.028 29101831
Roy, D; Talajic, M; Dubuc, M; Thibault, B; Guerra, P; Macle, L; Khairy, P. (2009). Atrial fibrillation and congestive heart failure. Curr Opin Cardiol 24: 29.19102036
Samoli, E; Stafoggia, M; Rodopoulou, S; Ostro, B; Declercq, C; Alessandrini, E; Díaz, J; Karanasiou, A; Kelessis, AG; Le Tertre, A; Pandolfi, P; Randi, G; Scarinzi, C; Zauli-Sajani, S; Katsouyanni, K; Forastiere, F. (2013). Associations between fine and coarse particles and mortality in Mediterranean cities: Results from the MED-PARTICLES Project. Environ Health Perspect 121: 932–938. 10.1289/ehp.1206124 23687008
Sanders, NJ; Barreca, AI; Neidell, MJ. (2020). Estimating causal effects of particulate matter regulation on mortality. Epidemiology 31: 160–167. 10.1097/EDE.0000000000001153 31834013
Schulz, AJ; Mentz, GB; Sampson, N; Ward, M; Dvonch, JT; De Majo, R; Israel, BA; Reyes, AG; Wilkins, D. (2018). Independent and joint contributions of fine particulate matter exposure and population vulnerability to mortality in the detroit metropolitan area. Int J Environ Res Public Health 15: 1209. 10.3390/ijerph15061209 29890666
Schwartz, J; Coull, B; Laden, F; Ryan, L. (2008). The effect of dose and timing of dose on the association between airborne particles and survival. Environ Health Perspect 116: 64–69. 10.1289/ehp.9955 18197301
Schwartz, J; Fong, K; Zanobetti, A. (2018a). A National Multicity Analysis of the Causal Effect of Local Pollution, [Formula: see text], and [Formula: see text] on Mortality. Environ Health Perspect 126: 87004. 10.1289/EHP2732 30235421
Schwartz, J; Wei, Y; Yitshak-Sade, M; Di, Q; Dominici, F; Zanobetti, A. (2021). A national difference in differences analysis of the effect of PM2.5 on annual death rates. Environ Res 194: 110649. 10.1016/j.envres.2020.110649 33385394
Schwartz, JD; Wang, Y; Kloog, I; Yitshak-Sade, M; Dominici, F; Zanobetti, A. (2018b). Estimating the Effects of PM2.5 on Life Expectancy Using Causal Modeling Methods. Environ Health Perspect 126: 127002. 10.1289/EHP3130 30675798
Shi, L; Zanobetti, A; Kloog, I; Coull, BA; Koutrakis, P; Melly, SJ; Schwartz, JD. (2015). Low-concentration PM2.5 and mortality: estimating acute and chronic effects in a population-based study. Environ Health Perspect 124: 46–52. 10.1289/ehp.1409111 26038801
Shin, HH; Cakmak, S; Brion, O; Villeneuve, P; Turner, MC; Goldberg, MS; Jerrett, M; Chen, H; Crouse, D; Peters, P; Pope, CA; Burnett, RT. (2014). Indirect adjustment for multiple missing variables applicable to environmental epidemiology. Environ Res 134: 482–487. 10.1016/j.envres.2014.05.016 24972508
Shin, HH; Gogna, P; Maquiling, A; Parajuli, RP; Haque, L; Burr, B. (2021a). Comparison of hospitalization and mortality associated with short-term exposure to ambient ozone and PM2.5 in Canada. Chemosphere 265: 128683. 10.1016/j.chemosphere.2020.128683 33158503
Shin, HH; Parajuli, RP; Gogna, P; Maquiling, A; Dehghani, P. (2021b). Pollutant-sex specific differences in respiratory hospitalization and mortality risk attributable to short-term exposure to ambient air pollution. Sci Total Environ 755: 143135. 10.1016/j.scitotenv.2020.143135 33168238
Shin, S; Burnett, RT; Kwong, JC; Hystad, P; van Donkelaar, A; Brook, J. R.; Goldberg, MS; Tu, K; Copes, R; Martin, R; Lia, Y; Kopp, A; Chen, H. (2019). Ambient Air Pollution and the Risk of Atrial Fibrillation and Stroke: A Population-Based Cohort Study. Environ Health Perspect 127: 87009. 10.1289/EHP4883 31449466
Son, JY; Lane, KJ; Miranda, ML; Bell, ML. (2020). Health disparities attributable to air pollutant exposure in North Carolina: Influence of residential environmental and social factors. Health Place 62: 102287. 10.1016/j.healthplace.2020.102287 32479364
Stieb, DM; Evans, GJ; To, TM; Brook, JR; Burnett, RT. (2020). An ecological analysis of long-term exposure to PM2.5 and incidence of COVID-19 in Canadian health regions. Environ Res 191: 110052. 10.1016/j.envres.2020.110052 32860780
Sun, S; Stewart, JD; Eliot, MN; Yanosky, JD; Liao, D; Tinker, LF; Eaton, CB; Whitsel, EA; Wellenius, GA. (2019). Short-term exposure to air pollution and incidence of stroke in the Women’s Health Initiative. Environ Int 132: 105065. 10.1016/j.envint.2019.105065 31382185
Tanzer, R; Malings, C; Hauryliuk, A; Subramanian, R; Presto, AA. (2019). Demonstration of a low-cost multi-pollutant network to quantify intra-urban spatial variations in air pollutant source impacts and to evaluate environmental justice. Int J Environ Res Public Health 16: 2523. 10.3390/ijerph16142523 31311099
Tessum, CW; Apte, JS; Goodkind, AL; Muller, NZ; Mullins, KA; Paolella, DA; Polasky, S; Springer, NP; Thakrar, SK; Marshall, JD; Hill, JD. (2019). Inequity in consumption of goods and services adds to racial-ethnic disparities in air pollution exposure. Proc Natl Acad Sci USA 116: 6001–6006. 10.1073/pnas.1818859116 30858319
Tessum, CW; Paolella, DA; Chambliss, SE; Apte, JS; Hill, JD; Marshall, JD. (2021). PM2.5 polluters disproportionately and systemically affect people of color in the United States. Science Advances 7. 10.1126/sciadv.abf4491
Tonne, C; Halonen, JI; Beevers, SD; Dajnak, D; Gulliver, J; Kelly, FJ; Wilkinson, P; Anderson, HR. (2015). Long-term traffic air and noise pollution in relation to mortality and hospital readmission among myocardial infarction survivors. Int J Hyg Environ Health 219: 72–78. 10.1016/j.ijheh.2015.09.003 26454658
U.S. EPA (U.S. Environmental Protection Agency). (1982). Air quality criteria for particulate matter and sulfur oxides (final, 1982) [EPA Report]. (EPA 600/8-82/029a). Washington, DC: Environmental Criteria and Assessment Office. http://cfpub.epa.gov/ncea/cfm/recordisplay.cfm?deid=46205
U.S. EPA (U.S. Environmental Protection Agency). (1996). Air quality criteria for particulate matter [EPA Report]. (EPA/600/P-95/001aF-cF. 3v). Research Triangle Park, National Center for Environmental Assessment-RTP Office NC.
U.S. EPA (U.S. Environmental Protection Agency). (2004). Air quality criteria for particulate matter (Final report, 2004) [EPA Report]. (EPA 600/P-99/002aF-bF). Washington, DC. http://cfpub.epa.gov/ncea/cfm/recordisplay.cfm?deid=87903
U.S. EPA (U.S. Environmental Protection Agency). (2009). Integrated science assessment (ISA) for particulate matter (Final report, Dec 2009) [EPA Report]. (EPA/600/R-08/139F). Washington, DC. http://cfpub.epa.gov/ncea/cfm/recordisplay.cfm?deid=216546
U.S. EPA (U.S. Environmental Protection Agency). (2011). Policy assessment for the review of the particulate matter national ambient air quality standards [EPA Report]. (EPA 452/R-11-003). Research Triangle Park, NC. http://nepis.epa.gov/exe/ZyPURL.cgi?Dockey=P100AUMY.txt
U.S. EPA (U.S. Environmental Protection Agency). (2013). Integrated science assessment for ozone and related photochemical oxidants [EPA Report]. (EPA/600/R-10/076F). Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Research and Development, National Center for Environmental Assessment-RTP Division. http://cfpub.epa.gov/ncea/isa/recordisplay.cfm?deid=247492
U.S. EPA (U.S. Environmental Protection Agency). (2015). Preamble to the integrated science assessments [EPA Report]. (EPA/600/R-15/067). Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Research and Development, National Center for Environmental Assessment, RTP Division. https://cfpub.epa.gov/ncea/isa/recordisplay.cfm?deid=310244
U.S. EPA (U.S. Environmental Protection Agency). (2016). Integrated review plan for the national ambient air quality standards for particulate matter [EPA Report]. (EPA-452/R-16-005). Research Triangle Park, NC. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=P100R5VE.txt
U.S. EPA (U.S. Environmental Protection Agency). (2018). Supplemental material: Chapter 6 (Cardiovascular Effects) Integrated Science Assessment for Particulate Matter.
U.S. EPA (U.S. Environmental Protection Agency). (2019). Integrated Science Assessment (ISA) for particulate matter (final report, Dec 2019) [EPA Report]. (EPA/600/R-19/188). Washington, DC. https://cfpub.epa.gov/ncea/isa/recordisplay.cfm?deid=347534
U.S. EPA (U.S. Environmental Protection Agency). (2020a). Integrated science assessment for oxides of nitrogen, oxides of sulfur, and particulate matter―ecological criteria (final). (EPA/600/R-20/278). Research Triangle Park, NC. https://cfpub.epa.gov/ncea/isa/recordisplay.cfm?deid=349473
U.S. EPA (U.S. Environmental Protection Agency). (2020b). Policy assessment for the review of the National Ambient Air Quality Standards for particulate matter. (EPA-452/R-20-002). Research Triangle Park, NC.
U.S. EPA (U.S. Environmental Protection Agency). (2020c). Responses to significant comments on the 2020 proposed rule on the National Ambient Air Quality Standards for particulate matter (April 30, 2020; 85 FR 24094). (EPA-HQ-OAR-2015-0072). https://www.epa.gov/sites/production/files/2020-12/documents/pm_naaqs_response_to_comments_final.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2021). Michael Regan administrator message to EPA employees on commitment to environmental justice, April 07, 2021. Available online
U.S. EPA (U.S. Environmental Protection Agency). (2022). Policy assessment for the reconsideration of the National Ambient Air Quality Standards for particulate matter [EPA Report]. (EPA-452/R-22-004). Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Air Quality Planning and Standards, Health and Environmental Impacts Division. https://www.epa.gov/naaqs/particulate-matter-pm-standards-policy-assessments-current-review-0
Ueda, K; Nitta, H; Ono, M; Takeuchi, A. (2009). Estimating mortality effects of fine particulate matter in Japan: A comparison of time-series and case-crossover analyses. J Air Waste Manag Assoc 59: 1212–1218. 10.3155/1047-3289.59.10.1212 19842328
USAFacts. (2022). US COVID-19 cases and deaths by state. Available online at https://usafacts.org/visualizations/coronavirus-covid-19-spread-map/ (accessed April 14, 2022).
van Donkelaar, A; Martin, RV; Brauer, M; Kahn, R; Levy, R; Verduzco, C; Villeneuve, PJ. (2010). Global estimates of ambient fine particulate matter concentrations from satellite-based aerosol optical depth: development and application. Environ Health Perspect 118: 847–855. 10.1289/ehp.0901623 20519161
van Donkelaar, A; Martin, RV; Li, C; Burnett, RT. (2019). Regional estimates of chemical composition of fine particulate matter using a combined geoscience-statistical method with information from satellites, models, and monitors. Environ Sci Technol 53: 2595–2611. 10.1021/acs.est.8b06392 30698001
van Donkelaar, A; Martin, RV; Spurr, RJ; Burnett, RT. (2015). High-resolution satellite-derived PM2.5 from optimal estimation and geographically weighted regression over North America. Environ Sci Technol 49: 10482–10491. 10.1021/acs.est.5b02076 26261937
Villeneuve, PJ; Goldberg, MS. (2020). Methodological Considerations for Epidemiological Studies of Air Pollution and the SARS and COVID-19 Coronavirus Outbreaks [Review]. Environ Health Perspect 128: 95001. 10.1289/EHP7411 32902328
Wang, B; Eum, KD; Kazemiparkouhi, F; Li, C; Manjourides, J; Pavlu, V; Suh, H. (2020). The impact of long-term PM2.5 exposure on specific causes of death: exposure-response curves and effect modification among 53 million U.S. Medicare beneficiaries. Environ Health 19: 20. 10.1186/s12940-020-00575-0 32066433
Wang, M; Hopke, PK; Masiol, M; Thurston, SW; Cameron, S; Ling, F; van Wijngaarden, E; Croft, D; Squizzato, S; Thevenet-Morrison, K; Chalupa, D; Rich, DQ. (2019). Changes in triggering of ST-elevation myocardial infarction by particulate air pollution in Monroe County, New York over time: a case-crossover study. Environ Health 18: 82. 10.1186/s12940-019-0521-3 31492149
Ward-Caviness, CK; Weaver, AM; Buranosky, M; Pfaff, ER; Neas, LM; Devlin, RB; Schwartz, J; Di, Q; Cascio, WE; Diaz-Sanchez, D. (2020). Associations between long-term fine particulate matter exposure and mortality in heart failure patients. J Am Heart Assoc 9: e012517. 10.1161/JAHA.119.012517 32172639
Weaver, AM; Mcguinn, L; Neas, L; Mirowsky, J; Devlin, RB; Dhingra, R; Ward-Caviness, C; Cascio, WE; Kraus, WE; Hauser, ER; Di, Q; Schwartz, J; Diaz-Sanchez, D. (2019). Neighborhood sociodemographic effects on the associations between long-term PM2.5 exposure and cardiovascular outcomes and diabetes. Environmental Epidemiology 3. 10.1097/EE9.0000000000000038
Weaver, AM; Wang, Y; Wellenius, GA; Bidulescu, A; Sims, M; Vaidyanathan, A; Hickson, DA; Shimbo, D; Abdalla, M; Diaz, KM; Seals, SR. (2021). Long-term air pollution and blood pressure in an African American cohort: The Jackson Heart Study. Am J Prev Med 60: 397–405. 10.1016/j.amepre.2020.10.023 33478866
Wei, Y; Wang, Y; Di, Q; Choirat, C; Wang, Y; Koutrakis, P; Zanobetti, A; Dominici, F; Schwartz, JD. (2019). Short term exposure to fine particulate matter and hospital admission risks and costs in the Medicare population: time stratified, case crossover study. BMJ 367: l6258. 10.1136/bmj.l6258 31776122
Wei, Y; Wang, Y; Wu, X; Di, Q; Shi, L; Koutrakis, P; Zanobetti, A; Dominici, F; Schwartz, JD. (2020). Causal effects of air pollution on mortality in Massachusetts. Am J Epidemiol 189: 1316–1323. 10.1093/aje/kwaa098 32558888
Wei, Y; Yazdi, MD; Di, Q; Requia, WJ; Dominici, F; Zanobetti, A; Schwartz, J. (2021a). Emulating causal dose-response relations between air pollutants and mortality in the Medicare population. Environ Health 20: 53. 10.1186/s12940-021-00742-x 33957920
Wei, YG; Coull, B; Koutrakis, P; Yang, JB; Li, LX; Zanobetti, A; Schwartz, J. (2021b). Assessing additive effects of air pollutants on mortality rate in Massachusetts. Environ Health 20: 19. 10.1186/s12940-021-00704-3 33622353
WHO (World Health Organization). (1989). Recommendations on stroke prevention, diagnosis, and therapy. Report of the WHO task force on stroke and other cerebrovascular disorders [Editorial]. Stroke 20: 1407–1431. 10.1161/01.STR.20.10.1407 2799873
Wing, JJ; Adar, SD; Sánchez, BN; Morgenstern, LB; Smith, MA; Lisabeth, LD. (2017). Short-term exposures to ambient air pollution and risk of recurrent ischemic stroke. Environ Res 152: 304–307. 10.1016/j.envres.2016.11.001 27829205
Wu, X; Braun, D; Kioumourtzoglou, MA; Choirat, C; Di, Q; Dominici, F. (2019). Causal inference in the context of an error prone exposure: Air pollution and mortality. Ann Appl Stat 13: 520–547. 10.1214/18-AOAS1206 31649797
Wu, X; Braun, D; Schwartz, J; Kioumourtzoglou, MA; Dominici, F. (2020a). Evaluating the impact of long-term exposure to fine particulate matter on mortality among the elderly. Science Advances 6: eaba5692. 10.1126/sciadv.aba5692 32832626
Wu, X; Netherly, RC; Sabath, MB; Braun, D; Dominici, F. (2020b). Air pollution and COVID-19 mortality in the United States: Strengths and limitations of an ecological regression analysis. Science Advances 6: eabd4049. 10.1126/sciadv.abd4049 33148655
Wyatt, LH; Devlin, RB; Rappold, A; Case, MW; Diaz-Sanchez, D. (2020a). Low levels of fine particulate matter increase vascular damage and reduce pulmonary function in young healthy adults. Part Fibre Toxicol 17: 58. 10.1186/s12989-020-00389-5 33198760
Wyatt, LH; Peterson, GCL; Wade, TJ; Neas, LM; Rappold, AG. (2020b). The contribution of improved air quality to reduced cardiovascular mortality: Declines in socioeconomic differences over time. Environ Int 136: 105430. 10.1016/j.envint.2019.105430 31884412
Wyatt, LH; Xi, YZ; Kshirsagar, A; Di, Q; Ward-Caviness, C; Wade, TJ; Cascio, WE; Rappold, AG. (2020c). Association of short-term exposure to ambient PM2.5 with hospital admissions and 30-day readmissions in end-stage renal disease patients: population-based retrospective cohort study. BMJ Open 10: e041177. 10.1136/bmjopen-2020-041177
Yanosky, JD; Paciorek, CJ; Laden, F; Hart, JE; Puett, RC; Liao, D; Suh, HH. (2014a). Spatio-temporal modeling of particulate air pollution in the conterminous United States using geographic and meteorological predictors. Environ Health 13: 63. 10.1186/1476-069X-13-63 25097007
Yanosky, JD; Paciorek, CJ; Laden, F; Hart, JE; Puett, RC; Liao, D; Suh, HH. (2014b). Spatio-temporal modeling of particulate air pollution in the conterminous United States using geographic and meteorological predictors - Supplementary material [Supplemental Data]. Environ Health 13.
Ye, D; Klein, M; Mulholland, JA; Russell, AG; Weber, R; Edgerton, ES; Chang, HH; Sarnat, JA; Tolbert, PE; Ebelt Sarnat, S. (2018). Estimating Acute Cardiovascular Effects of Ambient PM2.5 Metals. Environ Health Perspect 126: 027007. 10.1289/EHP2182 29467104
Yitshak-Sade, M; James, P; Kloog, I; Hart, JE; Schwartz, JD; Laden, F; Lane, KJ; Fabian, MP; Fong, KC; Zanobetti, A. (2019a). Neighborhood Greenness Attenuates the Adverse Effect of PM2.5 on Cardiovascular Mortality in Neighborhoods of Lower Socioeconomic Status. Int J Environ Res Public Health 16. 10.3390/ijerph16050814
Yitshak-Sade, M; Kloog, I; Zanobetti, A; Schwartz, JD. (2019b). Estimating the causal effect of annual PM2.5 exposure on mortality rates in the Northeastern and mid-Atlantic states. Environmental Epidemiology 3: e052. 10.1097/EE9.0000000000000052 31538134
Yitshak-Sade, M; Lane, KJ; Fabian, MP; Kloog, I; Hart, JE; Davis, B; Fong, KC; Schwartz, JD; Laden, F; Zanobetti, A. (2020). Race or racial segregation? Modification of the PM2.5 and cardiovascular mortality association. PLoS ONE 15: e0236479. 10.1371/journal.pone.0236479 32716950
Young, SS; Smith, RL; Lopiano, KK. (2017). Air quality and acute deaths in California, 2000-2012. Regul Toxicol Pharmacol 88: 173–184. 10.1016/j.yrtph.2017.06.003 28619682
Zanobetti, A; Dominici, F; Wang, Y; Schwartz, JD. (2014). A national case-crossover analysis of the short-term effect of PM2.5 on hospitalizations and mortality in subjects with diabetes and neurological disorders. Environ Health 13: 38. 10.1186/1476-069X-13-38 24886318
Zanobetti, A; Schwartz, J. (2009). The effect of fine and coarse particulate air pollution on mortality: A national analysis. Environ Health Perspect 117: 1–40. 10.1289/ehp.0800108 19165380
Zhang, W; Lin, S; Hopke, PK; Thurston, SW; van Wijngaarden, E; Croft, D; Squizzato, S; Masiol, M; Rich, DQ. (2018). Triggering of cardiovascular hospital admissions by fine particle concentrations in New York state: Before, during, and after implementation of multiple environmental policies and a recession. Environ Pollut 242: 1404–1416. 10.1016/j.envpol.2018.08.030 30142556
Zhang, Z; Wang, J; Kwong, JC; Burnett, RT; van Donkelaar, A; Hystad, P; Martin, RV; Bai, L; McLaughlin, J; Chen, H. (2021). Long-term exposure to air pollution and mortality in a prospective cohort: The Ontario Health Study. Environ Int 154: 106570. 10.1016/j.envint.2021.106570 33892223
Zigler, CM; Choirat, C; Dominici, F. (2018). Impact of National Ambient Air Quality Standards nonattainment designations on particulate pollution and health. Epidemiology 29: 165–174. 10.1097/EDE.0000000000000777 29095246