# EXECUTIVE SUMMARY

In June 2021, the U.S. Environmental Protection Agency (EPA) announced it will reconsider the December 2020 decision to retain the particulate matter (PM) National Ambient Air Quality Standards (NAAQS). As part of the reconsideration process, EPA indicated that it would develop a supplement to the 2019 Integrated Science Assessment for PM (2019 PM ISA) to thoroughly evaluate the most up-to-date science that became available after the literature cutoff date of the 2019 PM ISA that could either further inform the adequacy of the current PM NAAQS or address key scientific topics that have evolved since the 2020 PM NAAQS review was completed.

Within this Supplement, EPA presents an evaluation of recent studies (i.e., published since the literature cutoff date of the 2019 PM ISA) that potentially are of greatest relevance to the reconsideration of the PM NAAQS in the context of the findings of the 2019 PM ISA. The studies that formed the basis of the evaluation consist of U.S. and Canadian studies, specifically: (a) epidemiologic studies for health effect categories for which the 2019 PM ISA concluded a causal relationship (i.e., short- and long-term PM_2.5_ exposure^1^ and cardiovascular effects and mortality); (b) epidemiologic studies that employed statistical approaches that attempt to more extensively account for confounders and are more robust to model misspecification (i.e., used alternative methods for confounder control)^2^ or conducted accountability analyses; (c) studies that address key scientific topics that have evolved since the literature cutoff date for the 2019 PM ISA, including experimental studies conducted at near-ambient PM_2.5_ concentrations, epidemiologic studies that examined the association between PM_2.5_ exposure and severe acute respiratory syndrome coronavirus 2 (SARS-CoV-2) infection and coronavirus disease 2019 (COVID-19) death, and epidemiologic or exposure studies that examined disparities in PM_2.5_ exposure or health risks by race and ethnicity or socioeconomic status; and (d) studies that examined public preferences for visibility impairment and/or developed methodologies or conducted quantitative analyses of light extinction. This Supplement to the 2019 PM ISA does not represent a full multidisciplinary evaluation of evidence that results in the formation of weight-of-evidence conclusions (i.e., causality determinations), but instead puts the results of recent studies that encompass specific criteria in the context of the scientific conclusions presented within the 2019 PM ISA. As such, the Supplement indicates whether recent evidence supports (is consistent with), supports and extends (is consistent with and reduces uncertainties), or does not support (is not consistent with) the causality determinations detailed in the 2019 PM ISA for the health effects categories evaluated within this Supplement.

This Supplement to the 2019 PM ISA finds that recent studies further support, and in some instances extend, the evidence that formed the basis of the causality determinations presented within the 2019 PM ISA that characterizes relationships between PM exposure and health (i.e., cardiovascular effects and mortality) and welfare effects (i.e., visibility impairment). In brief, this Supplement finds the following:

- Recent U.S. and Canadian epidemiologic studies examining short- and long-term PM_2.5_ exposure and cardiovascular effects and mortality provide evidence that further supports, and in some instances extends, the evidence that contributed to the conclusion of a causal relationship detailed in the 2019 PM ISA. Relative to the studies evaluated in the 2019 PM ISA, many of the studies report positive associations at lower PM_2.5_ concentrations (i.e., annual PM_2.5_ concentrations ranging from 5.9 to 16.5 micrograms per cubic meter (µg/m^3^); mean 24-hour avg PM_2.5_ concentrations ranging from 7.1 to 15.4 µg/m^3^).
  ○ Recent U.S. and Canadian epidemiologic studies examining short- and long-term PM_2.5_ exposure and cardiovascular effects provide evidence that is consistent with the studies evaluated in the 2019 PM ISA. Studies examining short-term PM_2.5_ exposure report consistent positive associations for cardiovascular-related emergency department (ED) visits and hospital admissions, specifically for ischemic heart disease (IHD), myocardial infarction (MI), and heart failure (HF). For long-term exposure, strong evidence remains for cardiovascular-related mortality with support from studies of cardiovascular morbidity outcomes including coronary heart disease (CHD), stroke, and atherosclerosis progression, among individuals with preexisting diseases or patients followed after a cardiac event or procedure. Associations persisted across studies conducted in different geographic locations, populations with diverse demographic characteristics, and study designs (i.e., different exposure assessment methods, and confounder control).
  ○ Relatively few recent U.S. and Canadian epidemiologic studies examined short-term PM_2.5_ exposure and mortality; however, these studies continue to provide evidence of positive associations with both all-cause and total (nonaccidental) mortality as well as with cause-specific mortality outcomes.
  ○ A number of recent long-term PM_2.5_ exposure and mortality studies conducted in cohorts consisting of populations with diverse demographic characteristics and encompassing large geographic areas report consistent, positive associations, with most reporting mean annual PM_2.5_ concentrations ranging from 5.9 to 11.65 µg/m^3^.
    ■ Across epidemiologic studies examining both cardiovascular effects and mortality, sensitivity analyses as well as individual studies further inform uncertainties in the evidence base (i.e., copollutant confounding, control for confounders such as temporal trends and temperature, and the concentration-response [C-R] relationship). Such analyses increase confidence in the relationship for both short- and long-term PM_2.5_ exposures and both health effect categories, and further support the causality determinations presented in the 2019 PM ISA.
    ■ Since the completion of the 2019 PM ISA, numerous U.S. and Canadian epidemiologic studies conducted accountability analyses or employed statistical approaches that attempt to account more extensively for confounders and are more robust to model misspecification (i.e., used alternative methods for confounder control) to examine both short- and long-term PM_2.5_ exposure and cardiovascular effects and mortality. These studies, which used a variety of statistical methods to control for confounding bias, consistently report positive associations, which further supports the broader body of epidemiologic evidence for both cardiovascular effects and mortality.
  ○ Several recent U.S. and Canadian studies provide additional insight on the health effects of PM_2.5_, including a recent controlled human exposure study conducted at near-ambient concentrations, which provided initial evidence of both lung and cardiac function changes in young, healthy participants.
  ○ In response to the global COVID-19 pandemic, numerous studies provide initial assessments of short- and long-term PM_2.5_ exposure and SARS-CoV-2 infection and COVID-19 death. While some of these studies report initial evidence of positive associations, these studies are subject to methodological limitations and require additional exploration.
  ○ The 2019 PM ISA provided evidence that specific lifestages and populations are at increased risk of a PM_2.5_-related health effect. Recent U.S. and Canadian epidemiologic studies support and expand the evidence base within the 2019 PM ISA and indicate that there are both PM_2.5_ exposure and health risk disparities by race and ethnicity among minority populations, specifically Black populations. Additionally recent evidence supports the evidence presented in the 2019 PM ISA that there may be PM_2.5_ exposure and health risk disparities by socioeconomic status (SES), specifically among people of low SES.
- Recent studies continue to support a relationship between PM and visibility impairment and provide additional insights on the impact of choice of metric on preference study results, impacts of changing PM composition on the relationship between PM and visibility impairment, and alternative approaches to estimating light extinction.

1 Consistent with the scope of the 2019 PM ISA (Section P.3.1), short-term exposures are defined as those exposures occurring over hours up to 1 month, while long-term exposures are defined as those exposures occurring over 1 month to years.

2 In the peer-reviewed literature, these epidemiologic studies are often referred to as causal inference studies or studies that used causal modeling methods. For the purposes of this Supplement this terminology is not used to prevent confusion with the main scientific conclusions (i.e., the causality determinations) presented within an ISA. In addition, as is consistent with the weight-of-evidence framework used within ISAs and discussed in the Preamble to the Integrated Science Assessments, an individual study on its own cannot provide the evidence needed to make a causality determination, but instead represents a piece of the overall body of evidence.