# INTEGRATED SCIENCE ASSESSMENT TEAM FOR PARTICULATE MATTER

## Executive Direction

- Dr. Steven J. Dutton (Division Director)―Center for Public Health and Environmental Assessment, Office of Research and Development, U.S. Environmental Protection Agency, Research Triangle Park, NC
- Dr. Emily Snyder (Associate Division Director)―Center for Public Health and Environmental Assessment, Office of Research and Development, U.S. Environmental Protection Agency, Research Triangle Park, NC
- Dr. Jane Ellen Simmons (Branch Chief)―Center for Public Health and Environmental Assessment, Office of Research and Development, U.S. Environmental Protection Agency, Research Triangle Park, NC
- Dr. Christopher Weaver (Branch Chief)―Center for Public Health and Environmental Assessment, Office of Research and Development, U.S. Environmental Protection Agency, Research Triangle Park, NC

## Authors

- Mr. Jason Sacks (Assessment Lead, Integrated Science Assessment for Particulate Matter)―Center for Public Health and Environmental Assessment, Office of Research and Development, U.S. Environmental Protection Agency, Research Triangle Park, NC
- Dr. Barbara Buckley (Retired)―Center for Public Health and Environmental Assessment, Office of Research and Development, U.S. Environmental Protection Agency, Research Triangle Park, NC
- Dr. Stephanie Deflorio-Barker―Center for Public Health and Environmental Assessment, Office of Research and Development, U.S. Environmental Protection Agency, Research Triangle Park, NC
- Dr. Scott Jenkins―Center for Public Health and Environmental Assessment, Office of Research and Development, U.S. Environmental Protection Agency, Research Triangle Park, NC
- Dr. Ellen Kirrane―Center for Public Health and Environmental Assessment, Office of Research and Development, U.S. Environmental Protection Agency, Research Triangle Park, NC
- Dr. Alison Krajewski―Center for Public Health and Environmental Assessment, Office of Research and Development, U.S. Environmental Protection Agency, Research Triangle Park, NC
- Dr. Thomas Luben―Center for Public Health and Environmental Assessment, Office of Research and Development, U.S. Environmental Protection Agency, Research Triangle Park, NC
- Dr. Stephen McDow―Center for Public Health and Environmental Assessment, Office of Research and Development, U.S. Environmental Protection Agency, Research Triangle Park, NC
- Dr. Michael Stewart―Center for Public Health and Environmental Assessment, Office of Research and Development, U.S. Environmental Protection Agency, Research Triangle Park, NC

## Contributors

- Dr. Jean-Jacques Dubois―Center for Public Health and Environmental Assessment, Office of Research and Development, U.S. Environmental Protection Agency, Research Triangle Park, NC
- Mr. Kevin Park―Oak Ridge Associated Universities, Inc., Center for Public Health and Environmental Assessment, Office of Research and Development, U.S. Environmental Protection Agency, Research Triangle Park, NC
- Mr. R. Byron Rice―Center for Public Health and Environmental Assessment, Office of Research and Development, U.S. Environmental Protection Agency, Research Triangle Park, NC

## Management, Technical, and Quality Assurance (QA) Support Staff

- Ms. Christine Alvarez―Center for Public Health and Environmental Assessment, Office of Research and Development, U.S. Environmental Protection Agency, Research Triangle Park, NC
- Ms. Andrea Bartolotti―Center for Public Health and Environmental Assessment, Office of Research and Development, U.S. Environmental Protection Agency, Research Triangle Park, NC
- Ms. Marieka Boyd―Center for Public Health and Environmental Assessment, Office of Research and Development, U.S. Environmental Protection Agency, Research Triangle Park, NC
- Ms. Shannon Cassel―Oak Ridge Associated Universities, Inc., Center for Public Health and Environmental Assessment, Office of Research and Development, U.S. Environmental Protection Agency, Research Triangle Park, NC
- Ms. Cheryl Itkin―Center for Public Health and Environmental Assessment, Office of Research and Development, U.S. Environmental Protection Agency, Washington, DC
- Ms. Maureen Johnson―Center for Public Health and Environmental Assessment, Office of Research and Development, U.S. Environmental Protection Agency, Washington, DC
- Mr. Ryan Jones―Center for Public Health and Environmental Assessment, Office of Research and Development, U.S. Environmental Protection Agency, Research Triangle Park, NC
- Ms. Emma Leath―Oak Ridge Associated Universities, Inc., Center for Public Health and Environmental Assessment, Office of Research and Development, U.S. Environmental Protection Agency, Research Triangle Park, NC
- Mr. Kevin Park―Oak Ridge Associated Universities, Inc., Center for Public Health and Environmental Assessment, Office of Research and Development, U.S. Environmental Protection Agency, Research Triangle Park, NC
- Ms. Jenna Strawbridge―Oak Ridge Associated Universities, Inc., Center for Public Health and Environmental Assessment, Office of Research and Development, U.S. Environmental Protection Agency, Research Triangle Park, NC

## Reviewers

- Dr. Wayne Cascio―Center for Public Health and Environmental Assessment, Office of Research and Development, U.S. Environmental Protection Agency, Research Triangle Park, NC
- Dr. Elizabeth Chan―Office of Air Quality Planning and Standards, Office of Air and Radiation, U.S. Environmental Protection Agency, Research Triangle Park, NC
- Dr. Nicole Hagan―Office of Air Quality Planning and Standards, Office of Air and Radiation, U.S. Environmental Protection Agency, Research Triangle Park, NC
- Dr. Iman Hassan―Office of Air Quality Planning and Standards, Office of Air and Radiation, U.S. Environmental Protection Agency, Research Triangle Park, NC
- Dr. Archana Lamichhane―Office of Air Quality Planning and Standards, Office of Air and Radiation, U.S. Environmental Protection Agency, Research Triangle Park, NC
- Ms. Sheila Igoe―Office of General Counsel, U.S. Environmental Protection Agency, Washington, DC
- Dr. Anthony Jones―Office of Air Quality Planning and Standards, Office of Air and Radiation, U.S. Environmental Protection Agency, Research Triangle Park, NC
- Dr. Samantha Jones―Center for Public Health and Environmental Assessment, Office of Research and Development, U.S. Environmental Protection Agency, Research Triangle Park, NC
- Mr. David Orlin―Office of General Counsel, U.S. Environmental Protection Agency, Washington, DC
- Dr. Lars Perlmutt―Office of Air Quality Planning and Standards, Office of Air and Radiation, U.S. Environmental Protection Agency, Research Triangle Park, NC
- Dr. Erika Sasser―Office of Air Quality Planning and Standards, Office of Air and Radiation, U.S. Environmental Protection Agency, Research Triangle Park, NC
- Mr. Timothy Watkins―Center for Environmental Measurement and Modeling, Office of Research and Development, U.S. Environmental Protection Agency, Research Triangle Park, NC
- Dr. Karen Wesson―Office of Air Quality Planning and Standards, Office of Air and Radiation, U.S. Environmental Protection Agency, Research Triangle Park, NC