# 5 SUMMARY AND CONCLUSIONS

The 2019 Integrated Science Assessment for Particulate Matter (2019 PM ISA) is a comprehensive, systematic evaluation of the state of the science with respect to the health and welfare effects of PM that built upon previous assessments conducted in support of the National Ambient Air Quality Standards (NAAQS) for PM (U.S. EPA, 2019). While the 2019 PM ISA presented key scientific conclusions that informed many policy-relevant questions, as detailed in Section 2, a subset of these conclusions was most informative in the process of establishing the 2020 PM NAAQS (as discussed in Section 1.2), which is under reconsideration. Specifically, extensive evidence spanning scientific disciplines supported the conclusion of a causal relationship between both short- and long-term PM_2.5_ exposure and cardiovascular effects and mortality. In addition, an assessment of those populations potentially at increased risk of a PM-related health effect identified many populations and lifestages that experience both health risk and/or exposure disparities with some of the strongest evidence being for minority populations, with more limited evidence for people of low socioeconomic status (SES). Finally, in the assessment of welfare effects, there is extensive evidence indicating a causal relationship between PM and visibility effects, specifically visibility impairment. These topics are the basis of the scientific evaluation conducted in this Supplement.

Recent studies published in the U.S. and Canada provide additional support for the conclusions of the 2019 PM ISA. Overall: (a) recent studies support, and in some instances strengthen, the evidence presented in the 2019 PM ISA; (b) many of the recent epidemiologic studies evaluated report positive associations in areas with annual average or mean 24-hour avg PM_2.5_ concentrations similar to, or in many cases lower, than those studies evaluated in the 2019 PM ISA; (c) some recent studies address key scientific topics for which the literature has evolved since the 2020 PM NAAQS review was completed, specifically since the literature cutoff date for the 2019 PM ISA, including examining health effects at near-ambient PM_2.5_ concentrations in experimental settings, and examining the association between PM_2.5_ exposure and COVID-19 infection and death, both of which provide preliminary evidence to further inform the PM_2.5_-health effects relationship; (d) recent studies support, and in some instances extend, the evidence base indicating that minority populations, specifically Black individuals, and low SES individuals, experience disparities in both PM_2.5_-related health risks and exposures compared with non-Hispanic White populations; and (e) recent studies further inform the role of PM on light extinction and visibility impairment. In conclusion, the results of recent studies evaluated in this Supplement to the 2019 PM ISA support, and in some instances extend, the evidence base that informed the scientific conclusions of the 2019 PM ISA.

Overall, this Supplement to the 2019 PM ISA found the following:

## Cardiovascular Effects

### Short-Term PM_2.5_ Exposure

- Recent U.S. and Canadian multicity studies conducted within populations with diverse demographic characteristics continue to report positive associations between short-term PM_2.5_ exposure and emergency department (ED) visits and hospital admissions for ischemic heart disease (IHD), myocardial infarction (MI), and heart failure (HF) in studies with mean 24-hour avg PM_2.5_ concentrations ranging from 7.1 to 15.4 µg/m^3^. Consistent with the evidence in the 2019 PM ISA, most recent studies report no evidence of an association with stroke, regardless of stroke subtype. Further, recent epidemiologic studies like those evaluated in the 2019 PM ISA often employed hybrid exposure assessment models that allowed for a broader inclusion of geographic locations outside of the traditional urban centers where ambient monitors are located. In addition, these studies report evidence that continues to indicate an immediate effect of PM_2.5_ on cardiovascular-related outcomes primarily within the first few days after exposure, and that associations generally persisted in models adjusted for copollutants. Furthermore, recent epidemiologic studies that conducted accountability analyses or employed alternative methods for confounder control also report positive associations across a number of statistical approaches, which further supports a relationship between short-term PM_2.5_ exposure and cardiovascular effects. Overall, recent epidemiologic studies published since the 2019 PM ISA support and extend the evidence that contributed to the conclusion of a causal relationship between short-term PM_2.5_ exposure and cardiovascular effects.

### Long-Term PM_2.5_ Exposure

- Consistent with studies evaluated in the 2019 PM ISA, some of the strongest evidence for long-term PM_2.5_ exposure and cardiovascular effects comes from epidemiologic studies examining cardiovascular mortality. Recent studies report consistent, positive associations for cardiovascular mortality, specifically IHD and stroke mortality, across different cohorts at varying spatial scales and across different exposure assessment and statistical methods with the majority having annual PM_2.5_ concentrations ranging from 8.6 to 13.7 µg/m^3^. In addition, recent studies of cardiovascular morbidity, specifically coronary heart disease (CHD), stroke, and atherosclerosis progression, most consistently report positive associations when focusing on individuals with preexisting diseases and among patients followed after a cardiac event or procedure, and not among the general population, which supports and extends the evidence presented in the 2019 PM ISA. Recent studies of cardiovascular mortality and morbidity also indicate that associations are relatively unchanged in copollutant models and that most assessments indicate a linear, no-threshold concentration-response (C-R) relationship with initial evidence of nonlinearity at lower concentrations for some outcomes. Finally, a few recent epidemiologic studies that employed alternative methods for confounder control, reduce some uncertainties related to potential confounding bias and further support a relationship between long-term PM_2.5_ exposure and cardiovascular effects. Overall, recent epidemiologic studies published since the 2019 PM ISA support and extend the evidence that contributed to the conclusion of a causal relationship between long-term PM_2.5_ exposure and cardiovascular effects.

## Mortality

### Short-Term PM_2.5_ Exposure

- Since the literature cutoff date for the 2019 PM ISA, relatively few multicity studies have been conducted in the U.S. and Canada; however, these studies add to the extensive evidence base evaluated in the 2019 PM ISA and in previous assessments that reported consistent positive associations across studies using different statistical models, exposure assessment approaches, and methods for confounder control. These recent studies continue to report associations at mean 24-hour average concentrations ranging from 8.8 to 12.4 µg/m^3^; support an immediate effect of PM_2.5_ on mortality (i.e., at lag 0 to 1 day); and report that associations remain relatively unchanged in copollutant models. Additionally, evidence continues to build that the heterogeneity in city-to-city PM_2.5_-mortality risk estimates can be attributed partly to exposure differences, such as housing characteristics. The assessment of the C-R relationship continues to support a linear, no-threshold relationship with confidence in the shape at concentrations as low as 5 µg/m^3^. The relationship between short-term PM_2.5_ exposure and mortality is further supported by recent epidemiologic studies that employed alternative methods for confounder control and report consistent, positive associations. Overall, recent epidemiologic studies published since the 2019 PM ISA provide additional support to the evidence base that contributed to the conclusion of a causal relationship between short-term PM_2.5_ exposure and mortality.

### Long-Term PM_2.5_ Exposure

- Recent epidemiologic studies conducted in the U.S. and Canada consisting of cohorts with mean annual PM_2.5_ concentrations mostly below 12 µg/m^3^, with the majority ranging from 5.9 to 11.65 µg/m^3^, add to the large evidence base indicating consistent, positive associations between long-term PM_2.5_ exposure and mortality detailed in the 2019 PM ISA. The reporting of consistent, positive associations across studies examining various exposure windows, approaches for confounder adjustment, and exposure assessment methods that used different sources of data and were conducted at different spatial resolutions increases confidence in the relationship between long-term PM_2.5_ exposure and mortality. In addition, recent studies further inform whether there is evidence of copollutant confounding; although there were some differences across studies, generally, associations persisted in copollutant models. The assessment of the C-R relationship continues to support a linear, no-threshold relationship at PM_2.5_ concentrations > 8 µg/m^3^. However, uncertainties remain about the shape of the C-R curve at lower PM_2.5_ concentrations (< 8 µg/m^3^), with some recent studies providing evidence for a sublinear, linear, or supralinear relationship at these lower concentrations. Finally, an extensive number of epidemiologic studies that conducted accountability analyses or employed alternative methods for confounder control have been conducted since the literature cutoff date of the 2019 PM ISA. Collectively, these studies that used different statistical approaches and cohorts spanning diverse geographic locations and populations provide additional support for the PM_2.5_-mortality relationship. Overall, recent epidemiologic studies published since the 2019 PM ISA support and extend the evidence that contributed to the conclusion of a causal relationship between long-term PM_2.5_ exposure and mortality.

## Additional Considerations Regarding the Health Effects of PM_2.5_

### Experimental Studies at Near-Ambient PM_2.5_ Concentrations

- ○ At the completion of the 2019 PM ISA, only a few controlled human exposure studies were identified that had been conducted in Europe and examined health effects with near-ambient PM_2.5_ concentrations (i.e., at concentrations around the 24-hour PM NAAQS of 35 µg/m^3^). These studies conducted in a population of older (55 years of age and older) overweight individuals provided initial evidence for vascular changes and reductions in heart rate variability (HRV) at low concentrations. A recent study in young, healthy participants also adds to the evidence base indicating effects at near-ambient PM_2.5_ concentrations, specifically changes in lung function, cardiac function, and inflammation. However, these results are inconsistent with the evidence for both lung function and inflammation examined in controlled human exposure studies evaluated in the 2019 PM ISA, which could be attributed to the higher ventilation rate and longer exposure duration used compared with other studies.

### SARS-CoV-2 Infection and COVID-19 Death

- ○ With the onset of the COVID-19 pandemic, recent epidemiologic studies examined whether both short-term and long-term PM_2.5_ exposure is associated with SARS-CoV-2 infection and COVID-19 death. While some of these studies reported positive associations, these studies overall were subject to methodological issues that may influence results. Specifically, many consisted of an ecological study design, studies were conducted during on ongoing pandemic while the etiology of COVID-19 was still not understood (e.g., there are important differences in COVID-19-related health outcomes, such as by race and SES), and studies did not account for crucial factors that could influence results (e.g., stay-at-home orders, social distancing, use of masks, and testing capacity). While there is initial evidence of positive associations with SARS-CoV-R infection and COVID-19 death, uncertainties remain due to methodological issues.

## Populations at Potentially Increased Risk of a PM-Related Health Effect

### Socioeconomic Status

- ○ Recent studies that use a variety of metrics to represent SES, including educational attainment and income, along with studies that used composite metrics to represent neighborhood SES, provide additional support indicating there may be disparities in PM_2.5_ exposure and health risk by SES. These studies indicate that the strongest evidence of a health risk disparity for low SES is for cause-specific mortality and certain health endpoints (i.e., MI and CHF) when compared with higher SES groups.

### Race and Ethnicity

- ○ Building upon the conclusions of the 2019 PM ISA, recent studies continue to support disparities in PM_2.5_ exposure and health risks by race and ethnicity, with the strongest evidence for minority populations, specifically Black populations. Black populations or individuals that live in predominantly Black neighborhoods experience higher PM_2.5_ exposures, in comparison with non-Hispanic White populations. Additionally, there is evidence of health risk disparities for both Hispanic and non-Hispanic Black populations compared with non-Hispanic White populations for cause-specific mortality and incident hypertension.

## Visibility Effects

- Recent studies indicate that using contrast instead of light extinction as a metric greatly reduced the variability in results in visibility preference studies. In addition, rapidly decreasing sulfate and increasing fire-related contributions to PM have led to a changing relationship between PM and visibility impairment, likely affecting estimates of light extinction. In response, alternate approaches to the application of the traditional IMPROVE algorithm for estimating light extinction have been developed that reduce the bias in light extinction estimates. Parallel efforts have better characterized light extinction by major contributors to PM, particularly for biomass burning. Overall, recent studies published since the 2019 PM ISA support and extend the evidence that contributed to the conclusion of a causal relationship between PM and visibility.