# 4 EVALUATION OF RECENT WELFARE EFFECTS EVIDENCE

The Integrated Science Assessment for Particulate Matter (2019 PM ISA) concluded a causal relationship for each of the three nonecological welfare effects categories evaluated: visibility effects, climate effects, and materials effects. However, the welfare effects studies evaluated within this chapter represent only those studies most informative in considering potential revisions to the PM NAAQS as defined by the scope of this Supplement (Section 1.2.2), specifically studies that inform the relationship between PM and visibility impairment. Within this section the evaluation of recent studies is performed in the context of the studies evaluated and scientific conclusions presented in the 2019 PM ISA. As a result, within the following section, the summary and causality determination from the 2019 PM ISA is presented prior to the evaluation of recent studies published since the literature cutoff date of the 2019 PM ISA that examine the relationship between PM and visibility impairment (Section 4.2). This approach allows for a full accounting of the evidence that formed the basis of the key scientific conclusions in the 2019 PM ISA with respect to visibility impairment and the identification of specific sections of the 2019 PM ISA that provide additional details on the total evidence base being considered in the process of reconsidering the PM NAAQS.

The studies evaluated in the following sections represent only those studies most informative in considering potential revisions to the PM NAAQS (i.e., that provide new information on public preferences and/or methodologies or quantitative analyses of visibility impairment). As a result, the summary section (Section 4.3) for visibility effects conveys how the evidence from recent studies fits within the scientific conclusions of the 2019 PM ISA, and indicates whether recent evidence supports (is consistent with), supports and extends (is consistent with and reduces uncertainties), or does not support (is not consistent with) the causality determination for visibility effects in the 2019 PM ISA.

## 4.1 Summary of Evidence for Visibility Effects from 2019 Integrated Science Assessment for Particulate Matter

Overall, visibility in most regions of the U.S. has improved since the 2009 PM ISA, as indicated by lower estimates of light extinction. The greatest improvements have occurred in the eastern half of the country, in regions with the poorest visibility. This has likely occurred because of a reduction in SO_2_ emissions, resulting in lower ammonium sulfate concentrations, because ammonium sulfate has historically accounted for a large fraction of PM_2.5_ mass in the eastern U.S., and also because ammonium sulfate is more effective than other PM_2.5_ components at scattering light. The resulting decrease in PM_2.5_ in the eastern part of the country has resulted in better visibility.

Rural visibility impairment is greatest in eastern U.S. regions, including the Southeast, East Coast, Mid-South, Central Great Plains, and Appalachian regions. In contrast, visibility is better, on average, in most regions of the western U.S. Urban visibility is also generally better in the western part of the country than in the east, except for urban areas in California and Alaska. In part, this reflects the difference in PM_2.5_ composition between the east and west, with a greater fraction being made up of ammonium sulfate in the eastern U.S. and of particulate organic matter in the west. The effectiveness of light extinction by PM_2.5_ depends on composition and relative humidity, with low scattering efficiency from PM_10−2.5_, moderate scattering efficiency by organic mass and sea salt, high scattering efficiency by ammonium sulfate and ammonium nitrate, and high total light extinction (scattering + absorption) by light-absorbing carbon. However, the difference in light extinction between the eastern and western U.S. also reflects considerably higher PM_2.5_ concentrations in the eastern U.S. and California than in the rest of the western U.S.

Altogether, new results and observations discussed in the 2019 PM ISA regarding atmospheric visibility provide evidence that atmospheric visibility has improved as PM concentrations have decreased, that regional and seasonal differences in atmospheric visibility parallel regional and seasonal PM concentration patterns, and that regional differences in the relationship between PM and visibility are due to differences in PM composition characteristics, rather than any factors beyond PM. These results confirm a well-established relationship between PM and visibility summarized in the 2009 PM ISA and earlier assessments. Overall, the evidence is sufficient to conclude that a causal relationship exists between PM and visibility impairment.

## 4.2 Recent Studies That Inform the Relationship between PM and Visibility Effects

Within the 2019 PM ISA (Section 13.2), studies that assessed the relationship between PM and visibility impairment were evaluated. These included preference studies to assess acceptability of visual air quality (Section 4.2.1), as well as field studies and computational methods to evaluate trends in visual air quality (Section 4.2.2). Some studies published since the literature cutoff date for the 2019 PM ISA provide additional insight into the PM-visibility impairment relationship.

### 4.2.1 Visibility Preference and Light Extinction

A recent study by Malm et al. (2019) reported results from a new visibility preference study and evaluated the consistency between previous visibility preference studies. The main conclusion of this study was that the level of acceptable visual air quality is more consistent across studies using metrics that evaluate the distinction of an object from a background than using metrics that evaluate the greatest distance at which an object can be observed. As described in the 2019 PM ISA, two fundamental characteristics of atmospheric visibility impairment are (1) a reduction in visual range, the greatest distance through the atmosphere at which a prominent object can be identified, and (2) a reduction in contrast, the sharpness with which an object can be distinguished from another object or background (Malm, 2016). Both of these concepts can be expressed in terms of an extinction coefficient (b_ext_), which relates the distance of an observed object to light extinction following the Beer-Lambert Law (U.S. EPA, 2019). In practice, assessment of visibility impairment typically involves estimating the amount of light extinction (b_ext_) from measurements of PM species concentrations (Section 4.2.2).

The demand for good visual air quality has been evaluated in multiple diverse locations using visibility preference studies with similar protocols. In these studies, respondents are shown photographic slides or hard copy photographs of a single scene under various visibility conditions and asked to (1) rate the visual air quality for each photograph on a scale from 1 (poor) to 7 (excellent) and (2) judge whether the visual air quality depicted in the image was considered to be acceptable or unacceptable. Visibility preference results from eight locations have been published between 1991 and 2019 using this approach (Malm et al., 2019), including five urban and two non-urban locations in the U.S. or Canada. Results from the five urban locations were all reported before publication of the 2009 PM ISA (U.S. EPA, 2009), where they are reviewed in detail. Results to these studies were generally reported in terms of light extinction (b_ext_), or related metrics concerned with the distance at which an object can be seen, like visual range. When results were compared between different locations, a wide range in acceptable values was observed for these metrics. For example, median acceptable visual range values ranged from 20 km in Washington, DC to 59 km in Denver (U.S. EPA, 2009).

Although no new visibility preference studies in the U.S. had been reported between the publication of the 2009 PM ISA and the 2019 PM ISA (U.S. EPA, 2019), an additional U.S. study of the Grand Canyon was published since that time, and previous studies that were summarized in the 2009 ISA were reanalyzed using alternative visibility metrics that reduced the variability in acceptability between settings and locations (Malm et al., 2019). Figure 4-1 (Malm et al., 2019) shows the percentage of observers that indicated acceptable visual air quality, labeled acceptable (%) on the y-axis, as a function of light extinction, labeled b_ext_ on the x-axis. Data are based on rankings of photographic images from six visibility preference studies conducted in Phoenix, AZ (ADEQ, 2003); Chilliwack and Abbotsford, BC (Pryor, 1996), Denver, CO (Ely et al., 1991), Washington, DC (Abt, 2001), and the Grand Canyon, AZ (Malm et al., 2019).

Figure 4-1 Percent acceptability levels plotted against light extinction (b_ext_) for each of the images used in studies for Washington, DC (WASH), Phoenix, AZ (PHX), Chilliwack, BC (CHIL), Abbotsford, BC (ABBT), Denver, CO (DEN), and the Grand Canyon, AZ (GRCA)

Figure 4 dash 1 shows percent acceptability levels plotted against atmospheric extinction coefficient for each of the images used in studies for Washington, DC (WASH), Phoenix, AZ (PHX), Chilliwack, BC (CHIL), Abbotsford, BC (ABBT), Denver, CO (DEN), and the Grand Canyon, AZ (GRCA).

Source: Malm et al. (2019)

These results clearly demonstrate a large range in light extinction (b_ext_) across different locations considered acceptable by 50% of observers, indicating that metrics based on light extinction are not universal indicators of visibility preference levels. For example, considerably more light extinction was regarded as acceptable by 50% of observers for the Washington, DC scene (192 Mm^−1^) than for the Grand Canyon, AZ scene (23 Mm^−1^) (Malm et al., 2019). For other locations the amount of light extinction considered acceptable by 50% of observers was intermediate between Washington, DC and the Grand Canyon, AZ (Malm et al., 2019). For context, urban monthly average b_ext_ derived from 2011 to 2014 Chemical Speciation Network (CSN) data presented in the 2019 PM ISA was within this range for at least 1 month in all 31 U.S. regions analyzed (U.S. EPA, 2019).

Ideally, the relationship between the acceptability rating and the metric used for visibility impairment would be independent of the scene being observed (Malm et al., 2019). However, Figure 4-1 shows that when using light extinction or any universal haze metric, the response was highly dependent on the scene. Malm et al. (1981) showed that visual air quality judgments like those applied in visibility preference studies are related to contrast of landscape features and thus are dependent on the integration of haze over the sight paths between the observer and landscape features. Based on these results, Malm et al. (2019) suggested that scene-dependent metrics like contrast, which integrate the effects of b_ext_ along the sight paths between observers and landscape features, are better predictors of preference levels than universal metrics like light extinction. The explanation for this is that light extinction alone is not a measure of haze (Malm et al., 2019), but of light attenuation per unit distance, and visible haze is dependent on both light extinction and distance to a landscape feature. As a result, more haze is required to affect a nearby feature than more distant features, and landscape features at different distances from an observer each have a unique sensitivity to changes in light extinction, and consequently to PM mass concentration (Malm et al., 2019).

Figure 4-2 shows acceptability levels for the same studies in Figure 4-1 plotted against apparent contrast of the distant feature most sensitive to haze. When the features reach the visual range, corresponding to a contrast between approximately −0.03 and −0.05, about 50% of observers rated the image as not acceptable. When acceptability is expressed as a function of contrast in Figure 4-2, the response is less dependent on scene, as indicated by a smaller difference between average acceptability between studies than when acceptability is expressed as a function of light extinction in Figure 4-1. This is because most features in the Grand Canyon, AZ scene were more than 10 km distant, while landscape elements in the other studies were closer (Malm et al., 2019).

Figure 4-2 Percent acceptability levels plotted against apparent contrast of distant landscape features for each of the images used in studies for Phoenix, AZ (PHX), Chilliwack, BC (CHIL), Abbotsford, BC (ABBT), Denver, CO (DEN), and the Grand Canyon, AZ (GRCA)

Figure 4 dash 2 shows percent acceptability levels plotted against apparent contrast of distant landscape features for each of the images used in studies for Washington, DC (WASH), Phoenix, AZ (PHX), Chilliwack, BC (CHIL), Abbotsford, BC (ABBT), Denver, CO (DEN), and the Grand Canyon, AZ (GRCA).

Source: Malm et al. (2019)

Malm et al. (2019) concluded that visibility preference studies suggest that about 50% of individuals would find visibility unacceptable if at any time the more distant landscape features nearly disappear, and that this occurs when these features are near the visual range and have contrast levels of approximately −0.03 to −0.05. Further, an acceptability level of 90% would require contrast levels to remain above a level of about −0.01.

### 4.2.2 Recent Estimates of Light Extinction Trends

The 2019 PM ISA reported that light extinction by PM was decreasing in most regions of the U.S. and that the greatest improvements had occurred in the eastern half of the country, in regions with the poorest visibility based on the analysis of Interagency Monitoring of Protected Visual Environments (IMPROVE) network (U.S. EPA, 2019). Analysis of IMPROVE network data since the publication of the 2019 PM ISA show that the trends of decreasing light extinction and decreasing contribution of ammonium sulfate to total light extinction have continued in the eastern U.S., but that in the western part of the country, changes in total light extinction were smaller, and the contribution of particulate organic matter to atmospheric light extinction was increasing due to increasing wildfire emissions (Hand et al., 2020). On average, light extinction decreased by 1.8% per year from 1990 to 2018 and by 2.8% per year from 2002 to 2018. In the eastern U.S., the light extinction coefficient decreased by 4.3% per year from 2002 to 2018 and was associated with major reductions of SO_2_ and NO_X_ emissions (Hand et al., 2020). The reduction in light extinction reported by Hand et al. (2020) is supported by the declining trend in sulfate concentrations detailed in the 2019 PM ISA (U.S. EPA, 2019).

The trend in light extinction is depicted in Figure 4-3, which shows regional time-series plots of estimated annual mean b_ext_ for major aerosol species aggregated from individual remote and rural monitors for the eastern U.S. (east of 100º W), the Intermountain West and Southwest (between 100º W and 116º W), and the West Coast (west of 116º W) from 2002 to 2018 as reported by Hand et al. (2020). The greatest declines in b_ext_ were observed in the eastern U.S., where annual mean total b_ext_ declined by 74% from 2002 through 2018 and light extinction by ammonium sulfate, which was estimated to account for 72% of total light extinction in 2002-2004, decreased by 148% (Hand et al., 2020). The annual mean b_ext_ was also significantly highly correlated (r = 0.096) with combined SO_2_ + NO_x_ total emissions in the eastern U.S. (Hand et al., 2020). During the period 2016–2018, the average contribution to total reconstructed light extinction in the eastern U.S. was 55% from ammonium sulfate and ammonium nitrate combined, 31% from carbonaceous aerosols, and 14% from fine dust, coarse particulate matter, and fine sea salt combined. Compared with 2016–2018, average contributions during 2002–2004 of 72% from ammonium sulfate and ammonium nitrate combined, 21% from carbonaceous aerosols, and 5% from fine dust, coarse particulate matter, and fine sea salt combined. Hand et al. (2020) also observed that the highest b_ext_ value had shifted westward from the Ohio Valley and Appalachians to the agricultural regions of the central U.S.

Figure 4-3 Annual mean reconstructed light extinction (b_ext_) for the a) East, b) Intermountain West/Southwest, c) West Coast by species, including ammonium sulfate (AS), ammonium nitrate (AN), particulate organic matter (POM), fine dust (FD), coarse mass (CM), and sea salt (SS)

Map insets show individual sites aggregated into regional means

Figure 4 dash 3 shows stacked bar graphs showing monthly average light extinction attributed to major P M 2.5 species for 2002 to 2018 for the Eastern U.S., Intermountain West and Southwest, and West Coast monitors of the IMPROVE network. Inset maps of the U.S. show the locations of IMPROVE network P M 2.5 speciation monitors grouped into 3 regions. There is a decreasing trend in total light extinction and for light extinction from sulfate in the East. There is less evidence for a trend in the West Coast and Intermountain West and Southwest, but large increases in organic mass in 2017 and 2018, likely due to wildfires.

Source: Hand et al. (2020)

In the western regions of the U.S., the reduction of total reconstructed b_ext_ was smaller, decreasing by 15% in the Intermountain West and Southwest and 25% along the West Coast (Hand et al., 2020). In these regions, the contribution of ammonium sulfate and nitrate had been roughly equal to the contribution of carbonaceous aerosols (i.e., organic mass and elemental carbon) during 2002–2004 in both regions, but in 2016–2018, light extinction became dominated by carbonaceous aerosols, which accounted for 45% of reconstructed total light extinction in the Intermountain/Southwest and 51% in the West Coast region. Although some of this change occurred because ammonium sulfate and nitrate also decreased in these regions, an increase in wildfire emissions was also a likely contributor (Hand et al., 2020). Therefore, the analysis conducted by Hand et al. (2020) indicates that the composition of haze has shifted away from being dominated by sulfate to having greater contributions from carbonaceous and crustal aerosols. Additionally, as emissions of SO_2_ and NO_X_ continue to decline, contributions to haze from unregulated sources including oil and gas extraction, agricultural activities, international sources, wildfires, and windblown dust seem to be increasing.

### 4.2.3 Recent Advancements in Visibility Monitoring and Assessment

The changing PM concentrations and composition in the U.S. have also resulted in an increasing bias in b_ext_ estimates (Prenni et al., 2019). An artifact of the method used to estimate light extinction from national monitoring network data could be contributing up to 1% per year in the eastern U.S. and 0.5% per year in the western U.S. to apparent long-term trends Hand et al. (2020). Research is progressing to address these concerns about increasing bias in light extinction estimates, and an alternative approach to estimating the split of component mass between large and small size modes reduced the bias (Prenni et al., 2019). A more detailed explanation of this approach in the context of the evolution of the IMPROVE algorithm used to estimate light extinction from the IMPROVE network is presented in the Appendix A, Section A.1.

Other recent research has addressed the effects of relative humidity on light extinction, the effect of increasing wildfires and atmospheric dust, and development of new instrumentation and measurement methods. A 25% underprediction was reported when reconstructed light extinction was compared with open-path cavity ringdown spectrometry measurements of light extinction in the Great Smoky Mountains National Park during the summer of 2016 by Gordon et al. (2018). The authors concluded that the accuracy of light extinction estimates from both the original and revised IMPROVE equations (Equations A-1 and A-2 in Appendix A, Section A.1) was reasonable at average relative humidity, but substantially lower at both higher and lower humidity

The importance of including relative humidity in estimating light extinction in urban areas of the eastern U.S. was demonstrated in the Baltimore, MD-Washington, DC area (Beyersdorf et al., 2016). On days when PM was transported from the north, PM_2.5_ concentrations averaged 5.4 micrograms per cubic meter (µg/m^3^) and the variability of light extinction was controlled primarily by differences in PM concentrations. However, substantially higher concentrations, averaging 18.4 µg/m^3^, were observed for westerly PM transport from the Ohio River Valley, PM was more hygroscopic, and the variability of light extinction was controlled by both PM_2.5_ concentration and relative humidity (Beyersdorf et al., 2016).

Recent decreases in SO_2_ and NO_X_ emissions have coincided with increasing PM emissions from wildland fires (U.S. EPA, 2019) as well as dust in some regions of the U.S. (Lambert et al., 2020). As a result, recent studies have focused on visibility impairment specifically from fire-related PM. Recent estimates of mass scattering efficiencies for wildland fire smoke ranged from 2.50 to 4.76 m^2^/g, and increased with particle median diameter, as expected from theoretical predictions (Laing et al., 2016). Mass scattering efficiencies of fire-related PM were observed to increase by 56% during the first 2−3 hours after emission, at least in part due to increasing particle size during atmospheric aging (Kleinman et al., 2020). The large and rapid change in mass scattering efficiencies during atmospheric aging presents a challenge for accurately estimating light extinction based on constant mass scattering coefficients, as in Equations A-1 through A-4 in Appendix A, Section A.1.

Recent studies have also introduced new instrumentation and measurement methods that could help to reduce uncertainties in light extinction. Multi-wavelength light attenuation methods used as a part of thermal/optical carbon analysis in the IMPROVE and Chemical Speciation Networks (2019 PM ISA, Section 2.4 and Section 13.2.4) were initiated in 2016 and are used to estimate brown carbon, which in turn can be used to estimate biomass burning contributions to atmospheric light absorption (Chow et al., 2021). Application of a paired-wavelength method to estimate light absorption by brown carbon resulted in a factor of two increase in the estimate of the contribution of brown carbon to light absorption in CSN network samples from 2016 to 2017 (Chow et al., 2021). These results suggest a considerably greater contribution of organic PM to light absorption by PM than could be estimated using network thermal/optical methods in place before 2016. This is a highly relevant result given that organic matter has recently overtaken sulfate as the most abundant PM_2.5_ component in many locations, and that wildland fire emissions are an increasing source of PM (U.S. EPA, 2019).

Capabilities for estimating light extinction from photographic images have also progressed. In the 2019 PM ISA photography is identified as one of several methods of measuring light extinction (U.S. EPA, 2019), and results from image processing techniques had been shown to be highly correlated with measured light extinction under hazy conditions. Additionally, a recent study demonstrated that light extinction could also be estimated quantitatively from photographic images under more pristine conditions from webcams that are routinely operated at the Grand Canyon and Great Smoky Mountains National Parks (Malm et al., 2018).

## 4.3 Summary of Recent Evidence in the Context of the 2019 Integrated Science Assessment for Particulate Matter Causality Determination for Visibility Effects

Recent studies published since the 2019 PM ISA have addressed several existing research gaps and emerging trends identified in the 2019 PM ISA. Analyzing visibility preference study results using contrast as a metric greatly reduced the variability in acceptability between studies that reported results in terms of light extinction or related metrics. Evaluation of uncertainties and development of alternative approaches to estimating light extinction using the IMPROVE algorithm as well as alternative methods for analyzing both light extinction and PM species have helped to meet new needs introduced by rapidly decreasing sulfate and increasing fire-related contributions to PM. New measurements of physical and optical properties of wildfire smoke also provide useful new data for understanding PM sources responsible for light extinction.

Some recent studies evaluated in this section provide the following new insights:

- The wide range in response to the level of acceptable visibility observed across different settings was reduced by accounting for the distances of 20–59 km between observer and landscape feature as a part of a visibility metric. This reduction was demonstrated by observation of a smaller variation across different settings using apparent contrast than light extinction.
- Impacts of the rapidly decreasing sulfate and increasing fire-related contributions to PM have been evaluated in recognition that the changing nature of PM composition in the U.S. is changing the relationship between PM and visibility impairment.
- The changing relationship between PM and visibility impairment has led to increased bias and spurred alternate approaches that have reduced bias in the IMPROVE algorithm used to estimate light extinction.

Additional recent studies further support the conclusions in the 2019 PM ISA, specifically:

- In polluted environments most of the light extinction (b_ext_) is due to mainly to scattering by PM_2.5_; although absorption by elemental carbon and some crustal materials, as well as scattering by coarse PM, are important in some locations.
- Light extinction (b_ext_) is generally elevated in urban centers compared with surrounding rural areas, particularly in the western U.S.
- In practice, b_ext_ is estimated with reasonable accuracy using routinely available PM species monitoring data using data on dry mass extinction efficiency and hygroscopicity growth functions for major species. Mass extinction efficiencies can vary by a factor of 10 or more between particulate species, which vary by region and season as well as by urban versus rural settings.
- Mass extinction efficiencies for sulfates, nitrates, and organics in rural areas tend to increase with increasing concentrations due to shifts in the size distributions and more recent studies have shown a similar dependency on concentration in urban and polluted environments.