# 3 EVALUATION OF RECENT HEALTH EFFECTS EVIDENCE

The following section focuses on the evaluation of recent health effects studies that fall within the scope of this Supplement as detailed in Section 1.2.2. Within this section the evaluation of recent studies is performed in the context of the studies evaluated and scientific conclusions presented in the Integrated Science Assessment for Particulate Matter (2019 PM ISA). As a result, within each of the following sections, the summary and causality determination from the 2019 PM ISA is presented prior to the evaluation of recent studies published since the literature cutoff date of the 2019 PM ISA that examine the relationship between short-term (i.e., hours up to 1 month) and long-term (i.e., over 1 month to years) PM_2.5_ exposure and cardiovascular effects (Section 3.1) and mortality (Section 3.2).^13^ This approach allows for a full accounting of the evidence that formed the basis of the key scientific conclusions in the 2019 PM ISA and the identification of specific sections of the 2019 PM ISA that provide additional details on the total evidence base being considered in the process of reconsidering the 2020 PM NAAQS.

In addition to the evaluation of recent U.S. and Canadian epidemiologic studies that examine the relationship between short-term and long-term PM_2.5_ exposure cardiovascular effects and mortality, this section also evaluates studies that address key scientific topics for which the literature has evolved since the 2020 PM NAAQS review was completed, specifically since the literature cutoff date for the 2019 PM ISA (Section 3.3). These topics that further inform the health effects attributed to PM_2.5_ exposure include experimental studies conducted at near-ambient concentrations (Section 3.3.1), studies that examine the role of PM_2.5_ exposure on severe acute respiratory syndrome coronavirus 2 (SARS-CoV-2) infection and coronavirus disease 2019 (COVID-19) death (Section 3.3.2), and studies that examine whether there are disparities in exposure to PM_2.5_ or the risk of PM_2.5_-related health effects by race/ethnicity or socioeconomic status (SES).

The studies evaluated in the following sections represent only those studies most informative in considering potential revisions to the PM NAAQS as defined by the scope of this Supplement (Section 1.2.2), that is, U.S. and Canadian epidemiologic studies and other studies that address key scientific topics. Therefore, the scientific information presented in this section does not represent the full multidisciplinary evaluation presented within the 2019 PM ISA, which would lead to the formation of a causality determination. As a result, the summary sections for each health effects category convey how the evidence from recent studies fits within the scientific conclusions of the 2019 PM ISA, and indicates whether recent evidence supports (is consistent with), supports and extends (is consistent with and reduces uncertainties), or does not support (is not consistent with) the causality determinations in the 2019 PM ISA.

## 3.1 Cardiovascular Effects

### 3.1.1 Short-Term PM_2.5_ Exposure

The following sections represent a summary of the evidence and the corresponding causality determination for short-term PM_2.5_ exposure and cardiovascular effects presented in the 2019 PM ISA (Section 3.1.1.1) along with an evaluation of recent epidemiologic studies that fall within the scope of the Supplement (i.e., studies conducted in the U.S. and Canada) and were published since the literature cutoff date of the 2019 PM ISA (Section 3.1.1.2).^14^ In addition, with the expansion of epidemiologic studies that used statistical approaches that attempt to more extensively account for confounders and are more robust to model misspecification (i.e., used alternative methods for confounder control), recent studies that employed such methods are also evaluated (Section 3.1.1.3), which can further inform the relationship between short-term PM_2.5_ exposure and cardiovascular morbidity. Finally, a summary of the results of recent studies evaluated in the section is presented in the context of the scientific conclusions detailed in the 2019 PM ISA (Section 3.1.1.4). The evaluation of recent studies presented in this Supplement adds to the collective body of evidence reviewed in the process of reconsidering the PM NAAQS.

#### 3.1.1.1 Summary and Causality Determination from 2019 Integrated Science Assessment for Particulate Matter

A large body of evidence evaluated in the 2019 PM ISA confirmed and extended the evidence from the 2009 PM ISA (U.S. EPA, 2009) indicating a causal relationship between short-term PM_2.5_ exposure and cardiovascular effects. The strongest evidence in the 2009 PM ISA was from epidemiologic studies of emergency department (ED) visits and hospital admissions for ischemic heart disease (IHD) and heart failure, with supporting evidence from epidemiologic studies of cardiovascular mortality. Changes in various measures of cardiovascular function in controlled human exposure studies provided some biological plausibility for these associations. In addition, animal toxicological studies reporting some evidence of reduced myocardial blood flow during ischemia, altered vascular reactivity, and ST segment depression provided additional biological plausibility.

In addition to evaluating evidence across scientific disciplines that examined the relationship between short-term PM_2.5_ exposure and cardiovascular effects, discussed below, the 2019 PM ISA characterized whether evidence supported biologically plausible mechanisms by which short-term PM_2.5_ exposure could lead to cardiovascular effects. This evaluation consisted of an assessment of animal toxicological, controlled human exposure, and epidemiologic studies that examined a range of cardiovascular effects (2019 PM ISA, Section 6.1.1). Plausible mechanisms were identified by which inhalation exposure to PM_2.5_ could progress from initial events to apical events reported in epidemiologic studies (2019 PM ISA, Figure 6-1). The first proposed pathway identified begins as respiratory tract inflammation leading to systemic inflammation. The second proposed pathway identified involves activation of sensory nerve pathways in the respiratory tract that lead to modulation of the autonomic nervous system. Once these pathways are initiated, there is evidence from experimental and observational studies that short-term exposure to PM_2.5_ may result in a series of pathophysiological responses that could lead to cardiovascular events such as ED visits and hospital admissions for IHD and heart failure, and ultimately mortality (2019 PM ISA, Figure 6-1).

In the 2019 PM ISA, evidence supporting the causality determination included generally positive associations from epidemiologic studies of hospital admissions and ED visits for cardiovascular-related effects, and in particular, for IHD and heart failure. Results from these observational studies were supported by experimental evidence from controlled human exposure and animal toxicological studies of endothelial dysfunction, as well as endpoints indicating impaired cardiac function, increased risk of arrhythmia, changes in heart rate variability (HRV), increases in blood pressure (BP), and increases in indicators of systemic inflammation, oxidative stress, and coagulation. Additional results from observational panel studies, although not entirely consistent, provided at least some evidence of increased risk of arrhythmia, decreases in HRV, increases in BP, and ST segment depression. Thus, epidemiologic panel studies also provided some support to the causality determination and to biological plausibility. Finally, epidemiologic studies of cardiovascular-related mortality provided additional evidence that demonstrated a continuum of effects from biomarkers of inflammation and coagulation, subclinical endpoints (e.g., HRV, BP, endothelial dysfunction), ED visits and hospital admissions, and eventually death. The evidence evaluated in the 2019 PM ISA also reduced uncertainties from the previous review related to potential copollutant confounding and limited biological plausibility for cardiovascular effects following short-term PM_2.5_ exposure. Evidence supporting the causality determination for short-term PM_2.5_ exposure and cardiovascular effects reached in the 2019 PM ISA is discussed below and summarized in Table 3-1, using the framework for causality determinations described in the Preamble to the ISAs (U.S. EPA, 2015).

Table 3-1 Summary of evidence for a causal relationship between short-term PM_2.5_ exposure and cardiovascular effects from the 2019 Integrated Science Assessment for Particulate Matter

Rationale for Causality Determination^a^ | Key Evidence^b^ | Key References and Sections in the 2019 PM ISA^b^ | PM_2.5_ Concentrations Associated with Effects^c^ (µg/m^3^)
Consistent epidemiologic evidence from multiple studies at relevant PM_2.5_ concentrations | Increases in ED visits and hospital admissions for IHD and heart failure in multicity studies conducted in the U.S., Canada, Europe, and Asia; Increases in cardiovascular mortality in multicity studies conducted in the U.S., Canada, Europe, and Asia. | Section 6.1.2.1; Section 6.1.3.1; Section 6.1.9 | 5.8−18.6; 5.8−18.0
Evidence from controlled human exposure studies at relevant PM_2.5_ concentrations | Consistent changes in measures of endothelial dysfunction; Generally consistent recent evidence for small increases in measures of blood pressure following CAPs exposure; Although not entirely consistent, there is additional evidence of conduction abnormalities, heart rate variability, impaired heart function, systemic inflammation/oxidative stress. | Section 6.1.13.2; Section 6.1.6.3; Section 6.1.4.3; Section 6.1.3.2; Section 6.1.10.2; Section 6.1.11.2 | 24−325; See Tables in identified sections
Consistent evidence from animal toxicological studies at relevant PM_2.5_ concentrations | Consistent changes in indicators of endothelial dysfunction.; Additional evidence of changes in impaired heart function, conduction abnormalities/arrhythmia, heart rate variability, blood pressure, systemic inflammation/oxidative stress. | Section 6.1.13.3; Section 6.1.6.4; Section 6.1.4.4; Section 6.1.3.3; Section 6.1.11.3 | 168.7−510; See Tables in identified sections
Epidemiologic evidence from copollutant models provides some support for an independent PM_2.5_ association | The magnitude of PM_2.5_ associations remain positive, but in some cases are reduced with larger confidence intervals in copollutant models with gaseous pollutants. Further support from copollutant analyses indicates positive associations for cardiovascular mortality. Recent studies that examined potential copollutant confounding are limited to studies conducted in Europe and Asia.; When reported, correlations with gaseous copollutants were primarily in the low to moderate range (r < 0.7). | Section 6.1.14.1
Consistent positive epidemiologic evidence for associations between PM_2.5_ exposure and CVD ED visits and hospital admissions across exposure measurement metrics | Positive associations consistently observed across studies that used ground-based (i.e., monitors), model (e.g., CMAQ, dispersion models), and remote sensing (e.g., AOD measurements from satellites) methods, including hybrid methods that combine two or more of these methods. | Kloog et al. (2014)
Generally consistent evidence for biological plausibility of cardiovascular effects | Strong evidence for coherence of effects across scientific disciplines and biological plausibility for a range of cardiovascular effects in response to short-term PM_2.5_ exposure. Includes evidence for reduced myocardial blood flow, altered vascular reactivity, and ST segment depression. | Section 6.1.1; Figure 6-1
Uncertainty regarding geographic heterogeneity in PM_2.5_ associations | Multicity U.S. studies demonstrate city-to-city and regional heterogeneity in PM_2.5_-cardiovascular ED visit and hospital admission associations. Evidence supports the supposition that a combination of factors including composition and exposure factors may contribute to the observed heterogeneity. | Section 6.1.2.1; Section 6.1.3.1

Note: This table corresponds to Table 6-34 in the 2019 PM ISA.

AOD = aerosol optical depth; CMAQ = Community Multiscale Air Quality model; CVD = cardiovascular disease; ED = emergency department; IHD = ischemic heart disease; µg/m^3^ = micrograms per cubic meter; PM_2.5_ = particulate matter with a nominal mean aerodynamic diameter less than or equal to 2.5 μm; ST = beginning of S wave to end of T wave.

a Based on aspects considered in judgments of causality and weight of evidence in causal framework in Table I and Table II of the Preamble to the ISAs (U.S. EPA, 2015).

b Describes the key evidence and references, supporting or contradicting, contributing most heavily to causality determination and, where applicable, to uncertainties or inconsistencies. References to earlier sections indicate where the full body of evidence is described in the 2019 PM ISA.

c Describes the PM_2.5_ concentrations with which the evidence is substantiated.

The generally consistent, positive associations observed in numerous epidemiologic studies of ED visits and hospital admissions for IHD, heart failure, and combined cardiovascular-related endpoints contributed to the evidence supporting a causal relationship between short-term PM_2.5_ exposure and cardiovascular disease (CVD). Among this body of evidence, nationwide studies of older adults using Medicare reported positive associations between PM_2.5_ concentrations and heart failure hospital admissions (2019 PM ISA, Section 6.1.3.1). Consistent with the results of these large Medicare studies, additional multicity studies conducted in the Northeast U.S. reported positive associations between short-term PM_2.5_ concentrations and ED visits or hospital admissions for IHD (2019 PM ISA, Section 6.1.2.1), whereas studies conducted in the U.S. and Canada reported positive associations between short-term PM_2.5_ concentrations and ED visits for heart failure. Results from epidemiologic studies conducted in single cities contributed additional support to the causality determination but are less consistent and reported both positive and null associations between PM_2.5_ concentrations and these endpoints (2019 PM ISA, Section 6.1.2 and Section 6.1.3). Overall, the body of IHD and heart failure epidemiologic evidence evaluated in the 2019 PM ISA agreed with the evidence from previous ISAs reporting mainly positive associations between short-term PM_2.5_ concentrations and ED visits and hospital admissions. In addition, several controlled human exposure, animal toxicological, and epidemiologic panel studies provided biologically plausible evidence that PM_2.5_ exposure could result in IHD or heart failure through pathways that include endothelial dysfunction, arterial thrombosis, and arrhythmia (2019 PM ISA, Section 6.1.1). Epidemiologic panel studies evaluated in the 2019 PM ISA also supported biological plausibility for IHD and heart failure endpoints by reporting some evidence of ST segment depression (2019 PM ISA, Section 6.1.2.2), with a controlled human exposure study and animal toxicological study showing decreased cardiac function following short-term PM_2.5_ exposure (2019 PM ISA, Section 6.1.3.2 and Section 6.1.3.3).

Results from additional controlled human exposure studies published since the 2009 PM ISA also support a causal relationship between short-term PM_2.5_ exposure and cardiovascular effects. The most consistent evidence from these studies is for endothelial dysfunction as measured by changes in brachial artery diameter (BAD) or flow-mediated dilatation (FMD). More specifically, and in contrast to the 2009 PM ISA for which a couple of studies did not find changes in endothelial function, multiple studies evaluated in the 2019 PM ISA that examined the potential for endothelial dysfunction reported an effect of PM_2.5_ on measures of blood flow (2019 PM ISA, Section 6.1.13.2) relative to filtered air (FA) exposure. Nevertheless, all studies were not in agreement with respect to the timing of the effect or the mechanism by which reduced blood flow occurred (i.e., endothelial-independent versus endothelial-dependent mechanisms). In addition to endothelial dysfunction, controlled human exposure studies evaluated in the 2019 PM ISA that used CAPs, but not filtered diesel exhaust (DE), generally reported evidence for small increases in blood pressure, although there were inconsistencies across studies with respect to changes in systolic blood pressure (SBP) and diastolic blood pressure (DBP). It is notable however, that CAPs studies evaluated in the 2019 PM ISA that reported increases in one measure of BP (e.g., SBP), but not the other (e.g., DBP) was found to be statistically significant, that other measure of BP usually changed as well, but the change was not found to be statistically significant (2019 PM ISA, Section 6.1.6.3). That said, the results of studies evaluated in the 2019 PM ISA are not in agreement with a couple of older controlled human exposure studies that reported no appreciable changes in blood pressure following short-term PM_2.5_ exposure. In addition, although not entirely consistent, there is further evidence from controlled human exposure studies evaluated in the 2019 PM ISA for conduction abnormalities/arrhythmia (2019 PM ISA, Section 6.1.4.3), changes in HRV (2019 PM ISA, Section 6.1.10.2), changes in hemostasis that could promote clot formation (2019 PM ISA, Section 6.1.12.2), and increases in inflammatory cells and markers (2019 PM ISA, Section 6.1.11.2). Thus, although uncertainties remain, controlled human exposure studies are in coherence with epidemiologic studies by demonstrating that short-term exposure to PM_2.5_ may result in the types of cardiovascular endpoints that could lead to ED visits and hospital admissions.

Animal toxicological studies published since the 2009 PM ISA also support a causal relationship between short-term PM_2.5_ exposure and cardiovascular effects. A study evaluated in the 2019 PM ISA demonstrated decreased cardiac contractility and left ventricular pressure in mice which was coherent with the results of epidemiologic studies that reported associations between short-term PM_2.5_ exposure and heart failure (2019 PM ISA, Section 6.1.3.3). In addition, like in the controlled human exposure studies, there was generally consistent evidence in animal toxicological studies for indicators of endothelial dysfunction (2019 PM ISA, Section 6.1.13.3). Studies in animals also provided evidence for changes in several other cardiovascular endpoints following short-term PM_2.5_ exposure. Although not entirely consistent, these studies provided at least some evidence of conduction abnormalities and arrhythmia (2019 PM ISA, Section 6.1.4.4), changes in HRV (2019 PM ISA, Section 6.1.10.3), changes in BP (2019 PM ISA, Section 6.1.6.4), and evidence for systemic inflammation and oxidative stress (2019 PM ISA, Section 6.1.11.3). Finally, these toxicological studies also provided evidence indicating that genetic background, diet, and PM composition may influence the effect of short-term PM_2.5_ exposure on some of these health endpoints.

As outlined above, across the scientific disciplines, there is evidence for a continuum of cardiovascular-related health effects following short-term exposure to PM_2.5_. These effects ranged from relatively modest increases in biomarkers related to inflammation and coagulation, to subclinical CVD endpoints such as endothelial dysfunction, to ED visits and hospital admissions for outcomes such as IHD and heart failure. This continuum of effects is supported by epidemiologic studies that reported a relatively consistent relationship between short-term PM_2.5_ exposure and CVD-related mortality. These epidemiologic studies also reduced a key uncertainty from the 2009 PM ISA by providing evidence that gaseous pollutants are not likely to confound the PM_2.5_-cardiovascular mortality relationship.

Taken together, the evidence described within the 2019 PM ISA extends the consistency and coherence of the evidence base reported in the 2009 PM ISA and 2004 AQCD. Direct evidence for PM_2.5_ exposure-related cardiovascular effects can be found in several controlled human exposure and animal toxicological studies. In coherence with these results are epidemiologic panel studies also finding that PM_2.5_ exposure is associated with some of the same cardiovascular endpoints reported in controlled human exposure and animal toxicological studies. The number of studies is limited that evaluate these endpoints, and there are some inconsistencies in results across some animal toxicological, controlled human exposure, and epidemiologic panel studies—although this may be due to substantial differences in study design, study populations, or differences in PM composition across air sheds. Nonetheless, the results from these epidemiologic panel, controlled human exposure, and animal toxicological studies, in particular those related to endothelial dysfunction, impaired cardiac function, ST segment depression, thrombosis, conduction abnormalities, and BP, provide coherence and biological plausibility for the consistent results from epidemiologic studies that reported positive associations between short-term PM_2.5_ concentrations and IHD and heart failure, and ultimately cardiovascular mortality. Overall, considering the entire evidence base, the evidence continues to be sufficient to conclude that a causal relationship exists between short-term PM_2.5_ exposure and cardiovascular effects.

#### 3.1.1.2 Recent U.S. and Canadian Epidemiologic Studies

Recent epidemiologic studies conducted in the U.S. and Canada build on the strong epidemiologic evidence base evaluated in the 2019 PM ISA, as well as in previous assessments, which provided the scientific rationale supporting a causal relationship between short-term PM_2.5_ exposure and cardiovascular effects (Section 3.1.1.1). In addition to examining the relationship between short-term PM_2.5_ exposure and specific cardiovascular outcomes (i.e., IHD and myocardial infarction [Section 3.1.1.2.1], cerebrovascular disease and stroke [Section 3.1.1.2.2], heart failure [Section 3.1.1.2.3], arrhythmia [Section 3.1.1.2.4], combined cardiovascular effects [Section 3.1.1.2.5], and cardiovascular mortality [Section 3.1.1.2.6]), analyses within these recent studies also further examined issues relevant to expanding the overall understanding of the effect of short-term PM_2.5_ exposure on cardiovascular outcomes. Specifically, recent studies assessed potential copollutant confounding (Section 3.1.1.2.7) and the lag structure of associations (Section 3.1.1.2.8). The following sections present an evaluation of recent epidemiologic studies conducted in the U.S. and Canada that inform each of the aforementioned topics within the context of the evidence base evaluated and summarized in the 2019 PM ISA. Study-specific details (e.g., study population, exposure assessment approach, confounders considered) for the epidemiologic studies evaluated in this section are presented in Appendix A (Table A-1).

##### 3.1.1.2.1 Ischemic Heart Disease and Myocardial Infarction

IHD is a chronic condition characterized by atherosclerosis and reduced blood flow to the heart. Myocardial infarction (MI), more commonly known as a heart attack, occurs when heart tissue death occurs that is secondary to prolonged ischemia. The effect of short-term PM_2.5_ exposure on acute MI, complications from recent MI, and other acute or chronic IHD are generally evaluated using International Classification of Diseases (ICD) codes recorded when a patient is admitted or discharged from the hospital or ED (ICD-Ninth Revision [ICD-9]: 410−414 or ICD-Tenth Revision [ICD-10]: I20−I25). In experimental or epidemiologic panel studies, indicators of MI include ST segment depression as measured by an electrocardiograph (ECG). The ST segment of an electrocardiogram recorded by surface electrodes corresponds to the electrical activity of the heart registered between ventricular depolarization and repolarization and is normally isoelectric.

The epidemiologic studies reviewed in the 2019 PM ISA (U.S. EPA, 2019) strengthened the evidence characterized in the previous ISA (U.S. EPA, 2009). Most of the evidence for IHD and MI in the 2009 PM ISA was from multicity epidemiologic studies of ED visits and hospital admissions [i.e., the U.S. Medicare Cohort Air Pollution Study (MCAPS) (Dominici et al., 2006), a four-city study in Australia (Barnett et al., 2006), and a study among older adults in several French cities (Host et al., 2008)]. The positive associations reported in these studies were an important line of evidence in the 2009 PM ISA concluding a causal relationship between short-term PM_2.5_ exposure and cardiovascular effects. Uncertainties noted in the 2009 PM ISA with respect to exposure measurement error for those not living near a PM_2.5_ monitor were reduced in the 2019 PM ISA with the consideration of studies that applied hybrid exposure assessment techniques that combine land use regression data with satellite aerosol optical depth (AOD) measurements and PM_2.5_ concentrations measured at fixed-site monitors to estimate PM_2.5_ concentrations. Further, compared with the 2009 PM ISA, the evidence in the 2019 PM ISA was expanded to include studies examining the association of short-term PM_2.5_ exposure ST segment depression in addition to ED visits and hospital admissions for MI.

A recent study extends the evidence presented in the 2019 PM ISA through its examination of the association between short-term PM_2.5_ exposure with hospital admissions for MI among the low-income and/or disabled Americans comprising the Medicaid population (deSouza et al., 2021). deSouza et al. (2021) reported a positive association between PM_2.5_ concentration (0−1 day average) and acute MI (OR: 1.1 [95% CI: 1.03, 1.7]). Recent studies have also addressed methodological challenges. Specifically, Krall et al. (2018) conducted an analysis to elucidate the interpretation of potentially uncertain single-city estimates. These authors used Poisson time-series regression to estimate the associations of 24-hour average PM_2.5_ concentration (lag Day 0) with ED visits for IHD and other cardiovascular outcomes for each of the five cities included in their study. To estimate the association across all cities and the posterior city-specific associations, they fit both traditional Bayesian hierarchical models in which associations were estimated for each outcome separately, and multi-cause multicity (MCM) Bayesian hierarchical models in which multiple cardiovascular outcomes were included in the model simultaneously so that a shared between-city variation could be estimated. The authors also performed analyses to determine whether their results were sensitive to the choice of exposure lag (Section 3.1.1.2.8) or the specification of time trends. The associations between 24-hour PM_2.5_ concentration and IHD ED visits in the traditional multicity model was 1.009 (95% Posterior Interval [PI]: 0.993, 1.025). The comparable association (1.009 [95% PI: 0.998, 1.022]) using MCM was more precise (i.e., narrower confidence intervals). As expected, the city specific estimates were relatively uncertain and heterogeneous across cities when there were a small number of daily ED visits. In another recent study, Leiser et al. (2019) designed an analysis to examine the association between short-term PM_2.5_ exposure and IHD and MI hospital admissions in which the competing risk of mortality was controlled and differences across sex and age categories were examined. These authors used Medicare data for residents, 65 years and older, of the contiguous counties of the Wasatch Front in Utah to examine the association between PM_2.5_ concentration and cardiac hospital re-admissions within 30 days of an index hospitalization, controlling for competing mortality risk. These authors found an association of 3-day average PM_2.5_ concentration (lag 0−2 day) with IHD (HR: 1.03 [95% CI: 0.96, 1.12]) and MI (HR: 1.03 [95% CI: 0.92, 1.16]). Confidence intervals for the age- and sex-stratified results, which were conducted to evaluate potential modification of the association, were generally overlapping.

In another analysis of older adults using Medicare data, Wei et al. (2019) estimated the association of short-term PM_2.5_ exposure with MI hospital admissions and a range of other health conditions, including some diseases that are rarely studied in relationship to PM_2.5_ exposure. Hospital admission data were ascertained using discharge data recorded for Medicare inpatient hospital claims in the continental U.S. (2000−2012). Rather than report a relative risk (RR) estimate, the authors reported the absolute risk per 10 million person-days associated with each 1 unit increase in lag 0−1 PM_2.5_ concentration (i.e., 0.29 [95% CI: 0.17, 0.40]).

Recent single city studies also add to the evidence base presented in the 2019 PM ISA. Liu et al. (2020) examined the modification of the association between short-term PM_2.5_ exposure and MI hospital admissions by long-term NO_2_ exposure. These authors performed a case-crossover study to estimate the association of short-term exposure to PM_2.5_ among individuals living in Calgary neighborhoods with higher long-term NO2 exposure (2004−2012). No association between 0−2-day average PM_2.5_ concentration with hospital admissions for MI among the entire population was observed [OR: 1.03 (95% CI: 0.96, 1.12)]. The association was null in the lowest tertile of long-term NO_2_ concentration (OR: 0.94 [95% CI: 0.86, 1.18]), but the association strengthened in terms of magnitude and precision with increasing NO_2_ concentration tertile (tertile 2, OR: 1.04 [95% CI: 0.94, 1.18]) and (tertile 3, OR: 1.10 [95% CI: 1.00, 1.19]). In addition, an extended analysis of a study reviewed in the 2019 PM ISA supports previous results that found a positive association between short-term PM_2.5_ exposure and ST elevation myocardial infarction (STEMI) (Evans et al., 2017). Specifically, Evans et al. (2017) performed a case-crossover analysis to examine the relationship between short-term PM_2.5_ concentration and STEMI in acute coronary syndrome or unstable angina patients (n = 362) in Monroe County, NY (2007−2012). The association between previous 1-hour PM_2.5_ concentration and STEMI reported by these authors (OR: 1.25 [95% CI: 0.99, 1.59]) was virtually identical to the association (OR: 1.26 [95% CI: 1.01, 1.57]) reported in a previous analysis of this population conducted by Gardner et al. (2014) that reported fewer patients (n = 338) and a shorter follow-up time (2007−2010).

Results of studies of IHD and MI included in the 2009 PM ISA, the 2019 PM ISA and recent studies published since the literature cutoff date of the 2019 PM ISA are summarized in Figure 3-1. Overall, recent studies support and extend the findings of the 2019 PM ISA with additional studies reporting positive associations between short-term PM_2.5_ exposure and both IHD and MI hospital admissions and ED visits.

Figure 3-1 Results of studies of short-term PM_2.5_ exposure and hospital admissions and emergency department visits for ischemic heart disease

Note: †Studies published since the 2009 PM ISA. *U.S. and Canadian studies published since the literature cutoff date (~January 2018) for the 2019 PM ISA. IHD = ischemic heart disease, MCM = multi-cause multicity; MI = myocardial infarction, NR = not reported; NSTEMI = non-ST segment elevation MI, STEMI = ST- elevation MI. Risk estimates are standardized to a 10 μg/m^3^ increase in PM_2.5_ concentrations.

Figure 3 dash 1 presents a summary of associations between short-term P M 2.5 exposure and hospital admissions or emergency department visits for ischemic heart disease based on a 10 micrograms per cubic meter increase in 24-hour average concentrations from recently published studies, studies included in the 2019 P M I S A and previously evaluated studies. Across studies there is evidence of primarily positive associations in studies conducted in the U.S. and Canada, with higher-magnitude associations observed for transmural or S T segment elevation myocardial infarctions. Overall, recent studies support and extend the findings of the 2019 PM ISA with additional studies reporting positive associations between short term P M 2.5 exposure and both I H D and M I hospital admissions and E D visits.

Source: Update of Figure 6-2, 2019 PM ISA.

##### 3.1.1.2.2 Cerebrovascular Disease and Stroke

Cerebrovascular disease (CBVD) typically includes conditions classified under ICD-10 codes I60−I69 (ICD-9: 430−438) such as hemorrhagic stroke (HS), cerebral infarction (i.e., ischemic stroke [IS]) and occlusion of the precerebral and cerebral arteries. IS results from an obstruction within a blood vessel that supplies oxygen to the brain, potentially leading to infarction, and accounts for 87% of all strokes (Goldberger et al., 2008). Hemorrhagic stroke is less common but results in a disproportionate number of fatalities. The HS subtype results from a brain aneurysm or leaking vessel in the brain and can be further categorized by brain region (e.g., intracerebral, or subarachnoid). Comorbidities that increase stroke risk but may also be associated with PM_2.5_ exposure include hypertension, diabetes, CHD, and atrial fibrillation. The 2009 PM ISA and the 2019 PM ISA described inconsistent results across epidemiologic studies that considered the relationship between short-term PM_2.5_ exposure and ED visits and hospital admissions for CBVD, with most studies reporting a lack of an association. Evidence relating to various stroke subtypes was also inconsistent. Results from recent studies of the association between short-term PM_2.5_ concentration and stroke expand the evidence but remain inconsistent overall. Specifically, a study of Medicaid recipients found a large magnitude positive association, while several analyses of established cohorts (Health Professionals Follow-Up [HPFU] study, Women’s Health Initiative [WHI], REasons for Geographic and Racial Differences in Stroke [REGARDS]) report null or inverse associations with stroke regardless of subtype.

Recent studies that analyze data from participants enrolled in several established cohort studies expand the evidence pertaining to stroke subtype. Fisher et al. (2019) estimated the associations of short-term PM_2.5_ exposure with several stroke types, which were ascertained through self-report and expert medical record review, among men enrolled in the HPFU study. The authors reported no evidence of positive associations between lag 0 to 3-day average PM_2.5_ concentration and total stroke (OR: 0.93 [95% CI: 0.78, 1.11]), ischemic (OR: 0.99 [95% CI: 0.81, 1.20]), hemorrhagic (OR: 0.80 [95% CI: 0.50, 1.27]), undetermined type (OR: 0.56 [95% CI: 0.26, 1.24]), and nonfatal stroke (OR: 1.05 [95% CI: 0.84, 1.27]). The authors also evaluated whether factors including age, BMI, smoking status, diabetes mellitus, hypertension, hypercholesterolemia, and current aspirin use potentially modified the associations with IS or HS; however, the number of stroke events within each strata was small and no statistical evidence of heterogeneity between stratified estimates was reported based on chi-square tests of model homogeneity. Sun et al. (2019) also estimated the association of short-term PM_2.5_ with total, hemorrhagic, and ischemic stroke but studied a different population (i.e., post-menopausal women enrolled in the WHI study). Stroke was ascertained through self-report and physician adjudication. Three-day average PM_2.5_ concentration (lag 0−2) was not associated with total (OR: 0.98 [95% CI: 0.92, 1.02]), ischemic (OR: 0.96 [95% CI: 0.90, 1.02]), or hemorrhagic stroke (OR: 1.02 [95% CI: 0.90, 1.17]) in this study. The authors also conducted stratified analysis to examine whether associations varied across categories of age at stroke onset, U.S. census region, smoking status, body mass index, and prior history of diabetes mellitus, hypertension, heart or circulation problems, or arterial fibrillation at enrollment. Across these different stratified analyses, only when examining the stratum for obese women was there some evidence that the association of total stroke with PM_2.5_ may be increased. Finally, McClure et al. (2017) performed a case-cross over analysis among participants in the REGARDS study to determine the association between PM_2.5_ exposure at single-day lags (1, 2, and 3 day lags) and stroke ascertained through self-report followed by a medical record. The REGARDS study oversampled participants in several southern states where stroke risk is high among Black residents in order to study geographic and racial differences in stroke. PM_2.5_ concentration was dichotomized (≤ 12 μg/m^3^ versus 12 to 150.4 μg/m^3^) and the odds of stroke in the higher category was compared with the odds of stroke in the lower category. After adjustment for temperature and relative humidity, no association was reported between PM_2.5_ exposure and stroke, regardless of the lag examined (OR: 0.99 [95% CI: 0.83, 1.19], lag 1). This finding persisted regardless of stroke subtype or exposure lag. Overall, analyses from three established and diverse cohorts did not present evidence of an association between short-term PM_2.5_ exposure and stroke.

Unlike the analyses described above, deSouza et al. (2021) examined the relationship between PM_2.5_ concentration (0−1 day average) and hospital admissions for IS among the low-income and/or disabled Americans comprising the Medicaid population. The OR for the association between PM_2.5_ (lag 0−1 day average) and IS was 1.12 (95% CI: 1.04, 1.20). In a study designed to gain an understanding of the heterogeneity in results across single-city studies, Krall et al. (2018) examined the associations of 24-hour PM_2.5_ concentration (lag 0) with ED visits for stroke. These authors estimated the associations across five cities using a traditional Bayesian hierarchical approach and a MCM Bayesian hierarchical model in which all outcomes were modeled simultaneously. The association of 24-hour PM_2.5_ concentration (lag 0) with ED visits for stroke was 1.008 (95% CI: 0.984, 1.034) in the traditional multicity model and more precise (i.e., narrower confidence intervals) 1.008 (95% PI: 0.995, 1.021) in the MCM model. However, in a single city study of recurrent IS in Nueces county Texas, Wing et al. (2017) did not report evidence of an association between PM_2.5_ concentration during the previous day (lag 1), and the odds of recurrent stroke (OR: 0.95 (95% CI: 0.71−1.28]).

Results of studies of short-term exposure to PM_2.5_ and ED visits or hospital admissions for stroke included in the 2009 PM ISA, the 2019 PM ISA and recent studies published since the literature cutoff date of the 2019 PM ISA are summarized in Figure 3-2. The epidemiologic evidence for an association between short-term PM_2.5_ and various stroke subtypes assessed in the 2019 PM ISA was characterized as inconsistent and limited. Some recent studies report evidence of a positive association with stroke while others report null or inverse associations. Therefore, the evidence pertaining to the effect of short-term PM_2.5_ exposure and stroke remains inconsistent overall.

Figure 3-2 Results of studies of short-term PM_2.5_ exposure and hospital admissions and emergency department visits for stroke

Note: †Studies published since the 2009 PM ISA. *U.S. and Canadian studies published since the literature cutoff date (~January 2018) for the 2019 PM ISA. NR = not reported. Risk estimates are standardized to a 10 μg/m^3^ increase in PM_2.5_ concentrations.

Figure 3 dash 2 presents a summary of associations between short-term P M 2.5 exposure and hospital admissions or emergency department visits for stroke based on a 10 micrograms per cubic meter increase in 24-hour average concentrations from recently published studies, studies included in the 2019 P M I S A and previously evaluated studies. Across studies there is evidence of both null and positive associations, with higher magnitude association for ischemic stroke compared to hemorrhagic stroke or transient ischemic attacks.

Source: Update of Figure 6-5, 2019 PM ISA.

##### 3.1.1.2.3 Heart Failure

Heart failure (HF) refers to a set of conditions in which pumping action of the heart is weakened. In congestive heart failure (CHF), the flow of blood from the heart slows, failing to meet the oxygen demands of the body, and returning blood can back up, causing swelling or edema in the lungs or other tissues (typically in the legs and ankles). The effect of short-term PM_2.5_ exposure on people with CHF―which is a chronic condition―is generally evaluated using ICD codes recorded when a patient is admitted or discharged from the hospital or ED. The relevant diagnostic codes for heart failure are ICD-9 428 and ICD-10 I50. These codes encompass left, systolic, diastolic, and combined heart failure. Similar to the other cardiovascular outcomes, the majority of the evidence in the 2009 PM ISA was from epidemiologic studies of hospital admissions and ED visits [i.e., multicity studies in the U.S.(Dominici et al., 2006) and Australia (Barnett et al., 2006)]. Studies evaluated in the 2019 PM ISA strengthened this line of evidence with additional multicity epidemiologic studies conducted in the U.S., Canada, and Europe generally reporting positive associations between short-term PM_2.5_ exposure and hospital admissions and ED visits for HF. Results from single-city studies tended to be less consistent. Several recent studies add to the body of evidence providing additional support for a positive association between short-term PM_2.5_ exposure and ED visits and hospital admissions for exacerbations of HF.

Recent studies conducted examined the association of short-term PM_2.5_ exposure with readmission to the hospital for HF within 30 days of an index hospitalization. Leiser et al. (2019) used Medicare data to examine the association of short-term PM_2.5_ exposure and cardiac hospital re-admissions among older adults within 30 days of the index hospitalization. These authors reported an association of 3-day average PM_2.5_ concentration (lag 0−2 day) with readmission for HF (HR: 1.10 [95% CI: 1.03, 1.19]). Confidence intervals of the age and sex stratified results were generally overlapping. In another study of 30-day hospital readmission, Wyatt et al. (2020c) characterized the association of short-term PM_2.5_ exposure with CHF among end-stage renal disease patients (i.e., those undergoing hemodialysis). Both readmission within 1 to 7 days and readmission between 8 to 30 days was evaluated. The RR for the association of 24-hour PM_2.5_ concentration (lag 0) with HF readmission within 1−7 days was 1.37 (95% CI: 1.14, 1.60). The association with late readmission (8−30 days) was 1.41 (95% CI: 1.25, 1.58). In another unique population, deSouza et al. (2021) estimated the association of PM_2.5_ concentration (0−1 day average) with CHF hospital admissions among the low-income and/or disabled Americans comprising the Medicaid population. The OR for the association between PM_2.5_ (lag 0−1 day average) and CHF was 1.10 (95% CI: 1.04, 1.16).

In addition to the studies described above that focus on 30-day hospital readmission, Krall et al. (2018) examined the association of 24-hour PM_2.5_ concentration (lag Day 0) with ED visits for CHF in an analysis in five cites that was designed to compare methods used for multicity studies. These authors estimated the multicity associations using a traditional Bayesian hierarchical approach and a MCM Bayesian hierarchical model in which all outcomes were modeled simultaneously. The association of 24-hour PM_2.5_ concentration (lag 0) with CHF was 1.003 (95% CI: 0.986, 1.021) in the traditional multicity model and 1.003 (95% PI: 0.992, 1.016) in the MCM model. In another study, Wei et al. (2019) used Medicare data (i.e., inpatient hospital claims) to estimate the association of short-term PM_2.5_ exposure with CHF hospital admissions in the continental U.S. between 2000 and 2012. Rather than report a RR estimate, the authors reported the absolute increase in risk of admission to hospital per 10 million person-days associated with each 1 μg/m^3^ increase in lag 0−1 PM_2.5_ (i.e., 0.68 [95% CI: 0.52 to 0.84]).

Results of studies of HF included in the 2009 PM ISA, the 2019 PM ISA and recent studies published since the literature cutoff date of the 2019 PM ISA are summarized in Figure 3-3. Overall, these studies support and extend the limited evidence in the 2019 PM ISA, reporting positive associations between short-term PM_2.5_ exposure and HF.

Figure 3-3 Results of studies of short-term PM_2.5_ exposure and hospital admissions and emergency department visits for heart failure

Note: †Studies published since the 2009 PM ISA. *U.S. and Canadian studies published since the literature cutoff date (~January 2018) for the 2019 PM ISA. ESRD = end-stage renal disease; HF = heart failure, HHD = hypertensive heart disease, NR = not reported; re-HA = readmission to the hospital for heart failure. Risk estimates are standardized to a 10 μg/m^3^ increase in PM_2.5_ concentrations.

Figure 3 dash 3 presents a summary of associations between short-term P M 2.5 exposure and hospital admissions or emergency department visits for heart failure based on a 10 micrograms per cubic meter increase in 24-hour average concentrations from recently published studies, studies included in the 2019 P M I S A, and previously evaluated studies. Across studies there is evidence of primarily positive associations. Overall, the recent studies support and extend the limited evidence in the 2019 P M I S A.

Source: Update of Figure 6-3, 2019 PM ISA.

##### 3.1.1.2.4 Arrhythmia

In epidemiologic studies, the association between short-term PM_2.5_ exposure and arrhythmia is generally evaluated using ICD codes (ICD-9 427 or ICD-10 149.9) for hospital admissions and ED visits. Out-of-hospital cardiac arrests (OHCA) that typically result from ventricular arrhythmia were evaluated with the body of evidence pertaining to arrhythmia. Overall, the evidence evaluated in the 2009 PM ISA and the 2019 PM ISA was limited. However, in the 2019 PM ISA, some evidence from epidemiologic panel studies indicated an association between short-term PM_2.5_ exposure and potential indicators of arrhythmia (e.g., ectopic beats and tachycardia). The small number of recent studies support a positive association of short-term PM_2.5_ exposure with arrythmias.

Recent studies examined the association of short-term exposure to PM_2.5_ and dysrhythmia adding to the limited evidence evaluated in the 2019 PM ISA. Wyatt et al. (2020c) examined 30-day hospital re-admission among end-stage renal disease patients (i.e., those undergoing hemodialysis). Both early re-admission within 1 to 7 days and later readmission after 8 to 30 days was evaluated. The RR for the association of 24-hour PM_2.5_ concentration (lag 0) with dysrhythmia and conduction disorder readmissions within 1−7 days was 1.48 (95% CI: 1.23, 1.74). The association with late re-admission (8−30 days) was 1.31 (95% CI: 1.13, 1.50). In another study of 30-day hospital re-admission, Leiser et al. (2019) estimated the association of PM_2.5_ concentration and cardiac arrhythmia among Medicare beneficiaries who survived a cardiovascular event, and examined differences across sex and age in models that adjusted for the competing risk of readmission due to a non-cardiovascular cause or death. These authors reported an inverse association of 3-day average PM_2.5_ concentration (lag 0−2 days) with re-admission for dysrhythmia or arrhythmia (HR: 0.88 [95% CI: 0.75, 1.02]). Confidence intervals of the age and sex stratified results were generally overlapping and did not provide evidence of effect modification. Krall et al. (2018) examined the association of 24-hour PM_2.5_ concentration (lag Day 0) with CVD ED visits in an analysis designed to compare methods for multicity analyses. These authors estimated the associations with CVD ED visits including visit for dysrhythmia across five cities using a traditional Bayesian hierarchical approach and a MCM Bayesian hierarchical model in which all outcomes were modeled simultaneously. The association between 24-hour PM_2.5_ concentration (lag 0) with ED visits for dysrhythmia was 1.009 (95% CI: 0.993, 1.023) in the traditional Bayesian hierarchical model and 1.009 (95% PI: 0.998, 1.022) in the MCM Bayesian hierarchical model. Finally, Wei et al. (2019) estimated the association of short-term PM_2.5_ exposure with arrhythmia hospital admissions in a study using discharge data recorded for Medicare inpatient hospital claims in the continental the U.S. (2000−2012). Rather than report a RR estimate, the authors reported the absolute increase in risk of admission to hospital per 10 million person-days associated with each 1 μg/m^3^ increase in lag 0−1 PM_2.5_ concentration (i.e., 0.26 [95% CI: 0.13 to 0.38]).

Results of studies of arrythmia included in the 2009 PM ISA, the 2019 PM ISA and recent studies published since the 2019 PM ISA are summarized in Figure 3-4. Overall, these studies extend the limited evidence evaluated in the 2019 PM ISA as they report positive associations between short-term PM_2.5_ exposure and arrhythmia in most studies. However, an analysis of Medicare recipients in Utah that adjusted for the competing risk of readmission for a non-cardiovascular cause or death reported an inverse association.

Figure 3-4 Results of studies of short-term PM_2.5_ exposure and hospital admissions and emergency department visits for arrhythmia

Note: †Studies published since the 2009 PM ISA. *U.S. and Canadian studies published since the literature cutoff date (~January 2018) for the 2019 PM ISA. HF = heart failure, HHD = hypertensive heart disease, NR = not reported. Risk estimates are standardized to a 10 μg/m^3^ increase in PM_2.5_ concentrations.

Figure 3 dash 4 presents a summary of associations between short-term P M 2.5 exposure and hospital admissions or emergency department visits for arrhythmia based on a 10 micrograms per cubic meter increase in 24-hour average concentrations from recently published studies, studies included in the 2019 P M I S A and previously evaluated studies. Across studies, generally inconsistent associations are observed, with some positive and some negative associations reported. All of the associations are relatively small in magnitude.

Source: Update of Figure 6-4, 2019 PM ISA.

##### 3.1.1.2.5 Combinations of Cardiovascular-Related Outcomes

In addition to analyses of individual CVDs (e.g., MI, stroke, and HF), epidemiologic studies examined CVDs in aggregate (i.e., specific combination of cardiovascular diseases). The 2009 PM ISA and the 2019 PM ISA reviewed multicity studies of adults ages 65 years and older that provided strong evidence of an association [(Bell et al., 2008; Host et al., 2008; Barnett et al., 2006); Table 6-19 of the 2019 PM ISA]. Studies of aggregate CVD have larger case counts than studies of specific CVDs, potentially providing statistical power needed to detect associations. Several recent studies examine the association between short-term exposure to PM_2.5_ and CVD hospital admissions and ED visits, and report results that are generally consistent with studies evaluated in the 2019 PM ISA.

In a study of low-income and/or disabled Americans enrolled in Medicaid deSouza et al. (2021) estimated the association of PM_2.5_ concentration (0−1 day average) with cardiovascular hospital admissions. The association of PM_2.5_ concentration (0−1 day average) with all CVD hospital admissions was 1.09 (95% CI: 1.06, 1.11). In addition, the authors reported that the association with all CVD hospital admissions was larger in magnitude when restricting the analysis to PM_2.5_ concentrations less than 25 micrograms per cubic meter (µg/m^3^) (OR: 1.13 [95% CI: 1.09, 1.16]). The association was similar among older and younger adults (OR: 1.09 [95% CI: 1.06, 1.13]) among those < 65 years old 1.08 (95% CI: 1.06, 1.09) versus among those ≥ 65 years old. In another study, Wyatt et al. (2020c) examined hospital admissions among end-stage renal disease patients (i.e., those undergoing hemodialysis). Same-day PM_2.5_ concentration (lag 0) was associated with an increase in the risk of CVD hospital admissions in this population (RR: 1.09 [95% CI: 1.02, 1.17]).

Some recent studies of ED visits report null associations between short-term PM_2.5_ concentration and aggregated CVD outcomes in adjusted models. Krall et al. (2018) examined the associations of 24-hour PM_2.5_ concentration (lag Day 0) with CVD ED visits, estimating the association across five cities using a traditional Bayesian hierarchical approach. A null association between 24-hour PM_2.5_ concentration (lag 0) with CVD ED visits was observed (1.0 [95% CI: 0.992, 1.009]) while positive associations were reported for specific cardiovascular outcomes evaluated. Ye et al. (2018) performed a study to estimate the association between short-term exposure to PM_2.5_ components that are not routinely measured, including water-soluble metals, and CVD ED visits for a five-county area of Atlanta during the period 1998 to 2013. In a single-pollutant model, these authors reported a positive association of 24-hour PM_2.5_ concentration (lag 0) with CVD ED visits; however, the association was null after adjustment for water-soluble iron (WS Fe), which may be an indicator for certain aspects of traffic pollution.

Evidence assessed in the 2019 PM ISA from multicity studies reported consistent positive associations between short-term PM_2.5_ exposure and cardiovascular-related ED visits and hospital admissions. Recent studies, including one in renal disease patients and another in the Medicaid population, support the conclusion of the 2019 PM ISA and extend the evidence base.

##### 3.1.1.2.6 Cardiovascular Mortality

As noted in the 2019 PM ISA, “studies that examine the association between short-term PM_2.5_ exposure and cause-specific mortality outcomes, such as cardiovascular mortality, provide additional evidence for PM_2.5_-related cardiovascular effects, specifically whether there is evidence of an overall continuum of effects” (2019 PM ISA, Section 6.1.9). Epidemiologic studies evaluated in the 2019 PM ISA, expanded upon the evidence presented in the 2009 PM ISA indicating consistent positive associations between short-term PM_2.5_ exposure and cardiovascular mortality (2019 PM ISA, Section 6.1.9). Experimental evidence (i.e., both animal toxicological and controlled human exposure studies) presented within both the 2009 PM ISA and 2019 PM ISA provided coherence and biological plausibility for the PM_2.5_-related cardiovascular mortality associations reported in epidemiologic studies. A recent multicity study conducted by Lavigne et al. (2018) in addition to examining short-term PM_2.5_ exposure and total (nonaccidental) mortality also examined cause-specific mortality and provided evidence that continues to support a relationship between short-term PM_2.5_ exposure and cardiovascular mortality (Section 3.2.1.2.2).

##### 3.1.1.2.7 Consideration of Copollutant Exposures

In the examination of potential confounding of the relationship between short-term PM_2.5_ exposure and cardiovascular effects by exposure to copollutants, it is informative to evaluate whether PM_2.5_ risk estimates are changed in copollutant models. As noted in the Appendix (Table A-1) to the 2019 PM ISA, copollutant models are not without their limitations, such as instances for which correlations are high between pollutants resulting in greater bias in results. However, a change in the PM_2.5_ risk estimate, after adjustment for a copollutant may indicate the potential for confounding. The evidence reviewed in the 2019 PM ISA represented an expanded set of studies that performed analyses using two-pollutant, also referred to as copollutant, models. These studies addressed a data gap, generally supporting an association of PM_2.5_ with cardiovascular-related health effects that persisted after adjustment for copollutant exposures (i.e., O_3_, NO_2_, SO_2_, CO, and PM_10−2.5_). In addition to copollutant models, a limited number of studies that examined the joint effects of multiple pollutants provided information on the role of PM_2.5_ within the complex air pollution mixture. Overall, the evidence and the available statistical methods were limited with respect to characterizing the multipollutant effects of air pollution on cardiovascular disease. This limited evidence neither consistently nor coherently indicated a stronger or weaker effect of combined exposure to PM_2.5_ and another pollutant compared with exposure to a single pollutant alone (Luben et al., 2018).

Recent studies that examine the potential confounding of the relationship between short-term PM_2.5_ exposure and cardiovascular effects by copollutants are limited; however, the results of available studies are consistent with the evidence evaluated in the 2019 PM ISA. deSouza et al. (2021) found that the positive single-pollutant association (OR: 1.09 [95% CI: 1.06, 1.11]) between all CVD and short-term PM_2.5_ observed among Medicaid recipients persisted in a two-pollutant model adjusted for ozone (OR: 1.10 [95% CI: 1.07, 1.12]). In another recent study, Wing et al. (2017) reported no association between short-term PM_2.5_ exposure and recurrent stroke in both single- and two-pollutant model that were adjusted for ozone. This study does not alter the conclusion of the 2019 PM ISA with respect to copollutant confounding because associations between PM_2.5_ exposure and stroke were not consistently reported.

##### 3.1.1.2.8 Lag Structure of Associations

An examination of the association between short-term PM_2.5_ exposure and cardiovascular effects across different lag days can inform whether PM_2.5_ elicits an immediate (e.g., lag 0–1 days), delayed (e.g., lag 2–5 days), or prolonged (e.g., lag 0–5 days) effect on these endpoints, and whether the effect of PM_2.5_ is consistent across cardiovascular endpoints. The evidence reviewed in the 2019 PM ISA supported an immediate effect of short-term PM_2.5_ exposure on hospital admissions and ED visits for aggregate CVD outcomes, IHD, HF, and OHCA, as well as for cardiovascular mortality. This evidence came from the evaluation of both single-day and multiday lags, as well as studies that evaluated subdaily lag periods. By contrast, the studies evaluated in the 2019 PM ISA did not provide evidence of a consistent lag period for the association of short-term PM_2.5_ exposure with CBVD and arrhythmia. Overall, stronger associations in terms of magnitude and precision were reported for immediate lags for most cardiovascular-related outcomes, and the associations tended to be stronger for immediate multiday lag periods (i.e., 0−1, 0−2) compared with immediate single-day lag periods (i.e., 0, 1).

Several recent studies conducted analyses to determine whether results were sensitive to the choice of exposure lag. Overall, the available studies continue to support an immediate effect of short-term PM_2.5_ exposure on MI. In a case-crossover analysis of STEMI among unstable angina patients, Evans et al. (2017) found that the association between previous 1-hour PM_2.5_ concentration and STEMI became less precise (i.e., wider confidence intervals) at exposure lags up to 24 or 48 hours and null with an exposure lag of 72 hours. In a multicity analysis of ED visits for a number of cardiovascular outcomes (i.e., IHD, CHF, Dysrhythmia), Krall et al. (2018) found that lags longer than their a priori choice (i.e., same-day exposure [lag 0]) did not produce substantially different results. Studies that examined the lag structure of associations in relation to stroke reported null associations that were unchanged regardless of the choice of lag (Fisher et al., 2019; McClure et al., 2017). In a study of recurrent IS in Nueces county Texas, Wing et al. (2017) reported null associations with short-term PM_2.5_ concentrations on lag Day 1, 2, and 3 and an inverse association with same day exposures.

#### 3.1.1.3 Recent Epidemiologic Studies Examining the PM_2.5_-Cardiovascular Effects Relationship through Accountability Analyses and Alternative Methods for Confounder Control

As discussed in Section 3.1.1.1, the 2019 PM ISA reported that there was sufficient evidence to conclude that a causal relationship exists between short-term PM_2.5_ exposure and cardiovascular effects. However, the body of evidence that supported this causality determination did not include any epidemiologic studies that conducted accountability analyses or employed alternative methods for confounder control because no such studies were published prior to the literature cutoff date for the 2019 PM ISA. Studies that conduct accountability analyses can provide insight on whether the implementation of environmental policies or air quality interventions result in changes/reductions in air pollution concentrations and the corresponding effect on health outcomes. Additionally, accountability studies can reduce uncertainties related to residual confounding of temporal and spatial factors. Alternative methods for confounder control seek to mimic randomized experiments through the use of study design and advanced statistical methods to reduce the potential bias of effects due to confounding more than traditional regression model approaches. Examples of alternative methods for confounder control are general propensity scores and inverse probability weighting models. Since the literature cutoff date for the 2019 PM ISA, several studies that conducted accountability analyses or implemented alternative methods for confounder control have been published, which further inform the relationship between short-term PM_2.5_ exposure and cardiovascular effects, specifically cardiovascular hospital admissions (Table A-2). The cardiovascular-related hospital admissions examined ranged from specific cardiovascular endpoints such cardiac arrhythmia, hypertension, ST segment elevation myocardial infarction to a broader assessment of all cardiovascular diseases.

Zhang et al. (2018) and Wang et al. (2019) both conducted accountability analyses that evaluated whether associations between short-term PM_2.5_ exposures and cardiovascular hospital admissions differed before, during, and/or after the implementation of environmental policies to improve air quality in cities in New York. Zhang et al. (2018) estimated the rate of cardiovascular hospital admissions associated with short-term PM_2.5_ concentrations, and whether the rates differed before (2005−2007), during (2008−2013), or after (2014−2016) the implementation of multiple national and state policies aimed at improving air quality in multiple cities in New York. Using a time-stratified, case-crossover design, the authors employed conditional logistic regression models to estimate the rate ratio for cardiovascular hospital admissions, examining associations withPM_2.5_ at lag 0 or averaged over the previous 1–7 days (lag 0–1, 0–2, 0–3, 0–4, 0–5, 0−6), adjusting for temperature and relative humidity. The excess rate of hospital admissions decreased over the entire time period for total cardiovascular disease (before: 1.4% [95% CI: 1.0, 1.8]; during: 1.1% [95% CI: 0.7, 1.5]; after: 1.0% [95% CI: 0.3, 1.17]), with the largest association, in terms of magnitude, observed in the “before” implementation period and weaker associations observed in the “after” implementation period for the 0–6 day lag average. Similar results were reported for cerebrovascular disease, ischemic stroke, chronic rheumatic heart disease, hypertension, ischemic heart disease, and myocardial infarction. The incidence rates of all disease categories decreased across the study period. However, there was no difference in the excess rate of most cardiovascular disease subgroups associated with each interquartile range increase in PM_2.5_ concentration “after” the implementation of environmental policies and actions (2014–2016) compared with “before” (2005–2007) or “during” (2008–2013) implementation. Conversely, there were increases in the excess rate of hospital admissions for cardiac arrhythmia and congestive heart failure in the “after” period compared with the “before” and “during” periods. Although the change in the excess rates for cause-specific cardiovascular hospital admissions was relatively small in magnitude and varied by lag period and location, overall, short-term increases in ambient PM_2.5_ concentrations were associated with increased rates of hospital admissions for total cardiovascular disease, cardiac arrhythmias, heart failure ischemic stroke, ischemic heart disease, and myocardial infarction.

Wang et al. (2019) also used a time-stratified case-crossover study design to examine whether the rate of ST segment elevation myocardial infarction (STEMI) is associated with PM_2.5_ concentrations in the previous few hours or days, and whether these associations were modified by periods in which there were changes in environmental policies in Rochester, NY. The authors hypothesized that increases in the rate of STEMI associated with short-term PM_2.5_ exposures would be smaller after the changes were implemented (2014−2016), compared with the periods before (2005−2007) and during (2008−2013) implementation. Within this study, referent days were selected as the same hour of the event on the same day earlier and later than the case event within the same month and calendar year. The analyses examined hourly exposures of 1 hour (lag hour 1), 3-hour avg (lag hours 0−2), 12-hour average (lag hours 0−11), 24-hour average (lag hours 0−23), 48-hour average (lag hours 0−47), and 72-hour average (lag hours 0−71) prior to the onset of STEMI symptoms. To examine whether the rate of STEMI was associated with different hourly average concentrations of PM_2.5_ and were modified by the period of when changes were implemented, two interaction terms for the “period” (a categorical variable to distinguish periods of before, during, and after implementation) and PM_2.5_ concentrations of the time period were included in the conditional logistic regression model. Over the entire study period, there was a decrease of approximately 30% in PM_2.5_ concentrations. Across the three periods, there was a decrease in the rate of STEMI for an interquartile range (7.59 μg/m^3^) increase in PM_2.5_ concentration in the previous hour (lag hour 0) (before: OR = 1.03 [95% CI: 0.91, 1.17]; during: OR = 1.07 [95% CI: 0.92, 1.24]; after: OR = 0.99[95% CI: 0.81, 1.21]). However, in the previous 72-hour (lag hours 0−71) period, the rate of STEMI increased with an IQR increase in PM_2.5_ concentration across the three periods from 0.91 (95% CI: 0.79, 1.05) before, 0.98 (95% CI: 0.82, 1.18) during, and 1.11 (95% CI: 0.88, 1.41) after implementation. Although the results of this accountability analysis are small in magnitude or null across the time periods, this study provides support that implementation of air quality policies can lead to reductions in PM_2.5_ concentrations and subsequently may affect health effects associated with PM_2.5_ exposures.

The use of alternative methods for confounder control can further inform the causal nature of the relationship between short-term PM_2.5_ exposure and cardiovascular effects through the use of advanced statistical methods to reduce uncertainties with respect to confounding. Recent epidemiologic studies that use these alternative methods have primarily focused on examining cardiovascular hospital admission rates. Inverse probability weighting (IPW) is an alternative method for confounder control that analyzes observational data in a way that approximates conducting a randomized experiment to make exposure independent of all potential confounders, rather than to control for the confounders in the outcome regression (Qiu et al., 2020). To explore the relationship between short-term PM_2.5_ exposure and cardiovascular disease hospital admissions, Qiu et al. (2020) used IPW propensity score methods in a case-crossover study design to examine an unconstrained distributed lag (lag 0−5) for acute myocardial infarction (AMI), CHF, and IS hospital admissions among New England Medicare participants between 2000 and 2012. In the first step, a linear regression model was fitted with the exposure lag of interest against the other five lags of PM_2.5_ exposure and six lags of ozone along with linear and quadratic terms for temperature (lag 0 and 1) and linear terms for relative humidity (lag 0 and 1) to control for potential confounding by meteorological conditions. In the second step, under the assumptions that no important confounders are omitted and correct specification of the propensity score models, for each of the six lags the outcome was regressed against PM_2.5_ at each individual lag with weights specific to each individual lag. After using the weights generated from propensity score models to predict the exposure at each lag of interest, copollutant exposure and meteorological variables were used to create a pseudo-randomized population. The pseudo-randomized population was subsequently used in conditional logistic regression models to regress cardiovascular hospital admissions against each exposure lag, estimating the marginal effect of each lag of exposure independent of covariates.

Using the IPW method, Qiu et al. (2020) reported an increase of 4.3% (95% CI: 2.2, 6.4) in AMI hospital admission rate, 3.9% (95% CI: 2.4, 5.5) in CHF rate, and 2.6% (95% CI: 0.4, 4.7) in IS hospital admission rate for a 10 μg/m^3^ increase in 24-hour average PM_2.5_ concentrations. While Qiu et al. (2020) reported associations using alternative methods for confounder control that further confirm an association between short-term PM_2.5_ exposure and cardiovascular-related hospital admissions, several assumptions were used by the authors when applying the IPW methods that are important to recognize. First, the authors assumed exchangeability, meaning that there was no unmeasured confounding, with the caveat that the authors did not have the resources to obtain all the potential unmeasured confounders. This assumption was tested through a series sensitivity analyses, testing the most critical confounder of temperature by including more lags of temperature and spline adjustments. Because the results from the sensitivity analyses involving temperature did not deviate from the estimates in the main analysis, it can be inferred that the most important confounders with available data were adjusted for and that the time-invariant variables are not potential confounders due to the case-crossover study design. The second assumption was positivity, which was guaranteed in the analysis through the positivity exclusion. Qiu et al. (2020) note that the positivity assumption means there are both exposed and non-exposed individuals at every level of the confounders. The last assumption is consistency, or that the observed outcome is exactly the same as the potential outcome the individual will have under the exposure assigned; however, this assumption is difficult to prove. Overall, the inverse probability weighted distributed lag model employed by Qiu et al. (2020) provides unconstrained, less conditional effect estimates that are less influenced by highly correlated covariates and reduces uncertainties regarding unmeasured confounders.

The recent studies that utilized accountability approaches and alternative methods for confounder control evaluated in this section provide additional support for a relationship between short-term PM_2.5_ exposure and cardiovascular effects. These studies reported consistent associations between cardiovascular hospital admissions with short-term PM_2.5_ exposures across different statistical methods and study designs, which reduce uncertainties related to potential confounder bias, and further supports the conclusions of the 2019 PM ISA.

#### 3.1.1.4 Summary of Recent Evidence in the Context of the 2019 Integrated Science Assessment for Particulate Matter Causality Determination for Short-Term PM_2.5_ Exposure and Cardiovascular Effects

Recent epidemiologic studies published since the 2019 PM ISA support and extend the evidence that contributed to the conclusion of a causal relationship between short-term PM_2.5_ exposure and cardiovascular effects in the 2019 PM ISA. Multicity analyses of the relationship between short-term exposure to PM_2.5_ and cardiovascular ED visits and hospital admissions were an important consideration in this causality determination. Recent studies support the evidence characterized in the 2019 PM ISA, extending the evidence relating to hospital admissions and ED visits for specific outcomes (i.e., IHD, MI, HF, and arrhythmia) with positive association observed across diverse populations (i.e., older adults enrolled in Medicare, Medicaid recipients, and patient populations). With respect to stroke, the evidence in the 2019 PM ISA was characterized as inconsistent. Recent studies of established cohorts (i.e., WHI, REGARDS, and HPFU) extend this evidence with observations of null or inverse associations between short-term PM_2.5_ exposure and stroke, regardless of stroke subtype. However, an association between short-term PM_2.5_ exposure and IS was observed in the Medicaid population.

Multiple studies included in the 2019 PM ISA applied hybrid exposure assessment techniques that combined land use regression with satellite AOD measurements and PM_2.5_ concentrations measured at fixed site monitors. Most recent studies also rely on exposure assessment strategies that characterize the temporal and spatial variability of short-term PM_2.5_ concentrations. Recent studies also performed analyses to address methodological challenges, including applying techniques to elucidate uncertainties related to the observation of variable results across single-city studies and controlling for competing mortality risks in studies of ED visits and hospital admissions.

The evidence in the 2019 PM ISA indicated that the associations between short-term PM_2.5_ exposure and cardiovascular effects generally persisted in models that were adjusted for copollutants. A recent study that reports copollutant model results supports the evidence characterized in the 2019 PM ISA that the effect of short-term PM_2.5_ exposure on the cardiovascular system is independent of ozone exposure. Recent studies continue to support an immediate effect of short-term PM_2.5_ exposure on the cardiovascular system that was described in the 2019 PM ISA. Finally, recent studies that employed alternative methods for confounder control or conducted accountability analyses when examining short-term PM_2.5_ exposure and cardiovascular-related hospital admissions provide additional support for a relationship between short-term PM_2.5_ exposure and cardiovascular effects while reducing uncertainties related to potential confounder bias.

### 3.1.2 Long-Term PM_2.5_ Exposure

The following sections represent a summary of the evidence and the corresponding causality determination for long-term PM_2.5_ exposure and cardiovascular morbidity presented within the 2019 PM ISA (Section 3.1.2.1) along with an evaluation of recent epidemiologic studies that fall within the scope of the Supplement (i.e., studies conducted in the U.S. and Canada) and were published since the literature cutoff date of the 2019 PM ISA (Section 3.1.2.2).^15^ In addition, with the expansion of epidemiologic studies that used statistical approaches that attempt to more extensively account for confounders and are more robust to model misspecification (i.e., used alternative methods for confounder control), recent studies that employed such methods are also evaluated (Section 3.1.2.3), which can further inform the relationship between long-term PM_2.5_ exposure and cardiovascular morbidity. Finally, a summary of the results of recent studies evaluated within the section is presented in the context of the scientific conclusions detailed in the 2019 PM ISA (Section 3.1.2.4). The evaluation of recent studies presented in this Supplement adds to the collective body of evidence reviewed in the process of reconsidering the PM NAAQS.

#### 3.1.2.1 Summary and Causality Determination from 2019 Integrated Science Assessment for Particulate Matter

The evidence reviewed in the 2009 PM ISA provided the rationale to conclude that there is a “causal relationship between long-term PM_2.5_ exposure and cardiovascular effects” (U.S. EPA, 2009). Studies of mortality from cardiovascular causes provided the strongest evidence in support of this conclusion. While several studies included in the 2009 PM ISA reported associations between long-term PM_10_ exposure and morbidity outcomes such as post-MI CHF and deep vein thrombosis (DVT), studies of PM_2.5_ were limited. One large prospective study of postmenopausal women reported an increased risk of cardiovascular events, including CHD and stroke, in association with long-term exposure to PM_2.5_ (Miller et al., 2007). Cross-sectional analyses provided supporting evidence and experimental studies demonstrating enhanced atherosclerotic plaque development and inflammation following long-term exposures to PM_2.5_ CAPs provided biological plausibility for the epidemiologic findings. In addition, evidence from the limited number of toxicological studies reporting CAPs-induced effects on hypertension and vascular reactivity were drawn upon to support the causality determination.

In addition to evaluating evidence across scientific disciplines that examined the relationship between long-term PM_2.5_ exposure and cardiovascular effects, the 2019 PM ISA characterized whether evidence supported biologically plausible mechanisms by which long-term PM_2.5_ exposure could lead to cardiovascular effects. This evaluation consisted of an assessment of animal toxicological, controlled human exposure, and epidemiologic studies that examined a range of cardiovascular effects (2019 PM ISA, Section 6.2.1). Plausible biological mechanisms were identified by which inhalation exposure to PM_2.5_ could progress from initial events to apical events reported in epidemiologic studies (2019 PM ISA, Figure 6-2). The first proposed pathway begins as respiratory tract inflammation leading to systemic inflammation. The second proposed pathway involves modulation of the autonomic nervous system. Once these pathways are initiated, there is evidence from experimental and observational studies that long-term exposure to PM_2.5_ may result in a series of pathophysiological responses that could lead to cardiovascular events such as IHD and heart failure (2019 PM ISA, Figure 6-1).

The evidence for the relationship between long-term exposure to PM_2.5_ and cardiovascular effects as characterized in the 2019 PM ISA is described below and summarized in Table 3-2, using the framework for causality determinations described in the Preamble to the ISAs (U.S. EPA, 2015).

Table 3-2 Summary of evidence for a causal relationship between long-term PM_2.5_ exposure and cardiovascular effects from the 2019 Integrated Science Assessment for Particulate Matter

Rationale for Causality Determination^a^ | Key Evidence^b^ | Key References and Sections in the 2019 PM ISA^b^ | PM_2.5_ Concentrations Associated with Effects^c^ (µg/m^3^)
Consistent epidemiologic evidence from multiple studies at relevant PM_2.5_ concentrations | Positive associations between long-term PM_2.5_ exposure and cardiovascular mortality in U.S. and Canadian cohorts; positive associations persisted after adjustment for common confounders. | Section 6.2.10; Figure 6-19 | Mean concentrations ranged from 4.08 (CCHS)−17.9 CA Teachers
Consistent epidemiologic evidence from multiple studies at relevant PM_2.5_ concentrations | Positive associations observed in studies examining varying spatial scales and across different exposure assessment and statistical methods. | Section 6.2.10
Evidence from copollutant models generally supports an independent PM_2.5_ association | Positive associations observed between long-term PM_2.5_ exposure and cardiovascular mortality remain relatively unchanged after adjustment for copollutants.; Correlations with ozone were generally moderate to high (0.49−0.73).; When reported, correlations with SO_2_, NO_2_, and PM_10−2.5_ ranged from weak to moderate (r = 0.25−0.55). | Section 6.2.15; Figure 6-21; Figure 6-22
Epidemiologic evidence supports a linear no-threshold C-R relationship | Most analyses support a linear, no-threshold relationship for cardiovascular mortality, especially at lower ambient concentrations of PM_2.5_.; Confidence in C-R relationship extends to 8 µg/m^3^ in Harvard Six Cities study. | Section 6.2.16; Lepeule et al. (2012)
Inconsistent evidence from epidemiologic studies of CHD or stroke | Association with coronary events, CHD, and stroke (mortality and morbidity combined) that persist after adjustment for SES reported in the WHI study.; Association with stroke but not CHD in the CA Teachers cohort.; No association with CHD or stroke in the NHS or HPFU. | Section 6.2.2; Section 6.2.3 | Range: 13.4−17.8
Generally consistent evidence of an association with CHD or stroke among those with preexisting disease | Consistent associations with MI in patient populations.; Association among women with diabetes in NHS. | Hartiala et al. (2016); Tonne et al. (2015); Koton et al. (2013); Hart et al. (2015b) | Mean: 15.5; Mean: 14.6; Mean: 23.9; Mean: 13.4
Some, but not all, epidemiologic studies provide evidence for effect of long-term PM_2.5_ on CAC | Longitudinal change in CAC observed in MESA but not in Framingham Heart Offspring study. | Section 6.2.4; Kaufman et al. (2016); Dorans et al. (2016) | Mean: 14.2; Median: 9.8
Consistent evidence from animal toxicological studies at relevant PM_2.5_ concentrations | Consistent changes in measures of impaired heart function and blood pressure.; Additional evidence of atherosclerosis, systemic inflammation, changes in endothelial function. | Section 6.2.5.2; Section 6.2.7.2; Section 6.2.4.2; Section 6.2.12.2; Section 6.2.14.2 | ~85−30; See Tables in identified sections
Generally consistent evidence for biological plausibility of cardiovascular effects | Strong evidence for coherence of effects across scientific disciplines and biological plausibility for a range of cardiovascular effects in response to long-term PM_2.5_ exposure. Includes evidence for impaired heart function, atherosclerosis, and increased blood pressure. | Section 6.2.1

Note: This table corresponds to Table 6-54 in the 2019 PM ISA.

CAC = coronary artery calcification; CCHS = Canadian Community Health Survey; C-R = concentration-response; CHD = coronary heart disease; HPFU = Health Professionals Follow-Up; MESA = Multi-Ethnic Study of Atherosclerosis; µg/m^3^ = micrograms per cubic meter; NHS = Nurses’ Health Study; NO_2_ = nitrogen dioxide; PM_2.5_ = particulate matter with a nominal mean aerodynamic diameter less than or equal to 2.5 μm; PM_10_ = particulate matter with a nominal mean aerodynamic diameter less than or equal to 10 μm; PM_10−2.5_ = particulate matter with a nominal mean aerodynamic diameter greater than 2.5 μm and less than or equal to 10 μm; r = correlation coefficient; SES = socioeconomic status; SO_2_ = sulfur dioxide.

a Based on aspects considered in judgments of causality and weight of evidence in causal framework in Tables I and II of the Preamble (U.S. EPA, 2015).

b Describes the key evidence and references contributing most heavily to causality determination and, where applicable, to uncertainties or inconsistencies. References to earlier sections indicate where the full body of evidence is described in the 2019 PM ISA.

c Describes the PM_2.5_ concentrations with which the evidence is substantiated.

The studies of long-term exposure to PM_2.5_ and cardiovascular mortality evaluated in the 2019 PM ISA continue to provide strong evidence of a causal relationship between long-term exposure to PM_2.5_ and cardiovascular effects. Results from U.S. and Canadian cohort studies demonstrated consistent, positive associations between long-term PM_2.5_ exposure and cardiovascular mortality (2019 PM ISA, Figure 6-19). Overall, the studies reporting positive associations examined the relationship at varying spatial scales and employed different exposure assessment and statistical methods (2019 PM ISA, Section 6.2.10). The studies were conducted in locations where mean annual average concentrations ranged from 4.08 to 17.9 µg/m^3^. Generally, most of the PM_2.5_ effect estimates relating long-term PM_2.5_ exposure and cardiovascular mortality remained relatively unchanged or increased in copollutant models adjusted for ozone, NO_2_, PM_10−2.5_, or SO_2_. In addition, most of the results from analyses examining the C-R function for cardiovascular mortality supported a linear, no-threshold relationship for cardiovascular mortality, especially at lower ambient concentrations of PM_2.5_.

The body of literature examining the relationship between long-term PM_2.5_ exposure and cardiovascular morbidity evaluated in the 2019 PM ISA had greatly expanded since the 2009 PM ISA, with positive associations reported in several cohorts. The findings from the WHI cohort of postmenopausal women (Miller et al., 2007), reporting associations of long-term PM_2.5_ and coronary events, were strengthened through a subsequent analysis, which considered potential confounding and modification by SES and applied enhanced exposure assessment methods (Chi et al., 2016). However, analyses of the Nurses’ Health Study (NHS) and California Teachers Study (CTS), both of which are cohorts of women and include extensive data on covariates (i.e., hormone use, menopausal status, and SES), were not entirely consistent with the WHI findings. Although the NHS cohort is comparable to WHI in that it is made of predominantly postmenopausal women, no associations with CHD or stroke were observed in this population (Hart et al., 2015b). An association with stroke, but not CHD, that was stronger among postmenopausal women was observed in the CTS (Lipsett et al., 2011). Several studies conducted among cardiovascular disease patient populations generally reported positive associations with MI (Hartiala et al., 2016; Tonne et al., 2015; Koton et al., 2013), and a sensitivity analysis of the NHS restricted to women with diabetes detected a positive association with CHD. Although the evidence is not consistent across the populations studied, heterogeneity is expected when the methods, or the underlying distribution of covariates vary across studies (Higgins, 2008).

Longitudinal change in measures of atherosclerosis in relation to long-term exposure to PM_2.5_ add to the collective evidence base (Hartiala et al., 2016; Kaufman et al., 2016; Gan et al., 2014; Künzli et al., 2010). Findings were somewhat variable across cohorts and depended, in part, on the vascular bed in which atherosclerosis was evaluated. Kaufman et al. (2016) reported an association of PM_2.5_ with coronary artery calcification (CAC) among middle to older aged adults in the MESA study, while Dorans et al. (2016) reported no association in the Framingham Heart Study. Associations of long-term exposure to PM_2.5_ with carotid intima media thickness (cIMT) were not consistently observed across cohorts or between analyses of the same cohort with variable methods. Relationships between PM_2.5_ and cIMT at younger ages were not observed. However, a toxicological study supported similar evidence from the 2009 PM ISA by demonstrating increased plaque progression in ApoE^-/-^ mice following long-term exposure to PM_2.5_ collected from multiple locations across the U.S. (Lippmann et al., 2013a). Thus, this study provided direct evidence that long-term exposure to PM_2.5_ may result in atherosclerotic plaque progression. This study was also coherent with the epidemiologic studies discussed above reporting positive associations between long-term exposure to PM_2.5_ and indicators of atherosclerosis.

A small number of epidemiologic studies also reported positive associations between long-term PM_2.5_ exposure and heart failure (2019 PM ISA, Section 6.2.5), blood pressure, and hypertension (2019 PM ISA, Section 6.2.7). These heart failure studies are in agreement with animal toxicological studies that demonstrated decreased cardiac contractility and function and increased coronary artery wall thickness following long-term PM_2.5_ exposure (2019 PM ISA, Section 6.2.5.2). Similarly, a limited number of animal toxicological studies demonstrated a relationship between long-term exposure to PM_2.5_ and consistent increases in BP in rats and mice are coherent with epidemiologic studies that reported positive associations between long-term exposure to PM_2.5_ and hypertension.

Longitudinal epidemiologic analyses also supported the observation of positive associations with markers of systemic inflammation (2019 PM ISA, Section 6.2.12), coagulation (2019 PM ISA, Section 6.2.13), and endothelial dysfunction (2019 PM ISA, Section 6.2.14). These results were in coherence with animal toxicological studies generally reporting increased markers of systemic inflammation and oxidative stress (2019 PM ISA, Section 6.2.12.2), as well as with toxicological studies that generally demonstrated endothelial dysfunction as evidenced by reduced vasodilation in response to acetylcholine (2019 PM ISA, Section 6.2.14).

There was also consistent evidence from multiple epidemiologic studies that long-term exposure to PM_2.5_ was associated with mortality from cardiovascular causes. Associations with CHD, stroke, and atherosclerosis progression were observed in several additional epidemiologic studies, providing coherence with the mortality findings. Results from copollutant models generally supported the independence of the PM_2.5_ associations. Additional evidence of the direct effect of PM_2.5_ on the cardiovascular system was provided by experimental studies in animals, which in part, demonstrate biologically plausible pathways by which long-term inhalation exposure to PM_2.5_ could potentially result in outcomes such as CHD, stroke, CHF, and cardiovascular mortality. Together, these epidemiologic and experimental studies constitute strong evidence that a causal relationship exists between long-term exposure to PM_2.5_ and cardiovascular effects.

#### 3.1.2.2 Recent U.S. and Canadian Epidemiologic Studies

Recent epidemiologic studies conducted in the U.S. and Canada build upon the strong epidemiologic evidence base evaluated in the 2019 PM ISA, as well as in previous assessments, which provided the scientific rationale supporting a causal relationship between long-term PM_2.5_ exposure and cardiovascular effects (Section 3.1.1.1). In addition to examining the relationship between long-term PM_2.5_ exposure and specific cardiovascular outcomes (i.e., IHD and myocardial infarction [Section 3.1.2.2.1], cerebrovascular disease and stroke [Section 3.1.2.2.2], atherosclerosis [Section 3.1.2.2.3], heart failure and impaired heart function [Section 3.1.2.2.4], cardiac electrophysiology and arrhythmia [Section 3.1.2.2.5], blood pressure and hypertension [Section 3.1.2.2.6], and cardiovascular mortality [Section 3.1.2.2.7]), analyses within these recent studies also further examined issues relevant to expanding the overall understanding the effect of long-term PM_2.5_ exposure on cardiovascular outcomes. Specifically, recent studies assessed potential copollutant confounding (Section 3.1.2.2.8) and the shape of the concentration-response (C-R) relationship (Section 3.1.2.2.9). The following sections present an evaluation of recent epidemiologic studies conducted in the U.S. and Canada that inform each of the aforementioned topics within the context of the evidence base evaluated and summarized in the 2019 PM ISA. Study-specific details (e.g., study population, exposure assessment approach, confounders considered) for the epidemiologic studies evaluated in this section are presented in Appendix A (Table A-3).

##### 3.1.2.2.1 Ischemic Heart Disease and Myocardial Infarction

The terms ischemic heart disease (IHD), coronary artery disease (CAD), and coronary heart disease (CHD) are generally interchangeable as they appear in the epidemiologic literature on the effects of air pollution. Most IHD is caused by atherosclerosis, which can result in the blockage of the coronary arteries and restriction of blood flow to the heart muscle. A myocardial infarction (MI) or heart attack is an acute event that results in heart muscle tissue death secondary to coronary artery occlusion. The epidemiologic studies included in the 2019 PM ISA represented a substantial expansion of the literature compared with the few studies available for review in the 2009 PM ISA. Overall, findings from these studies were not entirely consistent. The strongest evidence of an association with IHD was found in populations with preexisting diseases such as diabetes or cardiac patients that are followed after an acute event or procedure. Recent studies examine the association between long-term PM_2.5_ exposure and MI with most reporting results that are consistent with those studies evaluated in the 2019 PM ISA.

Recent analyses of the Canadian Ontario Population Health and Environment Cohort (ONPHEC) also add to the available evidence on the relationship between long-term PM_2.5_ exposure and cardiovascular effects. ONPHEC includes more than 5 million Canadian-born adults (35−85 years old at enrollment in 1996) who were registered with the provincial health service and had resided in Ontario for ≥ 5 years. In a prospective analysis, Bai et al. (2019) estimated the association between 3-year average PM_2.5_ concentrations and incident cases of acute MI. The study reported a positive association (HR: 1.07 [95% CI: 1.06, 1.09]). In addition, stratified analyses showed patterns of associations that indicated stronger effect estimates in the youngest (35−44 years) and oldest (75−85 years) age groups. Bai et al. (2019) also examined effect modification by oxidant gases, which was estimated as the redox weighted average of NO_2_ and O_3_ (O_x_). A stronger association, in terms of magnitude, with acute MI was observed in the highest tertile of (> 38.97 ppm) O_x_ concentrations (HR: 1.12 [95% CI: 1.09, 1.15]) compared with the lowest (HR: 1.04 [95%CI: 1.01, 1.06]) and middle tertiles (HR: 1.06 [95% CI: 1.00, 1.12]).

Chen et al. (2020) also analyzed data from the ONPHEC study but examined the association of annual average PM_2.5_ in the previous year with the incidence of acute MI. The authors conducted single pollutant analyses using both a traditional Cox proportional hazards model where PM_2.5_ is fit as a linear term and a Cox proportional hazards model where PM_2.5_ was fit as a nonlinear term. Model fit, which was assessed based on the Akaike information criterion (AIC) value, did not vary across models. The risk estimates were also virtually the same across models (i.e., HR = 1.14 [95% CI: 1.12, 1.16] in both models). In addition to conducting single-pollutant analyses, the authors introduced a new approach to assess whether the association of PM_2.5_ with acute MI varied depending on the proportion of PM_2.5_ attributed to selected components (i.e., sulfate, nitrate, ammonium, black carbon, organic matter, mineral dust, and sea salt). The study found that the model that adjusted for the proportion of each of the seven selected components was a better predictor of acute MI based on lower AIC values. In addition, Chen et al. (2020) reported that acute MI associations increased by an average of 10% when compared with single-pollutant results across each of the five regions of Ontario when using the component proportion adjusted approach. Overall, the component adjusted model provided some support that variability in the proportion of individual components that comprise PM_2.5_, could explain regional variability in risk estimates.

While the studies above focus on examining the relationship between long-term PM_2.5_ exposure and MI in cohorts of diverse populations, some recent studies have analyzed data from a cohort of women and cardiac catheterization patients. Elliott et al. (2020) examined the interaction between 24-month PM_2.5_ concentration and physical activity in association with MI among women enrolled in the NHS. Unlike an earlier analysis of this cohort that examined IHD (Hart et al., 2015b), the authors found a positive association of PM_2.5_ with MI (HR: 1.06 [95% CI: 1.00, 1.12]), although no statistical evidence of an interaction with physical activity was observed. In the previous analysis of the NHS cohort, Hart et al. (2015b) reported no association between long-term PM_2.5_ exposure and incident CHD (HR: 1.01 [95% CI: 0.96, 1.07]), although a positive association with IHD was observed among women with diabetes (HR: 1.10 [95% CI: 0.99, 1.21]). Weaver et al. (2019) studied cardiac catheterization patients residing in three counties in NC to determine the association of annual average PM_2.5_ concentration with MI, CAD, and hypertension. Among the objectives of this study was to understand the effect of sociodemographic characteristics on associations by assigning study participants to clusters based on the census block group of their residence that indicated specific sets of sociodemographic characteristics. Positive associations of annual average PM_2.5_ concentration with both CAD and MI were observed. The association with MI was observed across all sociodemographic clusters (OR for all clusters: 3.57 [95% CI: 2.10, 5.77]). The association with CAD was also observed across all clusters (OR: 1.40 [95% CI: 0.90, 2.19]) but was largely driven by one cluster (OR: 2.01 [95% CI: 1.00, 3.86]), which was urban and characterized by low poverty, low unemployment, and composed of relatively highly educated residents with managerial jobs.

In another study, Loop et al. (2018) conducted an analysis of the REGARDS cohort, a nationwide study which oversampled participants from states in the southern U.S. where there is known to be an increased risk of stroke. Participants who were free from CHD at baseline were followed for an average of 6 years. Loop et al. (2018) reported an inverse association between annual average PM_2.5_ concentration at baseline and nonfatal MI (HR: 0.74 [95% CI: 0.56, 0.98]). Loop et al. (2018) also examined associations for total CHD (i.e., CHD deaths and nonfatal MI cases combined) and reported no evidence of an association (HR: 0.89 [95% CI: 0.71, 1.11]).

The evidence informing the relationship between long-term exposure to PM_2.5_ and IHD, including the recent studies of MI, is summarized in Figure 3-5. Recent studies do not all report positive associations; however, the strongest evidence of a relationship continues to be for those with preexisting diseases or patient populations that are followed after a cardiac event or procedure such as catheterization.

Figure 3-5 Associations between long-term PM_2.5_ exposure and ischemic heart disease or myocardial infarction

Note: †Studies published since the 2009 PM ISA. *U.S. and Canadian studies published since the literature cutoff date (~January 2018) for the 2019 PM ISA. Circles represent point estimates; horizontal lines represent 95% confidence intervals for PM_2.5_. Black text and circles represent evidence included in the 2009 PM ISA; red text and circles represent evidence considered in 2019 PM ISAs; and blue text and circles represent recent studies published since the 2019 ISA. Mean concentrations in μg/m^3^. Hazard ratios are standardized to a 5 μg/m^3^ increase in PM_2.5_ concentrations. CATHGEN = Catheterization Genetics Study; CHD = Coronary Heart Disease; CTS = California Teachers Study; ESCAPE = European Study of Cohorts for Air Pollution; HNR = Heinz Nixdorf Recall study; HPFU = Health Professionals Follow-up Study; IHD = Ischemic Heart Disease; MI = myocardial infarction; MINAP = Myocardial Ischemia National Audit Project; NHS = Nurses’ Health Study; ONPHEC = Ontario Population Health and Environmental Cohort; REGARDS = REasons for Geographic and Racial Differences in Stroke; WHI = Women’s Health Initiative.

Figure 3 dash 5 presents a summary of associations between long term P M 2.5 exposure and ischemic heart disease or myocardial infarction from recently published studies, studies included in the 2019 P M I S A and previously evaluated studies. Measures of association (i.e., hazard ratios) are standardized to a 5 micrograms per cubic meter increase in P M 2.5 concentrations. Overall, most studies report positive associations. The strongest evidence of positive associations comes from studies conducted among those with preexisting diseases or patient populations that are followed after a cardiac event or procedure such as catheterization.

Source: Update of Figure 6-17, 2019 PM ISA.

##### 3.1.2.2.2 Cerebrovascular Disease and Stroke

Cerebrovascular disease typically includes the conditions hemorrhagic stroke, cerebral infarction (i.e., ischemic stroke), and occlusion of the precerebral and cerebral arteries. The 2009 PM ISA identified one study that indicated a positive association between PM_2.5_ and cerebrovascular morbidity and mortality (HR: 1.16 [95%CI: 1.04, 1.30]) in post-menopausal women (Miller et al., 2007). Although the results were not entirely consistent across studies or stroke subtype, some studies reviewed in the 2019 PM ISA provided evidence to support a positive association between long-term exposure to PM_2.5_ and stroke. Several recent studies that observe positive associations add to this evidence base (Figure 3-6).

Several studies examined the association between long-term PM_2.5_ concentration and stroke as discussed below. In a study of women enrolled in the NHS cohort, Elliott et al. (2020) reported an imprecise (i.e., wide confidence intervals relative to the size of the HR) association between 24 month average PM_2.5_ concentration and stroke that overlapped the null value (HR: 1.02 [95% CI: 0.96, 1.09]). An earlier analysis examining the association with annual average PM_2.5_ concentration in the NHS, reported an increased risk among women with diabetes (HR: 1.29 [95% CI: 1.14, 1.45]) but not in the population, overall (HR: 1.01 [95% CI: 0.96, 1.05]) (Hart et al., 2015b). Rhinehart et al. (2020) estimated the association of annual average PM_2.5_ concentration within 300 meters of the residence with stroke in a prospective analysis of residents of Allegheny County, PA, who were diagnosed with atrial fibrillation but had no history of stroke. This study reported a positive association (HR: 1.62 [95% CI: 1.00, 2.55]). As opposed to examining annual or 24-month average PM_2.5_ exposures, Shin et al. (2019) estimated the association between 5-year PM_2.5_ concentration and incident cases of stroke in a prospective analysis of the Canadian ONPHEC study and reported a positive association (HR: 1.05 [95% CI: 1.03, 1.07]).

Studies that examined the relationship of long-term PM_2.5_ exposure with CBVD and stroke are summarized in Figure 3-6. Recent studies support the evidence in the 2019 PM ISA and extend the evidence relating to the observation of associations among patients that are followed after a cardiac event or procedure.

Figure 3-6 Associations between long-term PM_2.5_ exposure and the incidence of stroke

Note: †Studies published since the 2009 PM ISA. *U.S. and Canadian studies published since the literature cutoff date (~January 2018) for the 2019 PM ISA. Circles represent point estimates; horizontal lines represent 95% confidence intervals for PM_2.5_. Black text and circles represent evidence included in the 2009 PM ISA; red text and circles represent evidence included in the 2019 PM ISA; blue text and circles represent evidence not included in the 2019 PM ISA. Mean concentrations in μg/m^3^. Hazard ratios are standardized to a 5 μg/m^3^ increase in PM_2.5_ concentrations. (U.S. EPA, 2018). ESCAPE = European Study of Cohorts for Air Pollution; GP = general practitioner; HNR = Heinz Nixdorf Recall; HPFU = Health Professional’s Follow-up; HS = hemorrhagic stroke; IS = ischemic stroke; MI = myocardial infarction; NHS = Nurses’ Health Study; ONPHEC = Ontario Population Health and Environment Cohort; WHI = Women’s Health Initiative.

Figure 3 dash 6 presents a summary of associations between long term P M 2.5 exposure and stroke from recently published studies, studies included in the 2019 P M I S A and previously evaluated studies. Measures of association (i.e., hazard ratios) are standardized to a 5 micrograms per cubic meter increase in P M 2.5 concentrations. Although study results were not entirely consistent, some studies reviewed in previous assessments provided evidence to support a positive association between long term exposure to P M 2.5 and stroke. Recent studies extend and support the previous evidence reporting associations among patients that are followed after a cardiac event or procedure.

Source: Update of Figure 6-18, 2019 PM ISA.

##### 3.1.2.2.3 Atherosclerosis

Atherosclerosis is the process of plaque buildup that forms lesions on the walls of the coronary arteries, which can lead to narrowing of the vessel, reduced blood flow to the heart and IHD. Atherosclerosis can be assessed within large arterial vascular beds in distinct regions of the body i.e., carotid intima-media thickness (cIMT), coronary artery calcification (CAC), ankle-brachial index (ABI), and the presence of plaques. Findings from studies reviewed in the 2009 PM ISA were inconsistent, reporting null or positive, but imprecise associations with cIMT, CAC, and ABI. Similarly, findings from studies reviewed in the 2019 PM ISA were not entirely consistent across populations, exposure assessment methods, and measures of atherosclerosis. Notably, an extended MESA analysis reported a longitudinal increase in CAC (4.1 Agatston unit increase per year [95% CI: 1.4, 6.8]) in association with annual average PM_2.5_ exposure, but no association (β: −0.90 µm per year [95%CI: −3.00, 1.30]) with cIMT (Kaufman et al., 2016). Exposure measurement error, variation in baseline measures of atherosclerosis as well as statistical power were noted as possible explanations for the lack of association observed in these studies. Consideration of copollutant confounding was generally limited across the evidence base reviewed in the 2019 PM ISA.

Several recent studies expand the evidence available to consider the association of long-term PM_2.5_ exposure with atherosclerosis. Following the analysis by Kaufman et al. (2016), Keller et al. (2018) estimated the association of PM_2.5_ concentration (i.e., multi-year average during the study period 2000−2012) with CAC progression among participants in MESA air residing in Baltimore, MD. The authors also assessed whether this association was modified by membership in clusters with different traffic-related air pollution (TRAP) component profiles. The authors reported a 23.0 Agatston unit per year increase (95% CI :14.2, 31.7) among participants overall. Keller et al. (2018) also reported a larger magnitude association with CAC progression (42.6 Agatston unit per year increase [95% CI: 25.7, 59.4]) in the cold season among those belonging to a cluster that was characterized as downtown with above average ratios of ultrafine and accumulation mode particles relative to NO_X_.

Among women enrolled in the Study of Women’s Health Across the Nation (SWAN), a cohort of U.S. women transitioning through menopause, Duan et al. (2019a) estimated the association of 5-year average PM_2.5_ concentration with cIMT. The study reported a 27.95 μm (95% CI: −2.90, 58.75) thicker mean cIMT in association with 5-year mean PM_2.5_ concentration in adjusted models. PM_2.5_ was also associated with an increase in increased mean inter-adventitial diameter (IAD), which is a marker of vascular remodeling and aging as well as a predictor of cardiovascular events, of 105.90 (95% CI: −63.00, 274.80). No association was reported with plaque presence (OR: 0.90 [95% CI: 0.50, 1.61]) or plaque severity index (plaque index 0−2, OR: 1.05 [95% CI: 0.53, 8.95] and plaque index > 2, OR: 0.62 [95% CI: 0.25, 1.47]) in the SWAN study. In an analysis of a subset of SWAN participants (Pittsburgh and Chicago only), Duan et al. (2019b) estimated the association of the same measures of atherosclerosis as Duan et al. (2019a) with annual average PM_2.5_ concentration reporting a 11.25 μm per year increase (95% CI: −3.05, 25.60) in mean cIMT. The authors also reported associations with plaque presence (OR: 2.10 [95% CI: 0.66, 6.63]) and plaque index progression (OR: 2.70 [95% CI: 0.77, 9.24]).

Recent studies support and extend the evidence characterized in the 2019 PM ISA with observations of associations with cIMT among women transitioning into menopause and potential effect modification by TRAP in the MESA study.

##### 3.1.2.2.4 Heart Failure and Impaired Heart Function

HF refers to a set of conditions including CHF in which the heart’s pumping action is weakened. With CHF the blood flow from the heart slows, failing to meet the oxygen demands of the body, and returning blood can back up, causing swelling or edema in the lungs or other tissues (typically in the legs and ankles). Risk factors for HF include IHD, high blood pressure, atrial fibrillation, and diabetes. The small number of epidemiologic studies reviewed in the 2019 PM ISA provided evidence supporting a possible relationship between heart failure and long-term exposure to PM_2.5_. In addition, an association with increased right ventricular (RV) mass was observed among MESA participants (Aaron et al., 2016). Right sided HF is typically a consequence of left-sided HF but can also result from damage to the pulmonary vasculature, which can result in increased RV mass, reduced flow to the left ventricle, and reduced left ventricular (LV) mass.

A recent study examining the association between long-term PM_2.5_ exposure and HF was conducted among participants in the Canadian ONPHEC study. In this prospective analysis, Bai et al. (2019) examined the relationship between 3-year moving average PM_2.5_ concentration with new cases of CHF. A positive association was reported, overall (HR: 1.07 [95% CI: 1.06, 1.07]), and a larger magnitude association was reported in the highest tertile of O_x_ concentrations in a stratified analysis examining potential effect modification (HR: 1.12 [95% CI: 1.10, 1.13]). The hazard ratios in the lowest and middle O_x_ tertiles were 1.04 (95% CI: 1.03, 1.06) and 1.06 (95% CI: 1.03, 1.07), respectively. This study supports the evidence in the 2019 PM ISA that indicates a positive association between long-term PM_2.5_ and HF; however, the evidence remains limited overall.

##### 3.1.2.2.5 Cardiac Electrophysiology and Arrhythmia

Electrical activity in the heart is typically measured using surface electrocardiography (ECG). ECGs measure electrical activity in the heart due to depolarization and repolarization of the atria and ventricles. Atrial fibrillation (AF) is the most common type of arrhythmia. Despite being common, clinical and subclinical forms of AF are associated with reduced functional status and quality of life and are associated with downstream consequences such as ischemic stroke (Prystowsky et al., 1996; Laupacis et al., 1994) and CHF (Roy et al., 2009), contributing to both CVD and all-cause mortality (Kannel et al., 1983). Ventricular fibrillation is a well-known cause of sudden cardiac death and commonly associated with MI, HF, cardiomyopathy, and other forms of structural (e.g., valvular) heart disease.

In an analysis of the WHI, which was reviewed in the 2009 PM ISA, Liao et al. (2009) found no association of long-term PM_2.5_ concentrations with supraventricular or ventricular ectopy, which are the most frequent forms of arrhythmia in the general population. A limited number of studies reviewed in the 2019 PM ISA found associations of long-term PM_2.5_ exposure with premature atrial contractions and ventricular conduction abnormalities, but not arrhythmias recorded on implantable cardioverter defibrillators. In a recent prospective analysis of the Canadian OPHEC study, Shin et al. (2019) estimated the association between 5-year average PM_2.5_ concentration and incident cases of AF and reported a positive association (HR: 1.03 [95% CI: 1.01, 1.04]). Overall, the evidence pertaining to the association between long-term PM_2.5_ exposure and various types of arrythmias remains limited.

##### 3.1.2.2.6 Blood Pressure and Hypertension

High blood pressure is typically defined as a systolic blood pressure above 140 mm Hg or a diastolic blood pressure above 90 mm Hg (U.S. EPA, 2019). Hypertension, the clinically relevant consequence of chronically high blood pressure, typically develops over years. The body of literature reviewed in the 2019 PM ISA was substantially larger than in the 2009 PM ISA with longitudinal analyses generally showing small magnitude increases in SBP, pulse pressure (PP), and mean arterial pressure (MAP) in association with long-term exposure to PM_2.5_. In addition, the expanded body of literature provided evidence of associations between long-term PM_2.5_ exposure and hypertension. Recent studies add to the evidence providing support for positive associations among post-menopausal women enrolled in the WHI study and in cardiac catheterization patients, but not among Black women enrolled in the Jackson Heart Study (JHS).

Honda et al. (2017) estimated the association of PM_2.5_ concentration with incident hypertension among post-menopausal women enrolled in the WHI. Annual average PM_2.5_ concentration was associated with incident hypertension. (HR: 1.17 [95% CI 1.10, 1.22]). The association with PM_2.5_ concentration increased among minority participants (i.e., Black, Asian/Pacific Islander, Hispanic/Latino race/ethnicity, which were characterized as non-White in the study) participants and those who lived in the Northeast U.S. By contrast, no association of 1-year or 3-year average PM_2.5_ concentration with hypertension was observed in a recent prospective analysis conducted by Weaver et al. (2021) of African American women enrolled in the JHS (1-year, RR: 1.00 [95% CI: 0.52, 2.03] and 3-year, RR: 1.10 [95% CI: 0.39, 2.84]). Further adjustment for diabetes did not change these findings. A cross-sectional analysis of PM_2.5_ concentration and prevalent hypertension conducted by Weaver et al. (2021) yielded similar results.

An association between long-term PM_2.5_ exposure and hypertension was also observed among cardiac catheterization patients in three counties in North Carolina (Weaver et al., 2019). In this study Weaver et al. (2019) estimated the association of annual average PM_2.5_ concentration with hypertension. No association between long-term PM_2.5_ exposure and hypertension was observed in the study population overall (OR: 0.90 [95% CI: 0.59, 1.34). The pattern of associations between long-term PM_2.5_ concentration and hypertension indicated larger magnitude associations among study participants who lived in two sociodemographic clusters, the first characterized as urban, having a high proportion of Black individuals and individuals in non-managerial occupations (denoted as Cluster 1) and the second characterized as urban, impoverished, having a high proportion of individuals who are unemployed, work in non-managerial occupations, are Black, and live in single parent homes (Cluster 2). The OR for Cluster 1 was 2.70 (95% CI: 0.95, 7.59) and the OR for Cluster 2 was 11.86 (95% CI: 2.10, 67.21).

The literature assessed in the 2019 PM ISA provided evidence of associations between long-term PM_2.5_ exposure and hypertension. Recent studies are generally consistent with this assessment, reporting positive associations among post-menopausal women enrolled in the WHI study and in cardiac catheterization patients. However, no association between long-term PM_2.5_ exposure and hypertension was observed among Black women enrolled in the JHS.

##### 3.1.2.2.7 Cardiovascular Mortality

Multiple epidemiologic studies (Section 3.2.2.2.2) reviewed in the 2009 PM ISA and in the 2019 PM ISA reported consistent positive associations between long-term PM_2.5_ exposure and cardiovascular mortality. Generally, these studies had extensive control for a wide range of potential confounders and the observed effect estimates remained relatively unchanged or increased in copollutant models adjusted for ozone, NO_2_, PM_10−2.5_, or SO_2_. Recent cohort studies, which are reviewed in detail in Section 3.2.2.2.2 provide additional evidence for associations with cardiovascular mortality outcomes across the distribution of PM_2.5_ concentrations (Hayes et al., 2020), the potential implications of a comorbidity on the PM_2.5_-cardiovascular mortality relationship (Pinault et al., 2018), and associations with individual cardiovascular mortality outcomes including IHD (Crouse et al., 2020; Wang et al., 2020; Cakmak et al., 2018; Pinault et al., 2017) and stroke (Crouse et al., 2020; Hayes et al., 2020; Wang et al., 2020; Pope et al., 2019; Pinault et al., 2017). Overall, these recent studies support the conclusions in the 2019 PM ISA of consistent positive associations of long-term PM_2.5_ exposure with cardiovascular mortality, and specifically with IHD- and stroke-related mortality. Although Pope et al. (2014) reported positive associations of long-term PM_2.5_ exposure with CHF mortality in a study of the ACS cohort evaluated in the 2019 PM ISA, a recent analysis of the Medicare cohort Wang et al. (2020) reported a null association. Recent studies also indicate that the combination of cardiovascular disease and diabetes together has a greater mortality risk than cardiovascular mortality alone and that cardiovascular diseases such as heart failure or previous MI may increase the risk of PM_2.5_-related all-cause mortality (Ward-Caviness et al., 2020; Malik et al., 2019).

##### 3.1.2.2.8 Copollutant Confounding

One approach to assessing the independence of the association between exposure to PM_2.5_ and a health effect, such as long-term exposure to PM_2.5_ and cardiovascular health effects is through the use of copollutant models. As noted in the Appendix (Table A-3) to the 2019 PM ISA, copollutant models are not without their limitations, such as instances when correlations are high between pollutants resulting in greater bias in results. However, in assessing the results from copollutant models, a change in the PM_2.5_ risk estimates, after adjusting for copollutants, may indicate the potential for confounding. A limited number of studies were available in the 2019 PM ISA to assess copollutant confounding of the association between long-term exposure to PM_2.5_ and cardiovascular morbidity. Considering these few available studies, risk estimates remained largely unchanged after adjustment for PM_10−2.5_, NO_2_, and PM_2.5_ from traffic sources. The limited number of recent analyses report some attenuation of risk estimates in models adjusted for O_3_ and NO_2_.

Several recent analyses of the ONPHEC study add to the evidence pertaining to copollutant confounding (Figure 3-7). Shin et al. (2019) reported that the association of long-term PM_2.5_ exposure with stroke (HR: 1.03 [95%CI: 1.01, 1.04]) persisted after adjustment for NO_2_ but was attenuated in the models with O_3_ and oxidant gases (O_x_) represented by the redox weighted average of NO_2_ and O_3_ (HR: 1.05 [95% CI: 1.03, 1.06] and HR: 1.03 [95% CI:1.02, 1.04], and HR: 1.02 [95% CI:1.00, 1.05], respectively). In an analysis of AF, these authors found that the association was slightly attenuated, but remained positive, in two-pollutant models that adjusted for NO_2_, O_3_ and redox weighted average of NO_2_ and O_3_ (O_x_) (HR: 1.03 [95% CI: 1.02, 1.04] and HR: 1.02 [95% CI: 1.01, 1.03], and HR: 1.02 [95% CI: 1.01, 1.03], respectively). In addition, a study of atherosclerosis in the SWAN cohort, Duan et al. (2019a) reported that the estimate for the association of long-term PM_2.5_ exposure with cIMT was slightly attenuated in a two-pollutant model that adjusted for O_3_ (24.45 μm [95% CI: −18.35, 67.25]). In a separate analysis of a subset of this cohort, however, Duan et al. (2019b) reported that associations with plaque presence and plaque index progression persisted in models adjusted for ozone (OR: 2.29 [95% CI: 0.70, 7.59]) for plaque presence and (OR 3.05 [95% CI: 0.86, 10.82] for plaque index progression). Overall, the limited evidence indicates that associations between PM_2.5_ and cardiovascular health effects persist, but may be slightly attenuated, in models that are adjusted for copollutants.

Figure 3-7 Associations between long-term exposure to PM_2.5_ and cardiovascular morbidity in single pollutant models and models adjusted for copollutants

Note: †Studies published since the 2009 PM ISA. *U.S. and Canadian studies published since the literature cutoff date (~January 2018) for 2019 PM ISA. Circles represent point estimates; horizontal lines represent 95% confidence intervals for PM_2.5_. Solid circles represent single pollutant results and open circles represent copollutant results. Hazard ratios are standardized to a 5 μg/m^3^ increase in PM_2.5_ concentrations.

Figure 3 dash 7 presents associations between long term exposure to P M 2.5 and cardiovascular morbidity outcomes reported in single pollutant models and models adjusted for copollutants reported in recently published studies, studies included in the 2019 P M I S A and previously evaluated studies. Measures of association (i.e., hazard ratios) are standardized to a 5 micrograms per cubic meter increase in P M 2.5 concentrations. Overall, the limited evidence indicates that associations between P M 2.5 and cardiovascular health effects persist, but may be slightly attenuated, in models that are adjusted for copollutants.

Source: Update of Figure 6-20, 2019 PM ISA.

##### 3.1.2.2.9 Examination of the Concentration-Response (C-R) Relationship between Long-Term PM_2.5_ Exposure and Cardiovascular Effects

An important consideration in characterizing the association between long-term PM_2.5_ exposure and cardiovascular effects is whether the C-R relationship is linear across the full concentration range that is encountered, or whether there are concentration ranges that exhibit departures from linearity. A limited number of studies evaluated in the 2019 PM ISA examined the shape of the C-R relationships for cardiovascular morbidity outcomes with the majority of studies lacking thorough evaluations of alternatives to linearity (2019 PM ISA, Table 6-51). Several recent studies expand the evidence pertaining to the shape of the C-R relationship for the incidence of MI, AF, stroke, and CHF. A number of these studies use statistical techniques that allow for departures from linearity (Table 3-3) generally supporting and extending the evidence characterized in the 2019 PM ISA showing linear, no-threshold C-R relationship for most CVD outcomes. However, there is some evidence for a sublinear or supralinear C-R relationship for some outcomes.

Table 3-3 Summary of studies examining the concentration-response (C-R) relationship or conducted threshold analyses for long-term exposure to PM_2.5_ and cardiovascular morbidity

Study Location―Cohort (Table/Figure from Reference) | Outcome | Exposure PM_2.5_ Mean: (Range) in µg/m^3^ | Statistical Analysis Summary
Bai et al. (2019); Figure 3-8; Ontario, Canada; ONPHEC | Acute MI incidence | Mean (IQR):9.6 (3.5) | Identified the shape of the C-R function for fully adjusted Cox models using SCHIF^**^ (Nasari et al., 2016).; A linear concentration-response relationship between acute MI and PM_2.5_ concentration was observed.
Chen et al. (2020); Figure 3-9; Ontario, Canada; ONPHEC | Acute MI Incidence | Mean: 8.61 | Identified the shape of the C-R function for fully adjusted Cox models using SCHIF^**^ (Nasari et al., 2016).; Restricted cubic splines with 4 df to assess linearity used in sensitivity analysis.; Approximately linear relationship observed with both methods.
Danesh Yazdi et al. (2019); Figure 3-10; Medicare Southeastern, U.S. | First hospital admission for MI | NR | Penalized spline to estimate the shape of the C-R relationship, with degrees of freedom chosen based on corrected AIC values.; C-R relationship continued down to low-exposure levels and persisted when the data set was restricted <12 μg/m^3^. The relationship was generally linear at concentrations below 14 μg/m^3^.
Loop et al. (2018); Figure 3-11; U.S. Nationwide; REGARDS | Nonfatal MI incidence | Median (IQR): 13.6 (2.7) | Predicted log hazard modeled as a linear function (nonlinear relationship tested using restricted cubic splines). Sensitivity analyses to test for interactions of PM_2.5_ with gender, race, and urbanicity were conducted to elucidate discrepant findings (i.e., inverse relationship). No statistically significant interactions observed (p = 0.05 level).; Inverse relationship between annual average PM_2.5_ exposure and nonfatal MI.
Shin et al. (2019); ONPHEC; Ontario, Canada | Atrial Fibrillation | Mean (IQR): 9.8 (4.0) | Identified the shape of the C-R function for fully adjusted Cox models using SCHIF (Nasari et al., 2016).; Sublinear relationship observed with some evidence of potential threshold at PM_2.5_ concentrations < 6 µg/m^3^.
Shin et al. (2019); ONPHEC; Ontario, Canada | Stroke | Mean (IQR): 9.8 (4.0) | Identified the shape of the C-R function for fully adjusted Cox models using SCHIF (Nasari et al., 2016).; Linear association was observed with no evidence of a threshold.
Danesh Yazdi et al. (2019); Medicare; Southeastern, U.S. | First hospital admission for stroke | NR | Penalized spline to estimate the shape of the C-R relationship, with degrees of freedom chosen based on corrected AIC values.; C-R relationship continued down to low-exposure levels and persisted when the data set was restricted <12 μg/m^3^. The relationship was generally linear at concentrations below 14 μg/m^3^.
Bai et al. (2019); Ontario, Canada; ONPHEC | CHF | Mean (IQR):9.6 (3.5) | Identified the shape of the C-R function for fully adjusted Cox models using SCHIF (Nasari et al., 2016).; A supralinear concentration-response relationship between CHF and PM_2.5_ concentration was observed.

AIC = Akaike information criterion; C-R = concentration-response; CAC = coronary artery calcification; CHF = congestive heart failure; df = degrees of freedom; ESCAPE = European Study of Cohorts for Air Pollution Effects, HR = hazard ratio, IHD = ischemic heart disease, IQR = interquartile range; MI = myocardial infarction; REGARDS = REasons for Geographic and Racial Differences in Stroke; SCHIF = Shape Constrained Health Impact Function.

Note:

** SCHIF models various shapes including supra-linear, near-linear, and sublinear forms and permits different shapes of the pollutant−outcome association in a monotonically nondecreasing manner but limits the amount of curvature in the shape.

† Studies included in the 2019 Integrated Science Assessment for Particulate Matter.

* Recent studies published since the literature cutoff date (~January 2018) for the 2019 Integrated Science Assessment for Particulate Matter.

Several studies evaluated the shape of the C-R function for the relationship between long-term PM_2.5_ exposure and MI, including two analyses of the ONPHEC study (Figure 3-8 and Figure 3-9), an analysis of the U.S. Medicare population (Figure 3-10), and an analysis of the REGARDS cohort (Figure 3-11). Approximately linear relationships were observed in the ONPHEC analyses (Chen et al., 2020; Bai et al., 2019) using Shape Constrained Health Impact Function (SCHIF) method (Nasari et al., 2016), which is described as a new class of variable coefficient risk functions that can capture potentially nonlinear associations, and in the Medicare analysis using penalized splines, which is described in Section 3.1.2.1 (Danesh Yazdi et al., 2019). Both methods allow for deviations from linearity. By contrast, Loop et al. (2018) found an inverse relationship between annual average PM_2.5_ exposure and nonfatal MI.

Figure 3-8 Concentration-response relationship for the association of PM_2.5_ concentration with acute myocardial infarction

Note: The gray shaded area represents the 95% confidence interval.

Figure 3 dash 8 presents the concentration-response relationship for the association (i.e., hazard ratio) of P M 2.5 concentration with acute myocardial infarction reported by Bai et al. (2019). A positive (i.e., increasing associations with increasing PM2.5 concentration) linear concentration response relationship between acute M I and P M 2.5 concentration was observed. The confidence interval for the association, which is depicted using gray shading, widens with increasing P M 2.5 concentration.

Source: Bai et al. (2019)

Figure 3-9 Concentration-response relationship for the association of PM_2.5_ concentration with acute myocardial infarction using SCHIF (A) and penalized splines (B) with 4 degrees of freedom

Note: The gray shaded area represents the 95% confidence interval.

Figure 3 dash 9 is a two-part figure, which was reprinted from Chen et al. (2020), presents the concentration-response relationship for the association of PM2.5 concentration with acute myocardial infarction using two methods: (A) Shape Constrained Health Impact Function or SCHIF and (B) penalized splines with 4 degrees of freedom. An approximately linear relationship indicating an increasing association with increasing P M 2.5 concentration, was observed with both methods.

Figure 3 dash 9 is a two-part figure, which was reprinted from Chen et al. (2020), presents the concentration-response relationship for the association of PM2.5 concentration with acute myocardial infarction using two methods: (A) Shape Constrained Health Impact Function or SCHIF and (B) penalized splines with 4 degrees of freedom. An approximately linear relationship indicating an increasing association with increasing P M 2.5 concentration, was observed with both methods.

Source: Chen et al. (2020)

Figure 3-10 Concentration-response relationship for the association of PM_2.5_ concentration with first admissions for myocardial infarction

Note: The gray shaded area represents the 95% confidence interval.

Figure 3 dash 10 presents the concentration-response (C-R) relationship for the association of PM2.5 concentration with first admissions for myocardial infarction reported by Danesh Yazdi et al. (2019). A positive C-R relationship (i.e., the association increased in increasing P M 2.5 concentration) was observed at low exposure levels (< 8 micrograms per cubic meter). The relationship was generally linear at concentrations below 14 micrograms per cubic meter.

Source: Danesh Yazdi et al. (2019)

Figure 3-11 Predicted log hazard for incident nonfatal myocardial infarction versus previous 1-year mean ambient PM_2.5_ concentration

Note: Gray bands are 95% prediction intervals.

Figure 3 dash 11 presents the predicted log hazard for incident non-fatal myocardial infarction versus previous 1 year mean ambient P M 2.5 concentration reported by Loop et al. (2018). This study observed an inverse relationship between annual average P M 2.5 exposure and nonfatal MI, indicating that the log hazard decreased with increasing P M 2.5 concentration.

Source: Loop et al. (2018)

Several additional analyses evaluated the shape of the C-R relationship for atrial fibrillation and stroke. In analyses of ONPHEC using SCHIF, a sublinear relationship was observed for atrial fibrillation with some evidence of potential threshold at PM_2.5_ concentrations < 6 µg/m^3^ (Shin et al., 2019), and a linear relationship with no evidence of a threshold was observed for stroke. Danesh Yazdi et al. (2019) also found a C-R relationship that was generally linear (i.e., at PM_2.5_ concentrations < 14 μg/m^3^) among Medicare recipients. One study assessed the shape of the C-R function for CHF, which was observed to be supralinear, flattening at higher concentrations at approximately 14 μg/m^3^ (Bai et al., 2019).

#### 3.1.2.3 Recent Epidemiologic Studies Examining the PM_2.5_-Cardiovascular Effects Relationship through Accountability Analyses and Alternative Methods for Confounder Control

Several studies in the 2019 PM ISA were assessed and in general, supported an association between long-term PM_2.5_ exposure and a variety of cardiovascular hospital admissions (2019 PM ISA, Section 6.2). However, the assessment of this outcome did not include any epidemiologic studies that conducted accountability analyses or employed alternative methods for confounder control because no such studies were prior to the literature cutoff date for the 2019 PM ISA. Since the literature cutoff date of the 2019 PM ISA, a few recent studies conducted accountability analyses or employed alternative methods for confounder control to evaluate the relationship of long-term PM_2.5_ exposure and cardiovascular hospital admissions (Table A-4).

Henneman et al. (2019) utilized a difference-in-difference (DID) approach to conduct an accountability analysis of emissions reductions from coal-fueled power plants in the U.S. between 2005 and 2012 on cardiovascular hospital admission rates for acute myocardial infarction, cardiovascular stroke, heart failure, heart rhythm disorders, ischemic heart disease, peripheral vascular disease, and all cardiovascular diseases among Medicare beneficiaries. DID methods are used to estimate the effect of a specific treatment or intervention, such as reductions in coal-fueled power plant emissions, by comparing the changes in outcomes over time prior to the treatment/intervention and after. For each 1 µg/m^3^ decrease in PM_2.5_ concentrations, the authors reported the change in hospital admissions per 10,000 person-years and found overall reductions for all cardiovascular diseases of −8.4 (95% CI: −12.67, −4.14), −0.01 (95% CI: −0.93, 0.91) for acute myocardial infarction, −1.95 (95% CI: −3.20, −0.70) for stroke, −4.26 (95% CI: −6.09, −2.43) for heart failure, and −3.87 (95% CI: −5.67, −2.08) for ischemic heart disease. However, an increase was reported for heart rhythm disorders 0.96 (95% CI: −0.21, 2.12). Overall, Henneman et al. (2019) found that reductions in annual PM_2.5_ concentrations from coal-fueled power plants resulted in corresponding reductions in a number of cardiovascular-related hospital admissions.

To examine the relationship between annual average PM_2.5_ concentrations and cardiovascular-related hospital admissions including myocardial infarction, stroke, and atrial fibrillation and flutter among Medicare beneficiaries, Danesh Yazdi et al. (2021) used a doubly robust additive model (DRAM). The steps for the approach used by Danesh Yazdi et al. (2021) is depicted in Figure 3-12. PM_2.5_ concentrations were derived from a spatiotemporal ensemble model. To control for potential confounding from individual, socioeconomic, access to care variables, and copollutants (ozone and NO_2_), an inverse probability weighting approach was applied through linear propensity score models to generate weights. The weights were then stabilized by taking the probability of the exposure as the numerator and the denominator as the probability density of the exposure as defined on the basis of the linear regression with PM_2.5_ as the outcome and covariates and other pollutants (ozone and NO_2_) as the predictors. If the inverse probability weights for the exposure and the adjustment for the weights in the outcome regression are correctly specified, it can be assumed that the estimated coefficient is unbiased. A weighted linear probability model showed that long-term exposure to PM_2.5_ was associated with increased admissions across all cardiovascular hospitalization outcomes. For each 1 µg/m^3^ increase in annual average PM_2.5_ concentrations, the authors estimated 2,536 (95% CI: 2,383, 2,691) additional admissions for ischemic stroke, 637 (95% CI: 483, 814) additional admissions for myocardial infarction, and 1,575 (95% CI: 1,426, 1,691) additional admissions for atrial fibrillation and flutter.

Figure 3-12 Analysis steps used by Danesh Yazdi et al. (2021) to examine long-term PM_2.5_ exposure and cardiovascular-related hospital admissions

Figure 3 dash 12 represents the study design of used by Danesh Yazdi et al. (2021) to examine long term P M 2.5 exposure and cardiovascular related hospital admissions. This first step shows the exposure modeling for P M 2.5 and two copollutants. Data derived from satellite measurements, chemical transport models, meteorological, and land use data were used in ensemble models to estimate P M 2.5, ozone, and nitrogen dioxide concentrations from three different machine learning algorithms of neural network, gradient boosting machine, and random forest. The second step shows the approach to creating the stabilized inverse probability weighting (I P W). Linear propensity score model for each pollutant were used to create the inverse probability weights of the exposure to control for individual, socioeconomic, and access to care variables and the copollutants. The third step shows the outcome regression. Weighted linear probability models for each outcome were used to control for individual, socioeconomic, and access to care variables and the copollutants. Lastly, the fourth step shows the process for developing the bootstrap weighted outcome regression model, which obtains the coefficients and confidence intervals. Additionally, the bootstrap weighted outcome regression model was used for the sensitivity analyses and effect measure modification analyses.

Source: Danesh Yazdi et al. (2021)

Zigler et al. (2018) used a hybrid approach of integrating an accountability analysis with an alternative method for confounder control to examine whether attainment status for the 1997 NAAQS led to an improvement in PM_2.5_ concentrations and subsequently health. By focusing on nonattainment designations, the authors are able to examine the role of local control strategies in reducing PM_2.5_ concentrations that occurred above and beyond reductions due to regional strategies. Within this study, Zigler et al. (2018) employed propensity scores, within a spatial hierarchical regression model to examine whether designation of nonattainment in 2005 for the 1997 PM NAAQS, for either the annual standard of 15 µg/m^3^ or the daily standard of 65 µg/m^3^, led to a corresponding reduction in ambient PM_2.5_ concentrations and hospitalization admission rates for cardiovascular-related outcomes (i.e., cardiovascular stroke, heart failure, heart rhythm disorders, ischemic heart disease, and peripheral vascular disease) among Medicare beneficiaries in the eastern U.S. from 2009 to 2012. Using publicly available date sources for the analysis, Zigler et al. (2018) compared average annual PM_2.5_ concentrations and selected cardiovascular hospital admission rates in nonattainment areas against those in attainment areas using a two-step approach and adjusting for confounding factors that differed between the areas.

In the first step, propensity scores were used to adjust for confounders by grouping attainment and nonattainment areas based on similarities in baseline characteristics, which are detailed in Appendix A (Table A-4). Under the assumption that these baseline factors comprise all factors that differ between locations in attainment and nonattainment areas and that the factors are correlated with both the exposure (ambient PM_2.5_ concentration) and each outcome (cardiovascular-related hospital admission rates), there should be no unmeasured confounders. To ensure that nonattainment areas are compared only with attainment areas with similar baseline factors, (1) propensity scores were estimated based on the probability that a monitoring location is in a nonattainment area, conditional on the baseline factors; (2) areas with features that are not comparable to other areas in the comparison group were identified and omitted (propensity score pruning); and (3) the remaining locations were grouped into quartiles, where attainment and nonattainment areas have similar baseline factors (e.g., population, PM_2.5_ concentrations, demographics) within each subgroup.

In the second step, a spatial hierarchical regression model was used to predict the potential annual ambient PM_2.5_ concentration in 2010–2012 that would have occurred in nonattainment areas if the designations had never occurred. For this part of the analysis, the spatial hierarchical model is estimated jointly with a log-linear model using the same confounding adjustment for propensity score group and additional covariates for each type of cardiovascular hospital admission. In addition to estimating the effect estimates for the overall average effects, a principal stratification approach was used to estimate “associative effects” and “dissociative effects.” Within this study, Zigler et al. (2018) define effect estimates for the “associative effects” as the effects of the nonattainment designations on cardiovascular-related hospital admissions among areas where the nonattainment designations are estimated to reduce ambient PM_2.5_ concentrations by at least 1 μg/m^3^, and “dissociative effects” as the effects of the nonattainment designations estimated to not affect PM_2.5_ concentrations by more than ±1 μg/m^3^.

Zigler et al. (2018) reported a slight reduction in the overall average effect for hospital admission rates for cardiovascular stroke, heart failure, and ischemic heart disease and an increase in the overall effect for hospital admission rates for peripheral vascular disease; however, 95% CIs were wide and included zero. There was no evidence of a reduction in hospital admission rates for heart rhythm disorders or peripheral vascular disease. When examining the average “associative effects,” the authors reported an average reduction of −2.38 (95% CI: −4.35, −0.44) and −2.60 (95% CI: −4.24, −1.14) for only heart failure and ischemic heart disease hospital admissions per 1,000 person-years, respectively. The authors reported a similar pattern of associations for the average “dissociative effects,” that is, slight reductions in hospital admission rates for only cardiovascular stroke and heart failure with wide 95% CIs that included the null. Overall, the results of Zigler et al. (2018) provide evidence that reductions in ambient PM_2.5_ concentrations and the selected cardiovascular hospital admissions could not be conclusively attributed to nonattainment designations against the backdrop of other regional strategies that impacted the eastern U.S.

The addition of these recent studies further supports the findings from the studies of the 2019 PM ISA. Overall, these studies reported consistent findings that long-term PM_2.5_ exposure is associated with increased hospital admissions for a variety of cardiovascular disease outcomes among large nationally representative study populations. The addition of studies that use methods to reduce uncertainties related to potential confounding bias with statistical methods and/or study design approaches, like DRAM used by Danesh Yazdi et al. (2021) or the DID approach used by Henneman et al. (2019), further increase confidence in the relationship between long-term PM_2.5_ exposure and cardiovascular effects.

#### 3.1.2.4 Summary of Recent Evidence in the Context of the 2019 Integrated Science Assessment for Particulate Matter Causality Determination for Long-Term PM_2.5_ Exposure and Cardiovascular Effects

Recent epidemiologic studies published since the 2019 PM ISA support and extend the evidence that contributed to the conclusion of a causal relationship between long-term PM_2.5_ exposure and cardiovascular effects. Numerous U.S. and Canadian cohort studies conducted in locations where the long-term PM_2.5_ concentration are less than 13 µg/m^3^ add to the strong evidence base that was characterized in the 2019 PM ISA describing the relationship between long-term PM_2.5_ and cardiovascular mortality, and specifically IHD- and stroke-related mortality. Overall, these recent cardiovascular mortality studies reported positive associations at varying spatial scales and across different exposure assessment and statistical methods. The associations between long-term PM_2.5_ exposure and cardiovascular mortality generally persisted in models that were adjusted for ozone, NO_2_, PM_10−2.5_, or SO_2_, and most analyses of the C-R function supported a linear, no-threshold relationship for cardiovascular mortality, especially at lower ambient concentrations of PM_2.5_ (Section 3.2.2.2.2).

Although results were not entirely consistent, evidence of positive associations between long-term PM_2.5_ exposure and cardiovascular morbidity (i.e., CHD, stroke, and atherosclerosis progression) were observed in epidemiologic studies reviewed in the 2019 PM ISA, providing coherence with the mortality findings described above. Recent studies support and the extend findings characterized in the 2019 PM ISA, providing additional evidence of positive associations between long-term PM_2.5_ exposure and cardiovascular outcomes including MI, stroke, arrhythmias, atherosclerosis, HF, and hypertension. Although positive associations are not reported in all studies, these recent studies also support and extend the most consistent evidence of cardiovascular effects reviewed in the 2019 PM ISA, which described positive associations among those with preexisting diseases and among patients that are followed after a cardiac event or procedure (Rhinehart et al., 2020; Ward-Caviness et al., 2020; Malik et al., 2019; Weaver et al., 2019). Recent studies also support and extend the evidence in the 2019 PM ISA regarding effect measure modification by income and SES (Section 3.3.3). Together these recent studies examining effect measure modification may explain inconsistency observed across cardiovascular morbidity studies by identifying factors that determine the heterogeneity.

The limited number of studies reviewed in the 2019 PM ISA found that risk estimates remained largely unchanged after adjustment for PM_10−2.5_, NO_2_, and PM_2.5_ from traffic sources. The few recent analyses report some attenuation of risk estimates in models adjusted for O_3_ and NO_2_. Recent studies also support and extend the evidence in the 2019 PM ISA pertaining to the joint effects of multiple pollutants indicating that associations may be modified by oxidant gases, PM_2.5_ composition and long-term exposure to NO_2_. Further, recent studies support and extend the evidence in the 2019 PM ISA pertaining to the shape of the C-R function for cardiovascular morbidity effects. Although still limited in number, recent studies characterizing the C-R relationship provide a more thorough examination of potential for departures from linearity. Evidence from these studies is generally consistent with that presented in the 2019 PM ISA, and shows a linear, no-threshold C-R relationship for most CVD outcomes. However, there is some evidence for a sublinear or supralinear C-R relationship for specific outcome (i.e., CHF and AF). Finally, a few recent epidemiologic studies that employed alternative methods for confounder control to reduce uncertainties related to potential confounding bias provide additional support for a relationship between long-term PM_2.5_ exposure and cardiovascular effects.

## 3.2 Mortality

### 3.2.1 Short-Term PM_2.5_ Exposure

The following sections represent a summary of the evidence and the corresponding causality determination for short-term PM_2.5_ exposure and mortality presented within the 2019 PM ISA (Section 3.2.1.1) along with an evaluation of recent epidemiologic studies that fall within the scope of the Supplement (i.e., studies conducted in the U.S. and Canada) and were published since the literature cutoff date of the 2019 PM ISA (Section 3.2.1.2).^16^ In addition, with the expansion of epidemiologic studies that used statistical approaches that attempt to more extensively account for confounders and are more robust to model misspecification (i.e., used alternative methods for confounder control), recent studies that employed such methods are also evaluated (Section 3.2.1.3), which can further inform the relationship between short-term PM_2.5_ exposure and mortality. Finally, a summary of the results of recent studies evaluated within the section is presented in the context of the scientific conclusions detailed in the 2019 PM ISA (Section 3.2.1.4). The evaluation of recent studies on short-term PM_2.5_ exposure and mortality presented in this Supplement adds to the collective body of evidence reviewed in the process of reconsidering the PM NAAQS.

#### 3.2.1.1 Summary and Causality Determination from 2019 Integrated Science Assessment for Particulate Matter

Multicity studies evaluated since the completion of the 2009 PM ISA continue to provide evidence of primarily positive associations between short-term PM_2.5_ exposures and total (nonaccidental) mortality from studies conducted mostly in urban areas using traditional exposure assignment approaches (i.e., average of all available monitors) as well as studies with a larger spatial coverage (i.e., urban and rural areas) employing new methods using multiple types of PM_2.5_ data (i.e., combination of monitoring, satellite, and land use regression [LUR]). Additionally, the evidence from studies evaluated in the 2019 PM ISA further substantiated the relationship between short-term PM_2.5_ exposure and mortality by providing additional information on potential copollutant confounding; effect modification (e.g., stressors, pollutants, season); geographic heterogeneity in associations; and the shape of the C-R relationship, which collectively reaffirmed that a causal relationship exists between short-term PM_2.5_ exposure and mortality. The body of evidence for total mortality was supported by generally consistent positive associations with cardiovascular and respiratory mortality.

In addition to evaluating epidemiologic studies that examined the relationship between short-term PM_2.5_ exposure and mortality, the 2019 PM ISA characterized whether evidence supported biologically plausible mechanisms by which short-term PM_2.5_ exposure could lead to mortality (2019 PM ISA, Section 11.1.1). This evaluation consisted of an assessment of animal toxicological, controlled human exposure, and epidemiologic studies of morbidity effects that are the largest contributors to total (nonaccidental) mortality, specifically, cardiovascular and respiratory morbidity (2019 PM ISA, Section 6.1.1 and Section 5.1.1, respectively). Plausible mechanisms were identified by which inhalation exposure to PM_2.5_ could progress from initial events to endpoints relevant to the cardiovascular system and to population outcomes such as ED visits and hospital admissions due to cardiovascular disease, particularly ischemic heart disease and congestive heart failure (2019 PM ISA, Section 6.1.1). Similarly, available evidence was characterized by which inhalation exposure to PM_2.5_ could progress from initial events to endpoints relevant to the respiratory system (2019 PM ISA, Section 5.1.1). However, the evidence for how the initial events and subsequent endpoints could lead to the observed increases in respiratory ED visits and hospital admissions, in particular for chronic obstructive pulmonary disease (COPD) and asthma was limited. In summary, although there was coherence of effects across the scientific disciplines (i.e., animal toxicological, controlled human exposure studies, and epidemiologic) and biological plausibility for PM_2.5_-related cardiovascular (2019 PM ISA, Chapter 6) and respiratory (2019 PM ISA, Chapter 5) morbidity, there was strong evidence indicating biological plausibility for PM_2.5_-related cardiovascular mortality with more limited evidence for respiratory mortality.

This section describes the evaluation of evidence for total (nonaccidental) mortality conducted in the 2019 PM ISA, with respect to the causality determination for short-term exposures to PM_2.5_ using the framework described in Table II of the Preamble to the ISAs (U.S. EPA, 2015). The key evidence, as it relates to the causal framework, is summarized in Table 3-4.

Table 3-4 Summary of evidence for a causal relationship between short-term PM_2.5_ exposure and total mortality from the 2019 Integrated Science Assessment for Particulate Matter

Rationale for Causality Determination^a^ | Key Evidence^b^ | Key References and Sections in the 2019 PM ISA^b^ | PM_2.5_ Concentrations Associated with Effects (µg/m^3^)^c^
Consistent epidemiologic evidence from multiple studies at relevant PM_2.5_ concentrations | Increases in mortality in multicity studies conducted in the U.S., Canada, Europe, and Asia.; Total mortality associations, further supported by increases in cardiovascular and respiratory mortality in multicity studies conducted in the U.S., Canada, Europe, and Asia. | Section 11.1.2; Figure 11-1; Figure 11-2; Section 5.1.9; Section 6.1.9 | Mean 24-h avg:; U.S. and Canada: 4.37−17.97; Europe: 13−27.7d; Asia: 11.8−69.9; Table 11-1
Epidemiologic evidence from copollutant models provides some support for an independent PM_2.5_ association | The magnitude of PM_2.5_ associations remain positive, but in some cases are reduced with larger confidence intervals in copollutant models with gaseous pollutants and PM_10−2.5_, supporting the limited evidence from the 2009 PM ISA. Further support comes from copollutant analyses indicating positive associations for cardiovascular and respiratory mortality. Recent studies that examined potential copollutant confounding are limited to studies conducted in Europe and Asia.; When reported, correlations with gaseous copollutants were primarily in the low (r < 0.4) to moderate (r ≥ 0.4 or < 0.8) range. | Section 11.1.4; Figure 11-3; Section 5.1.10.1; Section 6.1.14.1
Epidemiologic evidence supports a linear, no-threshold C-R relationship | Recent multicity studies conducted in the U.S. and Europe provide direct evidence of a linear, no-threshold C-R relationship at lower PM_2.5_ concentrations with initial evidence of a steeper slope, but extensive systematic evaluations of alternatives to linearity have not been conducted. | Section 11.1.10; Shi et al. (2015); Lee et al. (2015); Di et al. (2017a)
Biological plausibility from cardiovascular morbidity evidence | Strong evidence for coherence of effects across scientific disciplines and biological plausibility for a range of cardiovascular effects in response to short-term PM_2.5_ exposure, specifically for ischemic events and heart failure, which is supported by experimental evidence and epidemiologic studies examining hospital admissions and ED visits. The collective body of cardiovascular morbidity evidence provides biological plausibility for a relationship between short-term PM_2.5_ exposure and cardiovascular mortality, which comprises ~33% of total mortality. | Section 6.1.16; Table 6-33
Limited biological plausibility from respiratory morbidity evidence | Limited evidence for coherence of effects across scientific disciplines and biological plausibility, with the strongest evidence for exacerbations of COPD and asthma. The collective body of respiratory morbidity evidence provides limited biological plausibility for a relationship between short-term PM_2.5_ exposure and respiratory mortality, which comprises ~9% of total mortality. | Section 5.1.12; Table 5-18
Uncertainty regarding geographic heterogeneity in PM_2.5_ associations | Multicity U.S. studies demonstrate city-to-city and regional heterogeneity in PM_2.5_-mortality associations. Evidence supports that a combination of factors, including composition and exposure factors may contribute to the observed heterogeneity. | Section 11.1.6.3

Note: This table corresponds to Table 11-4 in the 2019 PM ISA.

avg = average; COPD = chronic obstructive pulmonary disease; C-R = concentration-response; ED = emergency department; h = hour; PM = particulate matter; PM_2.5_ = particulate matter with a nominal mean aerodynamic diameter less than or equal to 2.5 μm; PM_10−2.5_ = particulate matter with a nominal mean aerodynamic diameter greater than 2.5 μm and less than or equal to 10 μm; r = correlation coefficient.

a Based on aspects considered in judgments of causality and weight of evidence in causal framework in Table I and Table II of the Preamble to the ISAs U.S. EPA (2015).

b Describes the key evidence and references, supporting or contradicting, contributing most heavily to the causality determination and, where applicable, to uncertainties or inconsistencies. References to earlier sections indicate where the full body of evidence is described in the 2019 PM ISA.

c Describes the PM_2.5_ concentrations with which the evidence is substantiated.

d Median concentration from Samoli et al. (2013).

e Statistics taken from NHLBI (2017).

Collectively, the evidence from multicity studies of short-term PM_2.5_ exposures and mortality evaluated in the 2019 PM ISA generally demonstrated positive associations with total (nonaccidental) mortality, with increases ranging from 0.19% (Lippmann et al., 2013b) to 2.80% (Kloog et al., 2013) at lags of 0 to 1 days in single-pollutant models. These results were further supported by initial studies employing causal inference and quasi-experimental statistical approaches (2019 PM ISA, Section 11.1.2.1). Whereas most studies relied on assigning exposure using data from ambient monitors, some of the studies evaluated also employed hybrid modeling methods, which use additional sources of PM_2.5_ data (i.e., monitor, satellite, and LUR) to estimate PM_2.5_ concentrations and assign exposure, allowing for the inclusion of less urban and rural locations in analyses (Lee et al., 2015; Shi et al., 2015; Kloog et al., 2013). The studies evaluated expanded the assessment of potential copollutant confounding on the PM_2.5_-mortality relationship, and provided additional evidence supporting the conclusion that PM_2.5_ associations remain positive and relatively unchanged in copollutant models with both gaseous pollutants and PM_10−2.5_, but this conclusion was based on a limited number of multicity studies conducted in Europe and Asia where mean 24-hour avg PM_2.5_ concentrations are higher (2019 PM ISA, Table 3-1). However, the low (r < 0.4) to moderate correlations (r = 0.4 < 0.7) between PM_2.5_ and gaseous pollutants and PM_10−2.5_ increased the confidence in PM_2.5_ having an independent effect on mortality.

The positive associations for total (nonaccidental) mortality reported across the majority of studies evaluated was further supported by analyses focusing on cause-specific mortality that continue to provide evidence of generally consistent positive associations with both cardiovascular and respiratory mortality, except in the case of a multicity study conducted in Europe (Lanzinger et al., 2016). Risk estimates for cardiovascular mortality ranged from 0.09% (Lippmann et al., 2013b) to 2.32% (Lee et al., 2015), while those for respiratory mortality ranged from 0.09% (Lee et al., 2015) to 2.30% (Janssen et al., 2013), but overall associations tended to be larger in magnitude for respiratory mortality. For both cardiovascular and respiratory mortality there was a limited assessment of potential copollutant confounding, but for both outcomes, initial evidence indicated that associations remained positive and relatively unchanged in models with gaseous pollutants and PM_10−2.5_, which further supported the copollutant analyses conducted for total (nonaccidental) mortality. The strong evidence for ischemic events and heart failure detailed in the assessment of cardiovascular morbidity (2019 PM ISA, Chapter 6), provided strong biological plausibility for PM_2.5_-related cardiovascular mortality, which comprises the largest percent of total mortality [i.e., ~33%; NHLBI (2017)]. Although there was evidence for exacerbations of COPD and asthma, the collective body of respiratory morbidity evidence provided limited biological plausibility for PM_2.5_-related respiratory mortality (2019 PM ISA, Chapter 5).

In addition to examining potential copollutant confounding, a number of studies evaluated in the 2019 PM ISA also assessed whether statistical models adequately accounted for temporal trends and weather covariates. Across studies that evaluated model specification, PM_2.5_-mortality, associations remained positive, although in some cases were attenuated, when using different approaches to account for temporal trends or weather covariates (2019 PM ISA, Section 11.1.5). Seasonal analyses continued to provide evidence that associations were larger in magnitude during warmer months, but it remained unclear whether copollutants confound the associations observed. In addition to seasonal analyses, some studies also examined whether temperature modified the PM_2.5_-mortality relationship. Initial evidence indicated that the PM_2.5_-mortality association may be larger in magnitude at lower and higher temperatures, but this observation has not been substantiated by studies conducted in the U.S. (2019 PM ISA, Section 11.1.6.2).

At the completion of the 2009 PM ISA, one of the main uncertainties identified was the regional and city-to-city heterogeneity in PM_2.5_-mortality associations observed in multicity studies. Studies evaluated in the 2019 PM ISA examined both city specific as well as regional characteristics to identify the underlying factors that contribute to this heterogeneity (2019 PM ISA, Section 11.1.6.3). Analyses focusing on effect modification of the PM_2.5_-mortality relationship by PM_2.5_ components, regional patterns in PM_2.5_ components, and city-specific differences in composition and sources indicated some differences in the PM_2.5_ composition and sources across cities and regions, but these differences did not fully explain the heterogeneity observed. Additional studies examined whether exposure factors play a role in explaining the heterogeneity in PM_2.5_-mortality associations and found that some factors related to housing stock and commuting, as well as city-specific factors (e.g., land use, port volume, and traffic information), also explain some of the observed heterogeneity. Collectively, the studies evaluated indicated that the heterogeneity in PM_2.5_-mortality risk estimates cannot be attributed to one factor, but instead to a combination of factors, including, but not limited to, compositional and source differences, as well as exposure differences.

A number of studies evaluated conducted systematic evaluations of the lag structure of associations for the PM_2.5_-mortality relationship by examining either multiday lags or a series of single-day lags, and these studies continued to support an immediate effect (i.e., lag 0 to 1 days) of short-term PM_2.5_ exposures on mortality (2019 PM ISA, Section 11.1.8.1). Studies also conducted analyses comparing the traditional 24-hour avg exposure metric with a subdaily metric (i.e., 1-hour max). These initial studies provided evidence of a similar pattern of associations for both the 24-hour avg and 1-hour max metric, with a larger association for the 24-hour avg metric. Additionally, some studies examined alternative exposure metrics representing size fractions smaller than PM_2.5_ and reflecting number concentration (NC) and surface-area concentration (SC). The generally positive associations reported with mortality for these smaller PM size fractions supported the larger body of PM_2.5_-mortality evidence, but it is difficult to compare NC and SC metrics with the traditional mass-based metric.

Building off the initial analysis of the C-R relationship between short-term PM exposure and mortality that focused on PM_10_, multicity studies conducted in the U.S. and Europe examined the shape of the C-R relationship and whether a threshold exists specifically for PM_2.5_ (2019 PM ISA, Section 11.1.10). These studies used different statistical approaches and consistently demonstrated a linear relationship with no evidence of a threshold. Additionally, recent analyses conducted at lower PM_2.5_ concentrations (i.e., 24-hour avg PM_2.5_ concentrations < 30 µg/m^3^) provided initial evidence indicating that PM_2.5_-mortality associations persist and may be stronger (i.e., a steeper slope) at lower concentrations. However, to date, extensive analyses have not been conducted to systematically explore alternatives to linearity when examining the shape of the PM_2.5_-mortality C-R relationship.

Overall, epidemiologic studies evaluated in the 2019 PM ISA built upon and further reaffirm the conclusions of the 2009 PM ISA for total mortality. The evidence particularly from the assessment of PM_2.5_-related cardiovascular morbidity, with more limited evidence from respiratory morbidity, provided biological plausibility for mortality from short-term PM_2.5_ exposures. In conclusion, the primarily positive associations observed across studies conducted in various locations was further supported by the results from copollutant analyses that indicated robust associations, along with evidence from analyses of the C-R relationship. Collectively, this body of evidence is sufficient to conclude that a causal relationship exists between short-term PM_2.5_ exposure and total mortality.

#### 3.2.1.2 Recent U.S. and Canadian Epidemiologic Studies

The few recent multicity studies conducted in the U.S. and Canada build upon the strong epidemiologic evidence base evaluated in the 2019 PM ISA, as well as in previous assessments, which provided the scientific rationale supporting a causal relationship between short-term PM_2.5_ exposure and mortality (Section 3.1.1.1). In addition to examining the relationship between short-term PM_2.5_ exposure and all-cause or nonaccidental mortality (Section 3.1.1.2.1) and cause-specific mortality (Section 3.1.1.2.2), additional analyses within these recent studies also further examined issues relevant to expanding the overall understanding of the effect of short-term PM_2.5_ exposure on mortality. Specifically, recent studies have assessed potential copollutant confounding (Section 3.1.1.2.3), examined effect modification of the PM_2.5_-mortality relationship (Section 3.1.1.2.4), the lag structure of associations (Section 3.1.1.2.5), and assessed the shape of the concentration-response (C-R) relationship (Section 3.1.1.2.6). The following sections present an evaluation of recent multicity studies that inform each of the aforementioned topics within the context of the evidence base evaluated and summarized in the 2019 PM ISA. Study-specific details (e.g., study population, exposure assessment approach, confounders considered) for the epidemiologic studies evaluated in this section are presented in Appendix A (Table A-5).

##### 3.2.1.2.1 All-Cause and Total (Nonaccidental) Mortality

Since the literature cutoff date for the 2019 PM ISA, a limited number of multicity studies have been conducted within the U.S. and Canada (Shin et al., 2021a; Liu et al., 2019; Lavigne et al., 2018). Although few in number, these recent studies add to the extensive number of multicity studies evaluated in the 2019 PM ISA that were conducted globally, specifically in locations where mean 24-hour concentrations were generally < 20 µg/m^3^ (2019 PM ISA, Section P.3.1). Taken together, these studies provide consistent evidence of positive associations between short-term PM_2.5_ exposure and mortality across diverse geographic locations; in populations with a wide range of demographic characteristics; and using a variety of statistical models, approaches to confounder adjustment, and exposure assessment approaches (Figure 3-13).

Figure 3-13 Summary of associations between short-term PM_2.5_ exposure and total (nonaccidental) mortality in multicity studies

avg = average; μg/m^3^ = microgram per cubic meter; NMMAPS = National Morbidity, Mortality, and Air Pollution Study; PM = particulate matter; PM_2.5_ = particulate matter with a nominal mean aerodynamic diameter less than or equal to 2.5 μm; UFIREG = Ultrafine Particles―An Evidence-Based Contribution to the Development of Regional and European Environmental and Health Policy.

Note: †Studies published since the 2009 PM ISA. *U.S. and Canadian studies published since the literature cutoff date (~January 2018) 2019 PM ISA. Black circles = U.S. and Canadian multicity studies evaluated in the 2004 PM AQCD and 2009 PM ISA. Red circles = multicity studies and meta-analyses published since the completion of the 2009 PM ISA. Blue circles = multicity U.S. and Canadian studies published since the literature cutoff date of the 2019 PM ISA. Risk estimates are standardized to a 10 μg/m^3^ increase in PM_2.5_ concentrations.

^a^Results are from modeled PM_2.5_ analysis, analysis focusing on measured PM_2.5_ reported 1.21% (95% CI: 0.94, 1.47).

^b^Only four of the five cities measured PM_2.5_.

^c^Shi et al. (2015), Zanobetti et al. (2014), and Liu et al. (2019) only had data for all-cause mortality including accidental mortalities.

^d^Main model used in Young et al. (2017) included current and average of 3 previous days daily maximum temperature, daily minimum temperature, and maximum daily relative humidity.

^e^Sensitivity analysis in Young et al. (2017) focusing on only the San Francisco Bay air basin, dropping out the maximum daily relative humidity term, where the shortest duration of lag days examined was 0−3 days.

^f^Ueda et al. (2009) presented results for three different modeling approaches, which are presented here: generalized additive model (GAM), generalized linear model (GLM), and case-crossover.

^g^Atkinson et al. (2014) primarily focused on single-day lag results.

^h^Adar et al. (2014) focused on single-day lag results, specifically lag 0, 1, or 2.

Figure 3 dash 13 presents a summary of associations, depicted as the percent increase, between short-term P M 2.5 exposure and total (nonaccidental) mortality for a 10 micrograms per cubic meter increase in 24-hour average concentrations from recently published and previously evaluated multicity studies in the 2019 P M I S A and previous P M assessments. Across studies there is evidence of primarily positive associations in studies of all ages and people over the age of 65, and these results are further confirmed in recently published meta-analyses.

Source: Update of Figure 11-1, 2019 PM ISA.

Recent studies that conducted multicity analyses in the U.S. and Canada include a large international study that performed a global multicity analysis (Liu et al., 2019) and a few studies in Canada that relied on data from over 20 cities (Shin et al., 2021a; Lavigne et al., 2018). Using the Multi-City Multi-Country (MCC) Collaborative Research Network, Liu et al. (2019) was able to collect data globally, resulting in a data set consisting of air pollution and mortality data from 652 urban areas in 24 countries from 1986 to 2015. Although the goal of the study was to estimate a global estimate of the association between short-term PM_2.5_ exposure and mortality, the authors presented country specific estimates as well, including for the U.S. and Canada. The authors applied a uniform statistical model across all of the cities within the study consisting of a quasi-Poisson general additive model that controlled for temporal trends and weather covariates. In a second-stage analysis, the authors used a random-effects model to pool city-specific estimates into a country-specific estimate. All analyses relied on PM_2.5_ data for which the highest and lowest 5% of data was trimmed to remove outliers. In analyses of 25 Canadian cities from 1986 to 2011 and 107 U.S. cities from 1987 to 2006, the authors reported a 1.70% (95% CI: 1.17, 2.23) and 1.58% (95% CI: 1.28, 1.88) increase in mortality, respectively, at lag 0−1 days.

Recent studies conducted in Canada by Lavigne et al. (2018) and Shin et al. (2021a) focused on more recent years of data, 1998−2011 and 2001−2012, respectively, in comparison to Liu et al. (2019). Lavigne et al. (2018) focused on examining whether oxidant gases modified the association between short-term PM_2.5_ exposure and mortality in 24 Canadian cities (discussed in more detail in Section 3.2.1.2.4). In a time-stratified case-crossover analysis that adjusted for both mean temperature and location-specific temperature distributions and relative humidity, the authors reported a 0.76% (95% CI: 0.15, 1.21) increase in mortality at lag 0−2 days. The results of Lavigne et al. (2018) are consistent with those reported by Shin et al. (2021a) in a time-series study of 22 Canadian cities. The authors examined single-day lags ranging from 0 to 2 days using a two-stage hierarchical model consisting of a Poisson model in the first stage to examine city-specific associations and a Bayesian random effects model in the second stage to combine city-specific effects into a national estimate. Shin et al. (2021a) reported associations with mortality similar in magnitude at lag 0 (0.94% [0.43, 1.46]) and 1 day (0.90% [95% CI: 0.33, 1.41]) with no evidence of an association at lag 2. Although it is unclear as to why the magnitude of associations reported in Lavigne et al. (2018) and Shin et al. (2021a) differ from those reported by Liu et al. (2019), even though both are using a similar subset of cities, it could be attributed to the more recent years of data used in Lavigne et al. (2018) and Shin et al. (2021a) where there has been a decreasing trend in PM_2.5_ concentrations (Shin et al., 2021a).

###### Sudden Nonaccidental Mortality

The 2009 PM ISA reviewed a handful of small studies examining the association between PM_2.5_ exposure and out-of-hospital cardiac arrest (OHCA). No evidence of an association was reported. Section 6.1.4.1 of the 2019 PM ISA evaluated studies published since the 2009 PM ISA, which provided evidence for an association between short-term PM_2.5_ exposure and OHCA. This association was typically observed with PM_2.5_ concentrations averaged over the past 0 to 2 days, although associations with PM_2.5_ concentrations as far back as 4 days before the event have been reported. Additionally, all of the studies assessed in the 2009 and 2019 ISAs relied on a single monitor or an average of fixed-site monitors to estimate PM_2.5_ exposure, which restricts the study population to people living near monitors. While the previously evaluated studies focused on a cardiovascular outcome (i.e., OHCA) and as a result were discussed within the evidence for short-term PM_2.5_ exposure and cardiovascular effects, the results of these previous studies are summarized here as they can inform a recent study by Rappazzo et al. (2019) that examined out-of-hospital sudden unexpected deaths.

Rappazzo et al. (2019) conducted a time-stratified case-crossover analysis to examine the relationship between short-term PM_2.5_ exposure and out-of-hospital nonaccidental sudden unexpected deaths in a small population of individuals (n = 399) over a 2-year period that resided in Wake County, NC. In analyses examining both single-day lags ranging from 0 to 3 days and a 0−1 day lag, the authors reported a positive association at lag 1 (OR = 1.39 [95% CI: 0.96, 1.99]) that was smaller in magnitude when using a 0−1 day lag (OR = 1.18 [95% CI: 0.79, 1.78]). However, due to the small sample size within this study confidence intervals are large. In addition to single-pollutant models, the authors examined copollutant models across the single-day lags and reported that PM_2.5_ associations are relatively unchanged in models with NO_2_, SO_2_, ozone, and CO. This initial study focusing out-of-hospital sudden unexpected deaths from all nonaccidental causes, provides evidence consistent with the relatively limited number of previous studies examining OHCA.

##### 3.2.1.2.2 Cause-specific Mortality

Single and multicity studies evaluated in the 2009 PM ISA that examined cause-specific mortality reported consistent positive associations with both cardiovascular and respiratory mortality. The magnitude of the association was larger for respiratory mortality, but these associations also had wider confidence intervals due to the smaller number of respiratory-related deaths than cardiovascular-related deaths. Studies evaluated in the 2019 PM ISA added to this body of evidence but provided more consistent evidence of associations for cardiovascular mortality compared with respiratory mortality. Recent multicity studies conducted in Canada provide additional support for an association with cardiovascular mortality (Lavigne et al., 2018). Consistent with the evidence assessed in previous ISAs, recent studies report more variable results with wider confidence intervals for respiratory mortality (Shin et al., 2021b; Lavigne et al., 2018).

Figure 3-14 Summary of associations between short-term PM_2.5_ exposure and cardiovascular and respiratory mortality in multicity studies

avg = average; μg/m^3^ = microgram per cubic meter; PM = particulate matter; PM_2.5_ = particulate matter with a nominal mean aerodynamic diameter less than or equal to 2.5 μm; UFIREG = Ultrafine Particles―An Evidence-Based Contribution to the Development of Regional and European Environmental and Health Policy.

Note: †Studies published since the 2009 PM ISA. *U.S. and Canadian studies published since the literature cutoff date (~January 2018) for the 2019 PM ISA. Studies organized by lag structure, therefore, cardiovascular and respiratory mortality results are not in the same order. Black circles = U.S. and Canadian multicity studies evaluated in the 2004 PM AQCD and 2009 PM ISA. Red circles = multicity studies and meta-analyses published since the literature cutoff date of the 2009 PM ISA. Risk estimates are standardized to a 10 μg/m^3^ increase in PM_2.5_ concentrations. All ages examined for all studies except Lanzinger et al. (2016) and Shin et al. (2021b) which focused on ages ≥ 1 year old.

^a^Only four of the five cities measured PM_2.5_.

^b^Atkinson et al. (2014) primarily focused on single-day lag results.

^c^Adar et al. (2014) focused on single-day lag results, specifically lag 0, 1, or 2.

Figure 3 dash 14 presents a summary of associations, depicted as the percent increase, between short-term P M 2.5 exposure and cardiovascular and respiratory mortality for a 10 micrograms per cubic meter increase in 24-hour average concentrations from recently published and previously evaluated multicity studies in the 2019 P M I S A and previous P M assessments. Across studies there is evidence of generally consistent positive associations for both cardiovascular and respiratory mortality, with some evidence of associations larger in magnitude for respiratory mortality. However, confidence intervals are wider for respiratory mortality associations compared to cardiovascular mortality because respiratory mortality encompasses a smaller percent of total (nonaccidental) mortality.

Source: Update of Figure 11-2, 2019 PM ISA.

##### 3.2.1.2.3 Potential Copollutant Confounding of the PM_2.5_-Mortality Relationship

As discussed in Section 3.1.2.2.8, one approach to assessing the independence of the association between exposure to PM_2.5_ and a health effect, such as short-term PM_2.5_ exposure and mortality, can be examined is through the use of copollutant models. Appendix (Table A-1) to the 2019 PM ISA notes that copollutant models are not without their limitations, such as instances where correlations are high between pollutants resulting in greater bias in results. However, in assessing the results from copollutant models a change in the PM_2.5_ risk estimate, after adjustment for a copollutant, may indicate the potential for confounding.

At the time of the 2009 ISA, only a few studies had assessed the potential for confounding of the PM_2.5_-mortality association by co-occurring pollutants. In contrast, the 2019 ISA included a number of multicity studies that used copollutant models to evaluate this issue, including studies that examined both gaseous pollutants and other particle size fractions. These studies reported that associations were relatively unchanged in copollutant models, albeit with wider confidence intervals than single pollutant models (2019 PM ISA, Figure 11-3).

Of the recent multicity studies conducted in the U.S. and Canada, only Lavigne et al. (2018) conducted an assessment of copollutant confounding, with a focus on oxidant gases. Within this study, oxidant gases were defined as the daily combined oxidant capacity of ozone and NO_2_ based on the redox-weighted averages of both pollutants. In a copollutant model with oxidant gases, the association between short-term PM_2.5_ exposure and mortality is unchanged compared with the single pollutant model with both reporting a 0.76% increase in mortality at lag 0−2 days.

##### 3.2.1.2.4 Effect Modification of the PM_2.5_-Mortality Relationship

Multicity epidemiologic studies evaluated in the 2009 PM ISA and 2019 PM ISA provided evidence of city-to-city and regional heterogeneity in PM_2.5_-mortality associations. Within the 2019 PM ISA, studies were evaluated that examined factors that could modify the PM_2.5_-mortality association and potentially explain some of the observed heterogeneity in associations, including season (2019 PM ISA, Section 11.1.6.1), temperature (2019 PM ISA, Section 11.1.6.2), city and regional characteristics (Section 11.1.6.3) such as composition/mixtures (2019 PM ISA, Section 11.1.6.3.1), and exposure factors (i.e., residential infiltration factors and commuting factors) (2019 PM ISA, Section 11.1.6.3.2). Recent multicity studies provide additional insight into some of these factors that could modify the PM_2.5_-mortality association.

The 2009 PM ISA reported some evidence that PM_2.5_-mortality associations are larger in magnitude during the warm season, specifically the spring, with the majority of this evidence coming from U.S. multicity studies (Zanobetti and Schwartz, 2009; Franklin et al., 2008). As discussed in Section 11.1.6.1 of the 2019 PM ISA, across recent multicity studies, there was general agreement that PM_2.5_-mortality associations were larger in magnitude during warmer months. However, it remained unclear whether copollutants confound the seasonal patterns in the associations observed. Across most studies, the pattern of seasonal associations persisted using different methods to examine whether there was evidence of seasonal differences in associations, with some studies relying on stratified analyses (Dai et al., 2014; Samoli et al., 2013) and others incorporating interaction terms between PM_2.5_ and season (Pascal et al., 2014; Lippmann et al., 2013b). The recent studies conducted by Shin et al. (2021a) and Shin et al. (2021b) further inform seasonal analyses, but do not address the uncertainties identified in the 2019 PM ISA. Both studies assessed associations by season through stratified analyses in which the warm season is defined as April−September and the cold season as October−March. In Shin et al. (2021a), when focusing on lag 0, which had the largest magnitude of an association in all-year analyses, there is a clear pattern of the warm season driving the overall association; however, the reverse pattern is reported when focusing on lag 1, complicating the overall interpretation of results from this study. However, in Shin et al. (2021b), which focused on respiratory mortality a slight larger association, with wide confidence intervals, is reported for the warm season (1.0% [95% CI: −1.6, 3.5]) compared with the cold season (0.6% [95% CI: −2.2, 4.1]) at lag 1, the main lag examined for PM_2.5_ and mortality within the study. Across these recent studies there continues to be some evidence indicating larger associations during the warm season, but there are inconsistencies across the individual lags examined.

Within the 2019 PM ISA, an assessment of composition and mixtures (2019 PM ISA, Section 11.1.6.3.1) focused on whether differences in the pollutant mixture across cities could explain heterogeneity in the PM_2.5_-mortality association across cities and regions of the U.S. In the process of examining the association between short-term PM_2.5_ exposure and mortality across 24 Canadian cities, Lavigne et al. (2018) did not focus on whether effect modification by other pollutants could explain heterogeneity, but broadly whether oxidant gases, defined as the redox-weighted average of O_3_ and NO_2_, modify the PM_2.5_-mortality association. The authors examined the role of oxidant gases on the PM_2.5_-mortality relationship because previous studies have shown that oxidant gases can deplete antioxidants in the lung and increase permeability of the lung epithelium, and that oxidant gases may accelerate photochemical aging of PM_2.5_, potentially changing its toxicity (Lavigne et al., 2018). To assess whether there is evidence of effect modification of the PM_2.5_-mortality relationship by oxidant gases, the authors conducted stratified analyses across tertiles of oxidant gases based on the distribution of oxidant gases across all cities. For nonaccidental mortality, in analyses examining both lag 0 and lag 0−2 days for PM_2.5_, there was a consistent pattern of the PM_2.5_-mortality association being larger in magnitude for the third tertile of oxidant gases. However, there is some variability in the PM_2.5_-mortality association depending on the lag structure used to represent oxidant gases, with some evidence indicating that as the exposure for oxidant gases increased in length, there are larger PM_2.5_-mortality associations for both the second and third tertiles (Figure 3-15). The pattern of associations for nonaccidental mortality is similar for cardiovascular mortality, but there is no evidence of effect modification for respiratory mortality.

Figure 3-15 Odds ratio and 95% confidence intervals for lag 0 and lag 0−2 days of nonaccidental mortality across tertiles of lag 0, lag 0−2, and lag 0−4 oxidant gases across 24 Canadian cities

Figure 3 dash 15 from Lavigne et al. (2018) depicts the Odds Ratio and corresponding 95% Confidence Intervals for the association between short-term P M 2.5 exposure and nonaccidental mortality at lag 0-2 days, stratified across tertiles of oxidant gas concentrations, defined as the redox-weighted average of O3 and NO2, at lag 0, lag 0-2, and lag 0-4 across 24 Canadian cities. Across all lags examined the P M 2.5-mortality associations was largest in magnitude for tertile 3 of oxidant gases.

Source: Lavigne et al. (2018)

A recent study by Baxter et al. (2019) expands upon studies evaluated in the 2019 PM ISA (Baxter et al., 2017; Baxter and Sacks, 2014), which provided evidence indicating that combinations of exposure factors representative of residential infiltration (i.e., prevalence of central AC, mean year home was built, and mean size of home) explained some of the heterogeneity in the PM_2.5_-mortality association. As discussed in the 2019 PM ISA (Section 3.4, 2019 PM ISA), examining these exposure factors is important in the context of interpreting health effects associations reported in epidemiologic studies because they can affect the relationship between indoor and outdoor ambient PM concentrations and between personal exposure to ambient PM and ambient PM concentrations.

In a time-series analysis, Baxter et al. (2019) examined the association between short-term PM_2.5_ exposure and nonaccidental mortality in 312 core-based statistical areas (CBSAs) within the U.S. from 1999−2005. In a two-stage analysis, the authors first examined associations with mortality in each CBSA in a time-series analysis and then conducted a meta-regression using a fixed-effects inverse variance weighted linear regression to examine whether individual exposure factors or combinations of exposure factors explained observed heterogeneity. The variables examined within the meta-regression fall within five categories representative of housing characteristics, commuting, household heating, meteorological factors, and poverty measures. In the first-stage analysis, Baxter et al. (2019) reported a 0.95% (IQR of 2.25)^17^ increase in mortality across all CBSAs, but as depicted in Figure 3-16 there is extensive city-to-city variability in associations across the U.S.

Figure 3-16 Associations between short-term PM_2.5_ exposure and nonaccidental mortality at lag 1 for the 312 core-based statistical areas examined in Baxter et al. (2019)

Figure 3 dash 16 from Baxter et al. (2019) presents the pattern of associations for short-term P M 2.5 exposure and nonaccidental mortality at lag 1 across the United States for each of the 312 core-based statistical areas examined. Overall, there is heterogeneity in association across the country with some areas reporting no evidence of an association and other areas reporting positive associations that vary in magnitude.

Source: Baxter et al. (2019)

In the second-stage analysis, the authors conducted both a univariate and multivariate meta-regression. In the univariate regression, mortality associations larger in magnitude were observed for CBSAs with larger homes, more heating degree days, and a higher percentage of homes heating with oil, while cities with more gas heating had smaller associations. Across all univariate analyses, no individual factor explained much of the heterogeneity as reflected by R^2^ < 1%. For the multivariate model, a backward selection approach was used to develop the final model that included variables for gas heating use, heating degree days, cooling degree days, and variables for home size and age. Compared with the univariate models, the multivariate models explained a larger amount of the heterogeneity in mortality associations across the CBSAs examined, ranging from 11% to 13%. Overall, the results of Baxter et al. (2019) further support studies evaluated in the 2019 PM ISA, which indicated that a combination of factors that influence exposure to PM_2.5_, not an individual factor, explains some of the observed city-to-city and regional heterogeneity reported in multicity epidemiologic studies.

##### 3.2.1.2.5 Lag Structure of Associations

Within the 2009 PM ISA, the studies evaluated indicated that the effect of short-term PM_2.5_ exposure on mortality was immediate, occurring within the first few days after exposure, with the strongest evidence, in terms of magnitude and precision of the associations, in the range of 0 to 1 day. However, these studies defined the lags to examine a priori, often in accordance with the 1-in-3 or 1-in-6-day sampling schedule of ambient PM_2.5_ monitors. As detailed in Section 11.1.8.1 of the 2019 PM ISA, some studies published since the completion of the 2009 PM ISA conducted more extensive examinations of the lag structure of associations for short-term PM_2.5_ exposures and mortality and continue to support associations being largest in terms of magnitude and precision primarily within the first few days of exposure (i.e., lags of 0 to 1 day) as depicted in Figure 3-14.

Of the recent studies evaluated, Lavigne et al. (2018) and Shin et al. (2021a) in multi-city studies conducted in Canada examined the lag structure of associations primarily through examining single-day lags ranging from 0 to 2 days, with Lavigne et al. (2018) also examining a multi-day lag of 0−1 days. In the single-day lag analyses, Lavigne et al. (2018) and Shin et al. (2021a) both reported positive associations relatively similar in magnitude at lag 0 and 1 with no evidence of an association at lag 2. In the multi-day lag analysis focusing on lag 0−1 day, Lavigne et al. (2018) reported results similar in magnitude to the single-day lag analysis of lag 0 and 1 day. The single-day lag analyses in combination with the multi-day lag analysis conducted by Lavigne et al. (2018) supports the conclusions of previously evaluated studies in the 2009 and 2019 PM ISA that indicated associations largest in magnitude at lags of 0 to 1 day.

##### 3.2.1.2.6 Examination of the Concentration-Response (C-R) Relationship between Short-Term PM_2.5_ Exposure and Mortality

In the 2009 PM ISA, the examination of the PM-mortality C-R relationship was limited to studies of PM_10_. Within the multicity studies examined, there was evidence of a linear, no-threshold C-R relationship between short-term PM exposures and mortality with some evidence of differences in the shape of the C-R curve across cities. Studies evaluated in the 2019 PM ISA, focused specifically on examining the C-R relationship between short-term PM_2.5_ exposure and mortality. Although difficulties remain in assessing the shape of the PM_2.5_-mortality C-R relationship, as identified in the 2009 PM ISA, and studies had not conducted systematic evaluations of alternatives to linearity, the studies evaluated in the 2019 PM ISA continued to provide evidence of a no-threshold linear relationship, with less confidence at concentrations lower than 5 μg/m^3^. Additionally, those studies that conducted analyses focused on examining associations at lower PM_2.5_ concentrations provided initial evidence indicating that associations persist and may be larger (i.e., have a steeper slope) at lower PM_2.5_ concentrations.

Liu et al. (2019) in the global analysis examining the association between short-term PM_2.5_ exposure and mortality in 652 cities, also examined country-specific C-R relationships. For each country, a linear term for PM_2.5_ was added to the main model with a B-spline function with knots at the 25th and 75th percentiles of the mean PM_2.5_ concentration across all cities. In C-R analyses consisting of 107 U.S. cities (Figure 3-17a) and 25 Canadian cities (Figure 3-17b), analyses indicated a linear, no-threshold relationship at concentrations often experienced within the U.S. and Canada, with less certainty in the shape of the curve at concentrations less than approximately 8 µg/m^3^ and greater than 30 µg/m^3^.

Figure 3-17 Concentration-response curves for the United States (A) and Canada (B) using a B-spline function with knots at the 25th and 75th percentiles of PM_2.5_ concentrations across all cities in each location

Note: As noted in Liu et al. (2019), the “y-axis can be interpreted as the relative change from the mean effect of PM_2.5_ on mortality; the fraction of the curve below zero denotes a smaller estimate compared with the mean effect.”

Figure 3 dash 17 depicts the concentration-response curve for the U.S. (A) and Canada (B) from Liu et al. (2019) which is a study that examined the relationship between short-term P M 2.5 exposure and mortality across 652 cities globally. In models using a B-spline function with knots at the 25th and 75th percentiles of P M 2.5 concentrations across all cities in each country, there was evidence of a generally linear concentration-response relationship along the distribution of P M 2.5 concentrations often observed in the U.S.

Figure 3 dash 17 depicts the concentration-response curve for the U.S. (A) and Canada (B) from Liu et al. (2019) which is a study that examined the relationship between short-term P M 2.5 exposure and mortality across 652 cities globally. In models using a B-spline function with knots at the 25th and 75th percentiles of P M 2.5 concentrations across all cities in each country, there was evidence of a generally linear concentration-response relationship along the distribution of P M 2.5 concentrations often observed in the U.S.

Source: Adapted from Liu et al. (2019)..

While Liu et al. (2019) focused on nonaccidental mortality, Lavigne et al. (2018) examined the C-R relationship for nonaccidental mortality as well as cardiovascular- and respiratory-related mortality in an analysis of 24 Canadian cities. The authors used the same model for each mortality outcome, consisting of natural cubic splines with 3 df focusing on 0−2-day PM_2.5_ exposures. Across mortality outcomes examined in Lavigne et al. (2018), C-R curves support a linear relationship at PM_2.5_ concentrations often experienced in the U.S. and Canada, with less certainty in the shape of the curve for nonaccidental mortality at concentrations below approximately 5 µg/m^3^ as reflected by the lower bound of the 95% confidence interval (CI) going below the null and some evidence of nonlinearity in the respiratory mortality C-R relationship as reflected by the inflection point occurring around 7 µg/m^3^ (Figure 3-18). However, compared with nonaccidental mortality, for both cardiovascular and respiratory mortality, the lower bound of the 95% confidence interval was wider and below the null resulting in less confidence in the overall shape of the C-R curve for both mortality outcomes.

Figure 3-18 Concentration-response curves for nonaccidental, cardiovascular, and respiratory mortality using natural cubic splines with 3 degrees of freedom for associations with 0−2-day PM_2.5_ across 24 Canadian cities

Figure 3 dash 18 depicts the concentration-response curves for nonaccidental, cardiovascular, and respiratory mortality from Lavigne et al. (2018) a study that examined short-term P M 2.5 exposure and mortality across 24 Canadian cities. In models using a natural cubic spline with 3 degrees of freedom with 0-2 day P M 2.5 concentrations there was evidence of a linear concentration-response relationship for nonaccidental and cardiovascular mortality with nonlinearity in the respiratory mortality concentration-response relationship as reflected by the inflection point occurring around 7 micrograms per cubic meter.

Source: Lavigne et al. (2018)

Overall, recent studies, although limited in number continue to provide evidence of a linear, no-threshold relationship between short-term PM_2.5_ exposure and mortality. Additionally, analyses of nonaccidental mortality support previous studies evaluated that indicated confidence in the shape of the C-R relationship down to concentrations in the range of 5−8 µg/m^3^. However, consistent with studies evaluated in previous assessments, neither study conducted systematic evaluations of alternatives to linearity.

#### 3.2.1.3 Recent Epidemiologic Studies Examining the PM_2.5_-Mortality Relationship through Accountability Analyses and Alternative Methods for Confounder Control

Within the 2019 PM ISA, in assessing the relationship between short-term PM_2.5_ exposure and mortality several epidemiologic studies were evaluated that employed alternative methods for confounder control (referred to as causal modeling methods in the 2019 PM ISA, Section 11.1.2.1). These studies, which were limited to single-city analyses and used different statistical approaches provided evidence that further confirmed the consistent positive association between short-term PM_2.5_ exposure and mortality reported in numerous multi-city studies and further supported the conclusion of a causal relationship. Since the literature cutoff date of the 2019 PM ISA, additional epidemiologic studies have been identified that implemented alternative methods for confounder control, which further inform the relationship between short-term PM_2.5_ exposure and mortality (Table A-6).

Epidemiologic studies that use alternative methods for confounder control seek to mimic randomized experiments through the use of study design and statistical methods, which reduce the potential bias of effects due to confounding. One such method, generalized propensity score (GPS), estimates the conditional probability of an individual being exposed to the observed ambient concentration, accounting for all measured potential confounders. To assess the associations between short-term PM_2.5_ exposure and mortality, recent studies by Wei et al. (2020) and Wei et al. (2021b) used different GPS approaches.

Wei et al. (2020) evaluated the association between short-term PM_2.5_ exposure and all-cause mortality among Medicare beneficiaries residing in Massachusetts during 2000−2012. In the design stage, to construct the GPS, an ordinary least squares model was used to regress PM_2.5_ against a linear combination of covariates including the copollutants ozone and NO_2_ (Wei et al., 2020). In the analysis stage, an ordinary least squares regression was used to fit a linear probability model relating the outcome (death) with the observed exposures and the estimated GPS. Wei et al. (2020) reported 3.04 (95% CI: 2.17, 3.94) excess deaths per 10 million person-days for each 1 μg/m^3^ increase in short-term PM_2.5_ exposure. When the analysis was restricted to a range of PM_2.5_ concentrations, the number of excess deaths associated with a 1 μg/m^3^ increase in short-term PM_2.5_ exposure increased from 3.33 (PM_2.5_ concentrations < 35 ug/m^3^; 95% CI: 2.41, 4.11) to 14.56 (PM_2.5_ concentrations < 5 ug/m^3^; 95% CI: 3.96, 24.59), per 10 million person-days.

In a subsequent study, Wei et al. (2021b) used three GPS approaches (linear probability model, weighted least squares, and m-out-of-n random forests [moonRF]), for assessing additive effects of short-term exposures to PM_2.5_ and the copollutants O_3_, and NO_2_ on mortality rates among Medicare beneficiaries residing in Massachusetts between 2000 and 2012. To reduce the computational burden of the linear probability model GPS approach, weighted least squares and moonRF GPS approaches were proposed as alternatives. Consistent with Wei et al. (2020), for the linear probability model, the authors had both a design stage and an analysis stage. In the design stage, the GPS for PM_2.5_ concentrations was constructed by fitting a linear regression of the predicted PM_2.5_ concentration against a column vector of covariates. In the analysis stage, a linear probability model was fitted with the outcome of death, against the predicted PM_2.5_ concentration and the GPS.

For the weighted least squares method, there was also a design stage and an analysis stage. In the design stage, the person-days that had the same sex, race, age, Medicaid eligibility, ZIP code of residence, and date were aggregated as a single record and assigned the numbers of person-days for that record as weight. The GPS was constructed by fitting a weighted linear regression of the predicted PM_2.5_ concentration against all the covariates from this aggregated data set, with continuous covariates modeled with cubic polynomials. The average outcome for each aggregated person-day group was calculated and assigned to the person-day in the aggregated data set. A weighted linear regression was then fitted for the averaged outcome against the predicted PM_2.5_ concentration and the estimated GPS.

The moonRF method is based on the random forest method, which is a non-parametric machine learning approach of classification for possible nonlinear relationships and interactions through building individual decision trees through resampling. The m-out-of-n bootstrapping method resamples the m observations out of an original data set (1,…,n) without replacement, where m << n (Wei et al., 2021b). In the design stage, the number of person-days aggregated for each record in the aggregated data set was used as the frequency weight and sampled 62,000 person-days without replacement. With this sample, trees were built for PM_2.5_ to make predictions of the exposure for each person-day in the aggregated data set, which was repeated 100 times. The final predicted PM_2.5_ concentration for each person-day was obtained by averaging the predictions of the 100 trees. The GPS was constructed by using the averaged predictions of the 100 trees as the predicted PM_2.5_ concentration and covariates for each person-day in the aggregated data set. In the analysis stage, the authors fit a weighted regression of the averaged outcome against the predicted PM_2.5_ concentration and the estimated GPS using the aggregated data set to obtain the estimate for the additive effect of short-term PM_2.5_ exposure on mortality rate.

Wei et al. (2021b) reported that the linear probability model and the weighted least squares model produced identical results with the estimated annual number of early deaths associated with a 1 μg/m^3^ increase in 24-hour avg PM_2.5_ concentrations being 92 (95% CI: 67, 117). However, the moonRF approach estimated a smaller number of annual deaths 69 (95% CI: 44, 95). When restricting the analysis to person-days with 24-hour average PM_2.5_ concentrations below < 35 μg/m^3^, the authors estimated a larger annual number of early deaths for each method (101 [95% CI: 74, 127] for the linear probability model and weighted least squares approaches and 78 [95% CI: 52, 105] for the moonRF approach).

In another recent study that employed alternative methods for confounder control, using data from the National Center for Health Statistics in 135 U.S. cities, Schwartz et al. (2018a) utilized three statistical methods: instrumental variable analysis, a negative exposure control, and marginal structural models to estimate the association between local pollution, including PM_2.5_, and daily deaths. Instrumental variable analysis constructs a single or set of instrument variables that represent variations in the exposure that are randomized with respect to both measured and unmeasured confounders. The instrument variables considered were planetary boundary layer, wind speed, and sea level pressure. Negative exposure control identifies a negative exposure variable, which is likely to be correlated with unmeasured potential confounders but could not be a cause of the outcome of interest. Negative exposure controls serve as instruments for the unmeasured confounders. If such confounders exist, control for the negative exposure would be expected to reduce or eliminate the estimated effect of the exposure of interest. If no such confounders exist, then control for the negative exposure would be expected to have no change in the association between the exposure and outcome, which indicates no confounding by any measured or unmeasured variables. Marginal structural models estimate the marginal effects of exposure by using inverse probability weights of time-varying exposures to render the exposure independent of the measured covariates. If the exposure is independent of covariates, its effect on the outcome cannot be confounded by them and resulting estimates do not depend on the distributions of confounders. The instrumental variable approach estimated that mortality increased by 1.54% (95% CI: 1.12, 1.97) at lag 0−1 for a 10 μg/m^3^ increase in 24-hour avg PM_2.5_ concentrations. When restricted to days with 24-hour average PM_2.5_ concentrations below 25 μg/m^3^, the instrument for PM_2.5_ was associated with an increase of 1.70% (95% CI: 1.11, 2.29). With the negative control exposure method, there was −0:1% (95% CI: −0.5, 0.3) change in mortality. For the marginal structural models, there was an estimated 0.75% (95% CI: 0.35, 1.15) increase in mortality. When restricted to days with 24-hour average PM_2.5_ concentrations below 25 μg/m^3^, the marginal structural model also reported a 0.83% (95% CI: 0.39, 1.27) increase in mortality, albeit smaller in magnitude than the instrumental variable approach. Overall, the results of Schwartz et al. (2018a) continue to support a relationship between short-term PM_2.5_ exposure and mortality.

Recent epidemiologic studies that employed alternative methods for confounder control to examine the association between short-term PM_2.5_ exposure and mortality reported consistent positive associations within large cohorts across multiple cities in the U.S. Furthermore, the use of alternative methods for confounder control within these studies aims to reduce the uncertainties related to potential confounders that may bias reported associations. Overall, these recent studies further support the conclusions of the 2019 PM ISA with respect to short-term PM_2.5_ exposure and mortality.

#### 3.2.1.4 Summary of Recent Evidence in the Context of the 2019 Integrated Science Assessment for Particulate Matter Causality Determination for Short-Term PM_2.5_ Exposure and Mortality

The few multicity epidemiologic studies conducted since the literature cutoff date of the 2019 PM ISA, provide additional support to the evidence base that contributed to the conclusion of a causal relationship between short-term PM_2.5_ exposure and mortality. Recent U.S. and Canadian studies in combination with previously evaluated multicity studies provide evidence of consistent positive associations with all-cause and nonaccidental mortality, primarily within the first few days after exposure (i.e., lag 0 and 1 day), across studies conducted in different geographic locations and in populations with different demographic characteristics. Additionally, these positive associations persist across studies that used different statistical models, exposure assessment approaches, and methods for confounder control. Overall, recent studies continue to support a relationship between short-term PM_2.5_ exposure and mortality at lower mean 24-hour average concentrations, generally below 12 µg/m^3^, as detailed in the 2019 PM ISA.

The limited assessment of cause-specific mortality in recent studies provides similar results to previously evaluated studies demonstrating a consistent relationship with cardiovascular mortality and more variability in the magnitude and precision of associations with respiratory mortality. Consistent with studies evaluated in the 2019 PM ISA, recent studies indicate that associations between short-term PM_2.5_ exposure and mortality are relatively unchanged in copollutant models but may be larger in magnitude in the presence of some co-occurring pollutants (i.e., oxidant gases). In addition, factors that have been shown to vary between cities and regions of the U.S., such as housing characteristics, have been shown to explain some of the city-to-city and regional variability observed in PM_2.5_-mortality associations in multi-city epidemiologic studies. The continued assessment of the C-R relationship between short-term PM_2.5_ exposure and mortality further supports a linear, no-threshold relationship, with less confidence in the shape at concentrations below 5 µg/m^3^. Additionally, recent studies that employed alternative methods for confounder control provide additional support for a relationship between short-term PM_2.5_ exposure and mortality.

### 3.2.2 Long-Term PM_2.5_ Exposure

The following sections represent a summary of the evidence and the corresponding causality determination for long-term PM_2.5_ exposure and mortality presented within the 2019 PM ISA (Section 3.2.2.1) along with an evaluation of recent epidemiologic studies that fall within the scope of the Supplement (i.e., studies conducted in the U.S. and Canada) and were published since the literature cutoff date of the 2019 PM ISA (Section 3.2.2.2).^18^ In addition, with the expansion of in epidemiologic studies that used statistical approaches that attempt to more extensively account for confounders and are more robust to model misspecification (i.e., used alternative methods for confounder control), recent studies that employed such methods are also evaluated (Section 3.2.2.3), which can further inform the relationship between long-term PM_2.5_ exposure and mortality. Finally, a summary of the results of recent studies evaluated within the section is presented in the context of the scientific conclusions detailed in the 2019 PM ISA (Section 3.2.2.4). The evaluation of recent studies on long-term PM_2.5_ exposure and mortality presented in this Supplement adds to the collective body of evidence reviewed in the process of reconsidering the PM NAAQS.

#### 3.2.2.1 Summary and Causality Determination from 2019 Integrated Science Assessment for Particulate Matter

Cohort studies evaluated in the 2019 PM ISA provided consistent evidence of positive associations between long-term PM_2.5_ exposures and total (nonaccidental) mortality from studies conducted mainly in North America and Europe. Many analyses further evaluated the association between long-term PM_2.5_ exposures and the risk of mortality based on the original American Cancer Society (ACS) study (Pope et al., 1995), added new details about deaths due to cardiovascular disease (including IHD) and respiratory disease (including COPD), and extended the follow-up period of the ACS to 22 years (1982−2004). Adding to this evidence, U.S. and Canadian cohort studies demonstrated consistent, positive associations between long-term PM_2.5_ exposure and mortality across various spatial extents, exposure assessment metrics, and statistical techniques, and locations, where mean annual average concentrations are ≤ 12 µg/m^3^ (2019 PM ISA, Section 11.2.2.2). Additionally, the evidence from these studies reduced uncertainties related to potential copollutant confounding (2019 PM ISA, Section 11.2.3) and continued to provide strong support for a linear, no-threshold C-R relationship (2019 PM ISA, Section 11.2.4). The body of evidence for total mortality was supported by generally consistent, positive associations with cardiovascular and respiratory mortality.

In addition to evaluating epidemiologic studies that examined the relationship between long-term PM_2.5_ exposure and mortality, the 2019 PM ISA characterized whether evidence supported biologically plausible mechanisms by which long-term PM_2.5_ exposure could lead to mortality (2019 PM ISA, Section 11.2.1). This evaluation consisted of an assessment of animal toxicological, controlled human exposure, and epidemiologic studies of morbidity effects that are the largest contributors to total (nonaccidental) mortality, specifically, cardiovascular and respiratory morbidity and metabolic disease (2019 PM ISA, Section 6.2.1, Section 5.2.1, and Section 7.2.1, respectively). Plausible mechanisms were identified by which inhalation exposure to PM_2.5_ could progress from initial events to endpoints relevant to the cardiovascular system and to population outcomes such as IHD, stroke and atherosclerosis (2019 PM ISA, Section 6.2.1). Similarly, available evidence was characterized by which inhalation exposure to PM_2.5_ could progress from initial events to endpoints relevant to the respiratory system and to population outcomes such as exacerbation of COPD (2019 PM ISA, Section 5.2.1). In addition, there was evidence for plausible mechanisms by which inhalation exposure to PM_2.5_ could progress from initial events (e.g., pulmonary inflammation, autonomic nervous system activation) to intermediate endpoints (e.g., insulin resistance, increased blood glucose and lipids) and result in population outcomes such as metabolic disease and diabetes. In summary, there was coherence of effects across the scientific disciplines (i.e., animal toxicological, controlled human exposure, and epidemiologic studies) and biological plausibility for PM_2.5_-related cardiovascular (2019 PM ISA, Chapter 6), respiratory (2019 PM ISA, Chapter 5), and metabolic (2019 PM ISA, Chapter 7) disease, which supports the PM_2.5_-mortality relationship.

This section describes the evaluation of evidence included in the 2019 PM ISA for total (nonaccidental) mortality, with respect to the causality determination for long-term exposures to PM_2.5_ using the framework described in Table II of the Preamble to the ISAs (U.S. EPA, 2015). The key evidence, as it relates to the causal framework, is summarized in Table 3-5.

Table 3-5 Summary of evidence for a causal relationship between long-term PM_2.5_ exposure and total mortality from the 2019 Integrated Science Assessment for Particulate Matter

Rationale for Causality Determination^a^ | Key Evidence^b^ | Key References and Sections in the 2019 PM ISA^b^ | PM_2.5_ Concentrations Associated with Effects (µg/m^3^)^c^
Consistent epidemiologic evidence from multiple, high-quality studies at relevant PM_2.5_ concentrations | Positive associations between long-term PM_2.5_ exposure and mortality in the multiple analyses of the ACS and HSC cohorts, with effect estimates similar in magnitude, even after adjustment for common potential confounders. | Section 11.2.2.1 | Mean across studies: 11.4−23.6
Consistent epidemiologic evidence from multiple, high-quality studies at relevant PM_2.5_ concentrations | Positive associations between long-term PM_2.5_ exposure and mortality in the multiple analyses of the Medicare cohort, with effect estimates similar in magnitude, even after adjustment for common potential confounders. | Section 11.2.2.2 | Mean across studies: 8.12−12.0
Consistent epidemiologic evidence from multiple, high-quality studies at relevant PM_2.5_ concentrations | Positive associations between long-term PM_2.5_ exposure and mortality in the multiple analyses of Canadian cohorts, with effect estimates similar in magnitude, even after adjustment for common potential confounders. | Section 11.2.2.2 | Mean across studies: 8.7−9.1
Consistent epidemiologic evidence from multiple, high-quality studies at relevant PM_2.5_ concentrations | Positive associations between long-term PM_2.5_ exposure and mortality in the multiple North American occupational cohorts, even after adjustment for common potential confounders. | Section 11.2.2.2 | Mean across studies: 12.7−17.0
Consistent epidemiologic evidence from multiple, high-quality studies at relevant PM_2.5_ concentrations | Positive associations with cardiovascular, respiratory, and lung cancer mortality. | Section 6.3.10.1 | Mean across studies: 4.1−17.9
Consistent epidemiologic evidence from multiple, high-quality studies at relevant PM_2.5_ concentrations | Positive associations with cardiovascular, respiratory, and lung cancer mortality. | Section 5.2.10 | Mean across studies: 4.1−17.9
Consistent epidemiologic evidence from multiple, high-quality studies at relevant PM_2.5_ concentrations | Positive associations with cardiovascular, respiratory, and lung cancer mortality. | Section 10.2.5.1 | Mean across studies: 6.1−33.7
Epidemiologic evidence from copollutant models provides some support for an independent PM_2.5_ association | Positive associations observed between long-term PM_2.5_ exposure and total mortality remain relatively unchanged after adjustment for O_3_, NO_2_, and PM_10−2.5_.; When reported, correlations with copollutants were highly variable (low to high). | Section 11.2.3; Figure 11-20; Figure 11-21
Consistent positive epidemiologic evidence for associations between PM_2.5_ exposure and total mortality across exposure measurement metrics | Positive associations consistently observed across studies that used fixed-site (i.e., monitors), model (e.g., CMAQ, dispersion models), and satellite-based (e.g., AOD observations from satellites) methods, including hybrid methods that combine two or more of these methods. | Section 11.2.2.5; Jerrett et al. (2016)
Epidemiologic evidence supports a linear, no-threshold C-R relationship | No evidence for deviation from linearity in several U.S. and Canadian cohorts. | Section 11.2.2.3
Biological plausibility from studies of cardiovascular and respiratory morbidity and lung cancer incidence and mortality | Cardiovascular morbidity studies provide expanded body of evidence for associations between long-term PM_2.5_ exposure and CHD, stroke, and atherosclerosis, providing biological plausibility for a relationship between long-term PM_2.5_ exposure and cardiovascular mortality. | Section 6.3; Miller et al. (2007); Chi et al. (2016) | Mean across studies: 10.7−13.4
Biological plausibility from studies of cardiovascular and respiratory morbidity and lung cancer incidence and mortality | Respiratory morbidity studies provide some evidence for an association between long-term PM_2.5_ exposure and development of COPD, providing limited biological plausibility for a relationship between long-term PM_2.5_ exposure and respiratory mortality. | Section 5.2.5
Biological plausibility from studies of cardiovascular and respiratory morbidity and lung cancer incidence and mortality | Consistent epidemiologic evidence for associations between PM_2.5_ exposure and lung cancer incidence and mortality in cohort studies conducted in the U.S., Canada, Europe, and Asia. | Section 10.2.5.1; Figure 10-3 | Mean across U.S. and Canadian studies: 6.3−23.6

Note: This table corresponds to Table 11-8 in the 2019 PM ISA.

ACS = American Cancer Society; AOD = aerosol optical depth; CHD = coronary heart disease; CMAQ = Community Multiscale Air Quality; COPD = chronic obstructive pulmonary disease; C-R = concentration-response; HSC = Harvard Six Cities; μg/m^3^ = microgram per cubic meter; NO_2_ = nitrogen dioxide; O_3_ = ozone; PM_2.5_ = particulate matter with a nominal mean aerodynamic diameter less than or equal to 2.5 μm; PM_10−2.5_ = particulate matter with a nominal mean aerodynamic diameter greater than 2.5 μm and less than or equal to 10 μm.

a Based on aspects considered in judgments of causality and weight of evidence in causal framework in Table I and Table II of the Preamble.

b Describes the key evidence and references contributing most heavily to the causality determination and, where applicable, to uncertainties or inconsistencies. References to earlier sections indicate where the full body of evidence is described in the 2019 PM ISA.

c Describes the PM_2.5_ concentrations with which the evidence is substantiated.

The strongest evidence supporting the conclusion of a causal relationship between long-term PM_2.5_ exposure and total mortality in the 2009 PM ISA was derived from analyses of the ACS and Harvard Six Cities (HSC) cohorts. Extended analyses and reanalysis of these cohorts included in the 2019 PM ISA continued to support this relationship, demonstrating consistent positive associations for total (nonaccidental mortality) and across different cause-specific mortality outcomes. A series of analyses of the Medicare cohort of U.S. individuals provided additional support, culminating with the largest cohort study of nearly 61 million U.S. Medicare enrollees that reported positive associations with increases in PM_2.5_ concentrations and stronger associations in areas where the mean annual PM_2.5_ concentrations were ≤ 12 µg/m^3^ (Di et al., 2017b). Another series of studies conducted in Canada provided results consistent with those of the Medicare cohort (i.e., positive associations between long-term PM_2.5_ exposure and total mortality in areas where mean annual PM_2.5_ concentrations are ≤ 12 µg/m^3^). One difference between these studies was that the Canadian cohorts include all adults (age 25+ years) and the Medicare cohort only included adults age 65+ years, demonstrating that these effects are not specific to one lifestage, but affect all adults. Also, an additional line of evidence was available that includes results from a number of cohorts that recruited subjects based on their place of employment, including female nurses, female teachers, male health professionals, and male truck drivers, which show consistent, positive associations between long-term PM_2.5_ exposure and total mortality.

Evidence included in the 2019 PM ISA helped to reduce uncertainties related to potential copollutant confounding of the relationship between long-term PM_2.5_ exposure and mortality. Multiple studies evaluated ozone (2019 PM ISA, Figure 11-20) and NO_2_ (2019 PM ISA, Figure 11-21) in copollutant models and observed similar hazard ratios for PM_2.5_ regardless of whether ozone or NO_2_ were included in the model. This supports an independent effect of long-term PM_2.5_ exposure on mortality. Evidence for other potential copollutants (e.g., SO_2_, CO) was limited.

Studies evaluated in the 2019 PM ISA used a variety of both fixed-site (i.e., monitors), model (e.g., CMAQ, dispersion models), and satellite-based (e.g., AOD measurements from satellites) methods, including hybrid methods that combine two or more fixed-site, model, and/or satellite-based techniques to measure, estimate, or predict PM_2.5_ concentrations for use in assigning long-term PM_2.5_ exposure in epidemiologic studies. Overall, the exposure assessment technique had little influence on study results, with consistently positive associations of similar magnitude observed across studies using a variety of exposure assessment techniques. Notably, Jerrett et al. (2016) applied fixed-site measurements and satellite-based observations of AOD to a common data set, the ACS cohort, and calculated effect estimates for circulatory and IHD mortality associated with PM_2.5_ using both methods. They observed consistently positive associations between long-term PM_2.5_ exposure and mortality, regardless of the exposure assessment technique used to assign exposure. Additionally, Jerrett et al. (2016) combined multiple exposure assessment techniques into an ensemble model, weighted by model fit, and continued to observe similar positive associations with mortality. These results support an independent effect of long-term PM_2.5_ exposure on mortality that is not overtly influenced by or is a residual of the exposure assessment technique used in the study.

The number of studies that examined the shape of the C-R function for long-term PM_2.5_ exposure and mortality substantially increased between the 2009 PM ISA and the 2019 PM ISA. These studies used a number of different statistical techniques to evaluate the shape of the C-R function, including natural cubic splines, restricted cubic splines, penalized splines, thin-plate splines, and cutpoint analyses (2019 PM ISA, Table 11-7), and generally observed linear, no-threshold relationships down to 4−8 µg/m^3^. Few studies have conducted extensive analyses exploring alternatives to linearity when examining the shape of the PM_2.5_-mortality C-R relationship. Among these studies, there was some emerging evidence for a supralinear C-R function, with steeper slopes observed at lower PM_2.5_ concentrations. Although few, such supralinear C-R functions were most commonly observed for cardiovascular mortality compared with total (nonaccidental) or respiratory mortality.

The 2009 PM ISA concluded that there is not sufficient evidence to differentiate the components or sources more closely related to health outcomes when compared with PM_2.5_ mass, although the evidence for long-term exposure and mortality was limited. Several studies included in the 2019 PM ISA examined the relationship between long-term exposure to PM components and mortality (2019 PM ISA, Figure 11-24). Collectively, these studies continued to demonstrate that no individual PM_2.5_ component or source was a better predictor of mortality than PM_2.5_ mass.

Overall, epidemiologic studies examined in the 2019 PM ISA built upon and further reaffirmed the conclusions of the 2009 PM ISA for total mortality. The evidence, particularly from the assessment of PM_2.5_-related cardiovascular and metabolic diseases, with more limited evidence from respiratory morbidity, provided biological plausibility for mortality due to long-term PM_2.5_ exposures. In conclusion, the consistent positive associations observed across cohort studies conducted in various locations across North America were further supported by the results from copollutant analyses indicating robust associations independent of O_3_ and NO_2_. Collectively, this body of evidence was sufficient to conclude that a causal relationship exists between long-term PM_2.5_ exposure and total mortality.

#### 3.2.2.2 Recent U.S. and Canadian Cohort Studies

Recent cohort studies conducted in the U.S. and Canada build upon the strong evidence base evaluated in the 2019 PM ISA, as well as previous in assessments, which provided the scientific rationale supporting a causal relationship between long-term PM_2.5_ exposure and mortality (Section 3.2.2.1). In addition to examining the relationship between long-term PM_2.5_ exposure and all-cause or nonaccidental mortality (Section 3.2.2.2.1) and cause-specific mortality (Section 3.2.2.2.2), some studies also further examined issues relevant to expanding the overall understanding of the effect of long-term PM_2.5_ exposure on mortality. Specifically, recent studies have assessed the effect of long-term PM_2.5_ exposure on mortality in populations with underlying health conditions (Section 3.2.2.2.3), examined the role of long-term PM_2.5_ exposure on life expectancy (Section 3.2.2.2.4), examined potential copollutant confounding (Section 3.2.2.2.5), explored new and innovative methods for assessing confounding (Section 3.2.2.2.6), and assessed the shape of the concentration-response (C-R) relationship (Section 3.2.2.2.7). The following sections present an evaluation of recent cohort studies that inform each of the aforementioned topics within the context of the evidence base evaluated and summarized in the 2019 PM ISA. Study-specific details (e.g., study population, exposure assessment approach, confounders considered) for the epidemiologic studies evaluated in this section are presented in Appendix A (Table A-7).

##### 3.2.2.2.1 All-Cause and Total (Nonaccidental) Mortality

Recent North American cohort studies that examined the relationship between long-term PM_2.5_ exposure and mortality support and expand upon the cohort studies evaluated in the 2019 PM ISA that spanned diverse geographical areas and study populations. These recent studies build upon the studies evaluated in the 2019 PM ISA that addressed key uncertainties identified in the 2009 PM ISA (e.g., PM_2.5_-mortality associations at low concentrations, shape of the concentration-response [C-R] relationship).

Consistent with the North American cohort studies evaluated in the 2019 PM ISA (Figure 3-19), recent studies representing cohorts in the U.S. and Canada report a similar pattern of associations between long-term PM_2.5_ exposure and all-cause or nonaccidental mortality in locations with generally low mean annual PM_2.5_ concentrations (Figure 3-20). Whereas the use of hybrid exposure models, which includes some combination of monitoring, modeled, and satellite data, represented an advancement in methods in the 2019 PM ISA, recent studies primarily relied on these exposure assessment methods demonstrating the growth in their application and utility. Study-specific information for each of the recent studies evaluated in this section including information on the cohort, exposure assessment methodology, and PM_2.5_ concentrations over the study duration are detailed in Table A-7.

Figure 3-19 Associations between long-term PM_2.5_ exposure and total (nonaccidental) mortality in recent North American cohorts

ACS = American Cancer Society; adj = adjustment; Ag Health = Agricultural Health Study; Cancer Prev = Cancer Prevention; CanCHEC = Canadian Census Health and Environment Cohort; CCHS = Canadian Community Health Survey; CVD = cardiovascular; EFFECT = Enhanced Feedback for Effective Cardiac Treatment; exp = exposure; Health Prof = health professionals; IDW = inverse-distance weighting; IQR = interquartile range; km = kilometer; μg/m^3^ = microgram per cubic meter; MCAPS = Medicare Cohort Air Pollution Study; NIH-AARP = National Institutes of Health—American Association of Retired Persons; PM = particulate matter; PM_2.5_ = particulate matter with a nominal mean aerodynamic diameter less than or equal to 2.5 μm; Resp = respiratory; TrIPS = Trucking Industry Particle Study.

Note: †Studies published since the 2009 PM ISA. Associations are presented per 5 µg/m^3^ increase in pollutant concentration. Circles represent point estimates; horizontal lines represent 95% confidence intervals for PM_2.5_. Due to precise confidence intervals for estimates from some studies, the lines representing the confidence intervals cannot be viewed behind the point representing the effect estimate. Black text and circles represent evidence included in the 2009 PM ISA; red text and circles represent recent evidence not considered in previous ISAs or AQCDs. Study results from Pope et al. (2014) are representative of the results from the American Cancer Society cohort.

Figure 3 dash 19 is Figure 11 dash 18 from the 2019 P M ISA. This figure presents a summary of associations between long-term P M 2.5 exposure and total (nonaccidental) mortality for a 5 micrograms per cubic meter increase in average concentrations from recently published and previously evaluated North American studies. Across studies there is evidence of primarily positive associations conducted in locations with annual average P M 2.5 concentrations ranging from 6.3 to 23.4 micrograms per cubic meter.

Source: Figure 11-18, 2019 PM ISA.

Figure 3-20 Associations between long-term PM_2.5_ exposure and all-cause and total (nonaccidental) mortality in cohort studies in the United States and Canada published since the 2019 Integrated Science Assessment for Particulate Matter

avg = average; CanCHEC = Canadian Census Health and Environment Cohort; mCCHS = Canadian Community Health Survey―mortality cohort; km = kilometer; μg/m^3^ = microgram per cubic meter; NHIS = National Health Interview Survey; PM = particulate matter; PM_2.5_ = particulate matter with a nominal mean aerodynamic diameter less than or equal to 2.5 μm.

Note: *U.S. and Canadian studies published since the literature cutoff date (~January 2018) for the 2019 PM ISA. Associations are presented per 5 µg/m^3^ increase in pollutant concentration. Circles represent point estimates; horizontal lines represent 95% confidence intervals for PM_2.5_. Due to precise confidence intervals for estimates from some studies, the lines representing the confidence intervals cannot be viewed behind the point representing the effect estimate. Blue text and circles represent U.S. and Canadian studies published since the literature cutoff date of the 2019 PM ISA.

Figure 3 dash 20 presents a summary of associations between long-term P M 2.5 exposure and total (nonaccidental) mortality for a 5 micrograms per cubic meter increase in average concentrations from studies published since the literature cutoff date of the 2019 P M ISA that were conducted in the U.S. and Canada. Across studies there is evidence of consistent positive associations conducted in locations with annual average P M 2.5 concentrations ranging from 5.9 to 11.65 micrograms per cubic meter.

In the continuous evolution of studies aimed at assessing the relationship between long-term PM_2.5_ exposure and mortality, recent research efforts focus on identifying increasingly larger and more diverse cohorts, including the National Health Interview Survey (NHIS) cohort and the Medicare cohort. Pope et al. (2019) formed the NHIS cohort by linking participants from the NHIS from 1986 to 2014 with mortality data through 2015 resulting in approximately 1.5 million participants. The authors also formed a subcohort comprising over 650,000 participants that had individual-level data on smoking status and body mass index (BMI). In analyses of both the full cohort and subcohort, Pope et al. (2019) uses a combination of monitored and modeled PM_2.5_ data (see Table A-7) to estimate population-weighted 17-year average PM_2.5_ concentrations at the census tract centroid of each participant. In fully adjusted Cox regression models, the authors report associations with all-cause mortality similar in magnitude for both the full cohort (HR = 1.06 [95% CI: 1.05, 1.08]) and subcohort (HR = 1.06 [95% CI: 1.04, 1.07]). In a sensitivity analysis, back-casted PM_2.5_ concentrations were imputed from 1988 to 1998, allowing for the use of a 28-year average PM_2.5_ exposure window. In both the full cohort and subcohort, associations were attenuated, but remained positive when using the 28-year average exposure window, in comparison to the main analyses using the 17-year average exposure window (quantitative results not presented).

Lefler et al. (2019) expands upon the analyses initially conducted by Pope et al. (2019) by focusing on the NHIS subcohort with a primary focus being to examine potential sensitivity of PM_2.5_-mortality associations to spatially and temporally decomposed PM_2.5_. However, it is important to note that the spatial and temporal decomposition approaches employed by Lefler et al. (2019) attempt to examine the effect of distance to source and the sensitivity of exposure window on associations, respectively, and are not analogous to the decomposition methods discussed in Section 3.1.2.2.5, where the focus is on examining whether there is confounding due to unmeasured variables. To assess the temporal aspect, the authors employed two approaches to examine the sensitivity of associations to different exposure windows. In the first approach, they recreated cohorts for each year starting in 1992 that were then assigned either 2- or 5-year average PM_2.5_ concentrations with an overall effect across the entire study duration estimated through a fixed effects meta-analysis. In the second approach, the authors applied the same exposure windows used in Pope et al. (2019) (i.e., 17-year or 28-year average PM_2.5_ concentrations) as a comparison. Lefler et al. (2019) reported associations consistent in magnitude, regardless of the exposure windows used (HRs: 17-year: 1.06; 28-year: 1.04; 2-year: 1.05; 5-year: 1.05).

In the spatial decomposition approach, the authors developed exposure indicators indicative of PM_2.5_ emanating from different sources and defined them as local (< 1 km); neighborhood (1−10 km); mid-range (10−100 km); and regional (> 100 km). In developing each exposure indicator, Lefler et al. (2019) subtracted the minimum PM_2.5_ concentration identified within the defined circular buffers around each census tract for each year from 2000 to 2015. When focusing on results presented for an IQR increase in PM_2.5_ concentrations, positive associations were reported for each exposure indicator; however, there was some variability across each of the exposure indicators examined with the regional indicator being closer in magnitude to the primary PM_2.5_ exposure indicator (Figure 3-21). Overall, these results indicate that the mortality risk attributed to PM_2.5_ is not due solely to regionally or locally derived PM_2.5_.

Figure 3-21 Hazard ratios for spatially decomposed analyses for an interquartile range increase in PM_2.5_ concentrations for all-cause mortality

Figure 3 dash 21 is from Lefler et al. (2019) depicting hazard ratios for long-term P M 2.5 exposure and all-cause mortality for an interquartile range increase in P M 2.5 concentrations in an analysis examining the sensitivity in associations to spatially and temporally decomposed P M 2.5 using a subcohort of the National Health Interview Survey (NHIS). Positive associations were reported for each exposure indicator; however, there was some variability across each of the exposure indicators examined with the regional indicator being closer in magnitude to the primary P M 2.5 exposure indicator. These results indicate that the mortality risk attributed to PM2.5 is not due solely to regionally or locally derived P M 2.5.

Source: Lefler et al. (2019)

Although the majority of cohort studies focus primarily on adults, generally over the age of 20, a number of recent studies focus on only individuals 65 years of age and older that are Medicare beneficiaries. Wang et al. (2020) used a hybrid spatiotemporal exposure model (see Table A-7) to estimate exposures at each Medicare participant’s ZIP code centroid to examine nonaccidental mortality from 2000 to 2008. Using an exposure that represented the 12-month average PM_2.5_ concentration prior to death, the authors reported a HR of 1.03 (95% CI: 1.02, 1.03) in a Cox proportional hazards model that adjusted for state-level SES to account for urbanicity and annual mean gross adjusted income.

Recent cohort studies published since the 2019 PM ISA focus primarily on examining the relationship between long-term PM_2.5_ exposure and mortality in demographically diverse populations that are generally representative of the entire population in both the U.S. and Canada. Elliott et al. (2020) differs from those studies by focusing on an occupation-based cohort of female registered nurses (i.e., the NHS). Elliott et al. (2020) represents an updated and extended analysis of Hart et al. (2015a), which was evaluated in the 2019 PM ISA. Although the focus of Elliott et al. (2020) is on examining the interaction between long-term PM_2.5_ exposure and physical activity, and the risk of cardiovascular disease and mortality, the authors used a 24-month exposure window and more years of data (i.e., 1988−2008) in the overall analysis of the association between long-term PM_2.5_ exposure and mortality, which differs from Hart et al. (2015a), which used a 12-month exposure window for the years 2000−2008. In the fully adjusted Cox proportional hazards model the authors reported a HR of 1.07 (95% CI: 1.00, 1.15), which is consistent with previous studies of the NHS cohort (Figure 3-19).

While the studies discussed above add to the total body of evidence supporting a relationship between long-term PM_2.5_ exposure and mortality, key questions that often arise in the assessment of the evidence are (1) Do associations persist at low concentrations? and (2) Is there a point below which there is less confidence in that relationship? This led to two recent research efforts with a main focus on examining the relationship between long-term PM_2.5_ exposure and mortality at low concentrations. One of these studies conducted in the U.S., referred to as the Harvard Medicare study, focused on using a cohort of Medicare beneficiaries 65 years of age or older (Dominici et al., 2019), while another study conducted in Canada, referred to as the Mortality-Air Pollution Associations in Low Exposure Environments (MAPLE) study, relied on respondents from multiple years of the long-form Canadian Census Health & Environment Cohorts (CanCHEC) and/or participants from multiple years of the Canadian Community Health Survey (CCHS) (Brauer et al., 2019). A third study was conducted in Europe, using data from the European Study of Cohorts for Air Pollution Effects (ESCAPE) but is beyond the scope of this Supplement. Both of these research efforts conducted extensive analyses to further inform the PM_2.5_-mortality relationship in a series of studies, with a focus on examining associations at low PM_2.5_ concentrations, which are often considered as below the level of the current annual PM NAAQS of 12.0 µg/m^3^.

As detailed in the 2019 PM ISA (Section 11.2.2.1), the initial publication from the Harvard Medicare study applied a hybrid exposure model at a refined spatial resolution (i.e., 1 km^2^ grid cells) to assign PM_2.5_ exposures at the ZIP code level to all Medicare beneficiaries age 65 and older in the continental U.S. between 2000 and 2012 to examine long-term PM_2.5_ exposure and all-cause mortality (Di et al., 2017b). Di et al. (2017b) reported a HR of 1.041 (95% CI: 1.039, 1.042) for the relationship between PM_2.5_ and all-cause mortality (Figure 3-20) with associations remaining relatively unchanged in copollutant models with ozone estimated from the nearest monitor. The majority of recent studies that fall under the Harvard Medicare study primarily focus on examining alternative methods for confounder control and are evaluated in Section 3.1.2.3. However, a recent study by Wu et al. (2020a) builds on the original study by Di et al. (2017b) of the Medicare cohort, by including additional years of data up to 2016. Within this study, the authors focused on examining associations with all-cause mortality using both traditional and alternative methods for confounder control (Section 3.1.2.3), and the sensitivity of associations to different confounder adjustment (Section 3.1.2.2.5). In the main analysis, the authors reported a HR of 1.03 using both a Poisson and Cox model that adjusted for calendar year and meteorological variables including season, maximum daily temperature, and relative humidity. Although the regression models used by Wu et al. (2020a) include additional covariates not included in the models used in Di et al. (2017b), similar results were reported by both studies.

Recent studies that fall under the umbrella of the MAPLE study instituted various advancements in exposure assessment. Similar to the Harvard Medicare study (Dominici et al., 2019), MAPLE studies rely on a hybrid exposure model that is a combination of monitored, modeled, and satellite data. Within the MAPLE studies, as detailed in Table A-7, an exposure model was used that predicts PM_2.5_ concentrations at a 1 km^2^ grid cell through a combination of satellite-derived PM_2.5_ concentration estimates, and model predictions in GEOS-Chem that are calibrated using monitor data. The 1 km^2^ resolution PM_2.5_ concentrations are then aggregated to the postal code of residence. In the process of assigning exposures to cohort participants, the majority of epidemiologic studies examining long-term PM_2.5_ exposure and mortality tend to use exposure windows that consist of average PM_2.5_ concentrations for a single year or all years that PM_2.5_ data are available, which does not account for potential temporal changes in PM_2.5_ concentrations [U.S. EPA (2019), Table A-7]. In addition, the exposure assigned often includes the year of death which could result in exposure misalignment if the death occurred early in the year. In an attempt to address both issues, MAPLE studies use a primary exposure representing a 3-year average with a 1-year lag prior to death to ensure that the exposure window for each individual within the cohort occurs prior to death (Pinault et al., 2017). Finally, building on Crouse et al. (2015), which accounted for residential mobility during the course of the study, MAPLE studies, instead of assigning exposure based on residential address at baseline or excluding individuals from the cohort when residential location information was missing, developed a new method in which postal codes were imputed if missing to maintain the size of the cohort.

While the MAPLE studies discussed below employ the 3-year average, 1-year lag approach to assigning exposure, it remained unclear how the combination of temporal and spatial scale of exposure assessment impacted the association with nonaccidental mortality. Crouse et al. (2020), within the 2001 census cycle of CanCHEC, examined whether HRs varied depending on the combination of years of PM_2.5_ data used to assign exposure (i.e., 1-year avg, 3-year avg, or 8-year avg) and the spatial resolution of the exposure model (i.e., 1, 5, or 10 km). As depicted in Figure 3-20, across each temporal and spatial combination, associations are consistently positive, with the magnitude of the association being smallest when using the 1-year average. Additionally, the authors showed that the magnitude of the association declined as the spatial scale increased regardless of the temporal scale assigned. Although associations are larger in magnitude when using the 8-year average, they are relatively similar to the 3-year average (e.g., 1 km spatial scale: 8-year avg HR = 1.11 [95% CI: 1.10, 1.13]; 3-year avg HR = 1.10 [95% CI: 1.08, 1.11]). It is worth noting that the difference in results based on the exposure window used by Crouse et al. (2020) are not consistent with the results of Lefler et al. (2019), discussed above, that reported associations similar in magnitude when using shorter and longer duration exposure windows. However, because different cohorts and exposure assessment methods are used in each study it is not clear why these differences are observed. Overall, the results of Crouse et al. (2020) provide additional support for the use of the 3-year average, 1-year lag approach to assigning exposure predicted at the 1 km^2^ spatial scale within the MAPLE studies.

Of the MAPLE studies, Pinault et al. (2017) was the first to institute the series of exposure assessment advancements discussed above. Pinault et al. (2017) expands upon the initial analyses of the CanCHEC cohort conducted by Crouse et al. (2012) and Crouse et al. (2015), which focused on the 1991 CanCHEC [see U.S. EPA (2019), Section 11.2.2.1; Figure 3-19]. In addition to using the 2001 CanCHEC, which allowed for an updated analysis using a larger and more recent cohort, Pinault et al. (2017) was able to address some of the limitations of the original CanCHEC studies. Specifically, Pinault et al. (2017), used a hybrid exposure model that predicted concentrations at the 1 km^2^ spatial scale versus the 10 km^2^ spatial scale as was done in Crouse et al. (2012) and Crouse et al. (2015), potentially allowing for a better representation of spatial gradients in PM_2.5_ concentrations. In addition, Pinault et al. (2017) used a 3-year average, 1-year lag PM_2.5_ exposure instead of assigning exposure based on the average of all years of available PM_2.5_ data as was done for each previous CanCHEC study, and employed the new approach to capture missing data on residential location. In a Cox proportional hazards model that was stratified by age, sex, airshed, population center size, and included all available individual and ecological covariates the authors reported a hazard ratio (HR) with nonaccidental mortality of 1.08 (95% CI: 1.07, 1.10).

Most of the studies examining the CanCHEC cohort, such as Pinault et al. (2017), focused on an individual census year, but Pappin et al. (2019) examined all three census cycles (i.e., 1991, 1996, and 2001) individually and in a pooled analysis. Although, the main focus of Pappin et al. (2019) was to examine the C-R relationship across the different census cycles (Section 3.2.2.2.7), in examining the relationship between long-term PM_2.5_ exposure and mortality the authors expanded upon the regression model used in Pinault et al. (2017) and Crouse et al. (2016). This resulted in a regression model that included a variable to account for population size of a participant’s community (Pinault et al., 2017), a covariate to account for airshed of residence (Crouse et al., 2016), and a variable of neighborhood marginalization based on the Canadian Marginalization Index (CAN-Marg). In the pooled analysis, the authors reported a HR = 1.03 (95% CI: 1.02, 1.03) in the fully adjusted model.

In addition to the MAPLE studies focusing on the larger CanCHEC cohort, other studies either focused solely on the CCHS-mortality (mCCHS) cohort (Christidis et al., 2019) or relied on data from it due to its extensive individual-level data [Pinault et al. (2018) in Section 3.1.2.2.2 and Erickson et al. (2019) in Section 3.1.2.2.4]. Christidis et al. (2019) represents an extended analysis of Pinault et al. (2016), detailed in the 2019 PM ISA (Section 11.2.2.1), which increased the year of analysis by 1 year to 2012. While both Christidis et al. (2019) and Pinault et al. (2016) relied on the same cohort, there were fundamental differences between the two studies, including different contextual variables included in statistical models and different criteria around the inclusion of immigrants in the cohort, that resulted in a difference in the magnitude of the association in both studies even though both relied on a 3-year average, 1-year lag exposure [i.e., HR = 1.12 (95% CI: 1.09, 1.16) in Pinault et al. (2016) and HR = 1.05 (95% CI: 1.02, 1.09) in Christidis et al. (2019)]. Overall, the primary driver of the difference in the magnitude of the association in both studies can be attributed to Christidis et al. (2019) including immigrants that have resided in Canada for 10 or more years, who have substantially lower HRs of mortality compared with the non-immigrant population. This differs from Pinault et al. (2016) where only immigrants that resided in Canada for 20 or more years were included in the analysis. However, this difference due to years of residence in Canada may be specific to the mCCHS cohort. For example, Erickson et al. (2020) in an analysis focusing on immigrants within the 2001 CanCHEC, reported larger risk estimates for immigrants that resided in Canada for ≤ 10 years and 11−20 years (HRs of 1.09 and 1.11, respectively), compared with established immigrants (> 30 years residence) and non-immigrants (HR of 1.05 and 1.04, respectively).

An additional study conducted in Canada, the Ontario Health Study, that was not part of MAPLE, but used the same exposure model and a similar exposure assignment approach, provides continued support for a relationship between long-term PM_2.5_ exposure and mortality (Zhang et al., 2021). Whereas the CanCHEC cohort lacked information on some individual-level risk factors, the Ontario Health Study collected individual-level data on socio-demographics, medical history, lifestyle factors, and health care utilization from 2009 to 2017. In fully adjusted Cox models that included all individual-level and contextual variables, Zhang et al. (2021) used a 5-year average exposure with a 1-year lag and reported a HR of 1.20 (95% CI: 1.09, 1.32) for nonaccidental mortality. In a sensitivity analysis comparing the 5-year average exposure metric to alternative exposure windows of 4- and 3-year averages, the authors reported an increase in the magnitude of the association as the number of years increased, which is consistent with Crouse et al. (2020) discussed above.

##### 3.2.2.2.2 Cause-Specific Mortality

Studies that examine the association between long-term PM_2.5_ exposure and cause-specific mortality outcomes, including cardiovascular and respiratory mortality, can provide additional support for PM_2.5_-related cardiovascular and respiratory effects, specifically whether there is evidence of an overall continuum of effects. Some of the studies evaluated in Section 3.1.2.2.1, in addition to examining all-cause or nonaccidental mortality, conducted analyses of cardiovascular and respiratory mortality, which builds on the evidence detailed in the 2019 PM ISA (respiratory mortality, Section 5.2.10 and Section 11.2.2.3; cardiovascular mortality, Section 6.2.10 and Section 11.2.2.2). As detailed in Figure 3-22, recent cohort studies provide evidence of consistent positive associations in analyses of both cardiovascular and respiratory mortality. In addition to examining all cardiovascular and respiratory mortality outcomes, some studies also examined individual cardiovascular and respiratory mortality outcomes, as well as mortality in individuals with preexisting cardiovascular-related disease. The following sections provide an overview of the evidence presented in recent cohort studies with respect to cause-specific mortality.

Figure 3-22 Associations between long-term PM_2.5_ exposure and all cardiovascular disease and all respiratory disease mortality in recent North American cohorts

ACS = American Cancer Society; Ag Health = Agricultural Health Study; CanCHEC = Canadian Census Health and Environment Cohort; CCHS = Canadian Community Health Survey; CVD = cardiovascular disease; EFFECT = Enhanced Feedback for Effective Cardiac Treatment; IDW = inverse distance weighting; km = kilometer; LUR-BME = land use regression―Bayesian maximum entropy; mCCHS = Canadian Community Health Survey―mortality cohort; μg/m^3^ = microgram per cubic meter; NHIS = National Health Interview Survey; NIH-AARP = National Institutes of Health—American Association of Retired Persons; ONPHEC = Ontario Population Health and Environment Cohort; PM = particulate matter; PM_2.5_ = particulate matter with a nominal mean aerodynamic diameter less than or equal to 2.5 μm; TrIPS = Trucking Industry Particle Study; WHI = Women’s Health Initiative.

Note: †Studies published since the 2009 PM ISA. *U.S. and Canadian studies published since the literature cutoff date (~January 2018) for the 2019 PM ISA. Associations are presented per 5 μg/m^3^ increase in pollutant concentration. Circles represent point estimates, closed published before 2009 PM ISA, and open published after 2019 PM ISA; horizontal lines represent 95% confidence intervals for PM_2.5_. Due to precise confidence intervals for estimates from some studies, the lines representing the confidence intervals cannot be viewed behind the point representing the effect estimate. Black text and circles represent evidence included in the 2009 PM ISA; red text and circles represent recent evidence not considered in previous ISAs or AQCDs; and blue text and circles represent recent U.S. and Canadian studies published since the literature cutoff date of the 2019 PM ISA. Results from Crouse et al. (2020) are for 3-year average, 1-year lag PM_2.5_ concentrations at 1 km resolution.

Figure 3 dash 22 is an update to Figure 11 dash 19 in the 2019 P M I S A that presents a summary of associations between long-term P M 2.5 exposure and cardiovascular and respiratory mortality for a 5 micrograms per cubic meter increase in average concentrations from recently published and previously evaluated North American studies. Across studies there is evidence of primarily positive associations conducted in locations with annual average P M 2.5 concentrations ranging from 6.3 to 23.6 micrograms per cubic meter.

Source: Update of Figure 11-19, 2019 PM ISA.

###### Cardiovascular Mortality

Studies investigating cardiovascular mortality provided some of the strongest evidence for a cardiovascular effect related to long-term PM_2.5_ exposure in the 2009 PM ISA, which was further supported by studies evaluated in the 2019 PM ISA (Figure 3-22). Generally, across the cohort studies evaluated in the 2019 PM ISA, most of the PM_2.5_ effect estimates relating long-term PM_2.5_ exposure and cardiovascular mortality remained relatively unchanged or increased in magnitude in copollutant models adjusted for ozone, NO_2_, PM_10−2.5_, or SO_2_. The results of recent cohort studies provide additional evidence for associations with cardiovascular mortality outcomes across the distribution of PM_2.5_ concentrations, the potential implications of comorbidity on the PM_2.5_-cardiovascular mortality relationship, and associations with individual cardiovascular mortality outcomes.

In a study of the NIH-AARP cohort, which consists of participants ranging from 50 to 71 years of age, Hayes et al. (2020) examined not only the overall relationship between long-term PM_2.5_ exposure and cardiovascular-related mortality, but whether associations changed over different ranges of PM_2.5_ concentrations. In the main analysis, the authors applied a spatiotemporal model that predicted PM_2.5_ concentrations at the census tract and reported a HR of 1.06 (95% CI: 1.03, 1.08) for all cardiovascular mortality. This result was consistent with a sensitivity analysis that assigned exposure based on distance to monitor from participant residence when focusing on monitors 0−25 km away (HR = 1.07 [95% CI: 1.03, 1.10]), with more variability and less precision for greater distances (i.e., 25−50 km and 50−100 km) due to the smaller sample size and the increased exposure error that can occur as distance to monitor increases.

The results of Hayes et al. (2020) are consistent with another study focusing exclusively on cardiovascular mortality conducted by Chen et al. (2020) using the ONPHEC. Within ONPHEC, Chen et al. (2020) examined associations between long-term PM_2.5_ exposure and cardiovascular mortality in individuals 35−85 years of age using an exposure model similar to the one used in the MAPLE studies (Table A-7). In analyses using 1-year average PM_2.5_ exposures with a 1-year lag prior to death, the authors conducted single pollutant analyses using a traditional Cox proportional hazards model where PM_2.5_ is fit as a linear term and then a Cox proportional hazards where PM_2.5_ could be nonlinearly associated with cardiovascular mortality using the SCHIF detailed in Nasari et al. (2016). The authors reported that the nonlinear model is a better predictor of cardiovascular mortality through an assessment of model fit based on AIC. However, relatively similar HRs were reported for both the linear (HR = 1.11 [95% CI: 1.10, 1.12]) and nonlinear (HR = 1.10 [95% CI: 1.09, 1.12]) models, which are consistent with the results presented in other studies of cardiovascular mortality (Figure 3-22). In addition to conducting single-pollutant analyses, the authors introduced a new approach to assess whether the PM_2.5_-cardiovascular mortality association varies depending on the proportion of PM_2.5_ attributed to selected components (i.e., sulfate, nitrate, ammonium, black carbon, organic matter, mineral dust, and sea salt). In a Cox proportional hazards model that adjusted for the proportion of each of the seven selected components Chen et al. (2020) reported that cardiovascular mortality associations increased on average by 27% when compared with single-pollutant results across each of the five regions of Ontario. These results provide some evidence that variability in the proportion of individual components that comprise PM_2.5_, could explain regional variability in mortality risk estimates.

While there is evidence of consistent positive associations between long-term PM_2.5_ exposure and cardiovascular mortality (Figure 3-22), it is plausible that comorbidities may increase the overall risk of cardiovascular mortality. As a result, Pinault et al. (2018) examined both the CanCHEC and mCCHS cohorts to assess whether the combination of cardiovascular disease and diabetes together yielded larger PM_2.5_-mortality risk estimates than cardiovascular disease alone. Within CanCHEC, the authors identified all participants for whom, in addition to having cardiovascular disease as the primary cause of death, diabetes was mentioned on the death certificate, whereas for the mCCHS, which consisted of individual-level data, participants self-reported diabetes status by noting insulin or medication use to manage diabetes at baseline. In both analyses, the authors applied the same base hybrid exposure model used in the MAPLE studies, which ultimately resulted in a 3-year average PM_2.5_ concentration assigned to each participant, lagged 1-year prior to death (Table A-7). In both cohorts, there was an almost doubling of the HR for mortality for the combination of cardiovascular disease and diabetes compared with cardiovascular disease alone (CanCHEC: CVD, HR = 1.12 [95% CI: 1.10, 1.14], CVD+diabetes, HR = 1.23 [95% CI: 1.18, 1.28]; mCCHS: CVD, HR = 1.14 [95% CI: 1.08, 1.21], CVD+managed diabetes, HR = 1.23 [95% CI: 1.04, 1.46]).

In addition to the studies that examined all cardiovascular mortality outcomes, a number of studies also examined specific cardiovascular mortality outcomes (Figure 3-23). As described in Section 6.2.10 of the 2019 PM ISA, there were generally positive associations across studies for IHD mortality with a more limited assessment of other outcomes (e.g., cerebrovascular, heart failure, hypertensive disorders). Recent studies within the Medicare cohort (Wang et al., 2020), the CanCHEC cohort (Crouse et al., 2020; Cakmak et al., 2018; Pinault et al., 2017), and NIH-AARP cohort (Hayes et al., 2020) report positive associations with IHD, supporting the results of studies evaluated in the 2019 PM ISA. However, Cakmak et al. (2018) conducted a slightly different analysis of the CanCHEC cohort than Pinault et al. (2017) by using the 1991 CanCHEC and a 7-year average exposure instead of the 3-year average, 1-year lag exposure of the studies within MAPLE. Although Crouse et al. (2020) also examined the 2001 CanCHEC, as noted previously, the study focused on examining different temporal (1-, 3-, and 8-year average) and spatial (1, 5, and 10 km) scales of exposure assignment. Across each temporal scale the authors reported consistent positive associations regardless of spatial scale, but overall, the magnitude of the PM_2.5_-IHD association was smaller when using 1-year average PM_2.5_ concentrations. Of the studies that included an assessment of IHD mortality, only Cakmak et al. (2018) examined copollutant models and reported that IHD associations, although attenuated, remained positive in models with ozone (PM_2.5_: HR = 1.12 [95% CI: 1.10, 1.14]; PM_2.5_ + ozone: HR = 1.06 [95% CI: 1.04, 1.09]).

Figure 3-23 Associations between long-term PM_2.5_ exposure and cause-specific cardiovascular mortality in recent North American cohorts

ACS = American Cancer Society; AHSMOG = Adventist Health Study and Smog; AMI = acute myocardial infarction; AQCD = Air Quality Criteria Document; CA = California; CanCHEC = Canadian Census Health and Environment Cohort; CBVD = cerebrovascular disease; CCHS = Canadian Community Health Survey; CHD = coronary heart disease; CI = confidence interval; CVD = cardiovascular disease; EFFECT = Enhanced Feedback for Effective Cardiac Treatment; HF = heart failure; IDW = inverse-distance weighting; IHD = ischemic heart disease; km = kilometer; NHIS = National Health Interview Survey; NIH-AARP = National Institutes of Health–American Association of Retired Persons; PM_2.5_ = particulate matter with a nominal mean aerodynamic diameter less than or equal to 2.5 μm; WHI = Women’s Health Initiative.

Note: †Studies published since the 2009 PM ISA. *U.S. and Canadian studies published since the literature cutoff date (~January 2018) for the 2019 PM ISA. Associations are presented per 5 µg/m^3^ increase in pollutant concentration. Circles represent point estimates; horizontal lines represent 95% confidence intervals for PM_2.5_. Due to precise confidence intervals for estimates from some studies, the lines representing the confidence intervals cannot be viewed behind the point representing the effect estimate. Black text and circles represent evidence included in the 2009 PM ISA; red text and circles represent recent evidence not considered in previous ISAs or AQCDs, with open red circles representing studies published since the 2019 PM ISA; and blue text and circles representing U.S. and Canadian studies published since the literature cutoff date of the 2019 PM ISA. Study results from Pope et al. (2014) are representative of the results from the American Cancer Society cohort.

Figure 3 dash 23 is an update to Figure 6 dash 19 in the 2019 P M I S A that presents a summary of associations between long-term P M 2.5 exposure and cardiovascular mortality for a 5 microgram per cubic meter increase. Studies published since the literature cutoff date for the 2019 P M I S A, which are in blue, add to the large number of studies evaluated in the 2019 P M I S A, which are in red, which collectively report generally positive associations across cardiovascular endpoints. See text discussion for more information.

Source: Update of Figure 6-19, 2019 PM ISA

Few studies to date have examined associations between long-term PM_2.5_ exposure and cerebrovascular disease or stroke mortality, but studies by Wang et al. (2020), Pinault et al. (2017), Crouse et al. (2020), and Hayes et al. (2020) along with a study within the NHIS cohort by Pope et al. (2019) add to the growing body of evidence indicating a positive relationship. Although Pope et al. (2014) in a study of the ACS cohort, evaluated in the 2019 PM ISA indicated a positive association with CHF mortality, in a recent study of the Medicare cohort Wang et al. (2020) reported a null association. Finally, a few studies using the CanCHEC cohort (Crouse et al., 2020; Pinault et al., 2017) examined the combination of cardiovascular mortality with either metabolic-related or diabetes mortality, and found that associations were similar in magnitude to cardiovascular mortality alone [e.g., within Pinault et al. (2017) all cardiovascular: HR = 1.12 (95% CI: 1.09, 1.14); all cardiovascular + diabetes: HR = 1.13 (95% CI: 1.10, 1.15)].

###### Respiratory Mortality

Evidence from studies investigating respiratory-related mortality provided limited and inconsistent evidence for a respiratory effect related to long-term PM_2.5_ exposure in the 2009 PM ISA (U.S. EPA, 2009). Studies evaluated in the 2019 PM ISA (Section 5.2.10; Figure 5-34) primarily focused on all respiratory mortality with a more limited assessment of COPD and respiratory infection. Across studies there was evidence of generally consistent, positive associations. Recent cohort studies provide an additional assessment of the relationship between long-term PM_2.5_ exposure and COPD and respiratory infection mortality.

Studies conducted within the NHIS (Pope et al., 2019) and Medicare (Wang et al., 2020) cohorts provided limited evidence of an association with chronic lower respiratory and COPD mortality, respectively (Figure 3-24). However, in a study of the CanCHEC cohort Pinault et al. (2017) reported a HR for COPD mortality of 1.11 (95% CI: 1.05, 1.18), which is similar in magnitude to the association reported in Pinault et al. (2016) within the CCHS cohort as detailed in the 2019 PM ISA. In another study of the CanCHEC cohort, which as noted earlier used a different exposure assessment approach compared with Pinault et al. (2017), Cakmak et al. (2018) reported evidence of a positive association between long-term PM_2.5_ exposure and COPD mortality in analyses of never movers. In addition, Cakmak et al. (2018) alone examined potential copollutant confounding of the PM_2.5_-COPD mortality relationship, but in analyses focused on movers and never movers, not the entire cohort. In models with O_3_, in both movers and never movers the authors reported larger HRs, albeit with wide confidence intervals, with ozone in the model, which was substantially larger for movers (movers: HR = 1.08 [95% CI: 1.03, 1.12]; never movers: HR = 1.05 [95% CI: 0.88, 1.26]).

Figure 3-24 Associations between long-term PM_2.5_ exposure and cause-specific respiratory mortality in recent North American cohorts

ACS = American Cancer Society; AQCD = Air Quality Criteria Document; CanCHEC = Canadian Census Health and Environment Cohort; CCHS = Canadian Community Health Survey; CI = confidence interval; LUR-BME = Land Use Regression―Bayesian Maximum Entropy; µg/m^3^ = micrograms per cubic meter; NHIS = National Health Interview Survey; PM_2.5_ = particulate matter with a nominal mean aerodynamic diameter less than or equal to 2.5 μm; TrIPS = Trucking Industry Particle Study.

Note: †Studies published since the 2009 PM ISA. *U.S. and Canadian studies published since the literature cutoff date (~January 2018) for the 2019 PM ISA. Associations are presented per 5 µg/m^3^ increase in pollutant concentration. Circles represent point estimates; horizontal lines represent 95% confidence intervals for PM_2.5_. Red text and circles represent recent evidence not considered in previous ISAs or AQCDs, with blue text and circles representing U.S. and Canadian studies published since the literature cutoff date of the 2019 PM ISA. Study results from Pope et al. (2014) are representative of the results from the American Cancer Society cohort.

Figure 3 dash 24 is a modification of Figure 5 dash 34 in the 2019 P M I S A that presents the associations between long-term exposure to P M 2.5 and respiratory mortality in recent U.S. and Canadian cohort studies. Overall, the hazard ratios presented are generally positive for mortality due to C O P D and respiratory infection.

Source: Modification of Figure 5-34, 2019 PM ISA.

The examination of respiratory infection mortality is more limited, with recent cohort studies examining either pneumonia alone (Wang et al., 2020; Pinault et al., 2017) or the combination of influenza and pneumonia (Pope et al., 2019). Across the studies, which employed different approaches to assign PM_2.5_ exposures including a 1-year average in the Medicare cohort (Wang et al., 2020), a 3-year average with a 1-year lag in the CanCHEC cohort (Pinault et al., 2017), and a 17-year average in the NHIS cohort (Pope et al., 2019), each reported positive associations with the magnitude of the association increasing as the length of the exposure window increased.

###### Other Mortality Outcomes

While cardiovascular- and respiratory-related mortality comprise the majority of mortality outcomes examined, as noted in the 2019 PM ISA, additional mortality outcomes are also associated with long-term PM_2.5_ exposure, including cardiopulmonary, diabetes, and lung cancer (2019 PM ISA, Section 10.2.5 and Section 11.2.2). Recent cohort studies published since the 2019 PM ISA also provide evidence of positive associations with cardiopulmonary (Lefler et al., 2019; Pope et al., 2019), diabetes/cardiometabolic disease (Crouse et al., 2020; Erickson et al., 2020; Lim et al., 2018; Pinault et al., 2017), and lung cancer (Crouse et al., 2020; Erickson et al., 2020; Erickson et al., 2019; Pope et al., 2019; Cakmak et al., 2018; Pinault et al., 2017) mortality.

##### 3.2.2.2.3 Long-Term PM_2.5_ Exposure and Mortality in Populations with Preexisting Conditions

In addition to recent studies examining cause-specific mortality, a few studies focused on examining the overall risk of mortality in individuals with preexisting cardiovascular conditions, specifically HF (Ward-Caviness et al., 2020) and previous MI (Malik et al., 2019). To date, relatively few studies have been conducted with the sole focus being on examining associations between long-term PM_2.5_ exposure and mortality within a cohort of individuals with a preexisting cardiovascular condition. Instead, studies have traditionally relied on the examination of effect modification, through stratified analyses, of the PM_2.5_-mortality association by specific cardiovascular conditions.

Ward-Caviness et al. (2020) examined associations between annual average PM_2.5_ exposure at the time of initial HF diagnosis with all-cause mortality in a hospital-based cohort within North Carolina developed from electronic health records of individuals diagnosed with heart failure. The authors assigned annual average PM_2.5_ exposures to each participant based on their residential address at the time of HF diagnosis. Exposures were assigned based on the nearest PM_2.5_ monitor and using the hybrid exposure model used in the Medicare studies discussed previously that estimated concentrations at 1 km^2^ (Table A-7). Over 10,000 of the 35,000 patients within the cohort died less than 1 year after diagnosis, which does not follow the traditional pattern of HF mortality. As a result, the authors excluded the year after diagnosis as a time at risk in the model. In a Cox proportional hazards model that controlled for individual-level covariates, distance to monitor, and neighborhood-level socioeconomic variables, Ward-Caviness et al. (2020) reported a HR for all-cause mortality of 1.84 (95% CI: 1.61, 2.01). In sensitivity analyses, associations were similar in magnitude to the main analysis when restricting it to participants <30 km from a PM_2.5_ monitor and larger in magnitude when applying the hybrid exposure model.

Whereas Ward-Caviness et al. (2020) examined the risk of mortality attributed to long-term PM_2.5_ exposure in the years following HF diagnosis over the entire study duration, Malik et al. (2019) focused on examining the 5-year survival for all-cause mortality following an MI event. A total of 5,650 patients with clinically diagnosed MI as defined by having biomarker evidence of myocardial necrosis and additional clinical evidence of MI, including prolonged ischemic signs/symptoms or electrocardiographic criteria of ST-segment changes, were enrolled in the Translational Research Investigating Underlying Disparities in Acute Myocardial Infarction (TRIUMPH) and Prospective Registry Evaluating Myocardial Infraction: Events and Recovery (PREMIER) studies. Using U.S. EPA’s downscaler Community Multi-Scale Air Quality Model (CMAQ), PM_2.5_ concentrations were estimated at the census tract centroid of each participants residence. Exposures assigned to each participant consisted of the 12-month average PM_2.5_ concentration prior to MI, which allowed for the examination of the association between PM_2.5_ exposure and survival after an MI. In a Cox regression model that controlled for numerous individual-level covariates as well as ozone, Malik et al. (2019) reported a HR of 1.34 (95% CI: 1.17, 1.54) for 5-year all-cause mortality.

Overall, the studies conducted by Ward-Caviness et al. (2020) and Malik et al. (2019) indicate that preexisting cardiovascular conditions substantially increase the risk of all-cause mortality. This is further reflected when comparing the magnitude of associations between these studies and the numerous cohort studies spanning diverse populations summarized in Section 3.1.2.2.1 and Figure 3-19.

##### 3.2.2.2.4 Studies of Life Expectancy

The 2019 PM ISA characterized a recent series of studies evaluating the relationship between long-term exposure to PM_2.5_ and mortality by examining the temporal trends in PM_2.5_ concentrations and changes in life expectancy. These studies generally observed that decreases in PM_2.5_ concentrations are associated with increases in life expectancy. A few recent studies add to this evidence base. Bennett et al. (2019) reported that PM_2.5_ concentrations in excess of the lowest observed concentration (2.8 μg/m^3^) were associated with a lower national life expectancy by an estimated 0.15 years for women and 0.13 years for men (Figure 3-25). Using a different approach, Ward-Caviness et al. (2020) compared participants residing in areas with PM_2.5_ concentrations > 12 μg/m^3^ to participants living in areas with PM_2.5_ concentrations < 12 μg/m^3^ and estimated that the years of life lost due to living in areas with higher PM_2.5_ concentrations was 0.84 years (95% CI, 0.73−0.95) over a 5-year period.

Figure 3-25 Estimated loss in life expectancy by county for females and males for PM_2.5_ concentrations in excess of the lowest observed PM_2.5_ concentration of 2.8 µg/m^3^

Figure 3 dash 25 is from Bennett et al. (2019) and it depicts the pattern of estimated loss in life expectancy by county across the U.S. for females and males for P M 2.5 concentrations in excess of the lowest observed P M 2.5 concentration of 2.8 microgram per cubic meter. See Section 3.2.2.2.4 for more information.

Source: Bennett et al. (2019)

##### 3.2.2.2.5 Potential Copollutant Confounding of the PM_2.5_-Mortality Relationship

As discussed in Section 3.1.2.2.8, one approach to assessing the independence of the association between exposure to PM_2.5_ and a health effect, such as long-term PM_2.5_ exposure and mortality, can be examined is through the use of copollutant models. The Appendix (Table A-1) to the 2019 PM ISA notes that copollutant models are not without their limitations, such as instances where correlations are high between pollutants resulting in greater bias in results. However, in assessing the results from copollutant models a change in the PM_2.5_ risk estimate, after adjustment for a copollutant, may indicate the potential for confounding.

At the completion of the 2009 PM ISA there was limited assessment of potential confounding of the relationship between long-term PM_2.5_ exposure and mortality by co-occurring pollutants. Studies evaluated in the 2019 PM ISA (Section 11.2.3) examined the potential for copollutant confounding by evaluating copollutant models that included O_3_ (Figure 11-20), NO_2_, PM_10−2.5_, SO_2_, and benzene (Figure 11-21). These studies addressed a previously identified data gap by informing the extent to which effects associated with exposure to PM_2.5_ are independent of coexposure to correlated copollutants in long-term analyses. Overall, PM_2.5_ effects to remained relatively unchanged in copollutant models adjusted for NO_2_, PM_10−2.5_, SO_2_, or benzene. Recent North American cohort studies conducted additional analyses that further inform whether the relationship between long-term PM_2.5_ exposure and mortality is confounded by gaseous pollutants or other particle size fractions (i.e., PM_10−2.5_).

In an analysis of the NHIS subcohort, Lefler et al. (2019) reported that the PM_2.5_-mortality association was relatively unchanged in copollutant analyses with SO_2_, NO_2_, O_3_, CO, and PM_10−2.5_. In addition to Lefler et al. (2019), within the Medicare cohort, Wang et al. (2020) also conducted an analysis of potential confounding of the PM_2.5_-mortality association with a focus on ozone and traffic-related pollution. The ozone analysis was conducted in a subset of the cohort that resided in ZIP codes within 6 miles of an ozone AQS monitor. To control for traffic-related pollution, instead of including NO_2_ in a copollutant model, Wang et al. (2020) regressed 12-month PM_2.5_ on NO_2_ and used the residuals as the exposure metric to estimate the PM_2.5_ association that is unrelated to traffic. The authors reported associations similar in magnitude in both a single (HR = 1.03 [95% CI: 1.02, 1.03]) and copollutant model with ozone (HR = 1.03 [95% CI: 1.02, 1.03]). Positive associations were also reported for the non-traffic PM_2.5_ analyses, and although the association was smaller in magnitude to the total PM_2.5_ analysis, this result provides evidence that the PM_2.5_-mortality association persists independent of traffic-related pollutants (HR = 1.01 [95% CI: 1.00, 1.01]).

A few studies within the MAPLE study also conducted analyses to assess potential copollutant confounding by gaseous pollutants. Within CanCHEC, Crouse et al. (2020) assessed potential copollutant confounding by ozone, NO_2_, and oxidant gases in sensitivity analyses using both 3-year and 8-year average PM_2.5_ concentrations at 1 km^2^ resolution. Associations between PM_2.5_ and mortality were found to be slightly attenuated but remained positive in copollutant models with each of the gaseous pollutants when using either 3-year or 8-year average PM_2.5_ exposures.

While there was no evidence of copollutant confounding in the analysis of CanCHEC by Crouse et al. (2020), there was some evidence in the pooled analysis of CanCHEC by Pappin et al. (2019). In the single-pollutant analysis, the authors reported a HR of 1.03 (95% CI: 1.02, 1.03) in the fully adjusted model, which is consistent with the copollutant model including NO_2_ (HR = 1.02 [95% CI: 1.01, 1.03]). However, there was no evidence of a PM_2.5_-mortality association in copollutant models with ozone (HR = 0.99 [95% CI: 0.98, 1.00]) and oxidants (HR = 0.98 [95% CI: 0.97, 0.98]). The ozone and oxidants results of Pappin et al. (2019) are consistent with those of Christidis et al. (2019) within the mCCHS cohort. However, Christidis et al. (2019) reported evidence of potential confounding by NO_2_. In a single-pollutant analysis, the authors reported a HR of 1.05 (95% CI: 1.02, 1.09). In copollutant models, PM_2.5_-mortality associations are null in models with ozone (HR = 1.00 [95% CI: 1.00, 1.01]) and oxidants (HR = 1.00 [95% CI: 0.99, 1.01]), and attenuated in a model with NO_2_ (HR = 1.01 [95% CI: 1.00, 1.02]).

Zhang et al. (2021) also conducted copollutant analyses when examining associations between long-term PM_2.5_ exposure and mortality in the Ontario Health Study. The authors reported that the PM_2.5_-mortality association in a single-pollutant model (HR = 1.20 [95% CI: 1.09, 1.32]) is relatively unchanged in a model with NO_2_ (HR = 1.18 [95% CI: 1.08, 1.30]), which is consistent with Lefler et al. (2019) in the NHIS cohort and Pappin et al. (2019) within CanCHEC. However, it is inconsistent with the results from the mCCHS cohort where Christidis et al. (2019) reported evidence of attenuation of the PM_2.5_-mortality association.

While there is some evidence from recent studies that PM_2.5_-mortality associations remain relatively unchanged in copollutant models, there are some differences in results across studies, particularly for copollutant analyses including ozone. This difference in results is most evident between MAPLE studies and other studies that previously examined copollutant confounding by ozone as summarized in Figure 11-20 of the 2019 PM ISA. This difference between studies could be attributed to the MAPLE studies using different spatial resolutions in estimating air pollutant concentrations, 1 km^2^ for PM_2.5_ and 21 km^2^ for ozone, potentially resulting in some degree of exposure error.

##### 3.2.2.2.6 Studies That Address the Potential Implications of Unmeasured Confounders on PM_2.5_-Mortality Associations

As discussed in Section 11.2.2.4 of the 2019 PM ISA, some recent studies used statistical techniques to reduce uncertainties related to potential unmeasured confounders that can further inform the relationship between long-term PM_2.5_ exposure and mortality. An initial study conducted by Janes et al. (2007) and then followed up by Greven et al. (2011) attempted to assess whether there is evidence of unmeasured confounding in the relationship between long-term PM_2.5_ exposure and mortality using data from the Medicare cohort from 2000 to 2006. In both studies the authors decomposed the association between PM_2.5_ and mortality into two components: (1) the association between the “national” trend in the monthly PM_2.5_ concentrations averaged over the previous 12 months and the national average trend in monthly mortality rates (purely temporal association); and (2) the association between the “local” trend in the deviation in the community-specific trend from the national average trend of monthly averages of PM_2.5_ and the deviation of the community-specific trends from the national average trend of mortality rates (residual spatiotemporal association). The authors concluded that differences in effect estimates at these two spatiotemporal scales raise concerns about confounding bias in these analyses, with the association for the national trend more likely to be confounded than the association for the local trend. However, in the process of decomposing the data, it eliminated all spatial variation in air pollution and mortality. Thus, while the results of the papers themselves provide evidence for an association between exposure to PM_2.5_ and mortality, it is not possible to directly compare the results of these studies to the results of other cohort studies investigating the relationship between long-term exposure to PM_2.5_ and mortality, which make use of spatial variability in air pollution and mortality data.

Similarly, Pun et al. (2017) completed a sensitivity analyses as part of their Medicare cohort study for the years 2000−2008 in which they decomposed PM_2.5_ into “temporal” and “spatiotemporal” variation, which is analogous to “national” and “local” respectively in Greven et al. (2011). The purpose of this sensitivity analysis was to determine the presence or absence of bias due to unmeasured confounding. Pun et al. (2017) observed positive associations for the “temporal” variation model and approximately null associations for the “spatiotemporal” variation model for all causes of death except for COPD mortality. The difference in the results of these two models for most causes of death suggests the presence of unmeasured confounding, though the authors do not indicate anything about the direction or magnitude of this bias. It is important to note that the “temporal” and “spatiotemporal” coefficients are not directly comparable to the results of other epidemiologic studies when examined individually and can only be used in comparison with one another to evaluate the potential for unmeasured confounding bias.

As a result of the studies noted above suggesting the presence of unmeasured confounders, including long-term time trends, Eum et al. (2018) focused specifically on whether temporal confounding exists in the PM_2.5_-mortality relationship using the Medicare cohort from 2000 to 2012. In a base model that did not account for temporal confounding the authors used the exact methods of Greven et al. (2011) to decompose PM_2.5_ into “temporal” and “spatiotemporal” components, with and without the inclusion of behavioral covariates from the Behavioral Risk Factor Surveillance System (BRFSS), to identify whether there was evidence of unmeasured confounding. Consistent with the previous studies larger associations were reported for the “temporal” compared with the “spatiotemporal” component, with results being positive for both components. As a result of the magnitude of associations between these two components being different, Eum et al. (2018) attempted to assess whether temporal confounding of the PM_2.5_-mortality relationship could explain the observed difference in results. The authors developed a base model that used data for the entire 13 year period and shorter periods ranging from 3 to 12 years (e.g., 2001−2012, 2009−2012) as well as three additional models: (1) residual-base model: calculated the residuals of a linear regression of PM_2.5_ on time in 4-year intervals (i.e., 2000−2004, 2005−2008, and 2009−2012), for which the residuals were then used as the exposure in the base model; (2) spline-based model: added a penalized spline with two knots per year to the base model; and (3) decomposition-based model: added the temporal component of decomposed PM_2.5_ to the base model based on the approach described in Greven et al. (2011). In analyses of the base model, the authors observed that as the years of data included in the analysis increased so did the magnitude of the mortality risk ratio (MRR) (Figure 3-26). Contrary to the base model, as depicted in Figure 3-26, there was a steady decline in the MRR for both the spline-based and decomposition-based models while MRRs remained relatively stable using the residual-based model. These results provide some evidence indicating that long-term temporal trends in PM_2.5_ concentrations may be one source of unmeasured confounding to consider in long-term exposure studies lasting many years, and that a residual-based approach could potentially account for those trends.

The results of Eum et al. (2018) are consistent with a confounder analysis of temporal trends conducted by Wu et al. (2020a), originally discussed in Section 3.1.2.2.1. In the main analysis, the authors controlled for temporal trends by adjusting for calendar year and also included meteorological variables to account for season (i.e., summer and winter), maximum daily temperature, and relative humidity. In Cox and Poisson models that did not adjust for calendar year, HRs increased in analyses of both the entire cohort (Cox, main analysis, HR = 1.03 [95% CI: 1.03, 1.04]; Cox, minus calendar year, HR = 1.08 [95% CI: 1.08, 1.09]) and those limited to individuals living in locations where PM_2.5_ concentrations were ≤ 12 µg/m^3^ for the entire study duration (main analysis, HR = 1.17 [95% CI: 1.16, 1.18]; minus calendar year, HR = 1.25 [95% CI: 1.24, 1.27]), indicating that not accounting for temporal trends may overestimate associations. In addition, in analyses that excluded meteorological variables, HRs were relatively unchanged compared with the main analysis (Cox, HR = 1.03 [95% CI: 1.02, 1.03]), indicating they are not a source of residual confounding in long-term exposure studies.

Figure 3-26 Mortality risk ratios for a 10 µg/m^3^ increase in PM_2.5_ by length of study for the base model and temporal adjusted models in Eum et al. (2018)

Figure 3 dash 26 is from Eum et al. (2018) and it depicts the mortality risk ratios for a 10 microgram per cubic meter increase in P M 2.5 by length of study for the base model and temporal adjusted models. See Section. 3.2.2.2.6 for more information on the interpretation of this figure.

Source: Eum et al. (2018)

Although there is extensive evidence of a relationship between long-term PM_2.5_ exposure and mortality provided by numerous cohort studies discussed throughout this section, potential residual confounding remains a concern as reflected in the studies discussed above. Of these studies, only Eum et al. (2018) and Wu et al. (2020a) attempted to address a specific potential source of confounding (i.e., long-term trends). Erickson et al. (2019) also examined the potential implications of unmeasured confounders on the PM_2.5_-mortality relationship by using an approach that indirectly adjusts for missing covariates via partitioned regression, based on an approach developed by Shin et al. (2014). This approach controls for unmeasured potential confounders that are not available in the primary data set for an individual cohort by using data from an ancillary matching data set. Shin et al. (2014) suggested that in applying indirect adjustment it is important for the primary data set and ancillary data set to have a similar distribution of the primary exposure (i.e., PM_2.5_) among subjects across demographic characteristics, and to conduct a “gold-standard” evaluation to assess the magnitude of bias correction by excluding and indirectly adjusting for specific variables in both data sets. Erickson et al. (2019) applied both of these suggestions by using three cohorts from the MAPLE studies. Specifically, the 2001 CanCHEC, which represented the main data set, and the CCHS as the ancillary matching data set were used for validation analyses, while the assessment of the direction and magnitude of bias of this approach was conducted using the mCCHS cohort as the ancillary data set that contained information, missing in CanCHEC, on cigarettes/day, alcohol use, fruit and vegetable intake, and leisure exercise.

A multi-step process was used to conduct this analysis that consisted of the following: (1) assess the representativeness of the primary data set (i.e., CanCHEC) to the ancillary data set (CCHS) to compare absolute and proportional differences in the distribution of PM_2.5_ concentrations within the two populations; (2) conduct an internal validation to assess the degree of bias in HRs when applying the indirect adjustment; and (3) conduct an external validation to assess bias of using CCHS as the ancillary data set to indirectly adjust CanCHEC. In (1), Erickson et al. (2019) applied sampling weights to the CCHS to ensure the distribution of PM_2.5_ concentrations was the same across demographic and socioeconomic characteristics at baseline. For (2), the authors used a “gold-standard” that consisted of removing and indirectly adjusting for variables available within the CanCHEC cohort (i.e., education and income). The results of this adjustment were then compared with a “True Model” that adjusted for education, income, and all other individual-level covariates. To conduct the internal validation, a “Partial Model” was developed that excluded education and income. The coefficient and variance terms for education and income were derived from the “True Model” with PM_2.5_ excluded. The coefficient and variance terms for education and income were used to indirectly adjust for each covariate in the “Partial Model” resulting in the “Internal (validation) Model.” A comparison of the “True Model” and “Internal (validation) Model” allows for an assessment of the indirect adjustment approach. In (3), the authors used a similar approach to the internal validation for conducting the external validation using variables available in both CanCHEC and CCHS (i.e., education and income) instead of using only the CanCHEC data. Finally, after going through each of the aforementioned steps to validate the indirect adjustment approach, Erickson et al. (2019) used the data from mCCHS on cigarettes/day, alcohol use, fruit and vegetable intake, and leisure exercise to indirectly adjust for the covariates within CanCHEC. For all analyses both time-varying and static PM_2.5_ concentrations were evaluated, but for comparison with the exposure assignment approach used within the MAPLE studies, the results below primarily focus on the time-varying exposure.

In the internal and external validations, which focused on the educational and income variables, in analyses of nonaccidental, cardiovascular, IHD, and lung cancer mortality, the authors reported an overall reduction (i.e., bias) in the HRs compared with the “True Model” when indirectly adjusting for the covariates. There was a 3%−5.6% bias across mortality outcomes for the “Partial Model,” which did not control for either covariate, which was reduced to 1.7%−2.9% and 1.3%−2.3% in the internal and external validation analyses, respectively. The results of the validation analyses were further confirmed in the main analysis using the mCCHS cohort as the ancillary data set, where there was an approximately 1.5% increase in the HR when indirectly adjusting for missing covariates in the CanCHEC cohort. Additionally, the results using the ancillary data set within the CanCHEC cohort for nonaccidental, cardiovascular, and IHD mortality were consistent in magnitude to those reported in mCCHS.

The methods detailed by Erickson et al. (2019) provide an approach to address the issue of unmeasured confounders, but this method is limited by the availability of an ancillary data set. In addition, the direction and magnitude of the bias is dependent upon the direction and magnitude of the correlation between air pollution and the missing covariates within the population of interest. However, the direction of the bias can vary when using this confounder adjustment approach, with an underestimation of the HR observed when using a time-varying exposure and an overestimation observed when using a static exposure when compared with the “True Model.” Overall, the results of Erickson et al. (2019) indicate that the lack of data for some covariates leads to an underestimation, not an overestimation, of the PM_2.5_-mortality association.

In conclusion, recent studies that further evaluate the potential implications of unmeasured confounders on the association between long-term PM_2.5_ exposure and mortality indicate that bias can occur in either direction. However, across the studies evaluated, the control for unmeasured confounders as detailed in Eum et al. (2018), Wu et al. (2020a), and Erickson et al. (2019) do not result in the elimination of the association, but instead provide additional confirmation that an association between long-term PM_2.5_ exposure and mortality exists when accounting for additional confounders.

##### 3.2.2.2.7 Examination of the Concentration-Response (C-R) Relationship between Long-Term PM_2.5_ Exposure and Mortality

An important consideration in characterizing the association between long-term PM_2.5_ exposure and mortality is whether the concentration-response (C-R) relationship is linear across the full concentration range that is encountered, or if there are concentration ranges where there are departures from linearity. The 2009 PM ISA characterized the results of an analysis by Schwartz et al. (2008) that demonstrated that the shape of the C-R curve was generally linear. A substantially larger number of studies was evaluated in the 2019 PM ISA, which provided strong evidence for a linear, no-threshold concentration-response relationship for long-term PM_2.5_ exposure and total (nonaccidental) mortality [U.S. EPA (2019); Section 11.2.4]. Although analyses of the Harvard Six Cities study (Lepeule et al., 2012) and the U.S. Medicare cohort (Di et al., 2017b; Shi et al., 2015) reported linear, no-threshold C-R relationships down to 8, 6 and 5 µg/m^3^, respectively, evidence presented in the 2019 PM ISA demonstrated less certainty in the shape of the C-R curve at mean annual PM_2.5_ concentrations generally below 8 µg/m^3^, though some studies characterized the C-R relationship with certainty down to 4 µg/m^3^ (e.g., analyses of the CanCHEC (Pinault et al., 2016)).

A number of recent studies conducted analyses that further inform the shape of the C-R relationship for the association between long-term PM_2.5_ exposure and mortality and are summarized in Table 3-6. Generally, the results of these analyses continue to support a linear, no-threshold relationship for total (nonaccidental) mortality, though there is some evidence for a sublinear (shallower slope at lower concentrations and steeper slope at higher concentrations) (Zhang et al., 2021; Pope et al., 2019) or supralinear (steeper slope at lower concentrations and shallower slope at higher concentrations) (Christidis et al., 2019; Pappin et al., 2019; Pinault et al., 2017) relationship at lower ambient PM_2.5_ concentrations. Many of the recent studies that conducted C-R analyses include concentration ranges that extend below the level of the current annual PM_2.5_ NAAQS of 12 µg/m^3^.

Table 3-6 Summary of studies examining the concentration-response (C-R) relationship or conducted threshold analyses for long-term PM_2.5_ exposure and mortality

Study Location―Cohort (Table/Figure from Reference) | Exposure; PM_2.5_ Mean; Range in µg/m^3^ | Statistical Analysis
Study Location―Cohort (Table/Figure from Reference) | Exposure; PM_2.5_ Mean; Range in µg/m^3^ | Summary
Christidis et al. (2019); mCCHS; (Figure 2) | PM_2.5_ estimates at 1 km^2^ over 3-yr average (3-yr/1-km model) with single-yr lag assigned to postal code of residence; 5.9 (0.4-17.2) | C-R: SCHIF fits a class of flexible, but monotonically nondecreasing functions to select best fitting model; Supralinear at lower concentrations (< 5 µg/m^3^)
Elliott et al. (2020); Nurses’ Health Study; (Table 2) | 24-mo average ambient PM_2.5_ exposures were estimated at residential addresses using a spatiotemporal prediction model; 13.7; (NR) | Exposure categories (quintiles); Monotonic (linear) relationship demonstrated by HRs remaining generally consistent and statistically significant. P for trend = 0.07
Pappin et al. (2019); CanCHEC; (Figure 2) | PM_2.5_ estimates at 1 km over 3-yr average (3-yr/1-km model) with single-yr lag assigned to postal code of residence; 6.68−7.95 (0.37−20.0) | C-R analysis, three-step approach: (1) restricted cubic splines (RCS) with a large number of knots; (2) smooth potential erratic predictions from the large number of knots using monotonically increasing smoothing splines (MISS); and (3) fit the SCHIF to the MISS predictions
Pappin et al. (2019); CanCHEC; (Figure 2) | PM_2.5_ estimates at 1 km over 3-yr average (3-yr/1-km model) with single-yr lag assigned to postal code of residence; 6.68−7.95 (0.37−20.0) | Supralinear at lower concentrations (< 5 µg/m^3^)
Pinault et al. (2017); CanCHEC; (Figure 2; Table S4) | PM_2.5_ estimates at 1 km over 3-yr average (3-yr/1-km model) with single-yr lag assigned to postal code of residence 7.37 (0.37−20.0) | C-R: SCHIF fits a class of flexible, but monotonically nondecreasing functions to select best fitting model (counterfactual is 0 µg/m^3^); cutpoint analyses: 0−5, 5−10, > 10 µg/m^3^
Pinault et al. (2017); CanCHEC; (Figure 2; Table S4) | PM_2.5_ estimates at 1 km over 3-yr average (3-yr/1-km model) with single-yr lag assigned to postal code of residence 7.37 (0.37−20.0) | Supralinear at lower concentrations (< 5 µg/m^3^); HRs remained positive and statistically significant in the two lowest cutpoint categories with highest HRs for the 0−5 µg/m^3^ category, consistent with the supralinear C-R function
Pope et al. (2019); NHIS Cohort; (Figure 4) | Population-weighted annual PM_2.5_ concentrations averaged for census-tract centroids.; 10.7; (2.5−19.2) | C-R: Integrated model that fit a class of flexible, but monotonically nondecreasing functions to select best fitting model.
Pope et al. (2019); NHIS Cohort; (Figure 4) | Population-weighted annual PM_2.5_ concentrations averaged for census-tract centroids.; 10.7; (2.5−19.2) | Generally linear, though some evidence of a shallower slope at lower concentrations (< 8 µg/m^3^)
Wang et al. (2020); Medicare Cohort; (Figure 1; Table S4) | Daily PM_2.5_ was estimated on a 6-km grid using a spatiotemporal model 10.3 (NR) | C-R: RCS model with 3 knots; Threshold: PM_2.5_ < 8, < 10, < 12 µg/m^3^
Wang et al. (2020); Medicare Cohort; (Figure 1; Table S4) | Daily PM_2.5_ was estimated on a 6-km grid using a spatiotemporal model 10.3 (NR) | C-R: Linear across distribution of exposure concentrations with no evidence of a threshold; HRs remained positive and statistically significant when only participants with exposure concentrations below 8, 10, or 12 µg/m^3^ were included
Ward-Caviness et al. (2020); HF Patient Cohort; (Table 2; Figure 3) | Nearest monitor (Threshold model) or Harvard’s 1 km × 1 km modeled PM_2.5_ surface (C-R figure); 10.3; (8−14) | Threshold model (PM_2.5_ < 12 µg/m^3^); C-R: limited to PM_2.5_ concentration within inner 95% of distribution (8−14 µg/m^3^)
Ward-Caviness et al. (2020); HF Patient Cohort; (Table 2; Figure 3) | Nearest monitor (Threshold model) or Harvard’s 1 km × 1 km modeled PM_2.5_ surface (C-R figure); 10.3; (8−14) | HRs remained positive and statistically significant when only participants with exposure concentrations below 12 µg/m^3^ were included; linear C-R curve, with greatest certainty between 9 and 13 µg/m^3^
Wu et al. (2020a); Medicare Cohort; (Figure 3) | An ensemble-based prediction model was used to estimate daily PM_2.5_ concentrations for a 1-km^2^ grid network across the contiguous U.S. 9.8 (NR) | Threshold model (PM_2.5_ <12 µg/m^3^)
Wu et al. (2020a); Medicare Cohort; (Figure 3) | An ensemble-based prediction model was used to estimate daily PM_2.5_ concentrations for a 1-km^2^ grid network across the contiguous U.S. 9.8 (NR) | HRs remained positive and statistically significant when only participants with exposure concentrations below 12 µg/m^3^ were included
Zhang et al. (2021); Ontario Health Study; (Figure 2; Tables S3, S8) | PM_2.5_ estimates at 1 km^2^ over 3-yr average (5-yr/1-km model) with single-yr lag assigned to postal code of residence 7.8 (NR) | C-R: SCHIF fits a class of flexible, but monotonically nondecreasing functions to select best fitting model; threshold model (PM_2.5_ < 10 and < 8.8 µg/m^3^); Categorical exposure (quartiles)
Zhang et al. (2021); Ontario Health Study; (Figure 2; Tables S3, S8) | PM_2.5_ estimates at 1 km^2^ over 3-yr average (5-yr/1-km model) with single-yr lag assigned to postal code of residence 7.8 (NR) | Sublinear relationship with shallower slope at lower concentrations and steeper slope at mid-range concentrations; HRs remained positive and statistically significant when only participants with exposure concentrations below 10 µg/m^3^ were included. Results were positive but attenuated and no longer statistically significant below 8.8 µg/m^3^; categorical exposure results demonstrate sublinear relationship, similar to C-R function with strongest association for concentrations > 8.5 µg/m^3^

CanCHEC = Canadian Census Health and Environment Cohort; HF = heart failure; HR = hazard ratio; km = kilometer; mCCHS = Canadian Community Health Survey―mortality cohort; NHIS = National Health Interview Survey; NR = not reported; SCHIF = Shape Constrained Health Impact Function.

Wang et al. (2020) and Ward-Caviness et al. (2020) observed linear, no-threshold concentration-response relationships for total (nonaccidental) mortality, with confidence in the relationship down to a concentration of 5 and 9 µg/m^3^, respectively. Using exposure categories (i.e., quintiles of exposure) to estimate the shape of the concentration-response relationship, Elliott et al. (2020) report evidence that supports a monotonic (linear) function.

Studies that relied on data from Canadian cohorts evaluated the shape of the concentration-response relationship using a SCHIF approach to model the function (Zhang et al., 2021; Christidis et al., 2019; Pappin et al., 2019; Pinault et al., 2017). The SCHIF approach, developed by Nasari et al. (2016), fits a class of flexible, but monotonically nondecreasing functions to select the best fitting model of the concentration-response relationship. Most of the studies that used the SCHIF approach (Christidis et al., 2019; Pappin et al., 2019; Pinault et al., 2017) identified a supralinear concentration-response relationship at relatively low PM_2.5_ concentrations (< 5 µg/m^3^) (for example, see Figure 3-27). In contrast, Zhang et al. (2021) applied the SCHIF approach to their analysis of the Ontario Health Study and identified a sublinear concentration-response relationship, with a more shallow slope observed for PM_2.5_ concentrations < 8 µg/m^3^. Analyses of exposure categories (i.e., quartiles) by Zhang et al. (2021) provides additional support for a sublinear concentration-response relationship. A similar sublinear relationship was reported by Pope et al. (2019) for a U.S. cohort (Figure 3-28).

Figure 3-27 Shape Constrained Health Impact Function predictions by PM_2.5_ concentration for the pooled CanCHEC cohort

Note: Uncertainty bounds are displayed as gray shaded area. The uncertainty bounds are anchored at zero because the logarithm of the hazard ratio is fixed at zero and its associated standard error is also set at zero.

Figure 3 dash 27 depicts the concentration-response relationship for P M 2.5 and mortality in the CanCHEC cohort; P M 2.5 concentrations are on the X axis and hazard ratio is on the Y axis. The figure depicts the concentration-response function anchored at zero and increasing with a steeper slope between 0 and 5 microgram per cubic meter P M 2.5. The slope of the concentration-response function continues to increase, but is less steep, between 5 and 15 microgram per cubic meter P M 2.5. The uncertainty bounds are shaded in gray around the concentration-response function; they are also anchored at zero and increase as P M 2.5 concentrations increase.

Source: Pappin et al. (2019)

Figure 3-28 Estimated concentration-response associations between PM_2.5_ and all-cause mortality with a flexible modeling approach within the NHIS cohort

Note: Shaded area represents the 95% uncertainty bounds.

Figure 3 dash 28 depicts the concentration-response relationship for P M 2.5 and all-cause mortality in the NHIS cohort; P M 2.5 concentrations are on the X axis and hazard ratio is on the Y axis. The figure depicts the concentration-response function anchored at zero and increasing with a shallow slope between 0 and 10 microgram per cubic meter P M 2.5. The slope of the concentration-response function continues to increase, and is steeper, between 10 and 20 microgram per cubic meter P M 2.5. The uncertainty bounds are shaded in gray around the concentration-response function; they are also anchored at zero and increase as P M 2.5 concentrations increase.

Source: Pope et al. (2019)

In addition to statistical analyses of the concentration-response relationship, several studies conducted threshold analyses to estimate associations between all-cause mortality and PM_2.5_ concentrations below a certain concentration. Pinault et al. (2017) reported that HRs remained positive and statistically significant when examining cut-point categories of 0−5 and 5−10 µg/m^3^, with the highest HRs for the 0−5 µg/m^3^ category, consistent with the supralinear concentration-response function estimated by the SCHIF analysis. Wang et al. (2020) observed that HRs remained positive and statistically significant when restricting analyses to participants with exposure concentrations below 8, 10, or 12 µg/m^3^. Similarly, Ward-Caviness et al. (2020) and Wu et al. (2020a) reported that HRs remained positive and statistically significant when restricting analyses to participants with exposure concentrations below 12 µg/m^3^. Zhang et al. (2021) noted that HRs remained positive and statistically significant when only participants with exposure concentrations below 10 µg/m^3^ were included, though the results were positive, but attenuated, and no longer statistically significant when restricting to exposure concentrations below 8.8 µg/m^3^.

In addition to examining the C-R relationship between long-term PM_2.5_ exposure and all-cause mortality, a limited number of studies evaluated the C-R relationship with cause-specific mortality. Wang et al. (2020) reported a linear, no-threshold C-R relationship for both cardiovascular and respiratory mortality. When the authors adjusted for ozone, the C-R relationship remained the same for cardiovascular mortality, but the C-R relationship for respiratory mortality became supralinear below 10 µg/m^3^. In threshold analyses, Wang et al. (2020) observed that HRs remained positive and statistically significant when restricting analyses to participants with exposure concentrations below 8, 10, or 12 µg/m^3^. In analyses stratified by PM_2.5_ concentration, Hayes et al. (2020) reported evidence of positive associations with cardiovascular mortality that increased in magnitude and decreased in precision as the range of PM_2.5_ concentrations examined increased from 8−12, to 12−20, and finally to over 20 µg/m^3^. When evaluating deaths due to diabetes, Lim et al. (2018) observed a linear C-R relationship, with the greatest confidence between 10 and 15 µg/m^3^. Overall, recent studies that evaluated the C-R relationship for long-term PM_2.5_ exposure and cause-specific mortality are consistent with those that examined all-cause mortality.

Consistent with the conclusions of the 2019 PM ISA, recent studies provide evidence that continues to support a linear, no-threshold C-R relationship for long-term PM_2.5_ exposure and all-cause or cause-specific mortality across the range of exposure concentrations observed in North American cohort studies, with some studies characterizing the C-R relationship with certainty down to 4 µg/m^3^ (i.e., the confidence intervals become relatively wide and in some instances the lower 95% CI crosses the null at this concentration). Generally, the evidence remains consistent in supporting a no-threshold relationship, and in supporting a linear relationship for PM_2.5_ concentrations > 8 µg/m^3^. However, uncertainties remain about the shape of the C-R curve at PM_2.5_ concentrations < 8 µg/m^3^, with some recent studies providing evidence for either a sublinear, linear, or supralinear relationship at these lower concentrations.

#### 3.2.2.3 Recent Epidemiologic Studies Examining the PM_2.5_-Mortality Relationship through Accountability Analyses and Alternative Methods for Confounder Control

Within the 2019 PM ISA, a few studies were evaluated that conducted analyses that further informed the relationship between long-term PM_2.5_ exposure and mortality through the use of alternative methods for confounder control (2019 PM ISA, Section 11.2.2.4). These initial studies provided additional support for a causal relationship between long-term PM_2.5_ exposure and mortality. Since the literature cutoff date of the 2019 PM ISA, additional epidemiologic studies have been identified consisting of accountability analyses as well as studies that implemented alternative methods for confounder control that have the ability to reduce uncertainties related to confounding bias in the examination of the relationship between long-term PM_2.5_ exposure and mortality (Table A-8). Study-specific details of the methods implemented in these recent studies can be found in Table 3-7.

Table 3-7 Description of methods from epidemiologic studies using accountability analyses or alternative methods for confounder control to examine long-term exposure to PM_2.5_ and mortality

Study/Location/Population (Cohort)/Years | Statistical Method | Results
Wei et al. (2020); Massachusetts; Medicare; 2000−2012 | Generalized Propensity Score (GPS): estimates the conditional probability of an individual being exposed to the observed concentration level, accounting for all measured potential confounders; In the design stage, an ordinary least squares (OLS) model regressed predicted PM_2.5_ concentrations against a linear combination of covariates, including the other pollutants (Table A-8). In the analysis stage, an ordinary least squares regression was used to fit a linear probability model relating mortality with the predicted PM_2.5_ concentration and the estimated GPS. | 35.4 (95% CI: 33.4, 37.6) excess deaths per 10 million person-days for each 1 µg/m^3^ increase in annual PM_2.5_ concentrations
Wei et al. (2021b); Massachusetts; Medicare; 2000−2012 | Three GPS approaches were used:; Linear Probability Model: In the design stage, GPS was constructed by fitting a linear regression of predicted PM_2.5_ concentration against a column vector of covariates including copollutants (Table A-8) In the analysis stage, a linear probability model was fitted with the outcome of death, against the predicted PM_2.5_ concentration and the GPS.; Weighted Least Squares: In the design stage, the person-days that had the same sex, race, age, Medicaid eligibility, ZIP code of residence, and date were aggregated as a single record and assigned the numbers of person-days for that record as a weight. The GPS was constructed by fitting a weighted linear regression of predicted PM_2.5_ concentrations against all the covariates from this aggregated data set, with continuous covariates modeled with cubic polynomials. The average outcome for each aggregated person-day group was calculated and assigned to the person-day in the aggregated data set. A weighted linear regression was fitted for the averaged outcome against the predicted PM_2.5_ concentration and the estimated GPS.; MoonRF: In the design stage, the number of person-days aggregated for each record was used as the frequency weight and sampled 62,000 person-days without replacement. With this sample, trees were built for PM_2.5_ to make predictions of the exposure for each person-day, which was repeated 100 times. The final predicted PM_2.5_ concentration for each person-day was obtained by averaging the predictions of the 100 trees. The GPS was constructed by using the averaged predictions of the 100 trees as the predicted PM_2.5_ concentrations and covariates for each person-day in the aggregated data set. In the analysis stage, weighted regression of the averaged outcome was fitted against the predicted PM_2.5_ concentration and the estimated GPS to obtain the effect estimate. | Linear Probability Model and Weighted Least Squares: 1053 (95% CI: 984, 1,122) annual early deaths for a 1 μg/m^3^ increase in annual PM_2.5_ concentrations; MoonRF: 1,058 (95% CI: 988, 1,127) annual early deaths for a 1 μg/m^3^ increase in annual PM_2.5_ concentrations
Wu et al. (2020a); U.S.; Medicare; 2000−2016 | Three GPS approaches were used that required GPS estimation as the first step. The conditional density of predicted annual average PM_2.5_ concentration on the 14 ZIP code or county-level covariates, with dummy variables for region and calendar year, were modeled using gradient boosting machine with normal residuals.; GPS matching: a matched pseudo-population was constructed. Once the covariate balance was achieved, a univariate Poisson regression model was fit to regress the death counts, with an offset of person-time term, on PM_2.5_ exposure, stratifying by the individual-level covariates and the same follow-up year.; GPS weighting: a weighted pseudo-population was constructed. Once the covariate balance of the weighted pseudo-population was achieved, a weighted univariate Poisson regression was fitted, regressing the death count, with an offset term of person-time, on PM_2.5_ exposure incorporating the assigned weights and stratifying by the individual-level covariates and the same follow-up year.; GPS adjustment: the conditional expectation of the death counts given the exposure and estimated GPS was modeled as a stratified Poisson regression with flexible formulation of bivariate variables, with the corresponding offset term of person-time. A univariate linear regression regressed the counterfactual mean hazard rates for each PM_2.5_ concentration, stratified by the individual-level covariates and the same follow-up year. | For a 10 μg/m^3^ increase in annual PM_2.5_ concentrations; GPS matching: HR = 1.068 (95% CI: 1.054, 1.083); GPS weighting: HR = 1.076 (95% CI: 1.065, 1.088); GPS adjustment: HR = 1.072 (95% CI: 1.061, 1.082)
Wu et al. (2019); New England (Vermont, New Hampshire, Connecticut, Massachusetts, Rhode Island, and Maine); Medicare; 2000−2012 | GPS: Regression calibration-GPS approach. The RC step of this approach adjusts for measurement error in a continuous exposure. The adjustment relies on two assumptions: transportability and nondifferential measurement error. Transportability assumes that the relationship between continuous exposure (X), the error-prone continuous exposure (W), and the error-free covariates associated with the measurement error (D) would be the same in the validation study where X is observed and the main study in which it is not. The nondifferential measurement error assumption is equivalent to the surrogacy assumption and means the conditional distribution of outcome given X, W, D depends only on X and D. The relationship between true exposures X and error-prone exposures W, conditional on other covariates D, was modeled using a regression model, specified by mean and variance. More specifically in the RC stage, Wu et al. (2019) obtained the PM_2.5_ exposure at each grid cell in New England and then fit the regression model to include 14 meteorological variables as predictors.; In the second step, the GPS is implemented. The authors define the GPS as the conditional probability of receiving each category of the exposure given other pre-exposed covariates (C) (Table A-8). There are two assumptions for the GPS implementation: overlap/positivity and weak unconfoundedness. The overlap/positivity assumption guarantees that for all possible values of C, the average treatment effect can be estimated for each category of the exposure without relying on extrapolation (Wu et al., 2019). Weak unconfoundedness assumes that the assignment mechanism is weakly unconfounded (Wu et al., 2019). Three GPS approaches were considered:; Subclassification GPS: individuals were classified into groups based on the GPS elements, with each group containing the observations having similar values of the corresponding estimated GPS elements.; Inverse Probability of Treatment Weighting GPS: weights each individual by the inverse of their GPS.; GPS matching: involves matching individuals who receive one category of exposure to individuals who received another category of exposure based on the estimated GPS.; For each of the three GPS approaches, Wu et al. (2019) used multinomial logistic regression with 16 area-level covariates as confounders to construct the GPS. After constructing GPS for each approach, a stratified log-linear outcome model with a person-time offset estimated the IRR of the effect of long-term PM_2.5_ exposure on all-cause mortality. The stratification variables were the individual-level covariates (age, as 5-yr age categories; race; sex; and Medicare eligibility). | Subclassification GPS:; IRR = 1.03 (95% CI: 1.01, 1.05); IPTW GPS: IRR = 1.02 (95% CI: 1.01, 1.04); Matching GPS: IRR = 1.03 (95% CI: 1.01, 1.05)
Schwartz et al. (2018b); Northeastern and mid-Atlantic States (Maine, New Hampshire, Vermont, Massachusetts, Rhode Island, Connecticut, New York, New Jersey, Delaware, Pennsylvania, Maryland, Washington, DC, Virginia, and West Virginia); Medicare; 2000−2013 | Inverse Probability Weights (IPW): A GPS was fitted with a linear regression of continuous predicted PM_2.5_ concentrations against the measured covariates. The IPW is constructed as the marginal probability density of exposure as the numerator and the probability density of each observation receiving the predicted PM_2.5_ concentration in a year given the covariates in that year as the denominator. Separate logistic regression models were fitted to estimate the risk of dying at that age given the annual average PM_2.5_ concentration at each subject’s residential ZIP code and age-specific IPW weights to allow the influence of potential confounders to change with age. | The estimated mean age at death for a population with an annual average PM_2.5_ concentration of 12 μg/m^3^ was 0.89 (95% CI: 0.88, 0.91) less years
Awad et al. (2019); U.S.; Medicare; 2000−2012 | IPW: Constructed from a GPS model in which the weights were the inverse conditional probabilities of the continuous exposure given the covariates (Table A-8). The weights were then stabilized using the marginal probability of exposure as the numerator and the denominator was the conditional density function of change in exposure where the vector of covariates evaluated at observed covariate values for each participant. The Cox proportional model estimated the effect of change in annual PM_2.5_ concentrations on the risk of all-cause mortality, stratified by ZIP code before moving, with the IPW to account for confounding after moving and follow-up time. | For a 10 μg/m^3^ increase in annual PM_2.5_ concentrations:; HR = 1.21 (95% CI = 1.20, 1.22) among White individuals; HR = 1.12 (95% CI = 1.08, 1.15) among Black individuals
Higbee et al. (2020); U.S.; National Center for Health Statistics; 1986−2015 | IPW: Constructed by taking the inverse of the conditional probability of the exposure to a given value from a continuous scale of PM_2.5_ concentrations and stabilized by multiplying the weights by the marginal probability of the PM_2.5_ concentration. The Cox proportional hazard models estimated the hazard ratios associated with a 10 μg/m^3^ increase in PM_2.5_ concentration. Each of the covariates (Table A-8) were included as confounders while constructing the IPW for weighting the estimated model. | For a 10 μg/m^3^ increase in annual PM_2.5_ concentrations:; All-cause mortality; HR = 1.12 (95% CI: 1.08, 1.15); Cardiopulmonary mortality; HR = 1.23 (95% CI: 1.17, 1.29)
Wei et al. (2021a); U.S.; Medicare; 2000−2016 | IPW: Proposed a decile binning, which divided PM_2.5_ concentrations by deciles and predicted the inverse probability of being assigned to the observed group for each observation, adjusting for copollutants (ozone and NO_2_), personal characteristics, meteorological, socioeconomic, behavioral, and medical access variables, and long-term time trend (Table A-8). The IPW was constructed in two stages―a design stage and an analysis stage. In the design stage, a randomized pseudo-population was constructed by weighting the observed population by the inverse probability of the exposure given all the measured confounders. In the analysis stage, the treatment effect was estimated among the constructed pseudo-population. The IPW for each PM_2.5_ decile was stabilized by using the probability of any observed exposure being within the decile as the numerator. The denominator was the inverse logistic link function of a gradient boosting machine model with logistic loss function for predicting the probability of the observed binned exposure given the set of confounders, weighted by the number of person-years aggregated in the stratum. A log-linear regression model was then fitted to estimate the number of deaths and PM_2.5_ decile category, weighted by the stabilized inverse probabilities. | 2nd decile group (mean annual PM_2.5_ concentration of 6.60 μg/m^3^): RR = 1.02 (95% CI: 1.02, 1.03); 10th decile group (mean annual PM_2.5_ concentration of 15.47 μg/m^3^): RR = 1.21 (95% CI: 1.20, 1.21)
Corrigan et al. (2018); U.S.; National Center for Health Statistics; 2000−2010 | Difference-in-Difference (DID): A linear regression model was used to estimate the association between the change in cardiovascular mortality rate and the change in PM_2.5_ across U.S. counties, adjusted for potential confounders. | 1.10 (95% CI: 0.37, 1.82) fewer cardiovascular deaths per year per 100,000 people for each 1 μg/m^3^ decrease in annual PM_2.5_ concentrations
Sanders et al. (2020); U.S.; Medicare; 2000−2013 | DID: Examined if policy actions reduced PM_2.5_ concentrations and mortality in treatment counties relative to control counties. DID flexibly captures the effects of treatment over time by using separate dummy variables for each year.; With the event study design in the DID models, nearest neighbor matching based on propensity score was used as an estimate of probability of attainment status. The independent variables used to estimate the propensity score were the mortality counts and the population for each year from 2000 to 2005 and were sampled without replacement.; An instrumental variable analysis was applied by dividing the mortality coefficient by the PM_2.5_ coefficient to obtain the estimate of the effect of PM_2.5_ on mortality, which is equivalent to a Wald instrument variable estimator, where the standard errors of the estimates were calculated. | After the regulatory changes in 2005, PM_2.5_ concentrations decreased 1.59 μg/m^3^ (95% CI: 1.39, 1.80) and mortality rates among those 65 years and older also decreased by 0.93% (95% CI: 0.10, 1.77).
Henneman et al. (2019); U.S.; Medicare; 2005−2012 | DID: Estimated changes in each morality associated with changes in annual PM_2.5_ concentrations. The differences between 2012 and 2005 mortality rates (per 10,000 beneficiaries) were estimated from a linear model that included the difference in PM_2.5_ concentrations from 2012 and 2005, controlled for changes in census and meteorological variables. | Reduction in all-cause mortality of −0.38 (95% CI: −2.76, 2.01) per 10,000 person-days for each 1 μg/m^3^ decrease in annual PM_2.5_ concentrations during the time period
Fan and Wang (2020); U.S.; Medicare; 1999−2013 | DID: Treatment counties based on the location of the power plant and wind direction. For each treatment county, covariate matching was used, with matching based on county characteristics to select controls. After constructing a set of treatment and control counties, the effect of annual PM_2.5_ on monthly age-adjusted mortality was estimated using an instrument variable (IV) approach to compare the before and after the retirement of coal plants between the treated and control counties. The instrumental variables were weather variables and time-varying socioeconomic variables. DID approach was also used to estimate the effect of coal plant retirements on PM_2.5_ and mortality among populations older than 65. | IV: a 1 μg/m^3^ reduction in annual PM_2.5_ concentrations led to 7.17 fewer deaths per 100,000 people per month, or a 1.7% lower monthly mortality rate among people older than 65 yr of age; DID: power plant retirement decreased both monthly PM_2.5_ concentrations by 2.1 μg/m^3^, and the monthly age-adjusted mortality by approximately 15 people per 100,000 people (or 3.6%) in treated counties, relative to control counties
Yitshak-Sade et al. (2019b); Maine, New Hampshire, Vermont, Massachusetts, Rhode Island, Connecticut, New York, New Jersey, Delaware, Pennsylvania, Maryland, Washington, DC, Virginia, and West Virginia; Medicare; 2000−2013 | DID: Used a Poisson survival analysis using the Anderson-Gill formulation with time-varying covariates. The data were randomly split into subsets due to computational limitations. The effect estimates were then pooled using a fixed-effect meta-analysis. | 4.04% (95% CI: 3.49, 4.59) increase in mortality rates for an IQR (3 μg/m^3^) increase in annual PM_2.5_ concentrations
Schwartz et al. (2021); U.S.; Medicare; 2000−2016 | DID: Applied the standard approach for continuous predictors. The mortality rate in a ZIP code given the demographic group (age, sex, race, Medicaid coverage) was associated with annual PM_2.5_ concentrations, given the time-invariant or slowly changing confounders in a ZIP code, and the time-varying confounders that are common across ZIP codes. The time-invariant confounders were controlled by fitting individual intercepts for each ZIP code, while the time-varying confounders were removed by fitting nonlinear time trend using a natural spine function of year with three degrees of freedom. An additive model was used to estimate the additive effect of PM_2.5_ on the probability of dying. | Probability of dying in each year increased by 3.85 × 10^−4^ (95% CI 1.95 × 10^−4^, 5.76 × 10^−4^) for each 1 μg/m^3^ increase in annual PM_2.5_ concentrations
Peterson et al. (2020); U.S.; National Center for Health Statistics; 1990−2010 | Accountability: To determine the portion of the temporal change in cardiovascular mortality attributable to the temporal change in the annual PM_2.5_ concentrations, linear models were fitted, adjusted for time variant covariates (age-standardized annual COPD mortality rates) and time-invariant covariates (median household income, percent of non-White population, and population). The authors first estimated the overall national temporal trend in annual cardiovascular mortality, which accounted for the temporal changes in the cardiovascular mortality adjusted for the time variant and time-invariant covariates, but not adjusted by PM_2.5_. Second, the national temporal trend in the annual PM_2.5_ concentrations was estimated, while adjusting for the time variant and time-invariant covariates. Then, the association between PM_2.5_ concentrations and cardiovascular mortality was estimated, assuming that this association was consistent nationally after adjusting for the covariates set and for other time-varying changes in cardiovascular morality unrelated to PM_2.5_ concentrations. The PM_2.5_-related cardiovascular mortality association was calculated as a product of the risk to cardiovascular mortality for each unit change in PM_2.5_ concentration. A county-level random intercept term was included in the models to account for variation due to repeated measures from the same county and difference in baseline cardiovascular morality rates. | 3.88 (95% CI: 3.56, 4.21) fewer deaths per 100,000 persons for each 1 μg/m^3^ reduction in annual PM_2.5_ concentrations
Zigler et al. (2018); Eastern U.S.; Medicare; 2000-2012 | Accountability and Propensity Score: To examine whether attainment status for the 1997 NAAQS led to an improvement in PM_2.5_ concentrations and subsequently health, the authors employed propensity scores, within a spatial hierarchical regression model to examine whether designation of nonattainment, for either the annual standard of 15 µg/m^3^ or the daily standard of 65 µg/m^3^, made in 2005 for the 1997 PM NAAQS led to a corresponding reduction in ambient PM_2.5_ concentrations and all-cause mortality. In the first step, propensity scores were used to adjust for confounders by grouping attainment and nonattainment locations based on similarities of baseline characteristics, including air pollution monitoring data, population demographics, meteorological data, baseline Medicare characteristics, and PM_2.5_ and mortality. In the second step, a spatial hierarchical regression model was used to predict the potential ambient PM_2.5_ concentration in 2010–2012 that would have occurred in nonattainment areas if the designations had never occurred. The model used in this step specifies linear adjustment terms for propensity score group indicators and several specific covariates, each including an interaction with the indicator of attainment status, while including a spatial random effect that accounts for the similarity of ambient air quality at nearby locations. For the analysis, the spatial hierarchical model is estimated jointly with a log-linear model for all-cause mortality, with the same confounding adjustment for propensity score group and additional covariates. In addition to estimating the effect estimates for the overall average effects, a principal stratification approach was used to estimate “associative effects” and “dissociative effects.” | Overall average effect: a reduction in the all-cause mortality rate by 1.25 (95% CI: −2.63, 0.11) deaths per 1000 beneficiaries; Average associative effects: a reduction in the all-cause mortality rate of 3.16 (95% CI: −5.19, −1.21) deaths per 1000 beneficiaries; Average disassociative effects: Quantitative results not presented

DID = difference-in-difference; GPS = generalized propensity score; HR = hazard ratio; IPTW = inverse probability treatment weighting; IPW = inverse probability weighting; IRR = incidence rate ratio; IV = instrument variable; moonRF = m-out-of-n random forests.

Wei et al. (2020), Wei et al. (2021b), and Wu et al. (2020a) implemented different GPS modeling approaches to assess associations between long-term PM_2.5_ concentrations and mortality among Medicare beneficiaries. GPS statistical approaches were developed as an extension of propensity score methods for continuous exposures and represent the relative likelihood of being exposed to the observed pollutant concentration and all measured confounders (Wei et al., 2020). The GPS approach estimates the conditional probability of an individual being exposed to the observed pollutant concentration, accounting for all measured potential confounders (Table A-8).

Wei et al. (2020) evaluated the association of long-term PM_2.5_ concentrations and all-cause mortality among Medicare beneficiaries residing in Massachusetts during 2000−2012 using a GPS approach. The authors define long-term exposure as a 1-year moving average of the PM_2.5_ concentration. Wei et al. (2020) reported that each 1 µg/m^3^ increase in long-term PM_2.5_ concentrations was associated with 35.4 (95% CI: 33.4, 37.6) excess deaths per 10 million person-days. When the analysis was restricted to different low-level concentrations, the number of excess deaths associated with a 1 μg/m^3^ increase in annual PM_2.5_ concentrations increased to 35.5 per 10 million person-days (95% CI: 33.4, 37.7) when restricting to PM_2.5_ concentrations ≤ 14 μg/m^3^ and to 60.7 per 10 million person-days (95% CI: 47.9, 73.9) when restricting to PM_2.5_ concentrations ≤ 7 μg/m^3^.

Whereas Wei et al. (2020) focused on a single GPS approach, Wei et al. (2021b) presented three GPS-based approaches in examining long-term PM_2.5_ concentrations and mortality including a linear probability model, weighted least squares, and m-out-of-n random forests (moonRF), for assessing the effect of long-term PM_2.5_ exposures on mortality rates among Medicare beneficiaries residing in Massachusetts between 2000 and 2012. The moonRF method is based on the random forest method, which is a non-parametric machine learning approach of classification for possible nonlinear relationships and interactions through building individual decision trees through resampling. To reduce the computational burden of the linear probability model GPS approach, weighted least squares and moonRF GPS approaches were proposed as alternatives. Wei et al. (2021b) showed that the linear probability model and the weighted least squares model produced nearly identical results. The annual number of early deaths associated with 1 μg/m^3^ increase in annual PM_2.5_ concentrations was 1,053 (95% CI: 984, 1,122) using linear probability model and weighted least squares approaches and was 1,058 (95% CI: 988, 1,127) using moonRF. When restricting the analysis to annual PM_2.5_ concentrations below < 12 μg/m^3^, 1,203 (95% CI: 1,126, 1,280) annual early deaths were associated with a 1 μg/m^3^ increase in annual PM_2.5_ concentrations when using both the linear probability model and weighted least squares approaches with a slightly higher number of early deaths with the moonRF approach (1,214 [95% CI: 1,137, 1,292]).

Similar to Wei et al. (2021b), Wu et al. (2020a) also assessed the association between long-term PM_2.5_ concentrations and mortality among Medicare beneficiaries between 2000 and 2016 using multiple GPS approaches including: (1) matching by GPS; (2) weighting by GPS; and (3) adjustment by GPS, meaning the GPS was included as a covariate in the health outcome model. Wu et al. (2020a) reported that the three GPS approaches yielded similar results with a 10 μg/m^3^ increase in annual PM_2.5_ concentrations corresponding to a reduction in mortality rate ranging from 6% to 7% (matching by GPS: HR = 1.07 [95% CI: 1.05, 1.08]; weighting by GPS: HR = 1.08 [95% CI: 1.07, 1.09]; and adjustment by GPS: HR = 1.07 (95% CI: 1.06, 1.08]). The estimated hazard ratios were even larger when restricting the cohort of Medicare enrollees to only those that lived in locations where annual PM_2.5_ concentrations were lower than 12 μg/m^3^: matching by GPS: HR = 1.26 (95% CI: 1.23, 1.29); weighting by GPS: HR = 1.27 (95% CI: 1.24, 1.30); and adjustment by GPS: HR = 1.23 (95% CI: 1.18, 1.28).

Whereas Wei et al. (2020), Wei et al. (2021b), and Wu et al. (2020a) used different GPS approaches to examine the association between long-term exposure to PM_2.5_ and mortality, Wu et al. (2019) developed a new two-stage GPS approach consisting of a regression calibration-GPS (RC-GPS) based adjustment for continuous error-prone exposure combined with GPS to adjust for potential confounding. The new proposed method provides a correction for measurement error in the exposure for both the design and analysis stages with GPS, allows the GPS implementation to be paired with any generalized linear model, and shows how standardized bias can be used to assess fit in the context of GPS analysis for categorical exposures. The RC approach was applied in conjunction with three GPS approaches: subclassification, inverse probability of treatment weighting (IPTW), and matching. After constructing GPS for each approach, a stratified log-linear outcome model with a person-time offset estimated the incidence rate ratio (IRR) of the effect of long-term exposure to PM_2.5_ on all-cause mortality. When applying the RC-GPS based adjustment, the authors reported IRRs that were consistent across the three GPS approaches: RC-GPS subclassification approach: IRR was 1.03 (95% CI: 1.01, 1.05); 1.02 (95% CI: 1.01, 1.04) for the IPTW GPS approach, and 1.03 (95% CI: 1.01, 1.05) for the GPS matching approach, when comparing moderate levels of PM_2.5_ concentrations (8 < PM_2.5_ ≤ 10 μg/m^3^) to low concentration (PM_2.5_ ≤ 8 μg/m^3^). When comparing high levels of PM_2.5_ concentrations (PM_2.5_ > 10 μg/m^3^) to low concentrations (PM_2.5_ ≤ 8 μg/m^3^), the IRRs were 1.04 (95% CI: 1.00, 1.07) for subclassification, 1.03 (95% CI: 1.01, 1.06) for IPTW, and 1.04 (95% CI: 1.02, 1.06) for matching.

In addition to GPS, other alternative methods for confounder control have been employed in epidemiologic studies including inverse probability weighting (IPW). IPW generates weights by taking the inverse of the conditional probability of the exposure of a pollutant concentration. The weight is then stabilized by multiplying the weights by the marginal probability of the level of exposure, meaning that by applying weights the exposure is no longer associated with the confounders (Higbee et al., 2020; Awad et al., 2019).

Schwartz et al. (2018b) and Awad et al. (2019) both applied IPW methods to estimate the effect of long-term exposure to PM_2.5_ on mortality among Medicare beneficiaries, while controlling for similar confounders (Table A-8). Schwartz et al. (2018b) estimated the marginal effect of annual PM_2.5_ concentrations on the distribution of life expectancy among Medicare beneficiaries residing in the northeastern and mid-Atlantic region of the U.S. between 2000 and 2013 by applying an IPW survival model. The estimated mean age at death for a population with an annual average PM_2.5_ concentration of 12 μg/m^3^ was 0.89 (95% CI: 0.88, 0.91) years less than estimated for a counterfactual PM_2.5_ concentrations of 7.5 μg/m^3^. Schwartz et al. (2018b) estimated that 23.5% of the Medicare population would die before 76 years of age if they were exposed to an annual PM_2.5_ concentration of 12 μg/m^3^ compared with 20.1% if the Medicare population was exposed to an annual average PM_2.5_ concentration of 7.5 μg/m^3^. Furthermore, the authors estimated that 40.8% of Medicare recipients would live past 85 years of age if exposed to an annual PM_2.5_ concentration of 12 μg/m^3^ PM_2.5_ compared with 44.5% at 7.5 μg/m^3^.

Awad et al. (2019) estimated the effect of a change in annual PM_2.5_ concentrations due to moving on the risk of mortality among Medicare beneficiaries from 2000 to 2012 in the U.S. from Cox proportional hazards using an IPW approach to control for potential confounding (Table A-8). The Cox proportional model estimated the effect of change in PM_2.5_ concentrations on the risk of all-cause mortality, stratified by ZIP code before moving, with the IPW to account for confounding after moving and follow-up time. Awad et al. (2019) estimated a HR of 1.21 (95% CI: 1.20, 1.22) among White individuals and 1.12 (95% CI: 1.08, 1.15) among Black individuals for a 10 μg/m^3^ increase in annual PM_2.5_ concentrations for all-cause mortality. When restricting the analysis to movers with PM_2.5_ concentration ≤ 12 μg/m^3^, the hazard ratio was 1.25 (95% CI: 1.24, 1.27) for White individuals and 1.08 (95% CI: 1.01, 1.14) for Black individuals for all-cause mortality.

Wei et al. (2021a) used an IPW approach to emulate a dose-response between PM_2.5_ and all-cause mortality from Medicare beneficiaries between 2000 and 2016. This newer IPW approach used decile binning, which divided PM_2.5_ concentrations into 10 equally sized deciles and predicted the inverse probability of being assigned to the observed group for each observation, adjusting for copollutants (i.e., ozone and NO_2_) and other covariates (Table A-8). The lowest decile group is treated as the reference with effects estimated for the other decile groups compared with the reference. The RR of all-cause mortality associated with long-term exposure to PM_2.5_ ranged from 1.02 (95% CI: 1.02, 1.03) at 6.60 μg/m^3^ (2nd decile group) to 1.21 (95% CI: 1.20, 1.21) at 15.47 μg/m^3^ (10th decile group). Assuming that the IPW models were correctly specified with the adjustment of copollutants and confounders, the dose-response curves demonstrated that in general, higher concentrations of PM_2.5_ are associated with a greater risk of all-cause mortality (Wei et al., 2021a). While the previous studies all used the IPW approach in analyses of Medicare beneficiaries, Higbee et al. (2020) examined the association between long-term exposure to PM_2.5_ and all-cause and cardiopulmonary mortality from the National Health Interview Survey from 1986 to 2015. Within this study the authors applied a series of Cox proportional hazards models, adjusted using IPW. The hazard ratio for all-cause mortality was 1.12 (95% CI: 1.08, 1.15) per 10 μg/m^3^ increase in PM_2.5_ concentration and for cardiopulmonary mortality, it was 1.23 (95% CI: 1.17, 1.29) per 10 μg/m^3^ increase in PM_2.5_ concentration.

In addition to GPS and IPW, additional epidemiologic studies used a difference-in-difference (DID) approach to control for unmeasured confounders. In this method, the mean exposure is calculated for exposed and non-exposed groups between two time periods, such as pre- and post-intervention (Schwartz et al., 2021; Yitshak-Sade et al., 2019b). The predictors of the outcome, such as socioeconomic status, education, and smoking status, are the same in each group in both time periods, therefore, theoretically the difference between outcomes in the two time periods in the exposed group cannot be confounded by those predictors (Schwartz et al., 2021).

To account for changes in PM_2.5_ concentrations due to policy or the implementation of an intervention, Corrigan et al. (2018), Sanders et al. (2020), Henneman et al. (2019), and Fan and Wang (2020) used DID methods to assess whether there was evidence of changes in associations with mortality due to changes in annual PM_2.5_ concentrations. Corrigan et al. (2018) examined whether there was a change in the cardiovascular mortality rate before (2000−2004) and after (2005−2010) implementation of the first annual PM_2.5_ NAAQS in 2005 based on mortality data from the National Center for Health Statistics (Table A-8). The authors reported 1.10 (95% CI: 0.37, 1.82) fewer cardiovascular deaths per year per 100,000 people for each 1 μg/m^3^ reduction in annual PM_2.5_ concentrations. When comparing whether counties achieved NAAQS compliance (attainment) or not (non-attainment), there were 1.96 (95% CI: 0.77, 3.15) fewer cardiovascular deaths for each 1 μg/m^3^ reduction in annual PM_2.5_ concentrations between the two periods for attainment counties, whereas for non-attainment counties, there were 0.59 (95% CI: −0.54, 1.71) fewer cardiovascular deaths between the two periods. Sanders et al. (2020) conducted a similar study as Corrigan et al. (2018) by attempting to isolate the relationship between regulation of and reductions in PM_2.5_ concentrations and associated mortality from Medicare beneficiaries between 2000 and 2013 (Table A-8). After the release of the first annual PM_2.5_ NAAQS implementation in 2005, annual PM_2.5_ concentrations decreased by 1.59 μg/m^3^ (95% CI: 1.39, 1.80), which corresponded to a reduction in mortality rates among individuals 65 years and older of 0.93% (95% CI: 0.10, 1.77).

While Corrigan et al. (2018) and Sanders et al. (2020) used DID to examine the relationship between changes in annual PM_2.5_ concentrations and mortality due to the PM_2.5_ NAAQS, Henneman et al. (2019) and Fan and Wang (2020), applied DID methods to explore the changes in PM_2.5_ concentrations following retirement of coal-fueled power plants and mortality. Henneman et al. (2019) conducted an accountability analysis of emissions reductions from coal-fueled power plants in the U.S. between 2005 and 2012 and whether there were corresponding reductions in all-cause mortality using Medicare data (Table A-8). The authors reported a reduction in all-cause mortality of −0.38 (95% CI: −2.76, 2.01) deaths per 10,000 person-days for each 1 μg/m^3^ reduction in annual PM_2.5_ concentrations during the time period. Fan and Wang (2020) also used Medicare data from 1999 to 2013 to estimate the relationship between mortality and low PM_2.5_ concentrations in response to the retirement of five large coal plants by applying both instrumental variable and DID approaches (Table A-8). The instrumental variable represents variations in the exposure (e.g., PM_2.5_) that are randomized with respect to both measured and unmeasured confounders and can therefore provide an estimate of the effect of the exposure (Schwartz et al., 2018a). The authors reported that a 1 μg/m^3^ reduction in annual PM_2.5_ concentrations corresponded to 7.17 fewer deaths per 100,000 people per month, or a 1.7% lower monthly mortality rate among people older than 65 years of age when applying an instrument variable approach. The power plant retirement decreased both monthly PM_2.5_ concentrations by 2.1 μg/m^3^, and the monthly age-adjusted mortality by approximately 15 people per 100,000 people (or 3.6%) in treated counties, relative to control counties, based on the DID approach.

Yitshak-Sade et al. (2019b) and Schwartz et al. (2021) also used DID approaches to evaluate the changes in long-term exposure to PM_2.5_ over time on mortality rates among Medicare beneficiaries. Yitshak-Sade et al. (2019b) applied a DID approach to the Medicare population of the northeastern and mid-Atlantic states to incorporate individual covariates and assess the effect of annual PM_2.5_ concentrations on all-cause mortality rates from 2000 to 2013 (Table A-8). For an IQR (3 μg/m^3^) increase in annual PM_2.5_ concentrations, the authors reported a 4.04% (95% CI: 3.49, 4.59) increase in mortality rates. In a sensitivity analysis, the mortality effect was modified by eligibility to Medicaid insurance and race, with larger associations among people who are eligible to receive Medicaid services (5.99% [95% CI: 4.38, 7.62] and among Black individuals (10.10% [95% CI: 8.56, 11.67]. Whereas Yitshak-Sade et al. (2019b) applied DID to a portion of Medicare beneficiaries, Schwartz et al. (2021) applied two DID approaches to assess whether changes in PM_2.5_ are associated with changes in mortality rates nationally among Medicare participants between 2000 and 2016 (Table A-8). The authors reported that the probability of dying in each year increased by 3.85 × 10^−4^ (95% CI: 1.95 × 10^−4^, 5.76 × 10^−4^) for each 1 μg/m^3^ increase in PM_2.5_ in that year. When the analysis was restricted to those beneficiaries residing in locations where PM_2.5_ concentrations are below 12 μg/m^3^ during the follow-up period, the probability of dying in each year increased to 4.26 × 10^−4^ (95% CI 1.43 × 10^−4^, 7.09 × 10^−4^) for 1 μg/m^3^ increase in annual PM_2.5_ concentrations.

Peterson et al. (2020) conducted an accountability analysis to examine which portion of the observed declining trend in cardiovascular mortality from the National Center for Health Statistics between 1990 and 2010 was associated with changes in ambient PM_2.5_. To determine the portion of the temporal change in cardiovascular mortality attributable to the temporal change in the ambient concentration of PM_2.5_, Peterson et al. (2020) fit linear models, and adjusted for time-variant covariates (age-standardized annual COPD mortality rates) and time-invariant covariates (median household income, percent of non-White population, and population). On average, each 1 μg/m^3^ reduction in annual PM_2.5_ concentrations was associated with 3.88 (95% CI: 3.56, 4.21) fewer deaths per 100,000 persons. When combined with the annual decline in PM_2.5_ concentrations, the PM_2.5_-trend accounted for 0.52 (95% CI: 0.48, 0.57) fewer deaths per 100,000 persons each year, for a total change of 10.44 (95% CI: 9.56, 11.32) fewer deaths per 100,000 persons over the entire study period.

Zigler et al. (2018) used a hybrid approach of integrating an accountability analysis with an alternative method for confounder control to examine whether attainment status for the 1997 NAAQS led to an improvement in PM_2.5_ concentrations and subsequently health, as previously discussed in Section 3.1.2.3. By focusing on nonattainment designations, the authors are able to examine the role of local control strategies in reducing PM_2.5_ concentrations that occurred above and beyond reductions due to regional strategies. Within this study, Zigler et al. (2018) employed propensity scores, within a spatial hierarchical regression model to examine whether designation of nonattainment in 2005 for the 1997 PM NAAQS (see Table 3-7), for either the annual standard of 15 µg/m^3^ or the daily standard of 65 µg/m^3^, led to a corresponding reduction in ambient PM_2.5_ concentrations and all-cause mortality rates among Medicare beneficiaries in the eastern U.S. from 2009 to 2012. Zigler et al. (2018) reported a reduction in the overall average effect for all-cause mortality across the nonattainment areas of 1.25 (95% CI: −2.63, 0.11) deaths per 1000 beneficiaries, which is similar in magnitude and precision to the average “dissociative effect” (i.e., the effects of the nonattainment designations estimated to not affect PM_2.5_ concentrations by more than ±1 μg/m^3^). When examining the average “associative effect” (i.e., the effects of the nonattainment designations on mortality rates among areas where the nonattainment designations are estimated to reduce ambient PM_2.5_ concentrations by at least 1 μg/m^3^), the authors reported a reduction in the all-cause mortality rate that was larger than the “dissociative effect” (−3.16 [95% CI: −5.19, −1.21] deaths per 1000 beneficiaries). Collectively, the results of Zigler et al. (2018) provide evidence that reductions in ambient PM_2.5_ concentrations and all-cause mortality could not be conclusively attributed to nonattainment designations against the backdrop of other regional strategies that impacted the eastern U.S.

Overall, recent epidemiologic studies employed a variety of alternative methods for confounder control such as GPS, IPW, and DID and reported consistent results among large study populations across the U.S. These alternative methods for confounder control in combination with accountability analyses reduce uncertainties related to confounder bias and further informs the relationship between long-term PM_2.5_ exposure and total mortality and supports the conclusions of the 2019 PM ISA.

#### 3.2.2.4 Summary of Recent Evidence in the Context of the 2019 Integrated Science Assessment for Particulate Matter Causality Determination for Long-Term PM_2.5_ Exposure and Mortality

Recent epidemiologic studies published since the 2019 PM ISA support and extend the evidence base that contributed to the conclusion of a causal relationship between long-term PM_2.5_ exposure and mortality. Numerous cohort studies conducted in the U.S. and Canada in locations with mean annual concentrations that, in many instances, are lower than those reported in studies evaluated in the 2019 PM ISA, add to the large evidence base indicating consistent, positive associations between long-term PM_2.5_ exposure and mortality. These positive associations were reported across studies using different: cohorts, exposure windows, approaches for confounder adjustment, and exposure assessment methods that used different sources of data and were conducted at different spatial resolutions. In addition, studies examining cause-specific mortality further expand upon the studies that reported consistent, positive associations with cardiovascular- and respiratory-related mortality as well as other mortality outcomes. Recent studies also provide some of the initial evidence demonstrating that individuals with preexisting health conditions (i.e., heart failure and diabetes) are at increased risk of mortality overall, which, until recently, was primarily examined in studies using stratified analyses, rather than a cohort of individuals with an underlying health condition.

Additional support for a relationship between long-term PM_2.5_ exposure and mortality stems from studies that examined the influence of potential confounding bias. While there is some evidence of potential confounding of the PM_2.5_-mortality association by copollutants within the MAPLE studies, this is not consistent with other recent studies evaluated in the U.S. and Canada that reported associations consistent in magnitude in both single and copollutant models or with the studies evaluated in the 2019 PM ISA. In addition to copollutants, a few studies examined whether additional potential confounders, such as temporal trends and meteorological variables, could explain the PM_2.5_-mortality association. Analyses examining these additional covariates, which have previously been hypothesized to be confounders of the association, further confirm that the relationship between long-term PM_2.5_ exposure and mortality is unlikely to be biased by these factors.

Consistent with the conclusions of the 2019 PM ISA, recent studies provide evidence that continues to support a generally linear, no-threshold C-R relationship for long-term PM_2.5_ exposure and all-cause or cause-specific mortality. Recent studies extend the evidence base by using novel statistical techniques for estimating the C-R relationship, by examining the C-R relationship among populations with relatively low PM_2.5_ concentrations, and by evaluating cause-specific mortality in addition to all-cause mortality. A limited number of recent studies add to and support the evidence from the 2019 PM ISA by examining the temporal trends in PM_2.5_ concentrations and changes in life expectancy. These studies generally observed that higher exposures to PM_2.5_ concentrations are associated with decreases in life expectancy.

Finally, a number of recent studies employed alternative methods for confounder control or conducted accountability analyses in the process of examining the relationship between long-term PM_2.5_ exposure and mortality. These studies, which used different statistical approaches for confounder control in combination with accountability analyses that examined the effect of policies or interventions on PM_2.5_ concentrations and mortality, collectively provide additional support for the consistent positive associations between long-term PM_2.5_ exposure and mortality reported in cohort studies spanning diverse geographic locations and populations.

## 3.3 Key Scientific Topics that Further Inform the Health Effects of PM_2.5_

This section evaluates recent studies that address specific scientific topics that further inform the relationship between PM_2.5_ exposure and health and are relevant to consider in the process of reconsidering the PM NAAQS. The topics covered in this section include recent experimental studies conducted at near-ambient concentrations, which can further inform the biological plausibility of health effects at the ambient concentrations reported in epidemiologic studies (Section 3.3.1); the role of PM_2.5_ exposure on COVID-19 infection and death (Section 3.3.2); and an evaluation of studies that examine PM_2.5_ exposure and health risk disparities among racial and ethnic groups and SES (Section 3.3.3).

### 3.3.1 Recent Experimental Studies at Near-Ambient Concentrations

Few controlled human exposure studies have investigated the effects of exposure to near ambient concentrations of PM_2.5_ (i.e., at or below the 24-hour NAAQS PM_2.5_ standard of 35 µg/m^3^). As discussed in Sections 6.1.10 and 6.1.13 of the 2019 PM ISA, one such study was conducted in Copenhagen (Hemmingsen et al., 2015b; Hemmingsen et al., 2015a). In this study, older (55−83 years) overweight study participants (n = 60) were exposed for 5 hours to urban street air that had an average PM_2.5_ concentration of 24 µg/m^3^ or particle-filtered urban street air while at rest. Notably, 27 of these participants had never smoked, while 33 former smokers had not smoked on average 20 years prior to study participation. The study was a randomized, repeated measures, single blinded cross-over study. Decreased vasomotor function was reported immediately (within 1 hour) after exposure when comparing nonfiltered with particle-filtered air. The decrease in nitroglycerin-mediated vasodilation was statistically significant, while the decrease in reactive hyperemia-induced vasodilation was not. These two responses represent endothelium-independent and endothelium-dependent mechanisms, respectively. In the companion study, Hemmingsen et al. (2015a) (2019 PM ISA, Section 6.1.11) observed no changes in blood biomarkers of oxidative stress or inflammation. Similarly, blood pressure, blood lipids, and metabolic biomarkers were unaffected by exposure. With respect to HRV, Hemmingsen et al. (2015b) found the high frequency domain was statistically significantly decreased and the low frequency domain was statistically significantly increased when nonfiltered street air was compared with particle-filtered street air. In addition, the standard deviation of NN intervals (SDNN) was statistically significantly reduced after first entering the nonfiltered chamber, but this effect did not persist. In addition, (Hemmingsen et al., 2015a) (2019 PM ISA, Section 10.2.2.2) found no evidence of oxidative stress or DNA damage in peripheral blood monocytes of participants exposed to unfiltered street air.

A recent study conducted at near ambient PM_2.5_ concentrations by Wyatt et al. (2020a) adds to this limited evidence base of controlled human exposure studies conducted at near ambient concentrations. This study was a randomized double-blind crossover study in healthy young participants (18−35 years, n = 21) who were subject to intermittent moderate exercise. Study participants were exposed for 4 hours to clean air or to an average concentration of 37.8 µg/m^3^ PM_2.5_ CAPs in Chapel Hill, NC. Ventilation rate was monitored, and workload adjusted so that participants achieved a ventilation rate of 20 L/min/m^2^ body surface area. Thus, dose was approximately the same among participants. When comparing mean values from the exposed and unexposed groups, changes in lung function were observed in PM_2.5_ exposed participants, including a statistically significant decrease in forced expiratory volume in one second/forced vital capacity (FEV1/FVC) ratio of 1.2% at 1-hour postexposure that returned to baseline by 20 hours postexposure. Decreases in peak expiratory flow (PEF) (1.8%) and FEV1 (0.8%) were also observed when comparing mean values from the exposed and unexposed groups at 1-hour postexposure, but they did not achieve statistical significance. Furthermore, when comparing mean values from the exposed and unexposed groups, markers of the acute phase response―serum amyloid A and C reactive protein―were increased at both 1 and 20 hours postexposure. Serum amyloid A was increased by 8.7% at 1-hour postexposure and by 34.6% at 20 hours postexposure. C reactive protein was increased by 9.1% at 1-hour postexposure and by 22.8% at 20 hours postexposure. These changes, except for C reactive protein at 20 hours postexposure, were statistically significant. Other statistically significant changes observed when comparing differences in mean values were increases in markers of vascular inflammation, soluble intercellular adhesion molecule 1 (sICAM) (10.7%) and soluble vascular cell adhesion molecule 1 (sVCAM) (6.6%), at 1-hour postexposure, decreases in percent blood neutrophils (5.7%) at 20 hours postexposure and decreases in blood LDH levels of 6.9% and 11.2% at 1 and 20 hours postexposure, respectively. The percentage of white blood cells other than neutrophils were unchanged by exposure, as were cytokines, red blood cells, and measures of blood chemistry. Hematocrit levels were decreased, but this change failed to reach statistical significance. No statistically significant changes were found in time domain measures of HRV in the study population as a whole, but SDNN was statistically significantly decreased in men and increased in women. No statistically significant results with respect to frequency domains were reported. P-wave duration, a measure of cardiac repolarization, was increased by 10.5% at 1-hour postexposure, a statistically significant change. Another measure of cardiac repolarization, QRS complex, was altered by PM_2.5_ exposure, but this change did not reach statistical significance. Some sex-related changes that reached statistical significance were found in HRV measures, cardiac repolarization parameters, FEV1 and PEF, however the small sample size precludes any conclusions.

The higher ventilation rate and longer exposure duration of Wyatt et al. (2020a) compared with most controlled human exposure studies of PM, is roughly equivalent to a 2-hour exposure of 75−150 µg/m^3^ PM_2.5_. Thus, dosimetric considerations may explain the observed changes in lung function and inflammation in this population of young healthy individuals exposed to near-ambient concentrations of PM_2.5_. While Wyatt et al. (2020a) provides evidence of some effects at lower PM_2.5_ concentrations, overall there is inconsistent evidence for changes in lung function (2019 PM ISA, Section 5.1.7.2 and Section 5.1.2.3.3) and inflammation (2019 PM ISA, Section 6.1.11.2.1) in other controlled human exposure studies conducted at higher PM_2.5_ concentrations evaluated in the 2019 PM ISA. Strengths of Wyatt et al. (2020a) include power calculations made based on the primary endpoints, normalization of results, and good diurnal control (i.e., all exposures occurred within a half hour of the same time―9:30 a.m.). However, a limitation of this study is that no Bonferroni corrections were made to account for the multiple comparisons made in the study; this limitation was acknowledged by the study authors.

### 3.3.2 PM_2.5_ Exposure and SARS-CoV-2 Infection and COVID-19 Death

With the advent of the global COVID-19 pandemic, several studies have emerged that evaluate the relationship between ambient air pollution, specifically PM_2.5_, on severe acute respiratory syndrome coronavirus 2 (SARS-CoV-2) (the virus responsible for COVID-19 disease) infections and COVID-19 deaths, including a few studies with locations in the U.S. and Canada. The following sections present an evaluation of studies that examined the relationship between short-term (Section 3.3.2.1) and long-term (Section 3.3.2.2) PM_2.5_ exposure and outcomes including SARS-CoV-2 infection and replication rate as well as COVID-19 hospital admissions and deaths. While there is no exact corollary within the 2019 PM ISA for these types of studies, there is evidence presented in the 2019 PM ISA that evaluates the potential relationship between short-term and long-term PM_2.5_ exposure and respiratory infection (2019 PM ISA, Section 5.1.5 and Section 5.2.6). Briefly, studies outlined in the 2019 PM ISA reported some evidence of positive associations between short-term PM_2.5_-exposure and ED visits and hospital admissions for respiratory infections, but interpretation of these results was complicated by the variability in the type of respiratory infection outcome examined (2019 PM ISA, Figure 5-7). Studies of long-term PM_2.5_ exposure were limited in number and although some positive associations were reported there was minimal overlap in respiratory infection outcomes examined across studies. As detailed in Section 5.1.1 and 5.1.5 of the 2019 PM ISA, exposure to PM_2.5_ has been shown to impair host defense, specifically altering macrophage function, providing a biologically plausible pathway by which PM_2.5_ exposure could lead to respiratory infection. Additionally, there is some evidence that exposure to PM_2.5_ can lead to decreases in an individual’s immune response and can subsequently facilitate replication of respiratory viruses (Bourdrel et al., 2021).

#### 3.3.2.1 Short-Term PM_2.5_ Exposure

Since the onset of the COVID-19 pandemic, studies have evaluated the relationship between short-term PM_2.5_ exposure and COVID-19 outcomes (Table A-9). Specifically, these studies examine whether or not daily-changes in PM_2.5_ can influence COVID-19 outcomes. A recent study conducted in Queens County, NY, evaluated the relationship between short-term PM_2.5_-exposure and incident SARS-CoV-2 infections and COVID-19 deaths between March 1, 2020 and April 20, 2020 (Adhikari and Yin, 2020). This time frame corresponds to the timing of the first wave of the pandemic in Queens County, NY (NYC, 2022). This study used negative binomial regression to independently model PM_2.5_ collected from stationary monitors, as well as several other meteorological factors to predict new SARS-CoV-2 infections and COVID-19 deaths, controlling for the lagged outcome (to account for potential autocorrelation of the time-series and new cases) and a trend for day. Using a 21-day moving average of PM_2.5_ exposure, the authors identified a null association between PM_2.5_ concentrations and increased risk of SARS-CoV-2 infection (IRR: 0.02 [95% CI: 0.01, 0.02] or COVID-19 death [IRR: 0.32 (95% CI: 0.10, 0.97)]).

#### 3.3.2.2 Long-Term PM_2.5_ Exposure

Several recent studies have evaluated long-term PM_2.5_-exposure and COVID-19 outcomes in North America (Chakrabarty et al., 2021; Mendy et al., 2021; Liang et al., 2020; Stieb et al., 2020; Wu et al., 2020b). These studies evaluated whether chronic PM_2.5_ exposure is related to increased susceptibility to COVID-19 outcomes. When considered together, these studies that examined the relationship between long-term PM_2.5_ exposure and the global COVID-19 pandemic have several methodological limitations (e.g., studies conducted during an ongoing pandemic) and as a result caution is warranted when interpreting results (Table A-10).

Two large ecological studies (Liang et al., 2020; Wu et al., 2020b) evaluated the association between long-term PM_2.5_ concentrations and county-level COVID-19 deaths in the U.S. The study by Wu et al. (2020b) evaluated COVID-19 death rates (ratio of COVID-19 deaths to county-level population) in 3,089 U.S. counties through June 18, 2020. At that point in the COVID-19 pandemic, over 40% of U.S. counties had zero cases. The MRR was predicted using a negative binomial regression using the 17-year average (2000−2016) of PM_2.5_ as the main exposure and controlling for 20 covariates (19 count-level, 1 state-level). Overall, the authors reported an increased risk of COVID-19 mortality (MMR: 1.69 [95% CI: 1.34, 2.19]). This result was validated by the use of over 80 sensitivity analyses. These sensitivity analyses included alternative methods by which to estimate PM_2.5_ exposure, model specifications, transformation of confounding variables, and repeating the analysis daily between April 18, 2020 and June 18, 2020 to evaluate temporal changes. Another ecological study by Liang et al. (2020), evaluated the mortality ratio (MR) (COVID-19 deaths per 1 million population) and the case fatality rate (CFR) (ratio of COVID-19 deaths to COVID-19 cases) within 3,122 U.S. counties between January 22, 2020 and July 17, 2020. At that point in the pandemic, many areas of the U.S. were still reporting zero cases (USAFacts, 2022). This study also relied on negative binomial regression and used 7-year average (2010−2016) PM_2.5_ as the main exposure of interest while controlling for county-level characteristics and meteorology. The authors estimated the MR to be 1.40 (95% CI: 1.08, 1.83), and CFR was estimated to be 1.18 (95% CI: 0.92, 1.49). When including either NO_2_ or O_3_ in the model, the results remained consistent (Figure 3-29).

Figure 3-29 Percent change in county-level COVID-19 case fatality rate and mortality rate in single and multipollutant models (January 22, 2020−July 17, 2020)

Figure 3 dash 29 from Liang et al (2020) depicts the percent change in COVID-19 Case Fatality and COVID-19 Mortality for each interquartile range (I Q R) (2.6 microgram per cubic meter) increase in P M 2.5 from January 22, 2020 to July 17, 2020. Case fatality and mortality are evaluated in single-pollutant, bi-pollutant (with either ozone or N O 2¬), and tri-pollutant models (with ozone and N O 2¬).

Source: Liang et al. 2020

In contrast, a Canadian ecological study by Stieb et al. (2020) evaluated SARS-CoV-2 infections within 111 Canadian Health Regions through May 18, 2020. These data were used to estimate the IRR of SARS-CoV-2 infections and the 17-year average (2000−2016) of PM_2.5_. This analysis used negative binomial regression and controlled for several health region-specific demographics and descriptors as well as meteorology. The authors reported null associations between long-term PM_2.5_ exposure and SARS-CoV-2 infections (IRR: 1.40 [95% CI: 0.86, 2.29]).

A small U.S. study conducted by Mendy et al. (2021) examined the relationship between COVID-19 hospitalizations, among individuals with a SARS-CoV-2 infection, and 10-year average (2008−2017) PM_2.5_ exposure, measured at the ZIP code level. This cross-sectional study within the University of Cincinnati Hospital System considered several different individual-level factors, such as self-reported age, race/ethnicity, and smoking status, along with other co-morbidities abstracted from medical records. However, this study did not consider community-based factors, such as population density. Mendy et al. (2021) observed that among individuals with a SARS-CoV-2 infection, those with COPD or asthma had increased odds of hospitalization associated with long-term PM_2.5_ exposure (OR: 11.16 [95% CI: 1.00, 128.24]) compared with those without COPD or asthma (OR: 0.42 [95% CI: 0.12, 1.54]).

In a departure from examining solely SARS-CoV-2 infections, deaths, or COVID-19 hospitalizations, another recent study evaluated the association between 6-year average PM_2.5_ concentrations (2012−2017) and the COVID-19 reproduction ratio (R0) for each state (Chakrabarty et al., 2021). The R0 refers to the approximate number of individuals that an infected individual would infect in a completely susceptible population. The R0 was calculated for the time between March 2, 2020 and April 30, 2020, which coincided with nationwide stay-at-home orders. Using a susceptible-exposed-infected-recovered (SEIR) model, confirmed COVID-19 cases were recorded by state and R0 was predicted, while controlling for over 40 different state-level variables. This study showed that long-term PM_2.5_ exposure was associated with increases in the R_0_ (ΔR0: 1.25 [95% CI: 0.24, 2.24]).

#### 3.3.2.3 Summary of Recent Epidemiologic Studies Examining PM_2.5_ Exposure and COVID-19 Infection and Death

The body of evidence that examined associations between long- and short-term PM_2.5_-exposure and COVID-19 outcomes consists mostly of studies employing an ecological study design. While some of these studies exploring the relationship between PM_2.5_ concentrations and SARS-CoV-2 infections and COVID-19 deaths reported positive associations, a number of methodological issues could influence results. Specifically, all of these studies were conducted in the midst of an ongoing pandemic before COVID-19 had reached many parts of the country and at that time the etiology of COVID-19 was still not well understood. In addition, recent investigations have noted important differences in COVID-19-related health outcomes based on occupation, race, socioeconomic status, and health insurance status, among others.

While all the included studies account for population density, with the exception of Mendy et al. (2021), they mostly do not consider other crucial factors that may strongly influence the spread of COVID-19. In particular, factors such as social distancing, stay-at-home orders, use of N95 masks, as well as other preventive measures are important for slowing the spread of SARS-CoV-2. Two critiques of the PM_2.5_ exposure and COVID-19 literature conducted by Bourdrel et al. (2021) and Villeneuve and Goldberg (2020) highlight the importance of control for race/ethnicity and other sociodemographic factors, which may strongly influence exposure or susceptibility to SARS-CoV-2. Additionally, they indicate the potential for exposure misclassification and the likelihood of underreporting of cases and deaths, particularly in the early stages of the pandemic. Taken together, there is limited evidence at this point in the COVID-19 pandemic to determine whether short- or long-term exposure to air pollutants, such as PM_2.5_, influence the spread or susceptibility of SARS-CoV-2 in the population.

### 3.3.3 Populations and Lifestages at Potentially Increased Risk of a PM-Related Health Effect

As discussed in the 2019 PM ISA in Chapter 12, the NAAQS are intended to protect public health with an adequate margin of safety, which includes protection for the population as a whole and for those groups potentially at increased risk for health effects from exposure to a criteria air pollutant [e.g., PM; see Preamble to the ISA (U.S. EPA, 2015)]. While there is strong evidence for PM-related health effects occurring in the exposed general population and in some specific populations or lifestages, it is also important to evaluate and characterize the evidence to determine whether there are populations or lifestages potentially at increased risk of a PM-related health effect, with specific emphasis placed on studies that compare responses to a reference population, where appropriate [see Preamble to the ISA (U.S. EPA, 2015)].

As discussed in the Preamble to the ISAs (U.S. EPA, 2015), the risk of health effects from exposure to an ambient air pollutant, including PM, may be modified as a result of intrinsic (e.g., preexisting disease, genetic factors) or extrinsic factors (e.g., sociodemographic or behavioral factors), differences in internal dose (e.g., due to variability in ventilation rates or exercise behaviors), or differences in exposure to air pollutant concentrations (e.g., more time spent in areas with higher ambient concentrations). Taking into consideration each of these factors, Chapter 12 of the 2019 PM ISA documented a full evaluation and characterization of the evidence and conveyed the overall confidence (i.e., adequate evidence, suggestive evidence, inadequate evidence, or evidence of no effect) as to whether specific populations or lifestages are at increased risk of a PM-related health effect (see Section 2.2.5) using a framework detailed in Table 12-1 of the 2019 PM ISA. As a result, this Supplement does not include a full evaluation and characterization of all studies published since the literature cutoff date of the 2019 PM ISA that provided evidence as to whether specific populations and lifestages are at increased risk of a PM-related health effect. Instead, given recent Agency guidance addressing environmental justice [e.g., U.S. EPA (2021)] and the expansion of studies examining the role of PM_2.5_ on populations with environmental justice concerns, the focus in this section is on recent studies that examine disparities in exposure or risk to PM by socioeconomic status (Section 3.3.3.1) and race and ethnicity (Section 3.3.3.2).

#### 3.3.3.1 Socioeconomic Status

The 2019 PM ISA noted that SES―a composite measure that can include metrics such as income, education, or occupation―plays a role in access to healthy environments and access to health care in the U.S., therefore indicating that SES may underlie differential risk for PM_2.5_-related health effects. Measures of SES can be examined on the individual level (e.g., personal income, education, occupation, etc.), at a community-level (e.g., median household income per census tract, percent of population with bachelor’s degrees), or as a “composite” metric incorporating several different SES measurements into one single score or metric. Additionally, some evidence demonstrated that having low income or residing in low-income areas results in stronger associations (i.e., larger in magnitude) between mortality and long-term PM_2.5_ exposures, when compared with their higher income counterparts. When considering educational attainment, as an indicator for SES, there was no clear pattern of differential risk when comparing those with low educational attainment and those with higher educational attainment. Taken together, the 2019 PM ISA concluded that the combination of exposure disparities and health evidence was suggestive that lower SES populations are at increased risk for PM_2.5_-related health effects compared with higher SES populations. The following sections present an evaluation of recent studies pertaining to both PM_2.5_ exposure among different SES groups (Section 3.3.3.1.1) and PM_2.5_-related health risks among different SES groups (Section 3.3.3.1.2).

##### 3.3.3.1.1 Exposure Disparity

Several recent studies within the U.S. and Canada evaluated the relationship between PM_2.5_ exposure and community-level SES since the completion of the 2019 ISA (Lee and Park, 2020; Richmond-Bryant et al., 2020; Son et al., 2020; Lee, 2019; Tanzer et al., 2019; Weaver et al., 2019; Rosofsky et al., 2018; Han et al., 2017). These recent studies add to the initial conclusions drawn within the 2019 ISA, which include that there is disparate PM_2.5_ exposure among lower SES communities. When considered together, on average, these additional studies provide further evidence that lower SES communities are exposed to higher concentrations of PM_2.5_ compared with higher SES communities (Figure 3-30a, Figure 3-30b―SES exposure, Table A-11). Specifically, Figure 3-30a and Figure 3-30b compare the mean exposure of low SES populations with that of higher SES populations, with a ratio value > 1 indicative of higher PM_2.5_ exposure among the group with lower SES.

Educational attainment is a common metric with which to assess the SES of a community. A study by Lee (2019) in the state of California observed that in 2016, census block-groups with a high percent (≥ 75th percentile) of low educational attainment had a higher exposure to PM_2.5_ (9.90 µg/m^3^) compared with those with a low percent (< 25th percentile) of low educational attainment (8.46 µg/m^3^). Rosofsky et al. (2018) conducted a study in Massachusetts that examined exposure differences by community-level educational attainment for both 2003 and 2010 but did not find as substantial of an exposure difference by educational attainment. Specifically, census block groups with more individuals with less than a high school education were exposed to PM_2.5_ concentrations of 11.3 µg/m^3^ in 2003 and 2010: 8.2 µg/m^3^ in 2010; whereas those with a master’s degree or higher were exposed to 11.2 µg/m^3^ in 2003 and 8.0 µg/m^3^ in 2010. Additionally, those with a high school education, post-secondary education, or bachelor’s degree were exposed to slightly lower PM_2.5_ concentrations ranging from 11.1 to 11.2 µg/m^3^ in 2003 and 7.9 to 8.0 µg/m^3^ in 2010 (Rosofsky et al., 2018).

Measures of poverty or household income are other indicators that can be used to assess SES in a community. Median household income was also evaluated in assessing potential exposure disparities in different communities in the study conducted by Rosofsky et al. (2018) noted above. Within this study it was observed that mutually exclusive census block groups with median household income categories with ranges < $75,000 ($50,000−$75,000; $35,000−$50,000; $20,000−$35,000; < $20,000) were exposed to slightly higher PM_2.5_ concentrations of PM_2.5_ in 2003 (11.2−11.4 µg/m^3^) and 2010 (8.0−8.2 µg/m^3^) compared with block groups with median household income ≥ $75,000 (11.1 µg/m^3^ in 2003 and 7.9 µg/m^3^ in 2010). Another study evaluating income differential in North Carolina provided some evidence that those living in census tracts with a median household income ≥ $52,269 (75th percentile) (11.3 µg/m^3^) are exposed to slightly higher concentrations of PM_2.5_ compared with census tracts above the 75th percentile (11.2 µg/m^3^) for median household income (Son et al., 2020). Instead of examining specific household income cut points, Lee (2019) specifically evaluated the percent living in poverty (defined as those living two times below the poverty line in the state of California). In 2016, those living in census block groups in poverty (9.7 µg/m^3^) were shown to be exposed to higher concentrations of PM_2.5_ compared with block groups not in poverty (8.7 µg/m^3^).

A study by Richmond-Bryant et al. (2020) using data from the National Emissions Inventory (NEI), evaluated potential changes in PM_2.5_ burden due to the closure of 92 coal-fired electricity generating units (EGUcf) facilities in the U.S. This study was an extension of the study presented in the 2019 PM ISA by Mikati et al. (2018). The authors demonstrated that census tracts below the poverty line were subject to a slightly greater decrease (8.8%) in EGUcf PM_2.5_ emissions compared with census tracts not below the poverty line (8.5%). However, when evaluating proportional burden, or the ratio of burden among each subgroup to the burden among the entire population, there was less than a 1% change for those above versus. below the poverty line. This study, while not including all sources of ambient PM_2.5_, generally indicates that census tracts below the poverty line experience a greater burden of exposure to PM_2.5_.

Several recent studies evaluated more complex measurements of community-level SES. These measurements, or “composite” characteristics incorporated several different SES measurements into one single score or metric and were applied in assessing potential disparities in PM_2.5_ exposure. A study conducted in Houston, TX, observed higher PM_2.5_ concentrations obtained from stationary monitors, in a single ZIP code with low SES characteristics (lower median household income, low percentage of non-Hispanic (NH)-White populations, and high percentages of NH-Black and Hispanic populations) (11.3 µg/m^3^) compared with ZIP codes with high SES characteristics (9.6 µg/m^3^) (Han et al., 2017). Similarly, a study by Lee and Park (2020) in the state of California, compared vulnerable with less vulnerable communities based on the Social and Health Vulnerability (SHV) metric within the Environmental Justice Screening Method. The SHV score is on a scale between 1 and 5 and is a composite of: percent residents of color, percent of residents twice below the national poverty line, home ownership, housing value, educational attainment, biological vulnerability (percent of residents < 5 and > 60 and birth outcomes), and civic engagement (linguistic isolation and voter turnout). Low vulnerability communities (SHV score 1−2) (6.8 µg/m^3^) had lower PM_2.5_ exposure, compared with communities with higher vulnerability (SHV score 4−5) (10.8 µg/m^3^). Additionally, Tanzer et al. (2019) reported that environmental justice (EJ) communities, as defined by the state of Pennsylvania as census tracts with ≥ 20% of the population living below the poverty line and/or ≥ 30% of the populations belonging to a minority group, had a slightly greater exposure to PM_2.5_ (10.6 µg/m^3^) compared with non-EJ communities (10.3 µg/m^3^). A study by Weaver et al. (2019) evaluated certain neighborhood clusters located within three counties (Durham, Orange, and Wake) in Central North Carolina. In this study, six clusters were derived using Ward’s hierarchical clustering for 11 sociodemographic factors at the census block group level including percent of the population: with at least a bachelor’s degree, in owner occupied housing, with income below the poverty level, on public assistance, who identify as Black, who identify as “other” race (neither Black nor White), unemployed, in nonmanagerial positions, of households with a single parent, and of vacant housing, and urban environment (Weaver et al., 2019). Cluster 1 was defined as urban and having a high percent of Black residents and nonmanagerial occupations. Cluster 2 was defined as urban and having a high percent of: poverty, Black residents, public assistance, single-parent homes, unemployment, and nonmanagerial occupations. Cluster 3 was defined as urban, high percent with bachelor’s degrees, and low percentages of: nonmanagerial occupations, poverty, and unemployment. Cluster 4 was defined as urban, and a high percentage of: other race, bachelor’s degrees, poverty, and owner-occupied housing. Cluster 5 was the only highly rural cluster and had a high percent of owner occupied housing, and low percentages of: poverty, Black individuals, and unemployment. Finally, Cluster 6 was similar to Cluster 5 but was more urban. When compared with Cluster 3 (urban, high bachelor’s degrees) (12.8 µg/m^3^), Cluster 2 (urban, high poverty, Black race) (13.2 µg/m^3^) and Cluster 1 (urban, high Black race) (12.9 µg/m^3^) were exposed to slightly higher concentration of PM_2.5_. Additionally, Clusters 4 and 5 either had the same level of exposure, or slightly lower levels of exposure compared with Cluster 3 (11.9−12.8 µg/m^3^). Overall, areas (clusters) with high relative SES disadvantage were exposed to higher concentrations of PM_2.5_, compared with areas with high relative SES advantage.

Figure 3-30a Differences in PM_2.5_ exposure by socioeconomic status

Note: †Studies published since the 2009 PM ISA. *U.S. and Canadian studies published since the literature cutoff date (~January 2018) for the 2019 PM ISA. Circles represent ratio of each SES group to the reference group; red text and circles represent evidence included in the 2019 PM ISA; blue text and circles represent evidence not included in the 2019 PM ISA. Reference concentrations in μg/m^3^. This figure builds on Figure 12-1 in the 2019 PM ISA.

Figure 3 dash 30 a presents a summary of the ratio (low S E S measures vs. high S E S measures) of P M 2.5 exposures for S E S measures of poverty, income, and unemployment status. Across studies, exposures among those with higher levels of poverty, lower income, and high unemployment have higher exposure compared to those with less poverty, higher income, and lower unemployment.

Figure 3-30b Differences in PM_2.5_ exposure by socioeconomic status (continued)

Note: *U.S. and Canadian studies published since the literature cutoff date (~January 2018) for the 2019 PM ISA. Circles represent ratio of each SES group to the reference group; red text and circles represent evidence included in the 2019 PM ISA; blue text and circles represent evidence not included in the 2019 PM ISA. Reference concentrations in μg/m^3^. This figure builds on Figure 12-1 in the 2019 PM ISA.

Figure 3 dash 30 b is a continuation of the previous figure and presents a summary of the ratio (low S E S measures vs. high S E S measures) of P M 2.5 exposures for educational attainment and composite S E S measures. Overall, exposures among those with less education and lower composite S E S scores had higher exposures than those with more education or higher composite S E S scores.

##### 3.3.3.1.2 Health Risk Disparity

Since the literature cutoff date of the 2019 PM ISA, several additional studies evaluated health disparities and short- and long-term PM_2.5_ exposure, stratified by individual and community-level SES. The 2009 PM ISA, summarized evidence that indicated an increased risk between mortality and long-term exposure to PM_2.5_ among groups with lower SES, which was further extended within the 2019 PM ISA. However, there was little evidence of any SES differences among studies assessing health outcomes, such as cardiovascular disease. Recent evidence is consistent with an increase in the risk of PM_2.5_-related health effects by SES as detailed in the 2019 PM ISA. Overall, there was minimal evidence of differential health risks by SES within studies assessing PM_2.5_-related all-cause or nonaccidental mortality. However, stronger associations in lower SES groups were often observed in studies assessing certain cause-specific mortality outcomes or other health endpoints. The following sections describe recent literature pertaining to short-term (Table A-12) and long-term (Table A-13) PM_2.5_ exposure and health risks among different SES groups.

###### Short-Term PM_2.5_ Exposure

###### Individual-Level SES

A recent time-stratified case-crossover analysis in North Carolina conducted by Son et al. (2020) evaluated the association between total mortality and PM_2.5_ exposure, stratified by individual median household income. The authors reported null associations for total mortality (excluding external causes) when stratified at the median household income (< $41,500) as well as by educational attainment.

###### Community-Level SES

Another time-stratified case-crossover by Yitshak-Sade et al. (2019a) examined the intersection of greenspace, cardiovascular mortality, PM_2.5_ exposure, and community-level educational attainment. This study showed that among census block groups with a low percentage of those without a high school diploma, there was a 1.42% (95% CI: −0.72, 3.62) increase in cardiovascular mortality in less green areas, and a 2.64% (95% CI: 0.46, 4.68) increase in cardiovascular mortality in more green areas associated with 2-day average (lag 0−1) PM_2.5_ exposure. However, in census block groups with a high percentage of those without a high school diploma, less greenspace was associated with a 3.31% (95% CI: 1.26, 5.41) increase, in cardiovascular mortality, while more greenspace was associated with a 2.64% (95% CI: 0.60, 4.72) increase in cardiovascular mortality. These results indicate that the association between PM_2.5_ and cardiovascular mortality was attenuated by greenspace only in census block groups with lower SES. Additionally, in a time-stratified case-crossover analysis in North Carolina, Son et al. (2020) reported null associations for total mortality (excluding external causes) when stratified at the median household income (< $41,500), or by educational attainment.

###### Long-Term PM_2.5_ Exposure

###### Individual-Level SES

Individual-level SES characteristics were evaluated within some recent studies. Specifically, a Canadian study evaluating individual-level household income and PM_2.5_-related nonaccidental mortality at the six-character postal code (equivalent to a street block or single large building in urban areas) level, reported the greatest magnitude of association in the lowest income category (< $25,000CAD HR: 1.61 [95% CI: 1.23, 2.12]) (Zhang et al., 2021). The overall magnitude of the association was reduced with each increasing income category. Additionally, this study also showed that risk of PM_2.5_-related cardiovascular and respiratory mortality were influenced by household income, with the strongest association noted among those in the lowest individual income category for cardiovascular mortality (< 25,000CAD HR: 4.58 [95% CI: 2.48, 8.47]) compared with the highest income category (≥ $100,000CAD HR: 1.46 [95% CI: 0.94, 2.25]). Fewer differences were noted between the lowest (< 25,000CAD HR: 3.20 [95% CI: 1.40, 7.34]) and the highest (≥ $100,000CAD HR: 4.48 [95% CI: 1.69, 11.83]) individual income categories and respiratory mortality.

###### Community-Level SES

The majority of recent studies focusing on SES evaluate the relationship between PM_2.5_ and health effects, stratified by community-level measures of SES. Specifically, some studies explore whether SES modifies the relationship between exposure to PM_2.5_ and total or all-cause mortality. Similarly, a study by Wang et al. (2020) evaluated over 53 million Medicare beneficiaries using a combination of hybrid machine learning and Cox proportional hazards to assess long-term PM_2.5_ exposure and mortality at the ZIP code level, but also showed null associations for PM_2.5_-related nonaccidental mortality by ZIP code level income (high, medium, low) (Figure 3-31).

Figure 3-31 Risk ratio of association between PM_2.5_ and mortality, stratified by socioeconomic status

SES = socioeconomic status.

Figure 3 dash 31 from Wang et al (2020) summarizes non-accidental and cause-specific risk ratios and 95% confidence intervals for a 10 microgram per cubic meter increase in 12-month average P M 2.5 concentrations stratified by community- level S E S (high, middle, and low income). In general, there were no differences in the effect when stratified by community-level income.

Source: Wang et al. (2020)

Using a more comprehensive method of assessing community-level SES, another Canadian study evaluated if a combination of greenspace and social deprivation modified the relationship between long-term PM_2.5_ exposure and total nonaccidental mortality (Crouse et al., 2019). Community-level deprivation was assessed using the Canadian Marginalization Index, which incorporates measures such as community-level material deprivation, residential instability, dependency, and ethnic concentration. Crouse et al. (2019) found that the group with the lowest deprivation and lowest amount of greenspace had a stronger association, in terms of magnitude, with nonaccidental mortality compared with groups with high deprivation and low greenspace. However, there was little difference in the association comparing high to low deprivation in areas with high greenspace (Figure 3-32).

Figure 3-32 Hazard ratios for the association between PM_2.5_ and mortality, by greenspace and community-level material deprivation

1 = low greenness and low deprivation; 2 = low greenness and high deprivation; 3 = high greenness and low deprivation; 4 = high greenness and high deprivation.

Figure 3 dash 32 from Crouse et al (2019) summarizes the hazard ratios for non-accidental, cardiometabolic, and cardiovascular mortality and an interquartile range (I Q R) (3.5 microgram per cubic meter) increase in P M 2.5 stratified by either high or low social deprivation combined with either high or low greenspace. The group with the lowest greenness and lowest deprivation had the highest hazard ratio (H R), followed by the group with the lowest greenness and the highest deprivation. The lowest H R was observed for the group with the highest greenness and the highest deprivation.

Source: Crouse et al. (2019)

A study by Bennett et al. (2019) evaluated life-expectancy changes and PM_2.5_ among differing SES groups in the U.S., using data from the National Center for Health Statistics. In this study, PM_2.5_ concentrations that were greater than the lowest observed concentration of 2.8 μg/m^3^ were associated with lower life expectancy among counties with: lower income, higher percent poverty, and those with a low percent of the population who graduated from high school. These differences were greater among females compared with males (Figure 3-33). In another study examining life expectancy, Jorgenson et al. (2020) evaluated the relationship between PM_2.5_ exposure, Black race, and income inequality. This study observed that PM_2.5_ had a stronger effect on life expectancy at birth in states with high income inequality. Black race further exacerbated the effect of PM_2.5_ exposure on life expectancy at birth.

Figure 3-33 County-level life expectancy losses due to PM_2.5_ exceeding 2.8 µg/m^3^

Q5 to Q1 difference = estimated difference in life expectancy loss between quintile 5 ($34,200−$114,000) and quintile 1 ($17,400−$24,900).

Figure 3 dash 33 from Bennett et al (2019) depicts the years of life expectancy lost associated with P M 2.5. Overall, life expectancy loss due to P M 2.5 was greater in counties with lower income, a higher proportion of residents below the poverty threshold, a lower proportion of the population that graduated from high school, and a higher percentage of Black or African American individuals.

Source: Bennett et al. (2019)

Numerous recent studies also evaluated whether the association between PM_2.5_ exposure and certain causes of death (i.e., cause-specific mortality) is modified by community-level SES. The study by Wang et al. (2020) using data on Medicare beneficiaries, consistently reported null associations in any cause-specific mortality by income (low, medium, high) (Figure 3-31). However, a cross-sectional study by Bevan et al. (2021) evaluated the association between PM_2.5_ exposure and age-adjusted cardiovascular mortality, modified by the 2015 Social Deprivation Index (SDI). The SDI is generated from a factor analysis using information collected from the American Community Survey, including county-level descriptors of race/ethnicity, income, housing, and education. The SDI ranges between 1 (least deprived) and 100 (most deprived). Bevan et al. (2021) demonstrated that when examining the annual average PM_2.5_ and age-adjusted cardiovascular mortality, stratified by SDI, there is increased risk of cardiovascular mortality in counties with higher social deprivation (SDI 1−25: 39.1 deaths/100,000 persons [95% CI: 32.1, 46.1]; SDI 26−50: 48.2 deaths/100,000 persons [95% CI: 38.5, 57.9]; SDI 51−75: 71.0 deaths/100,000 persons [95% CI: 57.6, 84.4]; SDI 76−100: 52.0 deaths/100,000 persons [95% CI: 30.9, 73.1]). In another study focusing on social deprivation, Wyatt et al. (2020b) estimated the change in PM_2.5_ concentration between 1990 and 2010 and the associated annual change in the age-adjusted cardiovascular mortality rate (CMR) in the U.S. A social deprivation variable was created using 1990 U.S. Census measures including: percent of households below the poverty line, median household income, percent of those ≥ with at least a high school education, civilian unemployment rate, percent female households with no spouse, percent vacant housing units, and percent owner occupied housing units. Overall, in the earliest years, the counties with the highest social deprivation benefited the least by the reduction in PM_2.5_. However, as time progressed through to 2010, reductions in CMR were the largest in the most deprived counties (Figure 3-34).

Figure 3-34 Estimated national and socioeconomic deprivation quintile-specific mortality rates

Note: Estimated national and socioeconomic deprivation (SED) quintile specific annual rates (95% confidence intervals). (A) depicts the change in PM_2.5_ (α); (B) depicts the change in cardiovascular mortality rate (CMR) per 1 µg/m^3^ change in PM_2.5_ (β); (C) depicts PM_2.5_-related change in CMR (αβ); and (D) depicts the PM_2.5_-related change in CMR as a portion of the overall CMR. A negative sign for α indicates a decrease in ambient PM_2.5_ concentrations, while a positive sign indicates an increase. A positive sign for β indicates an increase in CMR per unit increase in PM_2.5_, while a negative sign indicates a decrease. A negative sign for αβ indicates a net reduction in CMR related to PM_2.5_ change, whereas a positive sign indicates a net increase.

Figure 3 dash 34, Part A is from Wyatt et al (2020) describes the annual change in P M 2.5 between 1990 and 2010. The annual change in P M 2.5 differed by socioeconomic deprivation (S E D) quintile, the most deprived counties had the smallest reductions in exposure, whereas the least deprived counties had the largest reductions in exposure. Part B of this figure describes the annual change in cardiovascular mortality rate (C M R) per 1 microgram per cubic meter change in P M 2.5. Overall, the average reduction in C M R increased in the most deprived counties, stayed constant within the moderately deprived counties, and decreased in the least deprived counties. Part C of this figure describes the C M R change attributed to P M 2.5 (deaths/100,000 person-years). Overall, the average annual P M 2.5-related decrease in C M R was the largest in counties with moderate deprivation and the lowest in the highest deprived counties. Part D of this figure describes the P M 2.5-related change in C M R as a proportion of the overall C M R. Overall, the decrease in proportion of C M R was the largest in counties with moderate deprivation and the lowest in the highest deprived counties.

Source: Wyatt et al. (2020b)

Schulz et al. (2018) evaluated cardiopulmonary mortality and PM_2.5_ in the Detroit metropolitan area in 2013, stratified by area-level vulnerability. The census-tract level vulnerability index developed by the authors incorporated percent of households below the poverty index, median home value (reversed), percent of homes occupied by renters, percent of population > 24 with less than a high school education, linguistic isolation, percent people of color, and the percent of the population < 5 and ≥ 60 years of age. Hierarchical linear models, with a logit link independently evaluated PM_2.5_ and cardiopulmonary, cardiovascular, and IHD mortality associated with PM_2.5_ exposure and increased vulnerability. Both PM_2.5_ and vulnerability were independently associated with cardiopulmonary, cardiovascular, and IHD mortality, and the associations remained, when both PM and vulnerability were included. Additionally, the Canadian study on greenspace and social deprivation by Crouse et al. (2019) estimated that greenspace protected against PM_2.5_ attributable cardiovascular and cardiometabolic (defined as the combination of circulatory and diabetes) mortality, but demonstrated a stronger association in areas with low greenness and low deprivation (Figure 3-32).

A prospective analysis by Bai et al. (2019) evaluated the association between PM_2.5_ and either CHF or AMI, using the Canadian ONPHEC, by neighborhood-level income categories. The authors observed the strongest association for both CHF (HR: 1.12 [95% CI: 1.10, 1.13]) and AMI (HR: 1.12 [95% CI: 1.09, 1.15]) among those in the lowest income groups, compared with the uppermost income groups (CHF HR: 1.01 [95% CI: 1.00, 1.04], AMI HR: 1.03 [95% CI: 1.00, 1.06]). A study based on the same cohort also showed stronger associations for atrial fibrillation (HR: 1.06 [1.04, 1.08]) and stroke (HR: 1.08 [1.04, 1.13]) among the lowest income groups (Shin et al., 2019). The central North Carolina study by Weaver et al. (2019) evaluated the relationship between certain health outcomes, such as: coronary artery disease, MI, hypertension, and diabetes, among cardiac catheterization patients. When compared with Cluster 3 (urban, high percent with bachelor’s degrees, and low percentages of: nonmanagerial occupations, poverty, and unemployment) (OR: 0.70 [95% CI: 0.86, 1.07], per 5 µg/m^3^), there was a greater association between PM_2.5_ and hypertension in Cluster 1 (urban and having a high percent of Black residents and nonmanagerial occupations) (OR = 2.70, [95% CI: 0.95, 7.59], per 5 µg/m^3^) and 2 (urban and having a high percent of: poverty, Black residents, public assistance, single-parent homes, unemployment, and nonmanagerial occupations) (OR = 11.86, 95% [95% CI: 2.10, 67.21], per 5 µg/m^3^). While PM_2.5_ was associated with MI, the associations did not vary by cluster, and there were null associations noted for diabetes. However, the strongest association observed among CAD outcomes was in Cluster 3 (OR = 1.15 [95% CI: 1.00, 1.31], per 5 µg/m^3^) (Figure 3-35). Overall, this study concluded that areas with a relatively greater amount of social disadvantage had stronger associations in magnitude between PM_2.5_ and hypertension compared with areas with lower social disadvantage.

Figure 3-35 Odds ratios for the association between PM_2.5_ and cardiovascular outcomes and diabetes by neighborhood cluster

CAD = Coronary Artery Disease, MI = Myocardial Infarction. Results resented for 1 µg/m_3_ increase in PM_2.5_ concentrations.

Figure 3 dash 35 from Weaver et al (2019) describes the odds ratios (O Rs) for coronary artery disease (panel A), myocardial infarction (panel B), hypertension (panel C), and diabetes (panel D) in 6 different clusters based on sociodemographic factors in three counties (Durham, Orange, and Wake) in Central North Carolina. The O Rs for a 1 microgram per cubic meter increase in P M 2.5 were the highest in Clusters 1 and 2 for hypertension, compared to the other clusters. There were no differences in O Rs across clusters for the other health endpoints measured.

Source: Weaver et al. (2019)

#### 3.3.3.2 Race/Ethnicity

The 2019 PM ISA provided evidence indicating that people of different racial and ethnic backgrounds experience disparities in the risk of PM_2.5_-related health effects. When the 2009 PM ISA was finalized, there were relatively few studies evaluating whether race/ethnicity modifies the relationship between PM_2.5_ exposure and health effects. As a result, the 2009 PM ISA observed little evidence for increased PM_2.5_-related risk by race and some evidence of increased risk by Hispanic ethnicity. However, the 2019 PM ISA demonstrated evidence that there are consistent racial and ethnic disparities in PM_2.5_ exposure across the U.S., particularly for Black/African Americans, compared with non-Hispanic White individuals. Additionally, some studies provided evidence of increased PM_2.5_-related mortality and other health effects from long-term exposure to PM_2.5_ among Black individuals. Taken together, the 2019 PM ISA concluded that the evidence was adequate to conclude that race and ethnicity modify PM_2.5_-related risk, and that minority populations, particularly Black populations, are at increased risk for PM_2.5_-related health effects, in part due to disparities in exposure. The following sections present an evaluation of recent studies pertaining to both PM_2.5_ exposure among different racial and ethnic groups (Section 3.3.3.2.1) and PM_2.5_-related health risks among different racial and ethnic groups (Section 3.3.3.2.2).

##### 3.3.3.2.1 Exposure Disparity

Several recent studies conducted within the U.S. and Canada evaluated the relationship between PM_2.5_ exposure and racial and ethnic disparities since the literature cutoff date of the 2019 ISA. These recent studies add to the conclusions of the 2019 ISA, which included that there are disparities in PM_2.5_ exposure by race and ethnicity. When considered together, these additional studies provide further evidence that minority communities are exposed to higher concentrations of PM_2.5_, compared with predominantly White communities (Figure 3-38―Race exposure, Table A-14―Race exposure). Specifically, Figure 3-38 and compares the mean exposure of minority populations with that of nonminority populations, with a ratio value > 1 indicative of higher PM_2.5_ exposure among the minority group.

Recent evidence further indicates that disparities in exposure persist by race and ethnicity. Several multi-year cohort studies evaluated the potential disparity in long-term PM_2.5_ exposure by race/ethnicity. The Heart Strategies Concentration on Risk Evaluation (HeartSCORE) study, conducted in Pittsburg, PA, between 2001 and 2014, observed that Black participants (16.1 µg/m^3^) were exposed to slightly higher concentrations of PM_2.5_ compared with White participants (15.7 µg/m^3^) (Erqou et al., 2018). Similarly, the Veterans Cohort Study, conducted between 1976 and 2001 also showed that Black participants (15.7 µg/m^3^) were exposed to a substantially higher concentration of PM_2.5_ compared with White participants (13.9 µg/m^3^) (Lipfert and Wyzga, 2020). The NIH-AARP Diet and Health Study, conducted between 1995 and 2011, also identified disparities in PM_2.5_ exposure by race and ethnicity. When compared with White race (10.9 µg/m^3^), those of Black race (12.3 µg/m^3^) experience higher exposures to PM_2.5_, followed by Asian, Pacific Islander, or American Indian/Alaska Native (11.9 µg/m^3^) and Hispanic (11.4 µg/m^3^) individuals Lim et al. (2018). A study conducted among the Medicare population that moved outside of their original ZIP code between 2000 and 2012 observed that while post-move PM_2.5_ concentrations were lower among Black (pre-move: 13.02 µg/m^3^, post-move: 12.12 µg/m^3^) and White (pre-move: 11.88 µg/m^3^, post-move: 11.15 µg/m^3^) beneficiaries, a disparity in exposure was still present, with Black populations being exposed to elevated concentrations of PM_2.5_ compared with White populations (Awad et al., 2019). A study by Parker et al. (2018) using the Health Interview Survey also showed that a greater number (37.2%) of non-Hispanic Black and Hispanic (33.3%) individuals lived in the highest PM_2.5_ quartile, compared with White individuals (21.3%). Additionally, most White (26.1%) and Hispanic (34.7%) individuals lived in the lowest PM_2.5_ quartile, compared with only 10.5% of non-Hispanic Black individuals.

Other recent studies used data from the U.S. Census or American Community Survey to gather area-level measures of race and ethnicity. A study by Rosofsky et al. (2018) observed that despite declines in the PM_2.5_ concentrations during the study period, between 2003 and 2010 in Massachusetts, the relative disparity in PM_2.5_ exposure by race/ethnicity remained, with non-Hispanic Black (2003: 11.7 µg/m^3^, 2010: 8.4 µg/m^3^), non-Hispanic Asian (2003: 11.6 µg/m^3^, 2010: 8.2 µg/m^3^), and Hispanic (2003: 11.6 µg/m^3^, 2010: 8.4 µg/m^3^), populations experiencing higher PM_2.5_ exposures compared with non-Hispanic White (2003: 11.1 µg/m^3^, 2010: 7.8 µg/m^3^) populations. (Kelly et al., 2020) evaluated racial and ethnic disparities using nine different exposure models. Despite differences in the absolute concentrations estimated from each method, all exposure models demonstrated that areas of the U.S. with a high percentage of Black individuals experienced higher PM_2.5_ exposures compared with areas with a higher percentage of White individuals. Additionally, compared with areas with a predominant population of White individuals, areas with a predominant population of those classified as “other” race and Hispanic populations were also more highly exposed to PM_2.5_. The result of (Kelly et al., 2020) was supported in a study by Yitshak-Sade et al. (2020) using data collected from the Massachusetts Department of Public Health showed that only 6.0% of Black individuals were in the lowest quartile of PM_2.5_ exposure, while 8.1% were in the highest quartile. Additionally, Lee (2019) in a study conducted in the state of California, demonstrated that block-groups with a high percent (≥ 75th percentile) of people of color (9.98 µg/m^3^) compared with those with a low percent (< 25th percentile) of people of color (7.90 µg/m^3^) were exposed to higher concentrations of PM_2.5_.

Several recent studies used data from the NEI to evaluate racial and ethnic disparities in PM_2.5_ exposure. Richmond-Bryant et al. (2020) evaluated changes in burden due to the closure of 92 coal-fired electricity generating units (EGUcf). Estimated from the American Community Survey, the omission of the facilities resulted in an 11% reduction in absolute burden in census tracts with a majority of White individuals. However, census tracks with a majority of Black (6.6%) or Hispanic (4.4%) populations experienced less of a decrease in absolute burden. When considering the proportional burden―the ratio of absolute burden in a racial subgroup to the absolute burden of the total population―White census tracts had an overall decrease of 2.4%, while predominantly Hispanic and Black census tracts had an increase in proportional burden of 4.5 and 2.2%, respectively. A study by Tessum et al. (2019) estimated the disparities between the consumption of goods and services by each racial and ethnic group that produce PM_2.5_ and the amount of PM_2.5_ each racial and ethnic group is exposed to in order to estimate pollution inequity. Overall, the authors indicate that Black individuals are exposed to the highest concentration of PM_2.5_ (6.0 µg/m^3^), while only consuming 3.8 µg/m^3^, meaning that their estimated pollution inequity is 56%. Hispanic individuals were estimated to have a pollution inequity of 63% (exposed to 5.5 µg/m^3^, consuming 3.4 µg/m^3^), while White individuals have an estimated pollution inequity of −17% (exposed to 4.6 µg/m^3^, consume 5.5 µg/m^3^) (Figure 3-36). Another similar study by Tessum et al. (2021) showed that people of color are consistently exposed to PM_2.5_ caused by each emitter type in the U.S. The authors estimated Black (7.9 µg/m^3^), Asian (7.7 µg/m^3^), Hispanic (7.2 µg/m^3^) individuals are exposed to greater proportions of PM_2.5_ compared with White (5.9 µg/m^3^) individuals (Figure 3-37).

Figure 3-36 Racial and ethnic inequities in PM_2.5_ exposure caused by population-adjusted group consumption (“caused”) and total personal consumption (“exposed”)

Note: In this figure, pollution inequity is the percent difference between a group’s “exposed” and “caused” bars. Within each group of bars, the emitters (A) and end uses (B) responsible for the exposure are depicted with gray lines showing relationships among emitters and end uses.

Figure 3 dash 36 from Tessum et al (2019) describes the average P M 2.5 exposures experienced and caused (end uses) by Black, Hispanic, and White/Other populations. Black and Hispanic populations are on average exposed to a higher concentration of P M 2.5 from almost every emitter group compared to White/Other populations. However, the White/Other populations consume more and thus cause more exposure compared to Black and Hispanic populations in all seven end use categories.

Source: Tessum et al. (2019)

Figure 3-37 Source contributions to racial-ethnic disparity in PM_2.5_ exposure

Note: Individual source type contributions to exposure presented on the y-axis and % exposure disparity presented on the x-axis. Positive values are shaded red and negative values shaded blue. Dashed lines denote percent exposure caused by sources with positive exposure disparity.

Figure 3 dash 37 from Tessum et al (2021) describes P M 2.5 exposures by ethnic group (panels A to E). Overall, P O C, Black, Hispanic, and Asian populations have higher than average PM2.5 exposure, compared to White populations. The second half of the figure (panels F to J) describe the 14 source sectors that each racial group is exposed to. Overall, P O C, Black, Hispanic, and Asian populations are disproportionately exposed to higher-than-average concentrations from the majority of the evaluated source sectors.

Source: Tessum et al. (2021)

Figure 3-38 Difference in PM_2.5_ exposure by race

Note: †Studies published since the 2009 PM ISA. *U.S. and Canadian studies published since the literature cutoff date (~January 2018) for the 2019 PM ISA. Circles represent ratio of each racial or ethnic group to the reference group (White individuals). Red text and circles represent evidence included in the 2019 PM ISA; blue text and circles represent evidence not included in the 2019 PM ISA. Reference concentrations in μg/m^3^. NH: non-Hispanic. This figure builds on Figure 12-2 in the 2019 PM ISA.

Figure 3 dash 38 presents a summary of the ratio of P M 2.5¬ exposures experienced by minority populations compared to non-minority or White populations. Across studies, P M 2.5 exposures among Black, Hispanic, and other minority populations are higher compared to non-minority or White populations.

##### 3.3.3.2.2 Health Risk Disparity

Since the literature cutoff date of the 2019 ISA, several additional studies evaluated disparities in the risk of PM_2.5_-related health effects, stratified by race and ethnicity. A small number of studies were included in the 2009 PM ISA that summarized racial and ethnic disparities in PM_2.5_ mortality risk. The 2019 PM ISA further identified several studies which provided evidence for an increased association between mortality and long-term exposure to PM_2.5_ among minority groups. However, evidence of any racial or ethnic disparities and PM_2.5_-related health outcomes was inconsistent. The most recent evidence is consistent with differences in the risk of PM_2.5_-related health effects by race and ethnicity, as detailed in the 2019 PM ISA. While the studies that evaluated all-cause or total (nonaccidental) mortality were inconsistent, there was stronger evidence to indicate a greater risk of cause-specific mortality and some other health endpoints among people of color. In particular, individuals of Black race consistently were shown to have a greater risk for health outcomes associated with PM_2.5_ exposure. The following sections present an evaluation of recent studies pertaining to short-term (Table A-15) and long-term (Table A-16) PM_2.5_ exposure and PM_2.5_-related health risks among different racial groups.

###### Short-Term PM_2.5_ Exposure

In a time-stratified case-crossover analysis, Yitshak-Sade et al. (2019a) examined the intersection of greenspace, cardiovascular mortality, and PM_2.5_ exposure in Massachusetts. This study demonstrated that among census block groups with a low percentage of White individuals, there was a 3.55% (95% CI: 1.49, 5.65) increase in cardiovascular mortality in less green areas, and a 2.47% (95% CI: 0.43, 4.56) increase in cardiovascular mortality in more green areas associated with two-day average (lag 0−1) PM_2.5_ exposure. However, in census block groups with a high percentage of White individuals, less greenspace was associated with a 1.14% (95% CI: −1.00, 3.33) increase, in cardiovascular mortality, while more greenspace was associated with a 2.8% (95% CI: 0.62, 5.02) increase in cardiovascular mortality (Figure 3-39). These results indicate that regard less of greenspace, census block groups with low percentage of White individuals have a higher risk of PM_2.5_-related cardiovascular mortality. Additionally, the North Carolina case-crossover study by Son et al. (2020) also reported very little racial and ethnic differences in the magnitude of the association between short-term PM_2.5_ exposure and total mortality when stratified by race/ethnicity (non-Hispanic White OR: 1.01 [1.01, 1.01]; non-Hispanic Black OR: 1.01 [1.00, 1.02]; Hispanic OR: 0.97 [0.93, 1.02]; non-Hispanic Asian OR: 1.01 [0.97, 1.02]; non-Hispanic Other OR: 1.01 [0.97, 1.04]).

Another study examining short-term PM_2.5_ exposure and cardiovascular mortality conducted in Massachusetts used four different metrics in which to evaluate race and ethnicity within the state (Yitshak-Sade et al., 2020). There was a higher percent change in cardiovascular mortality among Black (4.78% [95% CI: −1.99, 12.02]) individuals compared with White (2.25% [95% CI: 0.80, 3.23]) associated with the two-day moving average (lag 0−1) of PM_2.5_. When evaluating the racial composition by census block group, there was a 1.62% (95% CI: 0.05, 3.22) increase in cardiovascular mortality in census block groups with 0% Black (10th percentile) compared with a 3.35% (95% CI: 1.57, 5.16) increase in cardiovascular mortality in census block groups with more than a 15% Black population (90th percentile) (see Figure 3-39). This study also evaluated two novel measures of racial segregation. The first was the Racial Residential Segregation (RRS) metric, which quantified the concentration of non-Hispanic Black and non-Hispanic White individuals in each census block group and could range between −1 (more Black individuals) to 1 (more White individuals). In census block groups with more White individuals (RRS 0.5 to 1) there was a 1.84% (95% CI: 0.31, 3.40) increase in cardiovascular mortality, whereas in census block groups with more Black individuals (RRS −1 to −0.5) there was a 15.37% (95% CI: 0.76, 31.99) increase in cardiovascular mortality. The second indicator examined was the Index of Racial Dissimilarity (IRD), which measured the dissimilarity between the distribution of non-Hispanic Black and non-Hispanic White individuals within the census block group to the larger census tract. A higher IRD is indicative of greater dissimilarity in the proportion of Black residents between the census block group and the census tract. There was no evidence of differences in cardiovascular mortality risk attributed to short-term PM_2.5_ exposure among any of the groups (Figure 3-40).

Figure 3-39 Percent change in cardiovascular disease mortality by PM_2.5_ exposure, stratified by census block group racial composition in Massachusetts (2001−2011)

Note: Results presented for a 10 µg/m^3^ increase in PM_2.5_.

Figure 3 dash 39 from Yitshak-Sade et al (2020) describes the percent change in PM2.5-related cardiovascular mortality within census blocks different proportions of Black or White populations. In general, counties with >15% Black residents had a greater increase in cardiovascular mortality compared to census blocks with a low (0%) of Black residents. In census blocks with a low proportion of White residents (<58%), there was a greater increase in cardiovascular mortality compared to census blocks with a high (98%) proportion of White residents

Source: Yitshak-Sade et al. (2020)

Figure 3-40 Percent change in cardiovascular disease mortality by PM_2.5_ exposure, stratified by the Racial Residential Segregation (RSS) metric and Index of Racial Dissimilarity in Massachusetts (2001−2011)

Note: Results presented for a 10 µg/m^3^ increase in PM_2.5_.

RRS = racial residential segregation, IRD = Index of Racial Dissimilarity.

Figure 3 dash 40 from Yitshak-Sade et al (2020) describes the percent change in cardiovascular mortality in census blocks by racial residential segregation (R R S) and the index of racial dissimilarity (I R D). Overall, census blocks with an R R S score <−0.01 (indicative of more Black individuals) had a higher increase cardiovascular mortality compared to census blocks with higher R R S scores (indicative of more White individuals). However, the I R D (a measure comparing the dissimilarity between the distribution of non-Hispanic Black and non-Hispanic White individuals within the census block group to the census tract) showed no differences when stratified.

Source: Yitshak-Sade et al. (2020)

###### Long-Term PM_2.5_ Exposure

A number of recent epidemiologic studies further evaluated whether race and ethnicity modify the association between all-cause (nonaccidental) mortality and long-term PM_2.5_ exposure. A study by Parker et al. (2018) using NHIS data evaluated all-cause mortality (excluding unintentional injuries) and PM_2.5_ by race and ethnicity. This study reported a larger association, in terms of magnitude, among Black (HR: 1.05 [95% CI: 1.03, 1.09]) and White (HR: 1.02 [95% CI: 1.00, 1.05]) individuals and a null association among Hispanic individuals (HR: 0.98 [95% CI: 0.94, 1.03]). However, Awad et al. (2019) in a study of Medicare beneficiaries who moved out of their ZIP code did not report results consistent with Parker et al. (2018). By utilizing data from the subpopulation of Medicare enrollees that moved, the authors were able to examine changes in PM_2.5_ exposure, thus creating a natural experiment that essentially randomized an individual’s exposure. Inverse probability weights were used to control for several select covariates. Among Black movers, the HR for all-cause mortality was lower (HR: 1.06 [95% CI: 1.04, 1.07]), compared with White movers (HR: 1.10 [95% CI: 1.10, 1.10]). Similarly, a recent study using data from the Veterans Cohort Mortality Study from 1976 to 2001 evaluated mortality risk among Black and White veterans. The RR were expressed in terms of the difference in the annual average and the minimum concentration of PM_2.5_, and the results are interpreted as the change in mortality that would result if all cohort members were exposed to the minimum concentration of PM_2.5_. The mortality rate using years 1976−2001 and PM_2.5_ measured between 1999−2001 was higher among White veterans (RR:1.05 [95% CI: 1.01, 1.10]) compared with Black veterans (RR: 0.82 [95% CI: 0.75, 0.89]). This effect was less pronounced when only examining the cohort between 1997 and 2001 (White RR: 1.03 [95% CI: 0.91, 1.17], Black RR: 0.96 [95% CI: 0.76, 1.21]) (Lipfert and Wyzga, 2020). Another study that examined the association between long-term PM_2.5_ exposure and nonaccidental mortality among Medicare beneficiaries by Wang et al. (2020) observed positive, but equal, RR among Black (RR: 1.02 [95% CI: 1.02, 1.02]) and White (RR: 1.03 [95% CI: 1.02, 1.03]) beneficiaries.

Bennett et al. (2019) evaluated life-expectancy changes and PM_2.5_ among differing racial groups in the U.S. In this study, counties with PM_2.5_ concentrations that exceeded 2.8 μg/m^3^ and had a high proportion of Black or African Americans were associated with lower life expectancy. This difference was also greater among females compared with males (Figure 3-33). The study by Jorgenson et al. (2020) that assessed the intersection between PM_2.5_ exposure, Black race, and income inequality also demonstrated that states with a high percentage of Black populations had worse life expectancy at birth associated with PM_2.5_. When including a three-way interaction between PM_2.5_, Black race, and income inequality, the slope for PM_2.5_ and life expectancy becomes more negative as the percent of the population that is Black and the income inequality increase. Overall, this study states that PM_2.5_ appears to have the largest effect on life expectancy in states with a high level of income inequality and a larger percentage of people of Black race (Figure 3-41).

Figure 3-41 Relationship between life expectancy and PM_2.5_ exposure by income inequality and percent Black

Figure 3 dash 41 from Jorgenson et al (2020) presents the three-way interaction between PM2.5 exposure, Black race, and income inequality. Each graph shows the slope for P M 2.5 (at the mean centered value) for low to high percentages of Black residents in the population, by percentiles of income share of the top 10%. Overall, the magnitude of the slope appears to be more negative as the percentage of the population that is Black and income inequality increase.

Source: Jorgenson et al. (2020)

Recent epidemiologic studies also evaluated specific causes of death attributable to PM_2.5_ stratified by race and ethnicity. In an analysis of the NIH-AARP Diet and Health Study (1995−2011), Lim et al. (2018) evaluated diabetes mortality. Minority participants (i.e., Non-Hispanic Black, Hispanic, Asian, Pacific Islander, or American Indian/Alaskan Native, or unknown race/ethnicity, referred to as “Other” in the study) had an association larger in magnitude between annual PM_2.5_ exposure and diabetes mortality (HR: 1.27 [95% CI: 1.02, 1.58]), compared with White participants (HR: 1.05 [95% CI: 0.96, 1.14]). However, other studies that examined whether there are disparities in PM_2.5_-related cause-specific mortality did not report results consistent with Lim et al. (2018). The study by Parker et al. (2018) that used data from the NHIS between 1997 and 2001 to evaluate heart disease mortality and annual PM_2.5_ exposure reported the largest association among White individuals (HR: 1.10 [95% CI: 1.05, 1.15]), with associations smaller in magnitude for Black (HR: 1.04 [95% CI: 0.94, 1.15] and Hispanic (HR: 1.03 [95% CI: 0.95, 1.12] individuals, and no evidence of an association for individuals of “other” races (HR: 0.90 [95% CI: 0.75, 1.07]). Finally, the study by Wang et al. (2020) evaluating over 53 million Medicare beneficiaries showed associations between PM_2.5_ and cause-specific mortality that were larger in magnitude among White beneficiaries compared with minority beneficiaries (i.e., Black, Asian, Hispanic race/ethnicity, referred to as “non-White” in the study) for cardiovascular mortality (White RR: 1.05 [95% CI: 1.05, 1.06], minority RR 1.03 [95% CI: 1.02, 1.03]), heart disease mortality (White RR: 1.07 [95% CI: 1.07, 1.08], minority RR 1.03 [95% CI: 1.02, 1.04]), and vascular disease mortality (White RR: 1.07 [95% CI: 1.06, 1.08], minority RR 1.05 [95% CI: 1.04, 1.06]).

In a study of post-menopausal women enrolled in the WHI, Honda et al. (2017) estimated the association between long-term exposure to PM_2.5_ and incident hypertension by individual race/ethnicity, and also by dichotomizing (White versus minority participants [i.e., Black, Asian/Pacific Islander, Hispanic/Latino, referred to as “non-White” in the study]). This study indicated that the association between PM_2.5_ and incident hypertension was larger in magnitude among Asian/Pacific Islander (HR: 1.34 [95% CI: 1.00, 1.64]), minority (i.e., non-White in the study) (HR: 1.27 [95% CI: 1.17, 1.38]), and Black participants (HR: 1.26 [95% CI: 1.06, 1.44]) compared with White participants (HR: 1.15 [95% CI: 0.99, 1.35]). However, a cross-sectional study evaluating a cohort of community center health patients located in 12 southeastern U.S. states evaluated self-reported cardiometabolic disease (defined as cardiovascular disease, stroke, and diabetes) and long-term PM_2.5_ exposure reported no differences in the association by race (Juarez et al., 2020) (Figure 3-42).

Figure 3-42 Probability of cardiometabolic disease and PM_2.5_ exposure, stratified by race, gender, and hypertension status

Figure 3 dash 42 from Juarez et al (2020) describes the probability of cardiometabolic disease (C M D) and increased concentrations of long-term PM¬2.5 exposure stratified by sex, race, and hypertension status. The probability of C M D was highest among Black males while White females had the lowest risk.

Source: Juarez et al. (2020)

#### 3.3.3.3 Summary of Recent Evidence on At-Risk Populations in the Context of Conclusions of the 2019 Integrated Science Assessment for Particulate Matter

Within the 2019 PM ISA, evidence was evaluated that indicated some populations and lifestages are at increased risk of a PM_2.5_-related health effect (2019 PM ISA, Chapter 12). These disparities between populations and lifestages were in some cases found to be attributed to differences in health risks as well as to exposure. When considering indicators for SES, such as income or educational attainment, having low income, or residing in a low-income area, studies were evaluated that reported associations larger in magnitude between mortality and long-term PM_2.5_ exposure, compared with populations with higher income or living in higher income neighborhoods. However, there was inconsistent evidence of differential risk when comparing across populations with low and high educational attainment. Studies evaluating composite metrics, including a combination of SES factors and even some measures of race/ethnicity, generally demonstrated associations larger in magnitude between various health outcomes and long-term PM_2.5_ exposure, thus demonstrating the complexity of SES indicators. Additionally, evidence was presented in the 2019 PM ISA that indicated a consistent disparity in PM_2.5_ exposure among different racial and ethnic groups. This disparity also translated to PM-related health risks, specifically demonstrating that Black populations were at higher risk for PM_2.5_-related health outcomes, such as mortality. Taken together, the 2019 PM ISA determined that the evidence was suggestive that people of low SES and adequate to indicate that race and ethnicity, specifically minority populations including Black populations, are at increased risk of PM_2.5_-related health effects, in part due to disparities in exposure. Overall, the recent studies support the conclusions of the 2019 PM ISA.

Recent epidemiologic studies published since the 2019 PM ISA supports the evidence that SES may modify the association between PM_2.5_ exposure and PM_2.5_-related health risk. Studies evaluating PM_2.5_-related health risks by SES add to the growing evidence presented in the 2019 PM ISA. In addition to the indicator-SES metrics (e.g., income, educational attainment), several recent studies explored composite measures of neighborhood SES, which consistently demonstrated a disparity in both PM_2.5_ exposure and the risk of PM_2.5_-related health outcomes. Additionally, the recent evidence supported the conclusions that lower SES is associated with cause-specific mortality and certain health endpoints (i.e., MI and CHF), but less so for all-cause or total (nonaccidental) mortality (Section 3.3.3.1).

Consistent with the evidence presented in the 2019 PM ISA, recent studies continue to support and extend the evidence that disparities in PM_2.5_ exposure and health risk exist among different racial and ethnic groups. Those of Black race, or who live in predominantly Black neighborhoods, are consistently subjected to the higher PM_2.5_ exposures, especially when compared with non-Hispanic White groups. Recent studies also continue to support racial and ethnic disparities in the association between PM_2.5_ exposure and cause-specific mortality or certain health endpoints (i.e., incident hypertension), especially when comparing Hispanic and non-Hispanic Black populations with non-Hispanic White populations. However, similar to SES, there was less consistency when evaluating PM_2.5_ exposure and all-cause or total (nonaccidental) (Section 3.3.3.2).

13 Throughout this Supplement, as detailed in the Preface of the 2019 PM ISA (Section P.3.2.2), risk estimates from epidemiologic studies examining short-term exposures are for a 10 μg/m^3^ increase in 24-hour avg PM_2.5_ concentrations and long-term exposures are for a 5 μg/m^3^ increase in annual concentrations, unless otherwise noted.

14 Throughout this section, as detailed in the Preface of the 2019 PM ISA (Section P.3.2.2), risk estimates from epidemiologic studies examining short-term exposures are for a 10 μg/m^3^ increase in 24-hour avg PM_2.5_ concentrations, unless otherwise noted.

15 Throughout this section, as detailed in the Preface of the 2019 PM ISA (Section P.3.2.2), risk estimates from epidemiologic studies examining long-term exposures are for a 5 μg/m^3^ increase in annual concentrations, unless otherwise noted.

16 Throughout this section, as detailed in the Preface of the 2019 PM ISA (Section P.3.2.2), risk estimates from epidemiologic studies examining short-term exposures are for a 10 μg/m^3^ increase in 24-hour avg PM_2.5_ concentrations, unless otherwise noted.

17 95% CIs were not presented in this study.

18 Throughout this section, as detailed in the Preface of the 2019 PM ISA (Section P.3.2.2), risk estimates from epidemiologic studies examining long-term exposures are for a 5 μg/m^3^ increase in annual concentrations, unless otherwise noted.