# 2 OVERVIEW OF MAIN CONCLUSIONS OF THE 2019 INTEGRATED SCIENCE ASSESSMENT FOR PARTICULATE MATTER

Overall Conclusions of the 2019 Particulate Matter (PM) Integrated Science Assessment (ISA)

- Evidence spanning scientific disciplines (i.e., atmospheric chemistry, exposure science, dosimetry, epidemiology, controlled human exposure, and animal toxicology) built upon evidence detailed in the 2009 PM ISA and reaffirmed a causal relationship between short- and long-term PM_2.5_ exposure and cardiovascular effects and total (nonaccidental) mortality, and a likely to be causal relationship for respiratory effects.
- Experimental and epidemiologic evidence supported a likely to be causal relationship between long-term PM_2.5_ exposure and nervous system effects.
- Evidence, primarily from studies of lung cancer incidence and mortality, in combination with the decades of research on the mutagenicity and carcinogenicity of PM supported a likely to be causal relationship between long-term PM_2.5_ exposure and cancer.
- Remaining uncertainties and limitations in the scientific evidence contributed to a suggestive of, but not sufficient to infer, a causal relationship and inadequate to infer the presence or absence of a causal relationship for all other exposure, size fraction, and health effects category combinations.
- Evidence built upon and reaffirmed that there is a causal relationship between PM and the nonecological welfare effects: visibility impairment, climate effects, and materials effects.
- The assessment of PM sources and components confirmed and continued to support the conclusion from the 2009 PM ISA: Many PM_2.5_ components and sources are associated with many health effects, and the evidence does not indicate that any one source or component is more strongly related with health effects than PM_2.5_ mass.
- Many populations (e.g., healthy, diseased) and lifestages (e.g., children, older adults) have been shown to be at risk of a health effect in response to short- or long-term PM exposure, particularly PM_2.5_. However, of the populations and lifestages examined, scientific evidence indicated that only some populations may be at [underlined: disproportionately increased risk] of a PM_2.5_-related health effect, including minority populations (often defined as non-White populations within individual studies), children, people with specific genetic variants in genes in the glutathione transferase pathway, people who are overweight or obese, people with preexisting cardiovascular and respiratory diseases, people of low socioeconomic status (SES), and people who smoke or were former smokers. Inadequate evidence exists to determine whether having diabetes, being in an older lifestage (i.e., older adults), residential location (including proximity to source and urban residence), sex, or diet increase the risk of PM_2.5_-related health effects.

## 2.1 Health Effects

The 2019 Integrated Science Assessment for Particulate Matter (2019 PM ISA) evaluated relationships between short-term and long-term exposures to PM (i.e., PM_2.5_, PM_10−2.5_, and UFPs) and an array of health effects described in epidemiologic, controlled human exposure, and animal toxicological studies. In the assessment of the overall evidence, the strengths and limitations of individual studies were evaluated based on scientific considerations detailed in the Appendix to the 2019 PM ISA. Short-term exposures are defined as those with durations of hours up to 1 month, with most studies examining effects related to exposures in the range of 24 hours to 1 week. Long-term exposures are defined as those with durations of more than 1 month to years. As detailed in the Preface of the 2019 PM ISA, the evaluation of the health effects evidence focuses on exposures conducted at concentrations of PM that are relevant to the range of human exposures across ambient microenvironments (up to 2 mg/m^3^, which is one to two orders of magnitude above ambient concentrations), and studies that (1) include a composite measure of PM^10^ or (2) apply some approach to assess the direct effect of a specific PM size-fraction when the exposure of interest is a source-based mixture (e.g., diesel exhaust, gasoline exhaust, wood smoke).

Consistent with the Integrated Synthesis chapter (Chapter 1) of the 2019 PM ISA, the subsequent sections and accompanying table (Table 2-2) summarize the key evidence that informed the causality determinations for relationships between PM exposure and health effects detailed in the 2019 PM ISA, specifically those relationships for which it was determined that a causal or likely to be causal relationship exists (Table 2-1). While the following sections of this chapter focus on health effects categories for which the evidence supported a causal or likely to be causal relationship, this Supplement as reflected in the Scope (Section 1.2.2) focuses on a narrower evidence base in subsequent chapters. These causality determinations draw from evidence related to the biological plausibility of PM-related health effects and the broader health effects evidence described in detail within the 2019 PM ISA in Chapter 5−Chapter 11, as well as information on dosimetry in Chapter 4 and exposure assessment in Chapter 3. Those relationships between PM and health effects for which the 2019 PM ISA concluded that the evidence supported a causality determination of suggestive of, but not sufficient to infer, a causal relationship or inadequate to infer the presence or absence of a causal relationship are not discussed within this chapter, but are more fully discussed in the 2019 PM ISA.

Table 2-1 Causal and likely to be causal causality determinations for short- and long-term PM_2.5_ exposure

Size Fraction | Health Effects Category | Exposure Duration | Causality Determination | Section
PM_2.5_ | Respiratory | Short-term | Likely to be causal | 2.1.1.1.1
PM_2.5_ | Respiratory | Long-term | Likely to be causal | 2.1.1.1.2
PM_2.5_ | Cardiovascular | Short-term | Causal | 2.1.1.2.1
PM_2.5_ | Cardiovascular | Long-term | Causal | 2.1.1.2.2
PM_2.5_ | Nervous system | Long-term | Likely to be causal | 2.1.1.3.1
PM_2.5_ | Cancer | Long-term | Likely to be causal | 2.1.1.4.1
PM_2.5_ | Mortality | Short-term | Causal | 2.1.1.5.1
PM_2.5_ | Mortality | Long-term | Causal | 2.1.1.5.2

PM_2.5_ = particulate matter with a nominal mean aerodynamic diameter less than or equal to 2.5 μm.

### 2.1.1 Health Effects of PM_2.5_

Substantial scientific evidence exists across disciplines (i.e., animal toxicology, controlled human exposure, and epidemiology) showing that both short- and long-term PM_2.5_ exposure can result in a range of health effects, from changes in circulating biomarkers to mortality. However, the strength of the PM_2.5_ exposure−health effects relationship varies depending on the exposure duration (i.e., short- or long-term) and broad health effects category (e.g., cardiovascular effects, respiratory effects) examined. Across the broad health effects categories examined in the 2019 PM ISA, the evidence supporting biological plausibility varies, but generally includes modulation of the autonomic nervous system and inflammation as part of the pathways leading to overt health effects. Discussions of subsequent events that could occur due to deposition of inhaled PM_2.5_ in the respiratory tract are detailed in the biological plausibility sections of each health chapter in the 2019 PM ISA and summarized in the following sections.

#### 2.1.1.1 Respiratory Effects

Scientific evidence presented in the 2019 PM ISA continues to support the conclusion of the 2009 PM ISA that there is a likely to be causal relationship between both short- and long-term PM_2.5_ exposure and respiratory effects. These causality determinations are based on the consistency of findings within disciplines; the coherence of evidence across disciplines, including epidemiologic and animal toxicological studies, with more limited evidence from controlled human exposure studies; and the evidence supporting biologically plausible pathways for respiratory effects, such as asthma exacerbation, development of asthma, chronic obstructive pulmonary disease (COPD) exacerbation, and respiratory mortality.

##### 2.1.1.1.1 Respiratory Effects Associated with Short-Term PM_2.5_ Exposure

Epidemiologic studies provide strong evidence for overt respiratory effects, including respiratory-related emergency department (ED) visits and hospital admissions and respiratory mortality associated with short-term PM_2.5_ exposure, with coherence provided by some evidence of respiratory effects from experimental studies. Collectively this evidence supported the conclusion of the 2009 PM ISA that there is a likely to be causal relationship between short-term PM_2.5_ exposure and respiratory effects (Table 2-2). This conclusion is based on multiple epidemiologic studies demonstrating generally consistent, positive associations with ED visits and hospital admissions for asthma, COPD, and combined respiratory-related diseases, as well as with respiratory mortality. Evidence from animal toxicological studies, although limited, was supportive of and provided biological plausibility for the associations observed in the epidemiologic studies related to exacerbation of asthma and COPD as well as respiratory infection.

Epidemiologic studies evaluated in the 2019 PM ISA continue to provide strong evidence for a relationship between short-term PM_2.5_ exposure and several respiratory-related endpoints, including asthma exacerbation (2019 PM ISA, Section 5.1.2.1), COPD exacerbation (2019 PM ISA, Section 5.1.4.1), and combined respiratory-related diseases (2019 PM ISA, Section 5.1.6), particularly from studies examining ED visits and hospital admissions. The consistent positive associations between short-term PM_2.5_ exposure and asthma and COPD ED visits and hospital admissions across studies that used different approaches to control for the potential confounding effects of weather (e.g., temperature) are supported by epidemiologic studies demonstrating associations with other respiratory-related effects, such as symptoms and medication use that are indicative of asthma and COPD exacerbations (2019 PM ISA, Section 5.1.2.2 and Section 5.1.4.2). The collective body of epidemiologic evidence for asthma exacerbation was more consistent in children than in adults. Epidemiologic studies examining the relationship between short-term PM_2.5_ exposure and respiratory mortality provided evidence of consistent positive associations, indicating a continuum of effects from morbidity to mortality (2019 PM ISA, Section 5.1.9).

Building off the studies evaluated in the 2009 PM ISA, epidemiologic studies evaluated in the 2019 PM ISA expanded the assessment of potential copollutant confounding. There was some evidence that PM_2.5_ associations with asthma exacerbation, combined respiratory-related diseases, and respiratory mortality remain relatively unchanged in copollutant models with gaseous pollutants (i.e., O_3_, NO_2_, SO_2_, with more limited evidence for CO) and other particle sizes (i.e., PM_10−2.5_) (2019 PM ISA, Section 5.1.10.1). The uncertainty as to whether there is an independent effect of PM_2.5_ on respiratory health, was partially addressed by findings from animal toxicological studies.

Animal toxicological studies of short-term PM_2.5_ exposure provided coherence and biological plausibility for asthma and COPD exacerbations by demonstrating asthma-related responses in an animal model of allergic airways disease and enhanced lung injury and inflammation in an animal model of COPD (2019 PM ISA, Section 5.1.2.4.4 and Section 5.1.4.4.3). There was also a broad body of animal toxicological studies examining respiratory effects due to short-term PM_2.5_ exposure, but most of this evidence was from studies conducted in healthy animals, and therefore, does not provide coherence with the results of epidemiologic studies examining effects in people with asthma or COPD. This evidence base also provided consistent evidence for respiratory irritant effects; limited evidence for altered host defense, greater susceptibility to bacterial infection, and allergic sensitization; and some evidence for pulmonary injury, inflammation, and oxidant stress. Controlled human exposure studies conducted in people with asthma or COPD provided minimal evidence of effects due to short-term PM_2.5_ exposure, such as decrements in lung function and pulmonary inflammation. These studies are limited in terms of endpoints evaluated and the size and health status of study subjects.

##### 2.1.1.1.2 Respiratory Effects Associated with Long-Term PM_2.5_ Exposure

Epidemiologic studies provided strong evidence for effects on lung development, with additional evidence for the development of asthma in children due to long-term PM_2.5_ exposure. Evidence from animal toxicological studies, although limited, was supportive of and provided biological plausibility for the associations reported in epidemiologic studies related to lung development and the development of asthma. There was also epidemiologic evidence supporting a decline in lung function in adults in response to long-term PM_2.5_ exposure. Collectively this evidence supported the conclusions of the 2009 PM ISA that there is a likely to be causal relationship between long-term PM_2.5_ exposure and respiratory effects (Table 2-2).

Epidemiologic studies evaluated in the 2019 PM ISA continued to support an association between long-term PM_2.5_ exposure and several respiratory-related endpoints in children and adults. In children, studies in multiple cohorts provided strong evidence for decrements in lung function growth (2019 PM ISA, Section 5.2.2.1.1). Robust and persistent effects were observed across study locations, exposure assessment methods, and time periods. An animal toxicological study demonstrating impaired lung development resulting from pre- and postnatal PM_2.5_ exposure provided biological plausibility for these findings (2019 PM ISA, Section 5.2.2.1.2). Results of prospective cohort studies in children also provided some evidence for asthma development in children and are supported by other studies examining asthma prevalence in children, childhood wheeze, and pulmonary inflammation (2019 PM ISA, Section 5.2.3). Biological plausibility was provided by an animal toxicological study of long-term PM_2.5_ exposure demonstrating the development of an allergic phenotype and increase in airway responsiveness (2019 PM ISA, Section 5.2.3.3.2). There was limited evidence of increased bronchitic symptoms and hospitalization in children with asthma in relation to long-term PM_2.5_ exposure (2019 PM ISA, Section 5.2.7). In adults, long-term PM_2.5_ exposure was found to be associated with accelerating lung function decline (2019 PM ISA, Section 5.2.2.2.2). Consistent evidence was observed for respiratory mortality and cause-specific respiratory mortality for COPD and respiratory infection (2019 PM ISA, Section 5.2.10), providing evidence of a continuum of effects in response to long-term PM_2.5_ exposure.

Only a few epidemiologic studies evaluated in the 2019 PM ISA have further examined potential copollutant confounding. There was some evidence that PM_2.5_ associations with respiratory mortality remained robust in models with some gaseous pollutants (2019 PM ISA, Section 5.2.10); however, there was limited assessment of potential copollutant confounding when examining respiratory morbidity outcomes. The uncertainty related to the independence of PM_2.5_ effects was partially addressed by findings of animal toxicological studies. Long-term exposure to PM_2.5_ resulted in oxidative stress, inflammation, and morphologic changes in both upper and lower airways (2019 PM ISA, Section 5.2.8), in addition to the asthma-related and lung development-related effects mentioned above. Epidemiologic studies examining the effects of declining PM_2.5_ concentrations provided additional support for a relationship between long-term PM_2.5_ exposure and respiratory health by demonstrating improvements in lung function growth and bronchitic symptoms in children, and improvement in lung function in adults in association with declining PM_2.5_ concentrations (2019 PM ISA, Section 5.2.11). However, the limited examination of copollutant confounding in studies of declining PM_2.5_ concentrations was a notable uncertainty given the corresponding decline in other pollutants over the time period of the evaluated studies.

#### 2.1.1.2 Cardiovascular Effects

Consistent with the conclusions of the 2009 PM ISA, more recently published scientific evidence further strengthens the conclusion that there is a causal relationship between both short- and long-term PM_2.5_ exposure and cardiovascular effects. These causality determinations are based on the consistency of findings within disciplines; coherence among evidence from controlled human exposure, epidemiologic, and animal toxicological studies; and evidence supporting biologically plausible pathways for cardiovascular effects, such as reduced myocardial blood flow, altered vascular reactivity, myocardial infarctions, and cardiovascular mortality.

##### 2.1.1.2.1 Cardiovascular Effects Associated with Short-Term PM_2.5_ Exposure

Strong evidence from epidemiologic studies demonstrating associations between cardiovascular ED visits and hospital admissions in combination with evidence for PM_2.5_-induced cardiovascular effects from controlled human exposure and animal toxicological studies confirmed and extended the conclusion of a causal relationship between short-term PM_2.5_ exposure and cardiovascular effects from the 2009 PM ISA (Table 2-2). This conclusion was based on multiple epidemiologic studies demonstrating associations with cardiovascular effects such as ischemic heart disease (IHD)- and heart failure (HF)-related ED visits and hospital admissions, as well as cardiovascular mortality. The epidemiologic evidence was supported by experimental studies demonstrating endothelial dysfunction, changes in blood pressure (BP), and alterations in heart function in response to short-term PM_2.5_ exposure. Additional evidence from epidemiologic, controlled human exposure, and animal toxicological studies also provided ample evidence of biologically plausible pathways by which short-term exposure to PM_2.5_ can result in overt cardiovascular effects.

Consistent with the 2009 PM ISA, the strongest evidence comes from epidemiologic studies that reported consistent positive associations between short-term PM_2.5_ exposure and cardiovascular-related ED visits and hospital admissions particularly for IHD (2019 PM ISA, Section 6.1.2.1) and HF (2019 PM ISA, Section 6.1.3.1), as well as cardiovascular-related mortality (2019 PM ISA, Section 6.1.9) across studies that used different approaches to control for the potential confounding effects of weather (e.g., temperature). While associations remained relatively unchanged across the copollutants evaluated, the evidence was especially consistent for air pollutants that are not typically associated with traffic (i.e., ozone, SO_2_, PM_10−2.5_). In some instances, associations in copollutant models were attenuated, but this was only observed for the traffic-related pollutants (i.e., NO_2_, CO), which generally had higher correlations with PM_2.5_ than other copollutants. This evidence from copollutant analyses from studies evaluated in the 2019 PM ISA generally indicates that the associations observed between short-term PM_2.5_ exposure and cardiovascular effects are not artifacts due to confounding by another air pollutant (2019 PM ISA, Section 6.1.14.1). These epidemiologic studies reduce a key uncertainty identified in the 2009 PM ISA by providing evidence that gaseous pollutants are not likely to confound the PM_2.5_-cardiovascular effects relationship.

The independence of PM_2.5_ effects is further addressed by findings of controlled human exposure and animal toxicological studies evaluated in the 2019 PM ISA. The most consistent evidence from controlled human exposure studies was for a PM_2.5_ effect on endothelial function (2019 PM ISA, Section 6.1.13). Multiple recent controlled human exposure studies reported that PM_2.5_ impaired some measure of vessel dilation following reactive hyperemia or pharmacological challenge relative to filtered air. Given the relationship between endothelial function and BP, these results were coherent with multiple controlled human exposure studies that reported changes in BP following short-term PM_2.5_ concentrated ambient particles (CAPs) exposure (2019 PM ISA, Section 6.1.6.3). However, these results were inconsistent with some controlled human exposure studies from previous reviews that did not find changes in endothelial function or BP. The results of controlled human exposure studies evaluated in the 2019 PM ISA are also coherent with evidence from animal toxicological studies demonstrating endothelial dysfunction and changes in BP or the renin angiotensin system following short-term PM_2.5_ exposure (2019 PM ISA, Section 6.1.13.3 and Section 6.1.6.4). Moreover, changes in endothelial function and BP reported in recent experimental studies were consistent with epidemiologic studies reporting associations between short-term PM_2.5_ exposure and IHD, as well as with limited epidemiologic panel study evidence of associations with BP. In addition, animal toxicological studies demonstrating that short-term PM_2.5_ exposure results in decreased cardiac contractility and changes in left ventricular pressure were coherent with epidemiologic studies reporting associations between short-term PM_2.5_ exposure and HF.

Collectively, the evidence from controlled human exposure, animal toxicological, and epidemiologic panel studies provided a biologically plausible pathway by which short-term PM_2.5_ exposure could result in cardiovascular effects such as those leading to an ED visit, hospital admission, or mortality. This proposed pathway (2019 PM ISA, Section 6.1.1) begins with pulmonary inflammation and/or activation of sensory nerves in the respiratory track and progresses to autonomic nervous system imbalance and/or systemic inflammation that can potentially affect cardiovascular endpoints such as endothelial function, heart rate variability (HRV), hemostasis, and/or BP. Changes in the aforementioned cardiovascular endpoints may then lead to the development of arrhythmia, thrombosis, and/or acute myocardial ischemia, potentially resulting in outcomes such as myocardial infarction, IHD, HF, and possibly death.

Overall, across the scientific disciplines, recent studies extended and supported the previous evidence for a continuum of cardiovascular-related health effects following short-term exposure to PM_2.5_. These effects range from relatively modest increases in biomarkers related to inflammation, to subclinical cardiovascular endpoints such as endothelial dysfunction, the overt outcomes of ED visits and hospital admissions, specifically for IHD and HF, and ultimately cardiovascular-related mortality.

##### 2.1.1.2.2 Cardiovascular Effects Associated with Long-Term PM_2.5_ Exposure

Multiple epidemiologic studies evaluated in the 2019 PM ISA and previous assessments that extensively control for potential confounders provided strong evidence of positive associations with cardiovascular mortality, which in combination with supporting evidence from recent studies examining cardiovascular morbidity reaffirmed the conclusion of a causal relationship between long-term PM_2.5_ exposure and cardiovascular effects in the 2009 PM ISA (Table 2-2). This conclusion was based on U.S. and Canadian cohort studies evaluated in the 2019 PM ISA that demonstrated consistent, positive associations between long-term PM_2.5_ exposure and cardiovascular mortality, with more limited evidence from studies examining long-term PM_2.5_ exposure and cardiovascular morbidity.

Epidemiologic studies consisting of U.S.-based cohorts and subsequent analyses of these cohorts, provided the basis of the conclusions in the 2009 PM ISA. These studies, in combination with cohort studies evaluated in the 2019 PM ISA, continued to demonstrate consistent, positive associations and support a strong relationship between long-term PM_2.5_ exposure and cardiovascular mortality. The results of these cohort studies are consistent across various spatial extents, exposure assessment techniques, and statistical techniques in locations where mean annual average concentrations are near or below 12 micrograms per cubic meter (µg/m^3^) (2019 PM ISA, Section 6.2.10).

The body of literature examining the relationship between long-term PM_2.5_ exposure and cardiovascular morbidity has greatly expanded since the 2009 PM ISA. Epidemiologic studies evaluated in the 2019 PM ISA examining cardiovascular morbidity endpoints consisted of several large U.S. cohort studies each focusing on populations with distinct demographic characteristics (e.g., postmenopausal women, male doctors) and extensive consideration of potential confounders. These studies have reported heterogeneous results, with several studies that adjusted for important confounders, including socioeconomic status (SES), reporting positive associations for cardiovascular morbidity endpoints. The strong associations reported between long-term PM_2.5_ exposure and coronary events (e.g., coronary heart disease [CHD] and stroke) among postmenopausal women in the Women’s Health Initiative (WHI) cohort, highlighted in 2009 PM ISA, were strengthened in an extended analysis that considered individual and neighborhood-level SES (2019 PM ISA, Section 6.2.3; Section 6.2.10). Recent analyses of other cohorts of women (i.e., Nurses’ Health Study [NHS], California Teachers Study [CTS]) that were comparable to WHI in that they considered menopausal status or hormone replacement therapy did not show consistent positive associations with CHD, myocardial infarction, or stroke. Longitudinal studies demonstrated that changes in the progression of atherosclerosis in relation to long-term exposure to PM_2.5_ were variable across cohorts and found to depend, in part, on the vascular bed in which atherosclerosis was evaluated (2019 PM ISA, Section 6.2.4.1). However, within a study focusing on the progression of atherosclerosis in a healthy population, the Multi-Ethnic Study of Atherosclerosis and Air Pollution (MESA-Air), an association was observed between long-term PM_2.5_ exposure and coronary artery calcification (CAC), which is a strong predictor of CHD (2019 PM ISA, Section 6.2.4). A small number of studies reported positive associations between long-term PM_2.5_ exposure and HF, BP changes, and hypertension. Longitudinal epidemiologic analyses also supported the observation of positive associations with markers of systemic inflammation, coagulation, and endothelial dysfunction. These HF studies were coherent with animal toxicological studies demonstrating decreased contractility and cardiac output and increased coronary artery wall thickness following long-term PM_2.5_ exposure (2019 PM ISA, Section 6.2.4.2). Moreover, animal toxicological studies finding a relationship between long-term exposure to PM_2.5_ and changes in BP in rats and mice were coherent with epidemiologic studies reporting positive associations between long-term exposure to PM_2.5_ and hypertension. Similarly, evidence of atherosclerotic plaque progression in a genetically susceptible mouse model was consistent with epidemiologic studies reporting associations between atherosclerosis and long-term PM_2.5_ exposure.

The body of evidence evaluated in the 2019 PM ISA also reduced uncertainties identified in the 2009 PM ISA related to potential copollutant confounding and the shape of the concentration-response (C-R) relationship for cardiovascular disease (CVD) effects following long-term PM_2.5_ exposure. Generally, most of the PM_2.5_ effect estimates relating long-term PM_2.5_ exposure to cardiovascular mortality remained relatively unchanged or increased in copollutant models adjusted for O_3_, NO_2_, SO_2_, and PM_10−2.5_ (2019 PM ISA, Section 6.2.15). In addition, most of the results from analyses examining the C-R function for cardiovascular mortality supported a linear, no-threshold relationship for cardiovascular mortality, especially at mean annual PM_2.5_ concentrations ≤ 12 µg/m^3^ (2019 PM ISA, Section 6.2.10). Some studies reported that the slope of the C-R curve tended to be steeper at lower concentrations, especially for IHD mortality, suggesting a supralinear C-R relationship. A limited number of cardiovascular morbidity studies examined the shape of the C-R relationship and generally reported a steeper C-R curve at lower concentrations (starting at ~10 µg/m^3^) with the slope of the C-R curve decreasing at higher PM_2.5_ concentrations (2019 PM ISA, Section 6.2.16).

Evidence from animal toxicological and epidemiologic studies also provided biologically plausible pathways by which long-term PM_2.5_ exposure could lead to cardiovascular effects such as CHD, stroke, and CVD-related mortality (2019 PM ISA, Section 6.2.1). These pathways initially involve autonomic nervous system changes and/or systemic inflammation that can potentially affect endpoints related to vascular function, altered hemostasis, hypertension, atherosclerotic plaque progression, and arrhythmia. Changes in cardiovascular endpoints such as these may then lead to IHD, HF, and possibly death.

Overall, there was consistent evidence from multiple epidemiologic studies that long-term exposure to PM_2.5_ is associated with cardiovascular mortality. Associations with CHD, stroke, and atherosclerosis progression were observed in several recent epidemiologic studies providing coherence for PM_2.5_-related cardiovascular mortality. Results from copollutant models generally support the independence of PM_2.5_ associations. Additional evidence of the direct effect of PM_2.5_ on the cardiovascular system was provided by experimental studies in animals demonstrating effects including atherosclerosis plaque progression and changes in cardiac contractility and BP.

#### 2.1.1.3 Nervous System Effects

##### 2.1.1.3.1 Nervous System Effects Associated with Long-Term PM_2.5_ Exposure

The 2009 PM ISA evaluated a small number of animal toxicological studies pertaining to the effects of long-term exposures to PM_2.5_ on the nervous system. Since the 2009 PM ISA, the literature base has greatly expanded with studies evaluated in the 2019 PM ISA providing new information that strengthens the lines of evidence indicating that long-term PM_2.5_ exposure may lead to effects on the brain that are associated with neurodegeneration (i.e., neuroinflammation and reductions in brain volume), as well as cognitive effects in older adults (Table 2-2). Animal toxicological studies provided evidence for a range of nervous system effects including neuroinflammation and oxidative stress, neurodegeneration, cognitive effects, and effects on neurodevelopment. Although the epidemiologic evidence was more limited in terms of the number of studies conducted, multiple studies generally supported associations between long-term PM_2.5_ exposure and changes in brain morphology, cognitive decrements, and dementia in adult populations. The consistency and coherence of the evidence across disciplines as it relates to region-specific brain inflammation, morphologic changes in the brain, cognitive effects, and dementia in adult populations supported that there is a likely to be causal relationship between long-term PM_2.5_ exposure and nervous system effects. Thus, the expanded evidence base allowed for the first-time, a causality determination for long-term PM_2.5_ exposure and nervous system effects.

There was strong evidence for biologically plausible pathways that may underlie nervous system effects resulting from long-term exposure to PM_2.5_. Studies demonstrated modulation of the autonomic nervous system leading to downstream consequences including cardiovascular effects (2019 PM ISA, Section 6.2.1). In addition, the pathway involving neuroinflammation in specific regions of the brain (i.e., the hippocampus, cerebral cortex, and hypothalamus) and morphologic changes in the brain indicative of neurodegeneration, is well substantiated and coherent across animal toxicological and epidemiologic studies (2019 PM ISA, Section 8.2.3 and Section 8.2.4). Specifically, morphologic changes induced in the hippocampus of animals were accompanied by impaired learning and memory and there was consistent evidence from multiple epidemiologic studies that long-term PM_2.5_ exposure is associated with reduced cognitive function (2019 PM ISA, Section 8.2.5). Further, the presence of early markers of Alzheimer’s disease pathology was demonstrated in animals following long-term exposure to PM_2.5_ CAPs, which was consistent with a small number of epidemiologic studies that reported positive associations with neurodegenerative changes in the brain (i.e., decreased brain volume) and Alzheimer’s disease or all-cause dementia (2019 PM ISA, Section 8.2.6). Although the loss of dopaminergic neurons in the substantia nigra, which is a hallmark of Parkinson’s disease, was demonstrated in animals (2019 PM ISA, Section 8.2.4), epidemiologic studies did not report associations with Parkinson’s disease (2019 PM ISA, Section 8.2.6). Overall, the lack of consideration of copollutant confounding introduces some uncertainty in the interpretation of the epidemiologic studies but this uncertainty was addressed, in part, by the direct evidence of effects provided by animal toxicological studies.

In addition to the findings described above, which are mostly relevant to adults, several recent studies of neurodevelopmental effects in children have also been conducted. Positive associations between long-term exposure to PM_2.5_ during the prenatal period and autism spectrum disorder (ASD) were consistently observed across multiple epidemiologic studies (2019 PM ISA, Section 8.2.7.2). However, several studies of performance on tests of cognitive function provided little support for an association. Overall, these epidemiologic studies of developmental effects were limited due to their lack of control for potential confounding by copollutants, the small number of studies, and uncertainty regarding critical exposure windows. A study in animals that found inflammatory and morphologic changes in the corpus collosum and hippocampus, as well as ventriculomegaly in young animals following prenatal exposure to PM_2.5_ CAPs provided initial evidence indicating a potential biologically plausible pathway for a relationship between PM_2.5_ and ASD.

#### 2.1.1.4 Cancer

##### 2.1.1.4.1 Cancer Associated with Long-Term PM_2.5_ Exposure

Experimental and epidemiologic evidence indicating genotoxicity, epigenetic effects (e.g., DNA methylation), and increased carcinogenic potential due to PM_2.5_ exposure, along with strong epidemiologic evidence for increases in lung cancer incidence and mortality, supported a likely to be causal relationship between long-term PM_2.5_ exposure and cancer (Table 2-2). This causality determination represented a change from the suggestive of a causal relationship^11^ determination reported in the 2009 PM ISA. The evidence base underlying this conclusion encompasses the decades of research on whole PM exposures and research evaluated in the 2019 PM ISA focusing specifically on PM_2.5_.

PM_2.5_ exhibits various characteristics of carcinogens, as shown in studies demonstrating genotoxic effects (e.g., DNA damage), epigenetic alterations, oxidative stress, and electrophilicity. The examination of the role of PM_2.5_ in cancer development has often focused on whether whole PM, not specific size fractions, has mutagenic properties and whether exposure to whole PM results in genotoxicity or carcinogenicity. Additionally, it has been well characterized that some components of PM_2.5_, specifically hexavalent chromium, nickel, arsenic, and polycyclic aromatic hydrocarbons are known human carcinogens. Extensive analyses of PM_2.5_ and PM_2.5_ extracts in the Ames Salmonella/mammalian-microsome mutagenicity assay demonstrated that PM_2.5_ contains mutagenic agents (2019 PM ISA, Section 10.2.2.1). Additional in vitro and in vivo toxicological studies indicated the potential for PM_2.5_ exposure to result in DNA damage, which was supported by limited human evidence (2019 PM ISA, Section 10.2.2.2). Some studies have also demonstrated that PM_2.5_ exposure can result in cytogenetic effects, specifically micronuclei formation and chromosomal aberrations (2019 PM ISA, Section 10.2.2.3), as well as differential expression of genes potentially relevant to genotoxicity or other aspects of cancer pathogenesis (2019 PM ISA, Section 10.2.2.4). Although inconsistently examined across studies, changes in cellular and molecular markers of genotoxicity and epigenetic alterations, which may lead to genomic instability, are demonstrated in response to PM_2.5_ exposure. Further, the carcinogenic potential of PM_2.5_ was demonstrated in an animal toxicological study in which chronic inhalation enhanced tumor formation that was initiated by exposure to urethane (2019 PM ISA, Section 10.2.4). Additionally, epidemiologic studies evaluated in the 2019 PM ISA encompassing multiple cohorts that are diverse in terms of both geographic coverage and population characteristics have provided evidence of primarily consistent positive associations between long-term PM_2.5_ exposure and lung cancer incidence and mortality, particularly in never smokers (2019 PM ISA, Section 10.2.5.1). Experimental and epidemiologic evidence of genotoxicity, epigenetic effects, and carcinogenic potential provides biological plausibility for epidemiologic results of lung cancer incidence and mortality. Although evaluated in a limited number of studies, the assessment of potential copollutant confounding, particularly with O_3_, indicated that PM_2.5_ associations with lung cancer incidence and mortality are relatively unchanged in copollutant models (2019 PM ISA, Section 10.2.5.1.3). There was limited evidence that long-term PM_2.5_ exposure is associated with cancers in other organ systems; however, there was initial evidence that PM_2.5_ exposure may reduce survival in individuals with cancer.

#### 2.1.1.5 Mortality

Consistent with the conclusions of the 2009 PM ISA, evidence from studies evaluated in the 2019 PM ISA reaffirmed and further strengthened that there is a causal relationship between both short- and long-term PM_2.5_ exposure and total mortality. These causality determinations were based on the consistency of findings across a large body of epidemiologic studies. Evidence from controlled human exposure, epidemiologic, and animal toxicological studies of respiratory and cardiovascular morbidity also provided coherence, as well as biological plausibility. Together, the consistency and coherence in the evidence collectively supported a continuum of effects by which short- and long-term PM_2.5_ exposure could result in mortality.

##### 2.1.1.5.1 Mortality Associated with Short-Term PM_2.5_ Exposure

Strong epidemiologic evidence from studies evaluated in the 2019 PM ISA, as well as in previous assessments, that examined total (nonaccidental) mortality in combination with evidence for cause-specific respiratory and cardiovascular mortality continued to support the conclusion of the 2009 PM ISA that there is a causal relationship between short-term PM_2.5_ exposure and total (nonaccidental) mortality (Table 2-2). This conclusion was based on multiple recent multicity studies conducted in the U.S., Canada, Europe, and Asia that continued to provide evidence of consistent, positive associations between short-term PM_2.5_ and total mortality, across studies that used different approaches to control for the potential confounding effects of weather (e.g., temperature). In addition, there was evidence of biological plausibility for cause-specific mortality and ultimately total mortality as demonstrated by the consistent and coherent evidence across scientific disciplines for cardiovascular morbidity, particularly ischemic events and HF (2019 PM ISA, Chapter 6), and respiratory morbidity, with the strongest evidence coming from studies of exacerbations of COPD and asthma (2019 PM ISA, Chapter 5).

Multicity studies evaluated in the 2019 PM ISA added to the body of evidence evaluated in the 2009 PM ISA and continued to support a positive association between short-term PM_2.5_ exposure and total mortality with percentage increases in mortality ranging from 0.19% to 2.80% at lags of 0 to 1 day in studies in which mean 24-hour avg concentrations were primarily < 20 µg/m^3^ (2019 PM ISA, Figure 11-1; Table 11-1).^12^ The positive associations observed across studies reflected traditional analyses using ambient monitors as well as analyses conducted in both urban and rural locations that used new exposure assignment techniques and relied on multiple sources of PM_2.5_ data (e.g., ambient monitors, statistical models, and satellite data). Whereas the analysis of potential copollutant confounding was limited to single-city studies and studies of PM_10_ in the 2009 PM ISA, recent multicity studies conducted in Europe and Asia indicated that PM_2.5_-mortality associations were relatively unchanged in copollutant models with gaseous pollutants and PM_10−2.5_ (2019 PM ISA, Section 11.1.4). These results from copollutant models further supported an independent effect of PM_2.5_ on mortality. The associations reported for total mortality were also supported by analyses demonstrating increases in cause-specific mortality, specifically for cardiovascular and respiratory mortality which comprise ~33% and ~9%, respectively, of total mortality [NHLBI (2017); 2019 PM ISA, Figure 11-2]. The consistent and coherent evidence across scientific disciplines for cardiovascular morbidity, particularly ischemic events and HF (2019 PM ISA, Chapter 6), and to a lesser degree for respiratory morbidity, with the strongest evidence for exacerbations of COPD and asthma (2019 PM ISA, Chapter 5), provided biological plausibility for cause-specific mortality and ultimately total mortality. The relationship between short-term PM_2.5_ exposure and total mortality was additionally supported by analyses of the concentration-response (C-R) relationship. Although alternatives to linearity have not been systematically evaluated, mortality studies evaluated in the 2019 PM ISA continued to support a linear, no-threshold C-R relationship (2019 PM ISA, Section 11.1.10).

##### 2.1.1.5.2 Mortality Associated with Long-Term PM_2.5_ Exposure

Strong epidemiologic evidence from cohorts in the U.S., Canada, and Europe evaluated in the 2019 PM ISA, as well as in previous assessments, continued to support the conclusion of the 2009 PM ISA that there is a causal relationship between long-term PM_2.5_ exposure and total mortality (Table 2-2). This conclusion was based on the evaluation of multiple cohorts that continued to provide evidence of consistent, positive associations, across studies that controlled for a range of individual- and ecological covariates, such as smoking status and SES. Additional evidence indicated coherence of effects across scientific disciplines for cardiovascular and respiratory morbidity and metabolic disease, which provided biological plausibility for cause-specific mortality and supported a causal relationship with total mortality.

Additional reanalyses and extensions of the American Cancer Society (ACS) and Harvard Six Cities (HSC) cohorts as well as new cohorts consisting of Medicare participants, people that live in Canada, or people employed in a specific job (e.g., teacher, nurse) provided further evidence of positive associations between long-term PM_2.5_ exposure and total mortality, particularly in areas with annual mean concentrations < 20 µg/m^3^, and in some cases below 12 µg/m^3^ (2019 PM ISA, Figure 11-17 and Figure 11-18). Across studies, positive associations were consistently observed regardless of the exposure assignment approach employed, with some studies relying on ambient monitors while others using modeled or remote sensing data or hybrid methods that combine two or more data sources. Recent studies have conducted analyses to examine potential copollutant confounding and indicated that associations between long-term PM_2.5_ exposure and total mortality are relatively unchanged in copollutant models, particularly for O_3_, with fewer studies examining NO_2_, and PM_10−2.5_ (2019 PM ISA, Section 11.2.3; Figure 11-20, Figure 11-21). The evidence for total mortality was further supported by analyses of cause-specific mortality, which reported positive associations with cardiovascular, respiratory, and lung cancer mortality. Biological plausibility for mortality due to long-term PM_2.5_ exposure was provided by the coherence of effects across scientific disciplines for cardiovascular morbidity, particularly for CHD, stroke, and atherosclerosis, and for respiratory morbidity, particularly for the development of COPD. Recent studies extensively examined the C-R relationship between long-term PM_2.5_ exposure and total mortality, specifically in several U.S. and Canadian cohorts, and collectively continued to support a linear, no-threshold C-R relationship (2019 PM ISA, Section 11.2.4; Table 11-7).

A series of studies evaluated in the 2019 PM ISA, examined the relationship between long-term exposure to PM_2.5_ and mortality by examining the temporal trends in PM_2.5_ concentrations to test the hypothesis that decreases in PM_2.5_ concentrations are associated with increases in life expectancy (2019 PM ISA, Section 11.2.2.5). These studies reported that decreases in long-term PM_2.5_ concentrations were associated with an increase in life expectancy across the U.S. for the multiple time periods examined.

Table 2-2 Key evidence contributing to causal and likely to be causal causality determinations for PM_2.5_ exposure and health effects evaluated in the 2019 Integrated Science Assessment for Particulate Matter

Key Evidence in 2019 PM ISA | Health Effect Category^a^ and Causality Determination | PM_2.5_ Concentrations Associated with Effects
Respiratory Effects and Short-Term PM_2.5_ Exposure (2019 PM ISA, Section 5.1): Likely to Be Causal Relationship; No Change in Causality Determination from the 2009 PM ISA; New Evidence Further Supports the Previous Determination.
Section 5.1.12; Table 5-18 | Epidemiologic evidence, consisting mainly of ED visits and hospital admissions, strongly supported a relationship with asthma exacerbation, COPD exacerbation, and combinations of respiratory-related diseases. Evidence for associations with respiratory symptoms and medication use are coherent with other findings for asthma and COPD exacerbation. Some epidemiologic studies examined copollutant confounding and reported that results are robust in models with gaseous pollutants (i.e., O_3_, NO_2_, SO_2_, and with more limited evidence for CO) and other particle sizes (i.e., PM_10–2.5_), especially for asthma exacerbation, combinations of respiratory-related ED visits and hospital admissions, and respiratory mortality. There was a large body of experimental evidence demonstrating respiratory effects due to short-term PM_2.5_ exposure. These experimental studies provided evidence for biologically plausible pathways by which PM_2.5_ exposure could cause a respiratory effect. Specifically, animal toxicological studies provided biological plausibility for asthma exacerbation, COPD exacerbation, and respiratory infection with some evidence of an independent effect of PM_2.5_ on respiratory endpoints. Controlled human exposure studies provided minimal evidence of respiratory effects such as altered lung function and pulmonary inflammation. Consistent positive associations with respiratory mortality provide evidence of a continuum of effects. | Mean ambient concentrations from epidemiologic studies for:; Hospital admissions and ED visits for asthma, COPD, respiratory infections, and combinations of respiratory-related diseases:; U.S. and Canada: 4.7–24. 6 µg/m^3^; Europe: 8.8–27.7 µg/m^3^; Asia: 11.8–69.9 µg/m^3^; Respiratory mortality:; U.S. and Canada: 7.9–19.9 µg/m^3^; Europe: 8.0–27.7 µg/m^3^; Asia: 11.8–69.9 µg/m^3^; Concentrations from animal toxicological studies for:; Allergic airway disease:; 442–596 µg/m^3^; COPD: 171–1,200 µg/m^3^; Altered host defense:; 100–350 µg/m^3^
Respiratory Effects and Long-Term PM_2.5_ Exposure (2019 PM ISA, Section 5.2): Likely to Be Causal Relationship; No Change in Causality Determination from the 2009 PM ISA; New Evidence Further Supports the Previous Determination.
Section 5.2.13; Table 5-27 | Epidemiologic evidence strongly supported a relationship with decrements in lung function growth in children. Additional epidemiologic evidence supported a relationship with asthma development in children, increased bronchitic symptoms in children with asthma, acceleration of lung function decline in adults, and respiratory mortality, including cause-specific respiratory mortality for COPD and respiratory infection. Some epidemiologic studies examined copollutant confounding and reported that results are robust in models with O_3_, NO_2_, and CO, especially for respiratory mortality. There was limited experimental evidence for respiratory effects from long-term PM_2.5_ exposure. However, animal toxicological studies provided biological plausibility for decrements in lung function and asthma development in children, and they reduced the uncertainty regarding the independent effect of PM_2.5_ for these endpoints. Animal toxicological studies also provided evidence for a wide variety of other subclinical effects, such as oxidative stress, inflammation, and morphologic changes. Epidemiologic studies examining the effects of declining PM_2.5_ concentrations strengthened the relationship between long-term PM_2.5_ exposure and respiratory health by demonstrating improvements in lung function growth and reduced bronchitic symptoms in children and improved lung function in adults as a result of lower PM_2.5_ concentrations. However, these studies have a limited examination of copollutant confounding, which was a notable uncertainty because concentrations of other pollutants have also declined. | Mean ambient concentrations from epidemiologic studies for:; Decrement in lung function growth:; 6–28 µg/m^3^; Asthma development in children:; 5.2–16.5 µg/m^3^; Bronchitic symptoms in children with asthma:; 9.9–13.8 µg/m^3^; Accelerated lung function decline in adults:; 9.5–17.8 µg/m^3^; Respiratory mortality:; 6.3–23.6 µg/m^3^; Concentrations from animal toxicological studies for:; Impaired lung development:; 16.8 µg/m^3^; Development of allergic airway disease:; 100 µg/m^3^
Cardiovascular Effects and Short-Term PM_2.5_ Exposure (2019 PM ISA, Section 6.1): Causal Relationship; No Change in Causality Determination from the 2009 PM ISA; New Evidence Further Supports the Previous Determination.
Section 6.1.16; Table 6-34 | There was strong evidence for coherence of effects across scientific disciplines and biological plausibility for a range of cardiovascular effects in response to short-term PM_2.5_ exposure. Consistent epidemiologic evidence from multiple studies at relevant PM_2.5_ concentrations provided evidence of increases in ED visits and hospital admissions for IHD and HF, as well as cardiovascular mortality in multicity studies conducted in the U.S., Canada, Europe, and Asia. These associations remained positive, but in some cases were reduced with larger uncertainty estimates, in copollutant models with gaseous pollutants. Controlled human exposure studies provided coherence and consistent evidence for changes in various measures of endothelial dysfunction and generally consistent evidence of changes in BP. These controlled human exposure studies were consistent with animal toxicological studies also demonstrating endothelial dysfunction, as well as changes in BP and the renin-angiotensin system. In addition, animal toxicological studies demonstrating that short-term PM_2.5_ exposure results in decreased cardiac contractility and left ventricular pressure were coherent with epidemiologic studies reporting associations between short-term PM_2.5_ exposure and HF. | Mean ambient concentrations from epidemiologic studies for:; IHD: 5.8–18.6 µg/m^3^; HF: 5.8–18.0 µg/m^3^; Concentrations from controlled human exposure studies:; 24–325 µg/m^3^ for 2 h; Concentrations from animal toxicological studies:; 178–190 µg/m^3^
Cardiovascular Effects and Long-Term PM_2.5_ Exposure (2019 PM ISA, Section 6.2): Causal Relationship; No Change in Causality Determination from the 2009 PM ISA; New Evidence Further Supports the Previous Determination.
Section 6.2.18; Table 6-54 | Multiple epidemiologic studies continued to provide evidence of consistent, positive associations between long-term PM_2.5_ exposure and cardiovascular mortality at lower ambient concentrations. The cardiovascular mortality associations were observed across different exposure assignment and statistical methods and were relatively unchanged in copollutant models with both gaseous (i.e., O_3_, NO_2_, SO_2_) and particulate (i.e., PM_10–2.5_) pollutants. The evidence for cardiovascular mortality was supported by a smaller body of epidemiologic studies that further explored associations between long-term PM_2.5_ exposure and cardiovascular morbidity. These studies reported some evidence for increased risk of PM_2.5_-related MI and stroke, specifically in individuals with a preexisting cardiovascular disease or diabetes. Recent epidemiologic studies also presented evidence for an effect of long-term PM_2.5_ exposure on subclinical features of cardiovascular morbidity, particularly progression of atherosclerosis as reflected by associations with CAC, with more limited evidence for other measures, such as cIMT. Key evidence from animal toxicological studies included consistent evidence for changes in BP, as well as some evidence for decreases in measures of heart function (e.g., contractility and cardiac output) and cardiac remodeling. Moreover, as in the previous review, there was also some additional evidence for atherosclerotic plaque progression in a genetically susceptible mouse model. | Mean ambient concentrations from epidemiologic studies for:; Cardiovascular mortality:; 4.1–17.9 µg/m^3^; Coronary events:; 13.4 µg/m^3^; CAC:; 14.2 µg/m^3^; CHD and stroke (in those with preexisting disease):; 13.4–23.9 µg/m^3^; Concentrations from animal toxicological studies for:; BP:; 85–375 μg/m^3^ (up to 15 weeks)
Nervous System Effects and Long-Term PM_2.5_ Exposure (2019 PM ISA, Section 8.2): Likely to Be Causal Relationship; Not Evaluated in the 2009 PM ISA; New Evidence Showing Brain Inflammation and Oxidative Stress, Neurodegeneration, Cognitive Effects, and Neurodevelopmental Effects.
Section 8.2.9; Table 8-20 | There was evidence that long-term exposure to PM_2.5_ can modulate the autonomic nervous system leading to downstream consequences, including cardiovascular effects (2019 PM ISA, Section 6.2.1). A second pathway involving neuroinflammation and morphologic changes in the brain indicative of neurodegeneration is well substantiated and coherent across animal toxicological and epidemiologic studies. This combination of evidence supported PM_2.5_-related reductions in brain volume and cognitive effects in older adults. The evidence relating to Parkinson’s disease, and neurodevelopmental effects was more limited. Consideration of copollutant confounding was generally lacking in the epidemiologic studies, but the uncertainty in interpreting the study findings was partly addressed by the direct evidence of effects provided by animal toxicological studies. | Mean annual concentrations from epidemiologic studies for:; Brain volume:; 11.1–12.2 μg/m^3^; Cognition:; 8.5 (5-yr avg)–14.9 μg/m^3^; Autism:; 14.0–19.6 μg/m^3^; Concentrations from animal toxicological studies for:; Brain inflammation/oxidative stress:; 65.7–441.7 μg/m^3^; Neurodegenerative changes:; 94.4 μg/m^3^; Neurodevelopment:; 92.7 μg/m^3^
Cancer and Long-Term PM_2.5_ Exposure (2019 PM ISA, Section 10.2): Likely to Be Causal Relationship; Change in Causality Determination from the 2009 PM ISA (Suggestive of a Causal Relationship) Due to Increased Evidence of Genotoxicity, Carcinogenicity, and Epigenetic Effects for PM_2.5_ and Lung Cancer Incidence and Mortality.
Section 10.2.7; Table 10-8 | Primarily positive associations from multiple epidemiologic studies reported increases in the risk of lung cancer incidence and mortality. This evidence was supported by analyses focusing on never smokers and limited evidence of associations with histological subtypes of lung cancer found in never smokers. Across studies that examined lung cancer incidence and mortality, potential confounding by smoking status and exposure to SHS was adequately controlled. A limited number of studies examined potential copollutant confounding, but associations were relatively unchanged in models with O_3_ with more limited assessment of other gaseous pollutants and particle size fractions. Experimental and epidemiologic studies provided evidence for a relationship between PM_2.5_ exposure and genotoxicity, epigenetic effects, and carcinogenic potential. Uncertainties exist due to the lack of consistency in specific cancer-related biomarkers associated with PM_2.5_ exposure across both experimental and epidemiologic studies; however, PM_2.5_ exhibits several characteristics of carcinogens, which provided biological plausibility for PM_2.5_ exposure contributing to cancer development. Additionally, there was limited evidence of cancer occurring in other organ systems, but there was some evidence that PM_2.5_ exposure may detrimentally affect survival from any type of cancer. | Mean annual concentrations from epidemiologic studies for:; Lung cancer incidence and mortality:; U.S. and Canada:; 6.3–23.6 µg/m^3^; Europe:; 6.6–31.0 µg/m^3^; Asia:; 33.7 µg/m^3^; Concentrations from animal toxicological studies for:; Carcinogenic potential:; 17.66 μg/m^3^
Total Mortality and Short-Term PM_2.5_ Exposure (2019 PM ISA, Section 11.1): Causal Relationship; No Change in Causality Determination from the 2009 PM ISA; New Evidence Further Supports the Previous Determination.
Section 11.1.12; Table 11-4 | There was consistent epidemiologic evidence from multiple multicity studies conducted in the U.S., Canada, Europe, and Asia for increases in total (nonaccidental) mortality at ambient concentrations, often below 20 µg/m^3^. The associations observed were relatively unchanged in copollutant models with gaseous pollutants and PM_10–2.5_, which was consistent with copollutant analyses for cardiovascular and respiratory mortality, but copollutant analyses were limited to studies conducted in Europe and Asia. Biological plausibility for the epidemiologic evidence for total mortality was provided by the strong cardiovascular morbidity evidence, particularly for ischemic events and HF, while support for biological plausibility was more limited from the respiratory morbidity evidence, with the strongest evidence for exacerbations of COPD and asthma. Although alternatives to linearity have not been systematically evaluated, recent mortality studies continued to support a linear, no-threshold C-R relationship. | Mean 24-h avg concentrations from epidemiologic studies for:; Total mortality:; U.S. and Canada:; 4.37–17.97 µg/m^3^; Europe:; 13–27.7 µg/m^3^; Asia:; 11.8–69.9 µg/m^3^
Total Mortality and Long-Term PM_2.5_ Exposure (2019 PM ISA, Section 11.2): Causal Relationship; No Change in Causality Determination from the 2009 PM ISA; New Evidence Further Supports the Previous Determination.
Section 11.2.7; Table 11-8 | There was consistent epidemiologic evidence from multiple studies reporting increases in the risk of total (nonaccidental) mortality from extended follow-ups of the ACS cohort and HSC cohort, as well as multiple studies focusing on a Medicare cohort, Canadian cohorts, and North American employment cohorts. The consistent increases in total mortality were observed across different exposure metrics based on ambient measurements, models, remote sensing, or hybrid methods that combine two or more of these methods, providing additional support for the mortality associations due to long-term PM_2.5_ exposure reported in the 2009 PM ISA that relied on exposure metrics from ambient monitors. The consistent epidemiologic evidence for total mortality was supported by positive associations for cardiovascular, respiratory, and lung cancer mortality. Biological plausibility for total mortality was provided by the strong cardiovascular morbidity evidence, particularly for CHD, stroke, and atherosclerosis, while there is more limited evidence for biological plausibility from the respiratory morbidity evidence, with some evidence for development of COPD. Extensive epidemiologic evidence provides additional support for a linear, no-threshold C-R relationship. A series of studies demonstrated that decreases in long-term PM_2.5_ concentrations were associated with an increase in life expectancy across the U.S. for multiple time periods examined. | Mean annual concentrations from epidemiologic studies for:; Total mortality: ACS/HSC cohorts:; 11.4–23.6 µg/m^3^; Medicare cohort:; 8.12–12.0 µg/m^3^; Canadian cohorts:; 8.7–9.1 µg/m^3^; Employment cohorts:; 12.7–17.0 µg/m^3^

ACS = American Cancer Society; avg = average; BP = blood pressure; CAC = coronary artery calcification; CHD = coronary heart disease; cIMT = carotid intima-media thickness; CO = carbon monoxide; COPD = chronic obstructive pulmonary disease; C-R = concentration-response; h = hour; HF = high frequency; HSC = Harvard Six Cities; IHD = ischemic heart disease; µg/m^3^ = micrograms per cubic meter; MI = myocardial infarction; NO_2_ = nitrogen dioxide; O_3_ = ozone; PM_2.5_ = particulate matter with a nominal mean aerodynamic diameter less than or equal to 2.5 μm; PM_10–2.5_ = particulate matter with a nominal mean aerodynamic diameter greater than 2.5 μm and less than or equal to 10 μm; SHS = second-hand smoke; SO_2_ = sulfur dioxide.

a A large spectrum of outcomes is evaluated as part of a broad health effect category including physiological measures (e.g., airway responsiveness, lung function), clinical outcomes (e.g., respiratory symptoms, hospital admissions), and cause-specific mortality. Total mortality includes all nonaccidental causes of mortality and is informed by the nature of the evidence for the spectrum of morbidity effects (e.g., respiratory, cardiovascular) that can lead to mortality. The sections and tables referenced in the 2019 PM ISA include a detailed discussion of the available evidence that informed the causality determinations.

## 2.2 Policy-Relevant Considerations

In the process of evaluating the current state of the science with respect to the effect of short- and long-term PM exposure on health, studies were identified and evaluated within the 2019 PM ISA that conducted analyses focused on addressing some of the main policy-relevant questions of this review, as detailed in the Integrated Review Plan for the National Ambient Air Quality Standards for Particulate Matter (U.S. EPA, 2016), such as:

- Is there new evidence aimed at disentangling the effect of PM from the complex air pollution mixture to inform a direct effect of PM on health, specifically the assessment of potential copollutant confounding?
- Is there new evidence to inform the current indicators (i.e., PM_2.5_ for fine particles and PM_10_ for thoracic coarse particles), averaging times (i.e., 24-hour avg, annual average), and levels of the PM NAAQS?
- Is there new evidence on the shape of the C-R relationship and whether a threshold exists between PM exposure and various health outcomes (e.g., mortality, hospital admissions), especially for concentrations near or below the levels of the current PM NAAQS?
- Is there new evidence that individual PM component(s) or source(s) (e.g., industrial facilities, roads, atmospheric formation), are more strongly associated with health effects than PM mass, particularly for health effects for which there is sufficient evidence of a strong relationship (e.g., cardiovascular effects, mortality) with PM exposure?
- Is there new evidence indicating that specific populations or lifestages are at increased risk of a PM-related health effect compared with a referent population?

The following sections summarize the evidence that can inform consideration of these policy-relevant questions, specifically: potential copollutant confounding (Section 2.2.1), timing of effects (Section 2.2.2), C-R relationship (Section 2.2.3), PM components and sources (Section 2.2.4), and populations potentially at increased risk of a PM-related health effect (Section 2.2.5).

### 2.2.1 Potential Copollutant Confounding

Studies evaluated in the 2019 PM ISA further examined the potential confounding effects of copollutants, both gaseous and particulate, on the relationship between short- and long-term PM_2.5_ exposure and health effects. These studies built upon the evidence detailed in the 2009 PM ISA and continued to provide evidence indicating that associations with PM_2.5_ are relatively unchanged in copollutant models. Evidence from epidemiologic studies, in combination with experimental studies detailed in multiple chapters of the 2019 PM ISA (i.e., “Respiratory Effects”―Chapter 5 and “Cardiovascular Effects”―Chapter 6 within the 2019 PM ISA) that examined exposure to PM (e.g., CAPs, resuspended PM, and whole mixtures in the presence and absence of a particle trap), demonstrate a direct effect of PM on health.

#### 2.2.1.1 Short-Term PM_2.5_ Exposure

Building upon the studies evaluated in the 2009 PM ISA, epidemiologic studies evaluated in the 2019 PM ISA have further examined whether copollutants confound associations between short-term PM_2.5_ exposure and respiratory and cardiovascular effects and mortality. These studies continued to demonstrate that PM_2.5_-associations are relatively unchanged in copollutant models with both gaseous (i.e., O_3_, NO_2_, SO_2_, and CO) and particulate (i.e., PM_10−2.5_) pollutants.

The examination of potential copollutant confounding on the relationship between short-term PM_2.5_ exposure and respiratory effects has been assessed most extensively through studies examining respiratory-related ED visits and hospital admissions, particularly for asthma, with more limited assessments of COPD and respiratory infection, and studies examining respiratory mortality (Section 5.1.10.1). Correlations between PM_2.5_ and gaseous and particulate pollutants varied across studies, with low to moderate correlations (i.e., r < 0.7) observed for NO_2_, SO_2_, CO, and PM_10−2.5_, and correlations spanning from low to high for O_3_. Across the studies that assessed copollutant confounding, O_3_ was most examined, followed by NO_2_ and PM_2.5._ Within these studies results were relatively unchanged in copollutant models. Although fewer studies focused on SO_2_ and CO, the results from copollutant analyses were consistent with studies evaluated in the 2009 PM ISA, indicating that results are relatively unchanged in copollutant models. Studies evaluated in the 2019 PM ISA that examined PM_10−2.5_ further expanded upon the initial results detailed in the 2009 PM ISA, and although results are consistent with observations from analyses of gaseous pollutants, there is greater uncertainty in these results due to the different methods employed across studies to estimate PM_10−2.5_ concentrations.

For cardiovascular effects, moderate to strong correlations were reported for NO_2_ and CO, with low to moderate correlations for O_3_, SO_2_, and PM_10−2.5_. Across studies of various cardiovascular-related ED visits and hospital admissions and cardiovascular mortality, results were relatively unchanged in copollutant models, but there were some instances of attenuation of the PM_2.5_ association in models with NO_2_ and CO (2019 PM ISA, Section 6.1.14.1). Overall, there was no observed difference in the trend or pattern of copollutant model results across cardiovascular endpoints (e.g., aggregate CVD endpoints, IHD, HF, cardiovascular mortality). However, the few instances of attenuation were with traffic-related pollutants (i.e., NO_2_, CO), which generally had higher correlations with PM_2.5_ than the other copollutants. As a result, it was difficult to distinguish whether the instances of observed attenuation in PM_2.5_ associations were due to confounding or collinearity with other pollutants.

Most epidemiologic studies evaluated in the 2019 PM ISA that examined the potential confounding effects of copollutants focused on respiratory and cardiovascular effects; only a few focused on mortality (2019 PM ISA, Section 11.1.4). Recent multicity studies conducted in Europe and Asia supported the results from single- and multicity studies examined in the 2004 PM AQCD and 2009 PM ISA that reported limited evidence of confounding by copollutants. Across studies that examined both gaseous and particulate (i.e., PM_10−2.5_) pollutants, low to moderate correlations were reported with PM_2.5_. Associations with PM_2.5_ were relatively unchanged in copollutant models across the various study locations examined.

In addition to conducting traditional copollutant analyses, epidemiologic studies of respiratory (2019 PM ISA, Section 5.1.10.1.1) and cardiovascular (2019 PM ISA, Section 6.1.14.1.1) effects have also examined the role of PM within the broader air pollution mixture. These studies do not inform whether PM is independently associated with a respiratory effect, but they can assess whether days with higher PM_2.5_ concentrations are more closely related to health effects. Studies of respiratory effects demonstrated that days when the air pollution mixture has high PM_2.5_ concentrations often represented the days with the largest associations (in terms of magnitude) with a respiratory effect. Additionally, results indicated that risk estimates for a mixture were often similar, but in some cases larger, than those reported for PM_2.5_ alone. However, for cardiovascular effects in general, the evidence neither consistently nor coherently indicated a stronger or weaker effect of combined exposure to PM_2.5_ and another pollutant compared with exposure to PM_2.5_ and other pollutants alone.

#### 2.2.1.2 Long-Term PM_2.5_ Exposure

Epidemiologic studies focusing on long-term PM_2.5_ exposure and health effects have traditionally provided a more limited assessment of the potential confounding effects of copollutants on PM_2.5_ associations. Studies evaluated in the 2019 PM ISA that provided an assessment of copollutant confounding directly addressed a previously identified uncertainty in the scientific evidence.

Across the health effects evaluated within the 2019 PM ISA, relatively few studies examined the potential confounding effects of copollutants on the relationship between long-term PM_2.5_ exposure and respiratory (2019 PM ISA, Section 5.2.13), cardiovascular (2019 PM ISA, Section 6.2.18), and cancer (2019 PM ISA, Section 10.2.7), with a general lack of studies assessing the role of copollutant confounding on observed associations with nervous system effects (2019 PM ISA, Section 8.2.9). These studies often did not examine the full suite of gaseous pollutants but tended to focus on traffic-related pollutants (i.e., NO_2_, NO_X_, and CO) and O_3_, with some studies also examining PM_10−2.5_. Across studies, low to moderate correlations (i.e., r < 0.7) were often observed between copollutants and PM_2.5_. Collectively, studies that examined the potential confounding effects of copollutants on the PM_2.5_ association with respiratory (i.e., lung function and asthma development) and cardiovascular effects (i.e., cardiovascular mortality), along with lung cancer incidence and mortality, reported associations that were relatively unchanged in copollutant models, but these assessments were conducted in a limited number of studies.

Several studies of long-term PM_2.5_ exposure and mortality examined potential copollutant confounding. Within studies that examined the potential confounding effects of copollutants on the relationship between long-term PM_2.5_ exposure and mortality, the most extensive analyses occurred for O_3_, with a limited number of studies examining NO_2_, SO_2_, PM_10−2.5_, and benzene. Studies that examined O_3_ reported correlations that were generally moderate (ranging from r = 0.49 to 0.73), with a few studies reporting weak correlations (r < 0.4). Overall, associations remained relatively unchanged in copollutant models for total (nonaccidental) mortality, cardiovascular, and respiratory mortality (2019 PM ISA, Figure 11-18). Studies focusing on copollutant models with NO_2_, PM_10−2.5_, SO_2_, and benzene were examined in individual studies, and across these studies the PM_2.5_-mortality association was relatively unchanged (2019 PM ISA, Figure 11-19).

### 2.2.2 Timing of Effects

An important question to address when evaluating the scientific evidence demonstrating health effects due to short-term PM_2.5_ exposure is the timing of observed effects. Studies have attempted to address this question through two primary avenues: (1) examining various averaging times of the exposure metric used to represent short-term PM_2.5_ exposure to determine whether PM_2.5_ concentrations averaged over time periods other than 24 hours are more closely associated with health effects and (2) assessing whether the relationship between exposure and effect is biologically plausible by examining the lag days over which associations are observed.

#### 2.2.2.1 Averaging Time

Most epidemiologic studies evaluated in the 2019 PM ISA that examined the relationship between short-term PM_2.5_ exposures and health effects relied primarily on an exposure metric averaged over 24-hours. Some recent studies, focusing on respiratory and cardiovascular effects and mortality, have examined whether there is evidence that subdaily exposure metrics are more closely related to health effects than the traditional 24-hour avg metric.

Epidemiologic studies that examined both respiratory-related ED visits and hospital admissions, as well as subclinical markers of respiratory effects, explored associations with subdaily exposure metrics (2019 PM ISA, Section 5.1.10.5). In studies of respiratory-related ED visits and hospital admissions, positive associations were not consistently observed with subdaily exposure metrics, and often there was no information on spatiotemporal variability of the subdaily metrics. Additionally, in a study that examined multiple subdaily averaging times and compared them with the 24-hour avg exposure metric, there was no difference in associations across metrics, but this result was limited to a single study location. Panel studies also examined subdaily exposure metrics through personal monitoring, but associations were not consistently observed at shorter averaging times for markers of pulmonary inflammation and changes in lung function.

A more limited number of studies examined subdaily exposure metrics and cardiovascular effects (2019 PM ISA, Section 6.1.14.3). Studies of ST elevation, myocardial infarction, out-of-hospital cardiac arrest, and cerebrovascular disease ED visits and hospital admissions reported positive associations with subdaily exposure metrics, but the magnitude of the association tended to be larger when averaging over multiple hours up to 1 day (i.e., 24-hour avg). These studies provided evidence that continues to support the use of a 24-hour avg exposure metric.

A few studies examined subdaily PM_2.5_ exposure metrics and associations with mortality, focusing on comparisons between the 24-hour avg and an hourly peak exposure metric (2019 PM ISA, Section 11.1.8.2). In these studies, positive associations were reported for both the 24-hour avg and hourly peak exposure metric, with the association often slightly larger in magnitude for the 24-hour avg metric. Collectively, the available evidence did not indicate that subdaily averaging periods for PM_2.5_ were more closely associated with health effects than the 24-hour avg exposure metric.

#### 2.2.2.2 Lag Structure of Associations

Often epidemiologic studies examined associations between short-term PM_2.5_ exposure and health effects over a series of single-day lags, multiday lags, or by selecting lags a priori. Studies evaluated in the 2019 PM ISA have expanded the assessment of the timing of effects by systematically examining lag days by focusing on whether there is evidence of an immediate (e.g., lag 0−1 days), delayed (e.g., lag 2−5 days), or prolonged (e.g., lag 0−5 days) effect of PM on health.

Epidemiologic studies of respiratory effects have primarily focused on examining the lag structure of associations for respiratory-related ED visits and hospital admissions, with most studies examining asthma exacerbation with a more limited assessment for COPD exacerbation and respiratory infection (2019 PM ISA, Section 5.1.10.3). Across the studies that examined asthma, COPD, respiratory infections, and combinations of respiratory-related diseases, the strongest association reported, in terms of magnitude and precision, was generally within a few days after exposure, but there was some evidence demonstrating the potential for a prolonged effect of PM_2.5_ (i.e., lags ranging from 0 to 5 days). Recent studies of respiratory mortality provided additional insight on the lag structure of associations for respiratory-related effects due to short-term PM_2.5_ exposure. Studies of respiratory mortality tended to support more immediate PM_2.5_ effects (i.e., lags of 0 to 2 days), but with initial evidence of stronger associations, in terms of magnitude and precision, at lags of 0−5 days. Collectively, the studies of respiratory morbidity and mortality that conducted systematic evaluations of PM_2.5_ associations across a range of lags provided evidence of effects within the range of 0−5 days after exposure.

As with respiratory effects, the majority of epidemiologic studies examining the lag structure of associations for cardiovascular effects focused on ED visits and hospital admissions. Studies of ED visits and hospital admissions for IHD, MI, and cardiovascular-related outcomes reported stronger associations for multiday lags, but these effects tended to be in the range of 0−1 or 0−2 days. When examining cerebrovascular disease, there was no evidence of an association at any of the lag days examined; however, when focusing on specific stroke types, particularly ischemic stroke, there was evidence of immediate effects at lags of 0 and 1 day, which was consistent with other cardiovascular outcomes. The immediate effects of PM_2.5_ on cardiovascular morbidity outcomes, specifically those related to ischemic events, were consistent with the lag structure of associations observed in studies of cardiovascular mortality that reported immediate effects (i.e., lag 0−1 day). There was some evidence indicating PM_2.5_-cardviovascular mortality associations with exposures over longer durations, but this was not supported by studies examining single-day lags that encompassed the same number of days.

An evaluation of epidemiologic studies of short-term PM_2.5_ exposure and mortality found that studies either conducted analyses of single-day lags over many days or various iterations of multiday lags (e.g., 0−1, 0−2, 0−3; 2019 PM ISA, Section 11.1.8.1). Across studies, associations were largest in terms of magnitude and precision for total (nonaccidental) mortality at lags of 0 to 1 day, but there was some evidence that associations remained positive at multiday lags up to 0−4 days. The combination of the multi- and single-day lag analyses provided further support of an immediate effect of short-term PM_2.5_ exposure on mortality.

### 2.2.3 Concentration-Response Relationship

In assessing the relationship between short- and long-term PM exposure and health effects, an important consideration is whether the relationship is linear across the full range of ambient concentrations and whether a threshold concentration exists below which there is no evidence of an effect. As detailed in the 2004 AQCD and 2009 PM ISA, conducting C-R and threshold analyses is challenging because of the “(1) limited range of available concentration levels (i.e., sparse data at the low and high end); (2) heterogeneity of (at-risk) populations (between cities); and (3) influence of measurement error” (U.S. EPA, 2004). Studies evaluated in the 2019 PM ISA that focused on the shape of the C-R curve expanded upon the health effects evaluated in previous reviews and continued to provide evidence of a linear, no-threshold relationship between both short- and long-term PM_2.5_ exposure and several respiratory and cardiovascular effects, and mortality. Some evidence indicated a steeper slope (i.e., supralinear curve) at lower concentrations for some outcomes (i.e., long-term PM_2.5_ exposure and mortality). Cutpoint analyses that focused on whether risk changed at different concentration ranges provided some evidence of nonlinearity, specifically in the relationship between short-term PM_2.5_ exposure and respiratory-related ED visits and hospital admissions. Although studies evaluated in the 2019 PM ISA have used many different statistical methods to examine the shape of the C-R relationship and generally provided evidence for a linear, no-threshold relationship, many of these studies have not systematically evaluated alternatives to a linear relationship.

#### 2.2.3.1 Short-Term Exposure

Epidemiologic studies evaluated in the 2019 PM ISA that examined the C-R relationship between short-term PM_2.5_ exposure and health were limited to studies of respiratory-related ED visits and hospital admissions (2019 PM ISA, Section 5.1.10.6) and mortality (2019 PM ISA, Section 11.1.10). Across studies that examined respiratory effects, different analytical methods have been employed to examine the C-R relationship, either explicitly examining the shape of the C-R curve and whether there was evidence of linearity across the full range of PM_2.5_ concentrations, or through cutpoint analyses that examine whether the risk of a PM_2.5_-related respiratory effect changed within specified ranges of PM_2.5_ concentrations. These studies primarily focused on asthma ED visits and hospital admissions, with some studies examining combinations of respiratory-related ED visits and hospital admissions. Studies that focused on the shape of the C-R curve provided initial evidence of a linear relationship for short-term PM_2.5_ exposure and both respiratory disease and asthma ED visits and hospital admissions, with less certainty at concentrations below 10 µg/m^3^. However, cutpoint analyses provided some initial evidence indicating nonlinearity in the relationship (i.e., larger risk estimates at various quintiles when compared with the lowest quintile) between short-term PM_2.5_ exposure and asthma ED visits and hospital admissions.

Studies that examined the C-R relationship for short-term PM exposure and mortality were initially limited to those focusing on PM_10_. Recent epidemiologic studies focused on PM_2.5_ and specifically the shape of the C-R curve at the low end of the PM_2.5_ concentration distribution. Evidence from U.S. studies conducted at lower PM_2.5_ concentrations compared with other countries, provided evidence indicating a linear relationship at concentrations as low as 5 µg/m^3^. The observations from C-R analyses were further supported by cutpoint analyses examining associations at different PM_2.5_ concentrations, as well as analyses that reported no evidence of a threshold. Overall, studies evaluated in the 2019 PM ISA focusing on short-term PM_2.5_ exposure and mortality supported a linear, no-threshold relationship at ambient PM_2.5_ concentrations lower than those evaluated in the 2009 PM ISA.

#### 2.2.3.2 Long-Term Exposure

The most extensive analyses of the C-R relationship between long-term PM exposure and a health effect have generally been for PM_2.5_ and mortality. Recent studies further expanded and provided new insights on the relationship between long-term PM_2.5_ exposure and mortality. In addition, these studies provided initial examinations of the C-R relationship for respiratory and cardiovascular effects, as well as for lung cancer incidence and mortality.

Although the C-R relationship for long-term PM_2.5_ exposure has not been assessed for most health effects, it has been extensively examined in studies of mortality (2019 PM ISA, Section 11.2.4). Across studies, a variety of statistical methods have been used to assess whether there is evidence of deviations in linearity. Studies have also conducted cutpoint analyses that focus on examining risk at specific ambient concentrations (2019 PM ISA, Table 11-7). These studies reported results that generally support a linear, no-threshold relationship for total (nonaccidental) mortality, especially at lower ambient PM_2.5_ concentrations, with confidence in the linear relationship as low as 5−8 µg/m^3^ in some studies. Additionally, there was initial evidence indicating that the slope of the C-R curve may be steeper (supralinear) at lower concentrations for cardiovascular mortality.

Few epidemiologic studies have examined the C-R relationship for long-term PM_2.5_ exposure and respiratory effects (2019 PM ISA, Section 5.2.3.1.2), but the ones that have focused on asthma incidence and childhood wheeze. Studies of asthma incidence that examined the shape of the C-R curve and whether risk changes at different quartiles of PM_2.5_ concentrations did not find any evidence of deviations in linearity and monotonically increasing risk, respectively. In an initial study of childhood wheeze, specifically repeated wheeze events, there was evidence of a linear C-R relationship with confidence in the linear relationship at long-term PM_2.5_ concentrations as low as 10 to 12 µg/m^3^.

A limited number of studies reported initial assessments of the C-R relationship for long-term PM_2.5_ concentrations and cardiovascular effects, specifically IHD incidence, CAC, and hypertension (2019 PM ISA, Section 6.2.16). For IHD incidence, there was evidence of a linear C-R relationship at concentrations below 15 µg/m^3^, which was consistent with the shape of the curve when compared with the full range of PM_2.5_ concentrations. Analyses of the relationship between long-term PM_2.5_ exposure and CAC indicated both linear and nonlinear relationships, while there is preliminary evidence of a linear relationship between long-term PM_2.5_ exposure and incidence of hypertension. A few studies that examined the relationship between long-term PM_2.5_ exposure and lung cancer incidence and mortality also examined the shape of the C-R curve by assessing its linearity and conducting cutpoint and threshold analyses (2019 PM ISA, Section 10.2.5.1.4). These collective assessments provided initial evidence supporting a no-threshold, linear relationship across the range of PM_2.5_ concentrations observed in the U.S., with confidence in a linear relationship as low as 5−10 µg/m^3^ in some studies.

### 2.2.4 PM Components and Sources

Building on the initial evaluation conducted in the 2004 PM AQCD, the 2009 PM ISA formally evaluated the relationship between exposures to PM components and sources and health effects. This evaluation found that many components and sources representative of combustion-related activities (e.g., motor vehicle emissions, coal combustion, oil burning, vegetative burning) were associated with a range of health effects. The 2009 PM ISA, therefore, concluded that “many [components] of PM can be linked with differing health effects and the evidence is not yet sufficient to allow differentiation of those components or sources that are more closely related to specific health outcomes.”

Building upon the evaluation of PM sources and components in the 2009 PM ISA, and as detailed in the Preface of the 2019 PM ISA, the 2019 PM ISA systematically evaluated whether specific PM components or sources were more strongly associated with health effects than PM mass by focusing on those studies that: (1) included a composite metric of PM (e.g., mass of PM_2.5_ and/or PM_10−2.5_, or in the case of ultrafine particles [UFP] mass, particle number) and PM components; (2) applied some approach to assess the particle effect (e.g., particle trap) of a mixture; or (3) conducted formal statistical analyses to identify source-based exposures (see 2019 PM ISA, Preface). Overall, these criteria allowed for a thorough evaluation of whether there was evidence that an individual component(s) and/or source(s) was more closely related to health effects than PM mass. Across the health effects categories evaluated in the 2019 PM ISA, most studies that examined PM sources and components focused on PM_2.5_. Thus, the following sections summarize the state of the science on PM_2.5_ components and sources for those health effects categories for which it was concluded within the 2019 PM ISA that there was a causal or likely to be causal relationship. Details on the PM_2.5_ components and sources evidence relevant to other health effects categories (e.g., Reproductive and Developmental Effects) are covered in the health chapters of the 2019 PM ISA.

Overall, recent studies continued to demonstrate that many PM_2.5_ components and sources were associated with health effects ranging from subclinical (e.g., changes in heart function, such as HRV, or circulating biomarkers) to the more overt (i.e., ED visits, hospital admissions, and mortality). The results of these studies confirmed and further supported the conclusion of the 2009 PM ISA that many PM_2.5_ components and sources are associated with many health effects and that the evidence does not indicate that any one source or component is consistently more strongly related with health effects than PM_2.5_ mass.

#### 2.2.4.1 Respiratory Effects

The examination of PM_2.5_ components and sources and respiratory effects was limited to epidemiologic studies (2019 PM ISA, Section 5.1.11). Epidemiologic studies that examined the relationship between respiratory health effects and short-term exposure to both PM_2.5_ mass (n = 113) and PM_2.5_ components, primarily focused on the components nitrate (n = 29), sulfate (n = 40), OC (n = 50), and EC/BC (n = 95). Across these studies, the health effects examined range from inflammation and changes in lung function to respiratory-related ED visits and hospital admissions. When examining the pattern of associations for individual PM_2.5_ components with those observed for PM_2.5_ mass, all the components examined (i.e., evaluated in at least three studies) were positively associated with a respiratory effect in at least a few studies (2019 PM ISA, Section 5.1.11.7). For EC/BC, the most extensively examined PM_2.5_ component, many studies reported positive associations, but some studies also reported results indicating no association, which was consistent with the pattern of associations for PM_2.5_ mass.

A more limited number of studies examined associations between long-term PM_2.5_ components exposure and respiratory effects (2019 PM ISA, Section 5.2.12). Similar to short-term exposure studies, most long-term exposure studies focused on EC/BC and did not observe a pattern of associations with respiratory effects different from that observed for PM_2.5_ mass. Collectively, positive associations were observed in studies examining short- and long-term PM_2.5_ component exposure and respiratory effects, but there was no evidence that any one component was more strongly associated with respiratory effects than PM_2.5_ mass.

Few studies examined the relationship between PM_2.5_ sources and respiratory health effects. Through analyses in which PM_2.5_ components were apportioned into source factors, positive associations were reported for several respiratory effects, particularly asthma exacerbation, and sources representative of combustion-related activities, such as traffic and biomass burning. No studies evaluated in the 2019 PM ISA examined long-term exposure to PM_2.5_ sources and respiratory effects.

#### 2.2.4.2 Cardiovascular Effects

Both epidemiologic and experimental studies examined the relationship between exposure to PM_2.5_ component and sources and cardiovascular effects (2019 PM ISA, Section 6.1.15). In short-term exposure studies, the epidemiologic evidence focused on studies examining cardiovascular-related ED visits and hospital admissions, with only a few studies examining other cardiovascular effects. Similar to respiratory effects studies, the cardiovascular effects studies that examined both PM_2.5_ mass and components (n = 14) focused most extensively on EC (n = 12), OC (n = 10), sulfate (n = 9), and nitrate (n = 9). Across all components examined, most were positively associated with cardiovascular-related ED visits and hospital admissions in at least one study (2019 PM ISA, Section 6.1.15). Although EC was positively associated with cardiovascular-related ED visits and hospital admissions in many of the studies evaluated, it was not possible to tell whether EC was independently associated or a marker of exposure to PM_2.5_ mass.

Few studies examined long-term exposure to PM_2.5_ components and cardiovascular effects, and those that did were consistent with the long-term exposure and respiratory effects studies that primarily focused on EC/BC (2019 PM ISA, Section 6.2.17). These studies did not provide evidence that any one component was more strongly associated with a cardiovascular effect. Collectively, studies examining short- and long-term PM_2.5_ components exposure continue to support that there is no evidence that any one component is more strongly associated with a cardiovascular effect than PM_2.5_ mass.

Epidemiologic and animal toxicological studies conducted source-based analyses using mathematical methods to apportion PM_2.5_ components into source factors (2019 PM ISA, Section 6.1.15.6 and Section 6.1.15.8). Epidemiologic studies focused on cardiovascular-related ED visits and hospital admissions and reported positive associations with sources representative of combustion-related activities (e.g., industrial combustion, traffic), with more limited evidence for wildfires. Animal toxicological studies, which focused on markers of heart function (e.g., HR, HRV), reported associations with a variety of source categories, but the associations were dependent on the location of the study (i.e., where the PM_2.5_ CAPs were collected). Additional studies focusing on long-term exposures to PM_2.5_ sources were fewer, with epidemiologic studies only examining traffic sources and animal toxicological studies reporting associations between a number of sources and various cardiovascular effects.

#### 2.2.4.3 Mortality

Epidemiologic studies that examined associations with PM_2.5_ components and sources and mortality have primarily focused on examining short- and long-term exposures to components (2019 PM ISA, Section 11.1.11 and Section 11.2.6). Both short- and long-term exposure studies reported consistent, positive associations with PM_2.5_ mass across all studies that also examined a PM_2.5_ component. Although the respiratory and cardiovascular effects studies focused mainly on EC/BC, the studies of mortality did not examine any one component disproportionately over the others. Of the PM_2.5_ components examined, each were found to be positively associated with mortality in at least a few studies, but overall, one component was not found to be as consistently associated with mortality as PM_2.5_ mass.

Compared with the 2009 PM ISA, in which most epidemiologic studies of mortality conducted formal source apportionment analyses, studies evaluated in the 2019 PM ISA have focused more exclusively on PM_2.5_ components. Of the limited number of studies that examined associations between short- and long-term source exposures and mortality, positive associations were observed for those sources representative of combustion-related activities, including traffic, coal, and vegetative fires.

### 2.2.5 Populations and Lifestages at Potentially Increased Risk of a PM-Related Health Effect

An important consideration in evaluating the scientific evidence for PM, and in determining the extent to which the NAAQS provides public health protection, is whether specific populations or lifestages are at increased risk of a PM-related health effect. As detailed in the preceding sections of this chapter and in health effects chapters of the 2019 PM ISA, a large body of evidence shows that health effects related to PM exposure, particularly PM_2.5_ exposure, occur across populations with diverse characteristics (e.g., children, older adults, people with preexisting cardiovascular diseases). Although this larger body of evidence provided information on the causal nature of the relationship between PM exposure and health effects, this section focuses on answering the following question:

Are there specific populations and lifestages at increased risk of a PM-related health effect, compared to a reference population? That is, is the magnitude of effect or exposure greater for some populations or lifestages compared to a reference population, where applicable?

The evaluation of populations and lifestages potentially at increased risk builds off the approach used in the 2009 PM ISA and involved application of a framework detailed in the 2013 O_3_ ISA to characterize the evidence informing whether a population or lifestage is at increased risk (U.S. EPA, 2013). The focus of this evaluation was on determining the extent to which specific factors may increase the risk of a PM-related health effect in a population or lifestage relative to a reference population, where applicable. Importantly, this evaluation builds on the conclusions drawn elsewhere in the 2019 PM ISA, taking into consideration the relationship between exposure to PM and health effects. As detailed in the Preamble to the ISAs (U.S. EPA, 2015), the evaluation of the evidence includes (1) epidemiologic studies that conducted stratified analyses, (2) evidence from animal toxicological studies using animal models of disease and epidemiologic or controlled human exposure studies conducted in specific populations (e.g., lung function growth in children, people with mild asthma), (3) information on the dosimetry of PM within the body, and (4) consideration of information on differential exposure to PM within a population or lifestage. Overall, the framework allows for a transparent characterization of the collective body of evidence to draw conclusions on the degree to which the scientific evidence indicates that a specific population or lifestage is at increased risk of a PM-related health effect (2019 PM ISA, Table 12-1).

The causality determinations briefly summarized within this section, which are more fully detailed in the health effects chapters of the 2019 PM ISA, suggest that the strongest evidence indicating an effect of short- and long-term PM exposure on health is for PM_2.5_ and the broad health categories of respiratory and cardiovascular effects, nervous system effects, cancer, and mortality. Thus, the assessment of populations and lifestages potentially at increased risk of a PM_2.5_-related health effect primarily focused on studies that form the basis of these causality determinations that also conducted analyses to inform whether there is differential risk in a specific population or lifestage. In evaluating studies, several factors can influence the ability to observe an association, including, but not limited to, publication bias (i.e., not reporting null findings when examining evidence of differential risk), variability in how indicators or metrics are defined across studies (e.g., socioeconomic status, obesity, age), and variability in the population as a whole, particularly with respect to behavioral differences, biological differences (e.g., obese versus nonobese), and adherence to treatment for preexisting diseases.

Of the factors evaluated (2019 PM ISA, Table 12-3 for a full list), children and race were the only factors for which it was concluded that “adequate evidence” was available, indicating that people of a specific lifestage and race are at increased risk of PM_2.5_-related health effects (2019 PM ISA, Section 12.5.1.1 and Section 12.5.4). Although stratified analyses do not indicate a difference in the risk of PM-related health effects between children and adults, there was strong evidence from studies focusing on children that demonstrated health effects only observable in growing children that were attributed to PM_2.5_ exposure. Specifically, epidemiologic studies evaluated in the 2019 PM ISA of long-term PM_2.5_ exposure provided strong evidence of impaired lung function growth with additional evidence of decrements in lung function and the development of asthma. The results of these longitudinal epidemiologic studies were consistent with and extended the evidence that was available in the 2009 PM ISA demonstrating health effects in children due to long-term PM_2.5_ exposure. The conclusion of “adequate evidence” for race was based on studies that examined whether there was evidence of increased risk for PM_2.5_-related health effects as well as studies that examined differential exposure by race. Multiple studies reported that minority populations (often defined as non-White populations within individual studies) across different geographical regions are exposed to higher PM_2.5_ concentrations and were at increased risk for PM_2.5_-related mortality, particularly due to long-term exposure. Collectively, the combination of evidence demonstrated that minority populations are at greater risk for both PM_2.5_-related health effects and PM_2.5_ exposure than are Whites.

There was “suggestive evidence” that populations with preexisting cardiovascular (2019 PM ISA, Section 12.3.1) or respiratory (2019 PM ISA, Section 12.3.5) disease, those who are overweight or obese (2019 PM ISA, Section 12.3.3), those with particular genetic variants (2019 PM ISA, Section 12.4), those who are of low SES (2019 PM ISA, Section 12.5.3), and those who are current or former smokers (2019 PM ISA, Section 12.6.1) are at increased risk for PM_2.5_-related health effects. Epidemiologic studies that conducted analyses stratified by preexisting cardiovascular disease tended to focus on hypertension, one of the most easily measurable cardiovascular conditions, and did not consistently indicate increased risk for several outcomes examined (e.g., mortality, stroke, BP). However, the strong evidence supporting a causal relationship between short- and long-term PM_2.5_ exposure and cardiovascular effects, which included cardiovascular-related mortality and ischemic heart disease (2019 PM ISA, Section 6.1.16 and Section 6.2.18) indicated that individuals with underlying cardiovascular conditions related to these serious outcomes may be at increased risk of a PM_2.5_-related health effect. Similarly, there were few studies that evaluated whether there is evidence of increased risk of a PM_2.5_-related health effect between people with preexisting asthma (2019 PM ISA, Section 12.3.5) and COPD (2019 PM ISA, Section 12.3.5) compared with people that do not have a preexisting respiratory disease. However, epidemiologic studies, particularly those studies examining short-term PM_2.5_ exposure and asthma or COPD ED visits and hospital admissions reported generally consistent positive associations (2019 PM ISA, Section 5.1.2.1 and Section 5.1.4.1), which represent exacerbations that are only possible in people with asthma or COPD. Therefore, there was limited evidence to support that people with preexisting respiratory diseases, specifically asthma or COPD, are at increased risk for a PM_2.5_-related health effect, but there was generally consistent evidence demonstrating these populations experience health effects due to a PM_2.5_ exposure.

Studies that examined whether being obese or overweight increased the risk of a PM_2.5_-related health effect, reported evidence of increased risk for mortality associated with long-term exposures to PM_2.5_, but inconsistent evidence was found for subclinical cardiovascular outcomes, when comparing obese or overweight individuals with normal weight individuals. However, the evaluation of studies focusing on differences in risk by weight were complicated by the different definitions of obesity used across studies.

The examination of whether specific genetic characteristics dictate increased risk of a PM_2.5_-related health effect involved studies of genetic variants. Across the large number of genetic variants examined there was a consistent trend for increased risk of respiratory and cardiovascular effects associated with PM_2.5_ exposure across gene variants involved in the glutathione transferase pathway. These results were consistent with underlying mechanisms that provided biological plausibility for PM_2.5_-related health effects and have shown that oxidative stress is an early response to PM_2.5_ exposure.

Epidemiologic studies have examined several measures of SES (e.g., income level, educational attainment) in assessing whether populations are at increased risk of a PM_2.5_-related health effect. In studies examining both differential exposure and increased risk of health effects, there was some evidence that low SES populations are more likely to have higher PM_2.5_ exposures and that low SES populations, as measured by metrics for income, are at increased risk of PM_2.5_-related mortality when compared with populations defined as higher SES. Finally, there was some epidemiologic evidence from studies examining long-term PM_2.5_ exposure and lung cancer incidence and mortality, as well as total mortality, that people who currently smoke or were former smokers may be at increased risk of a PM_2.5_-related health effect compared with never smokers.

For the remaining factors evaluated, “inadequate evidence” exists to determine whether having diabetes (2019 PM ISA, Section 12.3.2), being in an older lifestage (i.e., older adults; 2019 PM ISA, Section 12.5.1.2), residential location (including proximity to source and urban residence; 2019 PM ISA, Section 12.5.5), sex (2019 PM ISA, Section 12.5.2), or diet (2019 PM ISA, Section 12.6.2) increase the risk of PM_2.5_-related health effects. Across these factors there was either limited assessment of differential risk or exposure (i.e., residential location, diet), or inconsistency in results across studies to support evidence of increased risk of a PM_2.5_-related health effect (i.e., diabetes and sex). Instead, the inconsistency in the evidence makes the determination of disproportionately increased risk more difficult. For example, for older adults (2019 PM ISA, Section 12.5.1.2) there was a relatively small number of studies that examined whether there is evidence of differential risk between age groups. In the evaluation of these studies there was limited evidence indicating that older adults are at increased risk of PM_2.5_-related health effects compared with other age ranges; however, epidemiologic studies focusing only on older adults demonstrated associations with respiratory-related ED visits and hospital admissions with additional, but more limited, evidence of subclinical cardiovascular effects from epidemiologic panel studies and controlled human exposure studies.

## 2.3 Welfare Effects

Whereas the evaluation of the evidence for PM exposures and health effects was specific to exposure duration (i.e., short- and long-term) and PM size fraction (i.e., PM_2.5_, PM_10−2.5_, and UFP), the evaluation of the evidence for welfare effects focused generally on whether there was a causal relationship between PM and visibility impairment, climate effects, and effects on materials. As detailed below, the evidence continued to support a causal relationship between PM and visibility impairment (2019 PM ISA, Section 1.6.1), climate effects (2019 PM ISA, Section 1.6.2), and materials effects (2019 PM ISA, Section 1.6.3).

### 2.3.1 Visibility Impairment

It is well known that light extinction from pollution is primarily due to PM_2.5_, resulting in the 2019 PM ISA concluding there is a causal relationship between PM and visibility impairment, which was consistent with the conclusions of the 2009 PM ISA (Table 2-3). This conclusion was based on additional characterization of the effect of PM size and composition on light extinction.

The relationship between PM and light extinction has been well documented (2019 PM ISA, Section 13.2.2). Although reconstruction of light extinction is best achieved with detailed information on the size and composition of PM measurements, empirical relationships between light extinction of PM components are more practical and have been successfully evaluated and widely used (2019 PM ISA, Section 13.2.3). Light extinction has been found to vary depending on the available PM species monitoring data, with light extinction efficiencies varying by a factor of 10 between species. Additionally, the variation in PM species by region and season, as well as urban and rural location, can affect light extinction. The steep decline in PM_2.5_ sulfate of −4.6% per year in rural areas and −6.2% per year in urban areas from 2002 to 2012 (2019 PM ISA, Section 1.2.1) has affected the apportionment of light extinction among PM_2.5_ species. Although PM_2.5_ sulfate is still a major contributor to light extinction, visibility in many areas has improved, and a smaller and less seasonally variable fraction of light extinction can be attributed to PM_2.5_ sulfate, with an increasing share due to nitrate and organic matter (2019 PM ISA, Section 13.2.4).

### 2.3.2 Climate Effects

Substantial evidence indicates that PM affects the radiative forcing of the climate system, both through direct scattering and absorption of radiation, and indirectly, by altering cloud properties, resulting in the conclusion that there is a causal relationship between PM and climate effects, which was consistent with the conclusions of the 2009 PM ISA (2019 PM ISA, Table 1-3). This conclusion was based on multiple studies evaluated in the 2019 PM ISA that have strengthened the evidence for the effects of PM on radiative forcing and have improved the characterization of major sources of uncertainty in estimating PM climate effects, including the indirect radiative forcing effects associated with PM-cloud interactions, and the additional climate effects and feedbacks involving atmospheric circulation and the hydrologic cycle resulting from PM effects on radiative forcing.

Because of these radiative effects, the net effect of PM has been to cool the planet over the last century, masking some of the effects of greenhouse gases on warming (2019 PM ISA, Section 13.3.3). The decrease in PM concentrations in many developed countries over the last few decades has likely contributed to the recent shift toward “global brightening,” which may in turn have helped drive rapid warming in North America and Europe because this greenhouse-gas warming was unmasked (2019 PM ISA, Section 13.3.6). In developing countries in Asia, by contrast, PM concentrations have increased over the last several decades, but the associated radiative forcing effects are highly uncertain, due to uncertainties in emissions estimates and the lack of accurate information on the proportion of reflecting versus absorbing species. Although uncertainties in the relationship between PM and climate effects have been further studied and characterized since the 2009 PM ISA, there are still substantial uncertainties with respect to key processes linking PM and climate, specifically the interaction between clouds and aerosols. This is because of the small scale of PM-relevant cloud microphysical processes compared with the coarse resolution of state-of-the-art models, and because of the complex cascade of indirect effects and feedbacks in the climate system that result from a given initial radiative perturbation caused by PM.

### 2.3.3 Materials Effects

Multiple studies evaluated in the 2019 PM ISA further characterized soiling and corrosion processes associated with PM and add to the body of evidence of PM damage to materials. Approaches to quantify pollutant exposure corresponding to perceived soiling and damage continue to indicate that deposition can result in increased cleaning and maintenance costs and reduced usefulness of soiled material. The combination of this evidence resulted in the conclusion that there is a causal relationship between PM and effects on materials, which was consistent with the conclusions of the 2009 PM ISA (Table 2-3).

Assessments of the relationship between PM and effects on materials have often focused on quantitative assessments including the development of dose-response relationships and application of damage functions to stone used for historic monuments and buildings. Recent studies provided additional information on understanding soiling and corrosion process for glass and metals and have allowed for the development of new dose-response curves (2019 PM ISA, Section 13.4.3), particularly for glass, as well as new damage functions for materials (2019 PM ISA, Section 13.4.4). Additional evidence demonstrated that atmospheric soiling can affect energy costs and climate control, energy consumption of large buildings, and the efficiency of photovoltaic systems (2019 PM ISA, Section 13.4.2).

Table 2-3 Key evidence contributing to causal causality determinations for PM exposure and welfare effects evaluated in the 2019 Integrated Science Assessment for Particulate Matter

Key Evidence in 2019 PM ISA | Welfare Effect Category^a^ and Causality Determination
Visibility Impairment and PM Exposure (2019 PM ISA, Section 13.2): Causal Relationship; No Change in Causality Determination from the 2009 PM ISA; New Evidence Further Supports the Previous Determination.
Section 13.2.6 | Visibility impairment by atmospheric PM, with the strongest effects in the size range from 0.1 to 1.0 µm, was supported by numerous studies summarized in the 1969 PM AQCD (NAPCA, 1969), although the relationship between PM and atmospheric visibility impairment was well established decades earlier. Additional studies supporting the relationship have been described in subsequent documents, and additional new evidence is based on extensive simultaneous network measurements of PM_2.5_ and light extinction.
Climate Effects and PM Exposure (2019 PM ISA, Section 13.3): Causal Relationship; No Change in Causality Determination from the 2009 PM ISA; New Evidence Further Supports the Previous Determination.
Section 13.3.9 | Effects of PM on radiative forcing of the climate system through both absorption and scattering of radiation directly, as well as through indirect effects involving interactions between PM and cloud droplets, with corresponding effects on temperature, precipitation, and atmospheric circulation, was supported by numerous observational and modeling studies. Research since the 2009 PM ISA (U.S. EPA, 2009) has improved understanding of climate-relevant aerosol properties and processes, as well as characterized key sources of uncertainty in estimating PM climate effects, particularly with respect to PM-cloud interactions.
Materials Effects and PM Exposure (2019 PM ISA, Section 13.4): Causal Relationship; No Change in Causality Determination from the 2009 PM ISA; New Evidence Further Supports the Previous Determination.
Section 13.4.5 | Both soiling and corrosion associated with PM contribute to materials damage (U.S. EPA, 2009, 2004, 1982). Deposition of PM can physically affect materials by promoting or accelerating the corrosion of metals, by degrading paints, and by deteriorating building materials such as stone, concrete, and marble. Further characterization of PM effects on glass and metals, along with quantitative dose-response relationships and damage functions for stone and other materials lend additional support to the causal relationship in the 2009 PM ISA. Studies evaluated in the 2019 PM ISA showed that deposition of PM reduces energy efficiency of photovoltaic systems.

AQCD = Air Quality Criteria Document; PM = particulate matter.

a The sections referenced in the 2019 PM ISA include a detailed discussion of the available evidence that informed the causality determinations.

10 Composite measures of PM may include mass, volume, surface area, or number concentration.

11 Since the 2009 PM ISA, the causality determination language has been updated and this category is now stated as suggestive of, but not sufficient to infer, a causal relationship.

12 Throughout this Supplement, as detailed in the Preface of the 2019 PM ISA (Section P.3.2.2), risk estimates from epidemiologic studies examining short-term exposures are for a 10 μg/m^3^ increase in 24-hour avg PM_2.5_ concentrations and long-term exposures are for a 5 μg/m^3^ increase in annual concentrations, unless otherwise noted.