# 1 INTRODUCTION AND SCOPE

## 1.1 Introduction

The U.S. Environmental Protection Agency (EPA) completed the Integrated Science Assessment for Particulate Matter (PM ISA) in December 2019 (hereafter referred to as the 2019 PM ISA) (U.S. EPA, 2019). The 2019 PM ISA builds upon the evidence evaluated and scientific conclusions presented in prior assessments, including the 2009 PM ISA (U.S. EPA, 2009) and earlier assessments, e.g., 2004 PM Air Quality Criteria Document [AQCD; (U.S. EPA, 2004)] and 1996 PM AQCD (U.S. EPA, 1996). Within the 2019 PM ISA, evidence spanning scientific disciplines (e.g., atmospheric chemistry, exposure science, animal toxicological, human clinical, epidemiology) was evaluated to assess the causal nature of relationships between short- and long-term^3^ PM exposure and health and PM and nonecological welfare effects using a weight-of-evidence approach extensively detailed in the Preamble to the Integrated Science Assessments (U.S. EPA, 2015) and the Appendix of the 2019 PM ISA.^4^

The key science judgments (i.e., causality determinations) detailed within the 2019 PM ISA directly informed the development of conclusions outlined within the Policy Assessment for the Review of the PM NAAQS (2020 PM PA) (U.S. EPA, 2020b). These key science judgments formed the basis of the discussion on potential alternative primary and secondary National Ambient Air Quality Standards (NAAQS) for PM within the 2020 PM PA and were considered in EPA’s final decision in the 2020 review to retain the PM NAAQS (see Section 1.3.5, (U.S. EPA, 2022)).

On June 10, 2021, EPA announced it is reconsidering the December 2020 decision to retain the PM NAAQS “because available scientific evidence and technical information indicate that the current standards may not be adequate to protect public health and welfare, as required by the Clean Air Act. EPA explained that as part of the reconsideration process “the agency will develop a supplement to the 2019 [PM ISA] that will take into account the most up-to-date science” (EPA Press Office, 2021).^5^ As a result, the evidence presented within the 2019 PM ISA, along with the targeted identification and evaluation of new scientific information in this Supplement, provide the scientific basis to support a robust and thorough reconsideration of the 2020 PM NAAQS.

## 1.2 Rationale and Scope

In completing the review of the PM NAAQS in December 2020, EPA provisionally considered numerous studies published after the literature cutoff date (approximately January 2018) for the 2019 PM ISA. In reviewing these studies, as explained in Responses to Significant Comments on the 2020 Proposed Decision on the National Ambient Air Quality Standards for Particulate Matter, EPA “concluded that none of the studies materially change any of the broad scientific conclusions of the ISA regarding the health and welfare effects of PM or warrant reopening the air quality criteria for this review” (U.S. EPA, 2020c).

To inform the reconsideration of the PM NAAQS, EPA determined that a thorough evaluation is warranted of some studies that became available after the literature cutoff date of the 2019 PM ISA that could either further inform the adequacy of the current PM NAAQS or address key scientific topics that have evolved since the literature cutoff date for the 2019 PM ISA. Additionally, the evaluation of recent studies identified would occur in the form of a supplement and EPA would rely on the Supplement to the 2019 PM ISA and the 2019 PM ISA as the scientific foundation for the reconsideration, rather than revising the 2019 PM ISA or developing a new PM ISA. To facilitate the identification and evaluation of recent studies that warrant review, the developed a rationale (Section 1.2.1) and scope (Section 1.2.2) for this Supplement to the 2019 PM ISA to focus on specific PM-related health and welfare effects most pertinent to EPA in support of the reconsideration of the primary and secondary PM NAAQS. This targeted approach to developing the Supplement to the 2019 PM ISA for the purpose of reconsidering the 2020 PM NAAQS decision does not reflect a change to EPA’s approach for developing ISAs for NAAQS reviews.

### 1.2.1 Rational for Inclusion of Health and Welfare Effects

The causality determinations presented within the 2019 PM ISA (discussed in Section 2), in combination with the characterization of the science with respect to the health and welfare effects of PM presented in the 2020 PM PA, form the basis of the rationale for the health and welfare effects evaluated within this Supplement. The following section provides specific details on the rationale for the types of evidence included, which ultimately forms the basis of the scope that governs the studies considered for inclusion in this Supplement.

In selecting the health effects to evaluate within this Supplement, the primary rationale is based on the causality determinations for health effect categories presented in the 2019 PM ISA, and the subsequent use of the health effects evidence in the 2020 PM PA (U.S. EPA, 2020b). “In considering the public health protection provided by the current primary PM_2.5_ standards, and the protection that could be provided by alternatives, [EPA, within the 2020 PM PA] emphasized health outcomes for which the ISA determined that the evidence supports either a causal or a likely to be causal relationship with PM_2.5_ exposures” (U.S. EPA, 2020b). Although the 2020 PM PA initially focused on this broader set of evidence, the basis of the discussion on potential alternative standards primarily focused on health effect categories for which the 2019 PM ISA concluded a causal relationship (i.e., short- and long-term PM_2.5_ exposure and cardiovascular effects and mortality) as reflected in Figures 3-7 and 3-8 of the 2020 PM PA (U.S. EPA, 2020b). Therefore, within this Supplement the focus is only on the health effects evidence for which the 2019 PM ISA concluded a causal relationship.

In addition, this Supplement also considers recent health effects evidence that addresses key scientific topics for which the literature has evolved since the 2020 PM NAAQS review was completed, specifically since the literature cutoff date for the 2019 PM ISA. These key scientific topics include experimental studies conducted at near-ambient concentrations, epidemiologic studies that employed statistical approaches that attempt to more extensively account for confounders and are more robust to model misspecification (i.e., used alternative methods for confounder control)^6^ or conducted accountability analyses, studies that assess the relationship between PM_2.5_ exposure and severe acute respiratory syndrome coronavirus 2 (SARS-CoV-2) infection and coronavirus disease 2019 (COVID-19) death; and in accordance with recent EPA goals on addressing environmental justice [e.g., U.S. EPA (2021)], studies that examine disparities in PM_2.5_ exposure and the risk of health effects by race/ethnicity and socioeconomic status (SES).

In identifying the studies to consider for inclusion within this Supplement, the focus was on those studies conducted in locations that were most informative to the reconsideration of the 2020 PM NAAQS. This criterion resulted in an assessment of the scientific literature that is more refined compared with the 2019 PM ISA. While the 2019 PM ISA considered and included studies conducted globally when evaluating the evidence and forming causality determinations, the rationale for the scope of this Supplement is directly informed by policy considerations surrounding the types of scientific information included in the 2020 PM PA. In addition to focusing on studies for health effect categories for which the 2019 PM ISA concluded causal or a likely to be causal relationship, as noted above, the 2020 PM PA also focused on a narrower set of studies conducted in locations that are most relevant to informing the level, form, averaging time, and indicator of the NAAQS for PM. Specifically, the 2020 PM PA states that the emphasis is on “multicity studies that examine health effect associations in the U.S. or Canada, as such studies examine potential associations over large geographic areas with diverse atmospheric conditions and population demographics (e.g., U.S. EPA (2019), Sections 11.1 and 11.2). Additionally, studies examining associations outside the U.S. or Canada reflect air quality and exposure patterns that may be less typical of the U.S., and thus less likely to be informative for purposes of reviewing the NAAQS” (U.S. EPA, 2020b).^7^ Therefore, within this Supplement the studies considered for inclusion are limited to those studies conducted in the U.S. and Canada. However, it is the combination of the scientific evidence detailed in the 2019 PM ISA and this Supplement that forms the complete scientific record informing the reconsideration of the 2020 PM NAAQS.

Consistent with the rationale for the health effects, the selection of welfare effects to evaluate within this Supplement is based on the causality determinations reported in the 2019 PM ISA and the subsequent use of scientific evidence in the 2020 PM PA. The 2019 PM ISA concluded a causal relationship for each of the welfare effects categories evaluated (i.e., visibility, climate effects, and materials effects). While the 2020 PM PA considered the broader set of evidence for these effects, for climate effects and material effects, it concluded that there remained “substantial uncertainties with regard to the quantitative relationships with PM concentrations and concentration patterns that limit[ed] [the] ability to quantitatively assess the public welfare protection provided by the standards from these effects” (U.S. EPA, 2020b). Given these uncertainties and limitations, the basis of the discussion on conclusions regarding the secondary standards in the 2020 PM PA primarily focused on visibility effects. Therefore, this Supplement focuses only on visibility effects in evaluating newly available scientific information, and consistent with the health effects rationale, is limited to studies conducted in the U.S. and Canada.

### 1.2.2 Scope

Building on the rationale presented in Section 1.2.1, the scope of this Supplement provides specific criteria for the types of studies considered for inclusion within the Supplement. Specifically, studies must be peer reviewed and published between approximately January 2018 and March 2021, and satisfy the following criteria:

#### Health Effects

- U.S. and Canadian epidemiologic studies for health effect categories for which the 2019 PM ISA concluded a causal relationship (i.e., short- and long-term PM_2.5_ exposure and cardiovascular effects and mortality)
  ○ U.S. and Canadian epidemiologic studies that employed alternative methods for confounder control or conducted accountability analyses (i.e., examined the effect of a policy on reducing PM_2.5_ concentrations)^8^

#### Key Scientific Topics

- Experimental studies (i.e., controlled human exposure and animal toxicological) conducted at near-ambient PM_2.5_ concentrations experienced in the U.S.
- U.S.- and Canadian-based epidemiologic studies that examined the relationship between PM_2.5_ exposures and SARS-CoV-2 infection and COVID-19 death
- At-risk populations
  ○ U.S.- and Canadian-based epidemiologic or exposure studies examining potential disparities in either PM_2.5_ exposures or the risk of health effects by race/ethnicity or SES

#### Welfare Effects

- U.S. and Canadian studies that provide new information on public preferences for visibility impairment and/or developed methodologies or conducted quantitative analyses of light extinction

Given the scope of this Supplement (i.e., not focusing on the broader body of experimental studies), it is important to recognize the evaluation conducted does not encompass the full multidisciplinary evaluation presented within the 2019 PM ISA as described in the Preamble to the Integrated Science Assessments (U.S. EPA, 2015) that would result in weight-of-evidence conclusions on causality (i.e., causality determinations). Additionally, this scope does not allow for the evaluation of recent studies for health effect categories from the 2019 PM ISA for which a likely to be causal relationship was concluded nor an assessment as to whether recent evidence may strengthen the causality determination to a causal relationship.^9^ Therefore, this Supplement critically evaluates and provides key study-specific information for only those recent studies deemed to be of greatest significance for impending regulatory decisions regarding the PM NAAQS in the context of the body of evidence and scientific conclusions presented in the 2019 PM ISA. As such, the Supplement indicates whether recent evidence supports (is consistent with), supports and extends (is consistent with and reduces uncertainties), or does not support (is not consistent with) the causality determinations described in the 2019 PM ISA.

## 1.3 Development of the Supplement

The process used in developing this Supplement is consistent with the 2019 PM ISA as captured in the Preface and Appendix of the 2019 PM ISA. Because this Supplement builds on the 2019 PM ISA, that process is not reiterated but instead is cross referenced. Within the 2019 PM ISA, the Preface provides a detailed description of the process for developing ISAs (Section P.3.), including a discussion of the scope of the ISA (Section P.3.1.) and how evidence is evaluated (Section P.3.2.). A more detailed description of the process of evaluating evidence in ISAs is described in the Preamble to the Integrated Science Assessments (U.S. EPA, 2015) with information specific to the PM ISA in the Appendix of the 2019 PM ISA. Specifically, the Appendix describes in detail the various steps that encompassed the development of the PM ISA. These steps include the literature search and the evaluation of individual study quality, which details scientific considerations for evaluating the strength of inference from studies that examined the health effects of PM (2019 PM ISA, Section A.3.2., Table A-1). The information presented in Table A-1 in the 2019 PM ISA, which includes the identification and rationale behind advantageous study characteristics (e.g., study design, study population, exposure assessment) as well as information on the selection of results to present from individual studies, was relied upon in the process of considering and identifying recent studies evaluated within this Supplement.

## 1.4 Organization of the Supplement

The Supplement to the 2019 PM ISA is not intended to be a stand-alone document, but instead to build on the established scientific record regarding the health and welfare effects of PM presented in the 2019 PM ISA and prior assessments. As a result, this Supplement evaluates selected recent studies (i.e., studies published since the literature cutoff date of the 2019 PM ISA and that fall within the scope as outlined above) in the context of the scientific conclusions presented in the 2019 PM ISA.

This Supplement includes chapters and sections incorporated verbatim from the 2019 PM ISA to provide the background information and scientific conclusions necessary to put recent studies in the appropriate context. Section 2 of this Supplement consists of the Integrated Synthesis chapter (Chapter 1) of the 2019 PM ISA, which integrates and summarizes the overall scientific conclusions of the 2019 PM ISA. Section 3 represents the evaluation of the health effects evidence (i.e., short- and long-term PM_2.5_ exposure and cardiovascular effects and mortality) that falls within the scope of this Supplement. The organization of Section 3 is consistent with the overall organization of the health effects discussion in the 2019 PM ISA, which includes separate discussions of the evidence organized in relation to exposure duration (i.e., short- or long-term exposure) and then within the exposure duration sections discussions organized around specific health effects (e.g., myocardial infarction, nonaccidental mortality) and specific issues of importance (e.g., copollutant confounding, concentration-response relationship). In addition, within each section of Section 3, the summary and causality determination from the 2019 PM ISA is presented to capture the scientific conclusions of the ISA, which recent literature builds upon. The sections that follow in Section 3 evaluate and integrate the evidence from recent studies and ultimately assess the results of recent studies in the context of the causality determinations presented in the 2019 PM ISA. Additionally, Section 3 evaluates recent studies that assess key science topics that have evolved since the completion of the 2019 PM ISA. Study-specific details for the epidemiologic studies evaluated in Section 3, such as information on study population, exposure assessment, PM_2.5_ concentrations, and confounder control (e.g., copollutants) are detailed in tables presented in Section 3. Section 4 consists of an evaluation of recent studies that inform visibility effects and is organized similar to the health effects chapter. Therefore, Section 4 first presents the summary and causality determination from the 2019 PM ISA, then evaluates recent studies, and concludes by assessing new evidence in the context of the conclusions for visibility impairment presented in the 2019 PM ISA. Finally, Section 5 provides a summary and presents overarching conclusions based on the evaluation of recent studies within this Supplement.

3 Consistent with the scope of the 2019 PM ISA (Section P.3.1), short-term exposures are defined as those exposures occurring over hours up to 1 month, whereas long-term exposures are defined as those exposures occurring over 1 month to years.

4 Hereafter welfare effects refers to nonecological welfare effects, unless otherwise noted. The ecological effects resulting from the deposition of PM and PM components are being considered in a separate assessment as part of the review of the secondary (welfare-based) NAAQS for oxides of nitrogen, oxides of sulfur, and PM (U.S. EPA, 2020a).

5 See Section 1.4 of the Policy Assessment for the Reconsideration of the National Ambient Air Quality Standards for Particulate Matter for additional details (U.S. EPA, 2022).

6 In the peer-reviewed literature, these epidemiologic studies are often referred to as causal inference studies or studies that used causal modeling methods. For the purposes of this Supplement, this terminology is not used to prevent confusion with the main scientific conclusions (i.e., the causality determinations) presented within an ISA. In addition, as is consistent with the weight-of-evidence framework used within ISAs and discussed in the Preamble to the Integrated Science Assessments, an individual study on its own cannot inform causality, but instead represents a piece of the overall body of evidence.

7 This emphasis on studies conducted in the U.S. or Canada is consistent with the approach in previous reviews of the PM NAAQS (U.S. EPA (2011), section 2.1.3).

8 These studies do not include studies that instituted a specific action or intervention to reduce or mitigate exposure, such as the installation of high efficiency particle filters (HEPA) or indoor air cleaners.

9 The narrow scope also does not allow for the evaluation of recent studies for health effect categories from the 2019 PM ISA where suggestive of, but not sufficient to infer, a causal relationship and inadequate to infer the presence or absence of a causal relationship was concluded.