# Appendix A

Table A-1 Study-specific details for epidemiologic studies of short-term PM_2.5_ exposure and cardiovascular effects

Study/Location, Years | Study Population | Exposure Assessment | Mean and Upper Percentile Concentrations (µg/m^3^)^a^ | Outcome | Confounders Considered | Copollutant Examination
Wei et al. (2019); Continental U.S.; 2000−2012 | Medicare; ≥ 65 yr | Daily concentration for 1 × 1 km grid cells using validated satellite based neural network model calibrated using data from monitors (n = 1,928), C-V R2 = 0.83 overall, 0.78−0.88 by region (Di et al., 2016); Lag 0−1-day avg assigned based on ZIP code of residence. | NR | HA discharge data recorded on Medicare claims | Age, race, sex, MI, diet, time-invariant behavior factors, ZIP code-level SES, population density, ethnicity, access to parks, food, drug stores, day of week, seasonality, long-term trends.; Temperature controlled using cubic spline with up to 9 df. | Correlation (r):; NA; Copollutant models with: NA
Leiser et al. (2019); Wasatch Front, UT; (4 counties); 1999−2009 | Medicare; n = 19,602 (2,032 cardiac events); ≥ 65 yr | Daily average for ZIP code centroids (n = 123) using inverse distance weighting.; Lags 0, 1, 0−2, and 0−6 days. | Lag 0: 10.96; Lag 1: 10.95; 3-day avg: 10.96; 7-day avg: 10.79 | Hospital re-admission for IHD, MI (ICD-9 410), HF (ICD-9 428), dysrhythmia/arrhythmia (ICD 427) | Maximum daily temperature, ZIP code- level median house-hold income, Charlson Comorbidity Index, enrollment in Medicare part A and B. | Correlation (r):; NA; Copollutant models with: NA
Wing et al. (2017); Nueces county, TX; 2000−2012 | BASIC; n = 317 events; ≥ 65 yr | Daily PM_2.5_ concentration from centrally located monitor. Lag 1 day. | Median: 7.7; IQR: 5.6 to 10.7 | Passive and active surveillance of IS (i.e., acute onset neurologic lasting > 24 h) | Temperature and relative humidity, individual-level characteristics and time trends controlled by design | Correlation (r): NA; Copollutant models with: Ozone; Results did not change after co-adjustment
Evans et al. (2017); Monroe County, NY; 2007−2012 | Coronary syndrome/unstable angina patients (n = 362); Mean age: 62.3 ± 12.9 | Hourly average concentrations, one monitor, east side of Rochester adjacent to two major highways, patients reside within 15 miles of monitor. 1 h avg. | Mean (IQR):; 7.1 (7.62) all year;; 8.18 (5.96) Nov−Apr;; 7.08 (7.80) May−Oct; Upper (75th):; 10.30 all year;; 10.60 Nov−Apr; 9.80 May−Oct; Upper (Max):; 79.2 all year;; 79.20 Nov−Apr;; 64.01 May−Oct | Physician-diagnosed STEMI (> 1 mm in ≥ 2 contiguous precordial leads, or ≥ 2 adjacent limb leads, or new or presumed-new left bundle branch block with angina) | 3 h avg temp, RH | Copollutant models with: NA; Correlation (r):; Delta-C: 0.31; BC: 0.57; NO_2_: 0.38; SO_2_: −0.01; Ozone: 0.11; CO: 0.29
Liu et al. (2020); Calgary, Alberta Canada; 2004−2012 | APPROACH; n = 6,142 HAs; among patients admitted to cardiology services | Hourly concentrations from three monitors positioned to represent background used to compute daily average PM_2.5_ concentration.; Long-term NO_2_ concentrations at ZIP code of residential address estimated using LUR (Bertazzon et al., 2015). Lag 0, 1, 2 day and 3-, 5-day avgs. | Mean (SD): 9.79 (5.91); Median: 7.00; IQR: 6.17; Upper: NR | MI HAs captured in registry of cardiac catheterization patients | Temperature, RH | Copollutant models with: NA; Correlation (r):; O_3_: −0.2; O_3_ max: 0.08; NO: 0.08; CO: 0.07; PM_10_: 0.43
Krall et al. (2018); Atlanta, GA (20 counties); 2002−2008; Birmingham, AL (7 counties); 2004−2008; Dallas, TX (12 counties); 2006−2008; Pittsburgh, PA (3 counties); 2002−2008; St. Louis, MO, and IL (16 counties); 2002−2007 | Electronic billing databases of ED visits | Population-weighted average estimates estimated using 24 h avg from ambient monitors within each metropolitan area with CMAQ predictions (Friberg et al., 2017; Friberg et al., 2016). A priori lag 0 with sensitivity analyses for 2-day avg. | Mean (SD):; Atlanta: 15.4 (7.1); Birmingham: 14.5 (7.1); Dallas: 10.8 (4.7); Pittsburgh: 15 (8.6); St. Louis: 13.8 (6.7); IQR: 8.71 | ED visits:; CHF (ICD-9 428); Cardiac dysrhythmia (ICD-9 427); IHD (ICD-9 410−414); Stroke (ICD-9 433−437) | Weekday, season, holidays, meteorology (lag Day 0 maximum temperature, lag Day 0−2 dew-point temperature), the hospitals reporting data for each day, cubic splines with 1 df for long-term trends | Correlation (r):; Ozone; 0.47; EC: 0.5; OC: 0.68; SO_4_: 0.81 NH_4_: 0.77; (Correlations only reported when > 0.4); Copollutant models with: NA
Ye et al. (2018); Atlanta, GA; (5 counties); Aug 14, 1998−Dec 15, 2013 | | 24 h avg from one monitor (Jefferson Street). A priori lag 0. | Mean (SD): 14.46 (7.69); IQR: 9.28; 75th: 18.21 | CVD ED visits (i.e., IHD, Dysrhythmia, and CHF) | Temporal trends and meteorology (maximum temperature, cubic function of minimum and dew point temperature, day of week, holiday, season, hospital participation period) | Correlation (r):; CO: 0.47; NO_2_: 0.50; SO_2_: 0.24; Ozone: 0.44; WS Fe: 0.65; Copollutant models with: water-soluble Fe
Fisher et al. (2019); Contiguous U.S.; 1999−2010 | HPFS; Men; 40−75 yr in 1986; n = 51,529 | Validated kriging models to estimate daily PM_2.5_ concentration (Liao et al., 2006) Data from > 1,000 monitors used in model.; Lags up to 3 days prior to stroke event and 4-day avg. | Mean (SD): 12.9 (7.4) | Self-reported stroke adjudicated by physician medical record review Multiple strokes at least 1 yr apart included; OR Total Stroke; Lag 0−3 (avg):; 0.94 (0.80, 1.10); Lag 0: 1.01 (0.90, 1.14); Lag 1: 0.92 (0.82, 1.03); Lag 2: 0.93 (0.82, 1.04); Lag 3: 1.00 (0.89, 1.12) | Temperature controlled as a linear term (restricted cubic splines in sensitivity analysis) with individual-level covariates and time trends controlled by design | Correlation (r): NR; Copollutant models with: NR
Sun et al. (2019); U.S.; 1993−2012 | WHI; n = 5,417 confirmed events; Post-menopausal women aged 50−79 at enrollment | Daily PM_2.5_ concentrations estimated using Kriging model (Liao et al., 2006) and assigned to residential address of participant. PEs 0-0.27; SPEs: −0.11−0.04; RMSSs~1.Lag 0, 0−1, and 0−2-day averages. Sensitivity analyses to evaluate 4, 5, and 6-day moving averages. | Median: 10.8; 75th: 15.3; 95th: 26.1; IQR: 8.2 | Self-reported stroke (i.e., rapid onset of persistent neurologic deficit lasting > 24 h). Stroke type adjudicated by trained neurologists | Temperature and RH, individual-level characteristics and time trends controlled by design | Correlation (r):; PM_10_: 0.57; NO_2_: 0.44; NO_X_: 0.35; SO_2_: 0.30; Ozone: 0.20; Copollutant models with: NR
Wyatt et al. (2020c); U.S. nationwide; 2008−2014 | USRDS; Hemodialysis patients; n = 351,294 | Satellite derived PM_2.5_ concentration estimates (AOD) integrated with chemical transport model predictions, meteorology, land use variables for 1 km grid cells (Di et al., 2016). Lag 0 and examination using unconstrained distributive lag model. | Mean: 9.3; Range: 0.05−155.16 | CVD, dysrhythmia, HF 30-day hospital readmissions; (ICD-9 codes: 401−405, 410−411, 413, 426−27, 428) | Temperature and RH. Individual-level characteristics, county characteristics (i.e., population size, risk Characteristics) day of the week, seasonal and long-term time trends controlled by design. | Correlation (r): NR; Copollutant models with: NR
deSouza et al. (2021); Continental U.S.; 2000−2012 | Medicaid adults (low-income and/or disabled); n = 3,666,657 CVD HAs | Daily average at ZIP code of residence. Predictions for 1 km^2^ grid cells integrated remote sensing, chemical transport model outputs, meteorological and land-use variables. Ensemble model integrated machine learning algorithms. C-V R2 = 0.86 (Di et al., 2019). Lag Day 0−1 used in all analyses. | Mean (SD) 11.5 (7.3) | First HA for CVD (ICD-9 390−495); IHD (ICD-9 410−414); CHF (ICD-9 428); AMI 410.9; IS: (ICD-9 434.91) | Air and dew-point temperature (daily mean for 32 km^2^ grid cells in U.S); individual-level factors, seasonality and long-term trends controlled by design. | Copollutant correlation (r):; NR; Copollutant models with: Ozone
McClure et al. (2017); Continental U.S.; Exposure: 2003−2011; Outcome: 2003−2007 to 2011 | REGARDS; n = 30,239; n = 746 events | Integrated measurements from monitors and satellite derived PM_2.5_ concentrations (AOD) estimated for 10 × 10 km grid cells across the U.S. (Al-Hamdan et al., 2014). Exposure assigned based on residential address. Lags 0, 1, 2 days. | ≤ 12: n = 403 (53%); 12−150.4: n = 343 (47%) | Stroke (i.e., rapid onset of persistent neurologic deficit lasting > 24 h) defined by WHO criteria (WHO, 1989) ascertained by self-report and medical record review | Temperature and RH with individual characteristics and time trends controlled by design | Copollutant correlation (r):; NR; Copollutant models with: NR

AMI = acute myocardial infarction; APPROACH = Alberta Provincial Project for Outcome Assessment in Coronary Heart Disease; Avg = average; BASIC = Brain Attack Surveillance in Corpus Christi: BC = black carbon; CHF = congestive heart disease; CMAQ = Community Multi-Scale Air Quality; C-V = cross-validation; CVD = cardiovascular disease(s); ED = emergency department; h = hour; HA = hospital admission; HF = heart failure; HPFU = Health Professionals Follow-up Study; ICD-9 = International Classification of Disease 9th revision; IHD = ischemic heart disease; IQR = interquartile range; km = kilometer(s); LUR = land use regression; MI = myocardial infarction; NA = not applicable; NR = not reported; PE = prediction error; PM_10_ = particulate matter with a nominal mean aerodynamic diameter less than or equal to 10; r = correlation coefficient; REGARDS = REasons for Geographic and Racial Differences in Stroke; RH = relative humidity; RMSS = root mean square standardized; SD = standard deviation; SPE = standardized prediction error; STEMI = ST segment elevation myocardial infarction; USRDS = U.S. Renal Data System; WHO = World Health Organization; WS Fe = water-soluble iron.

Table A-2 Study-specific details for epidemiologic studies using accountability analyses or alternative methods for confounder control to examine short-term PM_2.5_ exposure and cardiovascular effects

Study/Location; Years | Population (Cohort) | Outcome | Exposure Assessment | PM_2.5_ Concentration (µg/m^3^) | Confounders | Copollutant Examination
Zhang et al. (2018); Albany, Bronx, Buffalo, Manhattan, Queens, and Rochester, NY; 2005−2016 | New York State Department of Health Statewide Planning and Research Cooperative System (SPARCS); n = 1,922,918 | Total cardiovascular disease; cardiac arrhythmia; cerebrovascular disease; chromic rheumatic heart disease; congestive heart disease; hypertension; ischemic heart disease; myocardial infarction; ischemic stroke | U.S. EPA Air Quality System for each of the six sites: Buffalo, Rochester, Albany, and New York City (Bronx, Manhattan, Queens). Hourly PM_2.5_ concentrations were measured using tapered element oscillating microbalance monitors and 24-h daily averages were computed for each site and each day for which measurements of at least 75% of the hours that day in that site were available (18 h). | Case Period Median (25th, 75th Percentile):; Albany: 7.2 (4.4, 11.4); Bronx: 8.8 (5.7, 13.8); Buffalo: 8.5 (5.6, 12.6); Manhattan: 10.5 (7.2, 15.3); Queens: 8.0 (5.2, 12.5); Rochester: 7.2 (4.5, 11.0); Control Period Median (25th, 75th Percentile):; Albany: 7.2 (4.4, 11.3); Bronx: 8.8 (5.7, 13.8); Buffalo: 8.5 (5.6, 12.6); Manhattan: 10.5 (7.2, 15.3); Queens: 7.9 (5.2, 12.5); Rochester: 7.1 (4.5, 10.9) | Temperature; relative humidity | Correlation (r): NA; Copollutant models with: NA
Qiu et al. (2020); Connecticut, Maine, Massachusetts, New Hampshire, Rhode Island, and Vermont; 2000−2012 | Medicare; Acute myocardial infarction n = 156,717; Congestive heart failure n = 207,774; Ischemic stroke n = 170,663 | Acute myocardial infarction; congestive heart failure; ischemic stroke | Daily ambient levels of PM_2.5_ (24 h averaged, μg/m3) and ozone (8-h maximum, ppb) were predicted at a spatial resolution of 1 km from amachine learning algorithm that combined satellite remote censoring data, chemical transport models, land use, and meteorology, using a neural network. Daily averaged values were constructed by averaging the exposure levels of all grid cells within each individual ZIP code | Mean (SD):; Acute myocardial infarction: 10.13 (6.48); Congestive heart failure: 10.08 (6.42); Ischemic stroke: 10.10 (6.47) | Temperature, relative humidity; Age, sex, race, smoking history, cholesterol, BMI, preexisting medical conditions | Correlation (r): NA; Copollutant models with: O_3_
Wang et al. (2019); Rochester, NY; 2005−2016 | University of Rochester Medical Center Cardiac Catherization Laboratory; n = 921 | ST segment elevation myocardial infarction (STEMI) | New York State Department of Environmental Conservation air quality monitoring site, where PM_2.5_, SO_2_, O_3_, CO, and black carbon were measured continuously throughout the study period (2005−2016) for patients residing within 15 miles of the monitoring station | Mean (SD) for All Years (2005−2016): 8.32 (7.17); Mean (SD) for Before (2005−2007): 10.37 (8.74); Mean (SD) for During (2008−2013): 8.31 (6.83); Mean (SD) for After (2014−2016): 6.67 (5.55) | Temperature and relative humidity | Correlation (r): NA; Copollutant models with: SO_2_, O_3_, CO, BC

BC = black carbon; BMI = body mass index; EPA = Environmental Protection Agency; NA = not applicable; PM_2.5_ = particulate matter with a nominal mean aerodynamic diameter less than or equal to 2.5; r = correlation coefficient; SD = standard deviation; SPARCS = New York State Department of Health Statewide Planning and Research Cooperative System; STEMI = ST segment elevated myocardial infarction.

Table A-3 Study-specific details for epidemiologic studies of long-term PM_2.5_ exposure and cardiovascular effects

Study/Location; Years | Population (Cohort) | Outcome | Exposure Assessment | Mean and Upper Percentile Concentration (µg/m^3^) | Confounders Considered | Copollutant Examination
Rhinehart et al. (2020); Allegheny County, PA; Jan 1, 2007; Rhinehart et al. (2020); Dec 1, 2017 | Resident of Allegheny County, PA, and diagnosed with AF (ECG, ablation, cardioversion [ICD-10 427.31]). Excluded those <18 yr, reporting history of stroke, cardiothoracic surgery or with no record of follow-up.; n = 31,414 | Diagnosis of ischemic stroke on uniform electronic health record | Exposure: 1-yr avg assigned across entire study period; Spatial saturation monitoring campaign (June−July 2012 and Jan−Mar 2013) and LUR to estimate 1-yr avg concentration within a 300 m buffer of participants geocoded address. | Mean: 10.6; Q4 (range): 11.11−15.74 | Age, sex, race, neighborhoodlevel income and education | Correlation (r): NA; Copollutant models with: NA
Chen et al. (2020); Ontario Canada; Outcome: 2001−2016; Exposure: 2000−2016 | ONPHEC (adults 35−85 yr residing ≥5 yr in Ontario Canada). Excluded prevalent cases of AMI | AMI ascertained using hospital discharge records (validation study: 89% sensitivity/93% specificity) | Annual PM_2.5_ concentration assigned at centroid of postal code of residence reported for each year.; AOD and PM_2.5_ simulated by the GEOS-Chem chemical transport model. PM_2.5_ measurements incorporated via geographically weighted regression. Final surface with 1 × 1 km resolution for Ontario (R square = 0.76 with ground level measurements) | Mean: 8.61; See Figure 1; (Chen et al., 2020) | Age, sex, income, education attainment, percentage of recent immigrants, unemployment rate, urban/rural residency, indicators for Greater Toronto Area and north/south | Correlation (r):; BC: 0.97; Mineral Dust: 0.94; See salt: 0.87; NO_3_: −0.87; Ammonium: 0.85; OM: 0.62; SO_4_: 0.73
Weaver et al. (2021); Jackson, MS; 2000−2004 to 2005−2008 | JHS; n = 5,306 African American adults; 20−95 yr at baseline (2000−2004) | Hypertension (BP ≥ 140 diastolic BP ≥ 90 mmHg) or self-report of hypertensive medication use | Annual and 3-yr avg PM_2.5_ concentration estimated for geocoded address. U.S. EPA Bayesian space.time downscaling fusion model to estimate census tract level PM_2.5_ concentration (Berrocal et al., 2012, 2010a, b). | Visit 1:; Annual average: 12.2 (IQR: 0.8); 3-yr avg: 12.4 (IQR: 0.4); Visit 2:; 12.1 (IQR: 0.8); 3-yr avg: 12.4 (IQR: 0.4) | Education, smoking status, nutritional status, physical activity, NSAID use, date of measurement, sex, BMI, neighborhood SES, age, and food environment within 1.5 miles | Correlation (r):; O_3_; Visit 1: PM_2.5_ (1-yr); PM_2.5_ (3-yr); 1-yr: 0.12; 0.05; 3-yr avg: −0.06; −0.03; Visit 2:; 1-yr: 0.07; 0.19; 3-yr avg: −0.32; −0.36; Copollutant models with: O_3_
Weaver et al. (2019); Durham, Wake, or Orange counties, NC; Exposure: 2000−2010; Outcome: 2001−2010 | CATHGEN; n = 2,254 cardiac catheterization patients residing in 3 NC counties. | CAD index > 23 (indicating 75% coronary vessel occlusion); MI ascertained using medical records | Annual average PM_2.5_ concentration prior to index case.; Daily mean PM_2.4_ estimated at 1 km spatial resolution using AOD with chemical transport model, land use variables and meteorology (Di et al., 2016) | Annual average: 12.7 (SD: 1.1) | Age, sex, BMI, race, and smoking status | Correlation (r): NR; Copollutant models with: NR
Loop et al. (2018); U.S. Nationwide; 2003−2007 (baseline) to 2012 | REGARDS; n = 17,126 Black and White adults (≥ 45 yr old) | Total CHD (deaths and nonfatal MI combined), nonfatal MI | Annual average PM_2.5_ concentration linked to geocoded residential address at baseline.; Daily PM_2.5_ concentration estimated for 10 × 10 km grid using ground-level monitoring data, satellite measurements of AOD. | Median: 13.6; 75th: 14.8 | 1-yr mean temperature, season, race, region, urbanicity, income, education, age, gender, pack-years, BMI, alcohol use, physical activity, and calendar year | Correlation (r): NR; Copollutant models with: NR
Honda et al. (2017); Exposure: 1980−2010; Outcome: 1993−1998 (recruitment) to 2010 | WHI; n = 44,255 post-menopausal women (average age 62 yr) | First self-report of medication for hypertension (SBP ≥140 mm Hg, or DBP ≥ 90 mm Hg) | Annual moving average PM_2.5_ concentration estimated with daily concentrations from the AQS and IMPROVE networks using a universal kriging model (CV R2 = 0.88) | Mean: 13.2 | Age, BMI, education, ethnicity, smoking status, physical activity, sodium intake, neighborhood SES, household income, employment status, insurance status, history of high cholesterol, history of cardiovascular disease, history of diabetes, clinical trial study arm, and WHI clinical site | Correlation (r): PM10: 0.56; PM_10−2.5_: 0.03; Copollutant models with: NR
Duan et al. (2019b); Pittsburgh and Chicago, U.S. | SWAN; n = 417 Black and White women (mean age 51 yr at baseline) | cIMT by ultrasound and plaque burden (i.e., four levels, with 0 for no plaque to 3 for a plaque taking up > 50% diameter of the artery) | Annual average 360 days prior to clinic visit calculated from monitors located within 20 km of residential address; Daily PM_2.5_ values retrieved from U.S. AQS; (Green et al., 2016; Ostro et al., 2014) | Mean: 16.5 (baseline); 75th: 17.1 (baseline) | Age, race, education, SES, BMI, and CVD risk factors (i.e., smoking, total cholesterol, HDL-c, triglyceride, menopause status, hormone use, fasting glucose, antidiabetic medication, and antihypertensive medication) | Correlation (r):; O_3_:; Copollutant models: with O_3_
Duan et al. (2019a); Detroit, MI; Oakland, CA; Pittsburgh, PA; Chicago, IL; and Newark, NJ; Exposure: 1999−2005; Outcome: 2009−2013 | SWAN; n = 1,188 women; Mean age 59.6 yr | Mean cIMT, max cIMT, IAD and plaque presence or severity (i.e., four levels, with 0 for no plaque to 3 for a plaque taking up > 50% diameter of the artery) | 5-yr avg 360 days prior to each clinic visit calculated from monitors located within 20 km of residential address; Daily PM_2.5_ values retrieved from U.S. AQS (Green et al., 2016; Ostro et al., 2014) | Mean (SD): 14.9 (1.9); 75th: 16.1; Figure 2 | Age, race, education, SES, BMI, and CVD risk factors (i.e., smoking, total cholesterol, HDL-c, triglyceride, menopause status, hormone use, fasting glucose, antidiabetic medication, and antihypertensive medication) | Correlation (r):; O_3_: 0.56; Copollutant models : with O_3_
Keller et al. (2018); Baltimore, MD; Jul 2000−Aug 2002 through 2012; Exposure: Feb and Jun 2012 | MESA Air; n = 1,005 | CAC progression (Agatston units) | Spatiotemporal prediction models used to long-term average PM_2.5_ concentration from recruitment to exam based on each participants residential history (Keller et al., 2015). C-V R2 = 0.84. | Mean (SD): 15.9 (0.80) | Age, sex, race/ethnicity, site, scanner type, adiposity, physical activity, smoking, employment, total cholesterol, high-density lipoprotein level, triglyceride level, statin use, an index of neighborhood SES, education, and income | Correlation (r):; NR; Copollutant models: NR
Shin et al. (2019); Ontario Canada; Exposure: 1998−2012; Outcome: Apr 2001−Mar 2015 | ONPHEC; Ontario residents (adults 35−85 yr); n = 5,071,956; (those with history of AF and stroke excluded) | AF and Stroke (first hospital admission for ischemic or hemorrhagic stroke) ascertained using administrative databases | 5-yr moving average PM_2.5_ concentrations estimated at residence using AOD and PM_2.5_ simulated by the GEOS-Chem chemical transport model. Final surface with 1 × 1 km resolution for Ontario (R square = 0.82 for 2004×2008 5-yr mean) | Mean: 9.8 (SD: 2.9); IQR: 4.0; 75th: 11.9; Max: 20 | Age, sex, area level risk factors including SES, and geographic indicator variables to distinguish whether a participant’s residence was located in the north or south of Ontario and whether it was urban or rural | Correlation (r):; NO_2_: 0.65; O_3_ 0.275; Ox: 0.668; Copollutant models: with NO_2_, O_3_, Ox
Bai et al. (2019); Exposure: 1998−2012; Outcome: Apr 2001−Mar 2015 | ONPHEC; Ontario residents (adults 35−85 yr); n = 5,062,146 CHF; n = 5,141,172 AMI; (those with history of CHF and MI excluded) | CHF and AMI ascertained using registries based on hospital discharge data | 3-yr moving concentrations assigned to postal code participant residence estimated using AOD and PM_2.5_ simulated by the GEOS-Chem chemical transport model. Final surface with 1 × 1 km resolution for Ontario | Mean: 9.6 (2.8); IQR: 3.5; 75th: 11.4; Max: 20 | Age, sex, area level risk factors including SES, and geographic indicator variables that distinguished participants based on the location of their residence, i.e., north or south of Ontario and urban vs. rural | Correlation (r):; NO_2_: 0.4; O_3_ 0.2; Ox: 0.4; Copollutant models: NR
Elliott et al. (2020); Contiguous U.S.; Exposure:1988−2007; Outcome: 1988−2008 | NHS; n = 104,990; Women (35−55 at baseline in 1976) | MI (ICD-9 410) and Stroke (ICD-9 430−437) Self-reported physician diagnosed confirmed by medical record review | 24-mo moving average PM_2.5_ at residence using spatiotemporal prediction models for contiguous U.S. (C-V R^2^: 0.77) (Yanosky et al., 2014b). | 13.7 (1988−2008); 80th: 16.5 | Preexisting health conditions, smoking status, healthy eating, alcohol use, income, and education | Correlation (r):; NR; Copollutant models: NR
Danesh Yazdi et al. (2019); Southeastern U.S. (Florida, Alabama, Mississippi, Georgia, North Carolina, South Carolina, and Tennessee); 2000−2012 | Medicare data; n = 11,084,660; Older adults (65 plus yr) | First hospital admission for MI (ICD-9: 410), CHF (ICD-9 428) and Stroke (ICD-9 430−438), ascertained using Medicare data | Annual average PM_2.5_ concentrations predicted using AOD from satellites, land use, and chemical transport models to assign daily exposure in 1 ×1 km grid cells (C-V R^2^ = 0.86) (Di et al., 2016) | | State, sex, race, year, eligibility for Medicaid, and census measures of SES | Correlation (r):; NR; Copollutant models: NR

AF = atrial fibrillation; AMI = acute myocardial infarction; AOD = aerosol optical depth; AQS = Air Quality System; BMI = body mass index; CAC = coronary artery calcium; CATHGEN = Catheterization Genetics study; CHF = congestive heart failure; cIMT = carotid intimal-medial thickness; C-V = cross-validation; DBP = diastolic blood pressure; ECG = electrocardiogram; GEOS-Chem = Goddard Earth Observing System with global chemical transport model; HDL = high-density lipoprotein; IAD = inter-adventitial diameter; ICD = International Classification of Disease; IMPROVE = Interagency Monitoring of Protected Visual Environments; JHS = Jackson Heart Study; km = kilometer(s); MESA = Multi-Ethnic Study of Atherosclerosis and Air Pollution; MI = myocardial infarction; NHS = Nurses’ Health Study; ONPHEC = Ontario Population Health and Environment Cohort; Ox = redox weighted average of NO2 and O3; PM_2.5_ = particulate matter with a nominal mean aerodynamic diameter less than or equal to 2.5; PM10 = particulate matter with a nominal mean aerodynamic diameter less than or equal to 10; PM_10-2.5_ = particulate matter with a nominal mean aerodynamic diameter greater than 2.5 and less than or equal to 10; r = correlation coefficient; REGARDS = REasons for Geographic and Racial Differences in Stroke; SBP = systolic blood pressure SD = standard deviation; SES = socioeconomic states; SWAN = Study of Women’s Health Across the Nation; yr = year(s).

Table A-4 Study-specific details for epidemiologic studies using accountability analyses or alternative methods for confounder control to examine long-term PM_2.5_ exposure and cardiovascular effects

Study/Location; Years | Population (Cohort) | Outcome | Exposure Assessment | PM_2.5_ Concentration (µg/m^3^) | Confounders | Copollutant Examination
Danesh Yazdi et al. (2021); U.S.; 2000−2016 | Medicare; n = 63,006,793 | Myocardial infarction; ischemic stroke; atrial fibrillation, and flutter | High-resolution spatiotemporal ensemble models, each of which combined estimates from three different machine learning algorithms, including a neural network, a gradient boosting machine, and a random forest. The models used hundreds of predictors including land use terms, chemical transport model predictions, meteorologic variables, and satellite measurements to estimate daily levels of the pollutants on a scale of 1 km × 1 km. | Mean: 10.21; Median: 10.05; Range: 0.01−30.92 | Individual: sex, race, age, Medicaid eligibility; ZIP code level: proportion of the population > 65 yr of age living below the poverty line; population density; median value of owner occupied properties; proportion of the population listed as Black; median household income; proportion of housing units occupied by the owner; proportion of the population identified as Hispanic; proportion of the population > 65 yr of age who had not graduated from high school; lung cancer hospitalization rate; mean BMI; smoking rate; proportion of Medicare beneficiaries with at least one hemoglobin A1c test in a year; proportion of elderly diabetic beneficiaries who had a lipid panel test in a year; proportion of beneficiaries who had an eye examination in a year; proportion of beneficiaries with at least one ambulatory doctor visit in a year; and proportion of female beneficiaries who had a mammogram during a 2-yr period; region of residence | Correlation (r): NA; Copollutant models with: O_3_, NO_2_
Henneman et al. (2019); U.S.; 2005−2012 | Medicare | Acute myocardial infarction; cardiovascular stroke; heart failure; heart rhythm disorders; ischemic heart disease; all cardiovascular disease | Modeled national PM_2.5_ concentrations estimated by combining GEOS-Chem chemical transport model-simulated PM_2.5_, satellite-retrieved aerosol optical depth, and observed PM_2.5_ concentrations. Estimated monthly 0.1 longitude × 0.1 latitude PM_2.5_ concentrations were averaged to annual concentrations and spatially overlayed on U.S. ZIP codes.; Coal exposure: HYSLPLIT air parcel trajectory and dispersion model | Mean (IQR):; 2005: 10.0 (4.5); 2012: 7.2 (2.6); Difference between 2012 and 2005: −3.2 (2.4) | Median age; median household income; per-capita income; sex; race; fraction of population by county that smoked in 2000; temperature; specific humidity | Correlation (r): NA; Copollutant models with: NA
Zigler et al. (2018); Eastern U.S.; 2000-2012 | Medicare; N=3,892,984 Medicare fee-forservice beneficiaries and; N=1,620,778 Medicare managed-care beneficiaries | Cardiovascular stroke, heart failure, heart rhythm disorders, ischemic heart disease, peripheral vascular disease | U.S. EPA Air Quality System: Ambient PM_2.5_ measurements in operation between 1997 and 2012 and enumerated which were in areas designated as nonattainment for PM_2.5_ in 2005. Monitors were only included each year if the annual percentage of valid measurements for that year was at least 67%. | Mean (SD) for 2002-2004 in attainment areas: 11.59 (1.88); Mean (SD) for 2002-2004 in non-attainment areas: 14.48 (1.39); Mean (SD) for 2010-2012 in attainment areas: 9.39 (1.65); Mean (SD) for 2010-2012 in non-attainment areas: 11.13 (1.35) | Temperature, relative humidity, dew point, which were measured from climate monitors located within 150 km of the monitoring site; Age, sex, race, rural/urban, education, income, occupied housing, migration rate, house value among zip codes with controls located within 6 miles of the monitoring station; Smoking rate from the surrounding county | Correlation (r): NA; Copollutant models with: NA

EPA = Environmental Protection Agency; GEOS-Chem = Goddard Earth Observing System with global chemical transport model; HYSLPLIT = HYbrid Single-Particle Lagrangian Integrated Trajectory; IQR = interquartile range; km = kilometer(s); NA = not applicable; PM_2.5_ = particulate matter with a nominal mean aerodynamic diameter less than or equal to 2.5; r = correlation coefficient; SD = standard deviation.

Table A-5 Study-specific details for epidemiologic studies of short-term PM_2.5_ exposure and mortality

Study/Location Years | Study Population | Mortality Outcome | Exposure Assessment | Confounders in Statistical Model | Mean and Upper Percentile Concentrations (µg/m^3^) | Copollutant Examination
Liu et al. (2019); 652 cities globally; 107 cities in the U.S.; 25 cities in Canada; (U.S.: 1987−2006; Canada: 1986−2011) | All ages | All cause | Available PM_2.5_ data in the MCC database. Measurements for air pollutants from fixed-site monitoring networks operated by local authorities for each country. | DOW; RH; Temperature; Year | U.S.: 12.4; Canada: 9.3 | Correlation (r): NA; Copollutant models with: NA
Lavigne et al. (2018); U.S.; Canada; (24 cities); 1998−2011 | All ages; Nonaccidental: n = 1,179,491; Cardiovascular: n = 401,719; Respiratory: n = 105,980 | Nonaccidental; Cardiovascular; Respiratory | Daily (24-h) average PM_2.5_ concentrations from monitors in Canada’s NAPS network were used to estimate exposures. Exposure estimates were assigned to each study participant based on the monitoring station(s) located in participants’ city of residence. If PM_2.5_ measurements were available from multiple monitors in a single city, daily concentrations were averaged across monitors. | RH (lag 0−2); Temperature (lag 0−2) | Mean: 8.8; Max: 98.2 | Correlation (r):; NO_2_: 0.53; O_3_: 0.03; O_X_: 0.28; Copollutant models with: O_X_
Shin et al. (2021b); Canada; (24 cities)2001−2012 | > 1 yr of age; 65+ | Respiratory | Daily (24-h) average PM_2.5_ concentrations were calculated for each study city using ambient monitoring data available from Canada’s NAPS. Daily PM_2.5_ concentrations were averaged across monitors within a city when multiple monitoring sites were present. | DOW; Temperature (lag 0); Year | Mean:; Warm (April−September): 8; Cold (October−March): 6 | Correlation ®: NA; Copollutant models with: NA
Shin et al. (2021a); Canada; (22 cities); 2001−2012 | > 1 yr of age; 65+ | All cause | Daily (24-h) average PM_2.5_ concentrations were calculated for each study city using ambient monitoring data available from Canada’s NAPS. Daily PM_2.5_ concentrations were averaged across monitors within a city when multiple monitoring sites were present. | DOW; Temperature (lag 0); Year | Mean; Warm (April−September): 8; Cold (October−March): 6 | Correlation (r):; O_3_ warm: 0.4; O_3_ cold: −0.3; Copollutant models with: NA
Rappazzo et al. (2019); North Carolina; Mar 2013−Feb 2015 | 18−64 yr of age; n = 399 | Nonaccidental out-of-hospital sudden unexpected deaths | Hourly PM_2.5_ measurements from the Wake County central site monitor were obtained though EPA’s AQS data mart. Daily concentrations were calculated by averaging hourly measurements over 24-h (midnight to midnight). | Temperature (lag 0); RH (lag 0) | Mean: 10.93; 75th: 13.22; Max: 31.14 | Correlation (r):; CO: 0.45; NO_2_: 0.36; O_3_: 0.22; SO_2_: 0.18; Copollutant models with:; CO, NO_2_, O_3_, SO_2_
Baxter et al. (2019); U.S.; (312 CBSAs); 1999−2005 | All ages | Nonaccidental | Daily (24-h) mean PM_2.5_ concentrations from population-based monitors were obtained from EPA’s AQS. Concentrations were averaged across monitors within a CBSA/MD when multiple monitoring sites were present as detailed in Baxter et al. (2017). | DOW; Dew Point; Temperature (lag 0); Temperature (lag 0; lag 1, 2, 3); Year | --- | Correlation (r): NA; Copollutant models with: NA

AQS = Air Quality System; CBSA = core-based statistical area; DOW = day of week; EPA = Environmental Protection Agency; h = hour; MCC = Multi-City Multi-Country Collaborative Research Network; MD = metropolitan division; NA = not applicable; NAPS = National Air Pollution Surveillance System; PM_2.5_ = particulate matter with a nominal mean aerodynamic diameter less than or equal to 2.5; r = correlation coefficient; RH = relative humidity; yr = year(s).

Table A-6 Study-specific details for epidemiologic studies using alternative methods for confounder control to examine short-term PM_2.5_ exposure and mortality

Study/Location Years | Population (Cohort) | Outcome | Exposure Assessment | PM_2.5_ Concentrations (µg/m^3^) | Confounders | Copollutant Examination
Wei et al. (2020); Massachusetts; 2000−2012 | Medicare; n = 1,503,572 | All-cause mortality | Predicted daily ambient PM_2.5_, ozone, and nitrogen dioxide levels in each 1-km × 1-km grid cell across the contiguous U.S. using well-validated ensemble models | Mean (SD): 8.9 (5.4); Range: 0.1−65.3 | Temperature−air and dew point; Individual: sex; race/ethnicity; age; Medicaid eligibility; ZIP code level: annual median household income; median value of owner-occupied housing units; percentage of population living in poverty; percentage of the population with less than a high school education; population density; home ownership rate; County level: annual percentage of ever smokers; percentage of obese people | Correlation (r): NA; Copollutant models with: O_3_, NO_2_
Wei et al. (2021b); Massachusetts; 2000−2012 | Medicare; n = 1,503,572 | All-cause mortality | Daily concentrations of ambient PM_2.5_, ozone, and nitrogen dioxide at 1 km × 1 km grid cells were predicted using geographically weighted regressions that ensembled predictions from ensemble methods | Mean (SD): 8.9 (5.4); Range: 0.1−65.3 | Air surface temperature, dew point temperature, and relative humidity; Individual: sex, race, age, Medicaid eligibility; ZIP code level: median household income, median house value, percent of owner-occupied homes, percent of population living in poverty, percent of population below high school education, population density, percent of Black population and percent of Hispanic population, percent of persons over age 65 with an annual hemoglobin A1c test, an annual low-density lipoprotein test, and an annual eye exam in each hospital catchment area; County level: percent of ever smokers, lung cancer rate, and average BMI | Correlation (r): NA; Copollutant models with: O_3_, NO_2_
Schwartz et al. (2018a); U.S. (135 cities); 1999−2010 | National Center for Health Statistics; n = 7,277,274 | Mortality (daily deaths) | Obtained PM_2.5_ and NO_2_ from U.S. EPA’s Air Quality System Technology Transfer Network | Mean: 12.8; 25th Percentile: 7.5; 75th Percentile: 16.1 | Meteorologic: Daily mean temperature, wind speed, and sea-level pressure data | Correlation (r): NA; Copollutant models with: NO_2_

BMI = body mass index; EPA = Environmental Protection Agency; km = kilometer(s); NA = not applicable; PM_2.5_ = particulate matter with a nominal mean aerodynamic diameter less than or equal to 2.5; r = correlation coefficient; SD = standard deviation.

Table A-7 Study-specific details for epidemiologic studies of long-term PM_2.5_ exposure and mortality

Study | Study Population | Mortality Outcomes | Exposure Assessment | Confounders in Statistical Model | PM_2.5_ Concentrations (µg/m^3^) | Copollutant Examination
Pope et al. (2019); Contiguous U.S; PM_2.5_: 1999−2015 (1988−2015 in sensitivity analyses); Follow-up: 1986−2015 | NHIS; n = 1,599,329; deaths = 267,204; 18−84 yr of age | All cause; Cardiopulmonary; Cardiovascular; Cerebrovascular; Chronic lower respiratory; Influenza/pneumonia; Cancers; Influenza/pneumonia; Lung cancer; Other/unknown | Primary analyses:; Population-weighted annual PM_2.5_ concentrations averaged over the years 1999 to 2015 for census-tract centroids. PM_2.5_ concentrations were estimated from regulatory monitoring data and constructed in a universal kriging framework relying on information from geographic variables, including land use, population, and satellite-derived estimates of land use and air pollution as described in Kim et al. (2020). This method was shown to have good model performance, R2 = 0.78−0.90.; Sensitivity analyses: Census-tract mean PM_2.5_ concentrations for the years 1988 to 2015 were estimated using imputed data from 1988 to 1998, based on the relationship between monitored PM_10_ and PM_2.5_ concentrations, and primary modeled data from 1999 to 2015. Approach is described in Kim et al. (2020). | Age, sex, race-ethnicity using 104 variables for all interactive combinations of 13 age ranges, sex, and race-ethnicity; income (inflation-adjusted to 2015); education level; marital status; rural versus urban; U.S. census region; survey years; Subcohort analysis also included smoking status; BMI | Mean: 10.7; SD: 2.4; Range: 2.5−19.2 | Correlation (r): NA; Copollutant models with: NA
Lefler et al. (2019); U.S.; PM_2.5_: 1988−2015; Follow-up: 1987−2015 | NHIS―Subset; n = 635,539; deaths = 106,385; 18−84 yr of age | All cause; Cardiopulmonary | Annual average PM_2.5_ was modeled using regulatory monitors and land use data as described in Kim et al. (2020). Exposure estimates were assigned to home census tracts as either 2-yr (i.e., cohort year and previous year) or 5-yr (i.e., cohort year and previous 4 yr) average PM_2.5_ concentrations, 17-yr average PM_2.5_ concentrations (1999−2015), or 28-yr average PM_2.5_ concentrations (1988−2015). | Variables for all interactive combinations of 13 age ranges, sex, and race-ethnicity; marital status; inflation-adjusted household income; education; smoking status; BMI; U.S. census region; rural vs. urban; survey year | Mean: 10.67; SD: 2.37; IQR: 3.12 | Correlation (r):; CO: 0.42; SO_2_: 0.41; PM_10−2.5_: 0.19; NO_2_: 0.56; O_3_: 0.33; Copollutant models with: CO, PM_10−2.5_, SO_2_, O_3_, NO_2_
Wang et al. (2020); U.S.; PM_2.5_: 2000−2008; Follow-up: 2000−2008 | Medicare; n = 52,954,845; deaths = 15,843,982; 65−120 yr of age | Nonaccidental; Cardiovascular; IHD; Cerebrovascular; CHF; Respiratory; COPD; Pneumonia | Daily PM_2.5_ was estimated on a 6-km grid using a spatiotemporal model described in Yanosky et al. (2014a). Model inputs included monitored PM_2.5_, meteorological and geospatial covariates, and traffic-related PM estimated using a Gaussian line-source dispersion model. Medicare beneficiaries were matched to the grid point closest to their ZIP code centroid and PM_2.5_ concentrations were averaged for the 12-mo period prior to death. | Strata for age, race, sex, and ZIP code; ZIP code, and state SES | Mean: 10.3; SD: 3.2 | Correlation (r):; NO_2_: 0.59; O_3_: 0.24; Copollutant models with: O_3_
Elliott et al. (2020); U.S.; PM_2.5_: 1988−2007; Follow-up: 1988−2008 | Nurses’ Health Study; n = 104,990 female participants; deaths = 9,827; Average age 63.1 yr | Nonaccidental | 24-mo average ambient PM_2.5_ exposures were estimated at residential addresses using the spatiotemporal prediction model described in Yanosky et al. (2014a). Model predictions used publicly available monitoring data, geospatial predictors (road network data, residential and urban land use, density of PM_2.5_ and PM_10_ point-sources, elevation data) and monthly average meteorological data (windspeed, temperature, precipitation). | Age; race; incident cancer; family history of MI; smoking status; pack-years; overall diet quality; alcohol consumption; multivitamin use; individual-level SES | Mean: 13.7; SD: 3.5 | Correlation (r): NA; Copollutant models with: NA
Wu et al. (2020a); U.S.; PM_2.5_: 2000−2016; Follow-up: 2000−2016 | Medicare; n = 68,503,979; person-years = 573,370,257; deaths = 27,106,639; 65+ yr of age | All cause | An ensemble-based prediction model was used to estimate daily PM_2.5_ concentrations for a 1-km2 grid network across the contiguous U.S. [discussed in Di et al. (2019)]. Grid cell predictions were aggregated to ZIP codes, and annual averages for each ZIP code were calculated by averaging daily concentrations. Annual average PM_2.5_ concentrations in each ZIP code were then assigned to individuals who resided in that ZIP code for each calendar year. | Age; race/ethnicity; sex; Medicaid eligibility; County-level: average BMI; smoking rate; ZIP code level: proportion of Hispanic and Black residents; median household income and home value; proportion of residents in poverty, with high school diploma, and own their house; population density; summer/winter average max daily temperature and RH; Geographic region of U.S.; calendar year | Entire Cohort:; Mean: 9.8; SD: 3.2; Subset of cohort ≤ 12.0:; Mean: 8.4; SD: 2.3 | Correlation (r): NA; Copollutant models with: NA
Eum et al. (2018); U.S.; PM_2.5_: 2000−2012; Follow-up: Dec 2000−Dec 2012 | Medicare; n = 20,744,214; deaths = 5,484,947; 65+ yr of age | All cause | U.S. EPA Air Quality System (AQS) monitors. Included monitors with at least 8 calendar years of data, having 9+ months with 4+ measurements, which equaled 798 monitors. For each site, smoothed time-series using linear regression with thin plate splines with 4 df per year. Gaps longer than 90 days smoothed PM_2.5_ before and after each gap separately. Predicted values used to calculate moving averages for PM_2.5_ for each month. Yearly averages considered valid if 350+ days of data available. Exposure assigned to individuals that lived in ZIP codes with centroids within 6 miles of a valid monitor. | County-level proportion of non-Whites, current smokers, diabetes, asthma, individuals possessing health care plans, mean income, and mean BMI | Mean: 11.65; SD: 3.09 | Correlation (r): NA; Copollutant models with: NA
Crouse et al. (2020); Canada; PM_2.5_: 1998−2010; Follow-up: 2001−2011 | CanCHEC (2001); n = 2,452,665; deaths = 191,555; 25−89 yr of age | Nonaccidental; Cardiovascular; Cardiometabolic; IHD; Cerebrovascular; Respiratory; Lung cancer | Base model: PM_2.5_ estimates at 1 km over 3-yr average (3-yr/1-km model) with single-year lag assigned to postal code of residence. As detailed in van Donkelaar et al. (2015) PM_2.5_ exposures derived from AOD retrievals using GEOS-Chem calibrated to surface measurements by GWR.; Sensitivity analyses: Examined 1, 5, and 10 km spatial scales and 1, 3, and 8-yr temporal scales. | Age, sex; Community-level: time-varying indicator of size of each subject’s home community from most recent census; CAN-Marg Index; geographic airshed of subject’s residence; Individual-level: Aboriginal identity, visible minority status, marital status, highest level of education, employment status, and household income adequacy quintiles | 1-yr (Mean, Range); 1 km: 7.21 (0.0−20.0); 5 km: 6.59 (0.05−20.0); 10 km: 6.24 (0.21−20.0); 3-yr (Mean, Range); 1 km: 7.43 (0.00−20.0); 5 km: 6.79 (0.40−18.50); 10 km: 6.44 (0.60−18.16); 8-yr (Mean, Range); 1 km: 7.98 (0.35−18.36); 5 km: 7.27 (0.92−16.83); 10 km: 6.90 (0.79−16.40) | Correlation (r):; NO_2_: 0.49−0.62; O_3_: 0.44−0.58; O_x_: 0.60−0.68; Copollutant models with: O_3_, NO_2_, O_x_
Pinault et al. (2017); U.S.; PM_2.5_:1998−2010; Follow-up: May 15, 1991− Dec 31, 2011 | CanCHEC (2001); n = 2,448,500; deaths = 233,300; person-years = 25,484,400; 25−89 yr of age | Nonaccidental; Cardiometabolic; Cardiovascular; IHD; Cerebrovascular; Respiratory; COPD; Pneumonia; Lung Cancer | PM_2.5_ estimates at 1 km over 3-yr average (3-yr/1-km model) with single-year lag assigned to postal code of residence for years 1998−2012. As detailed in van Donkelaar et al. (2015) PM_2.5_ exposures derived from AOD retrievals using GEOS-Chem calibrated to surface measurements by GWR. PM_2.5_ concentrations extended back to 1998 by applying interannual variation of a published PM_2.5_ data set (Boys et al., 2014). Over North America R2 = 0.82 in locations where PM_2.5_ < 20 µg/m^3^. | Age, sex; Individual-level: Aboriginal identity, visible minority status, marital status, educational attainment, income adequacy quintile, labor force status; Population center size, airshed; Contextual: proportion of persons 25 or older who were unemployed, proportion that had not graduated from high school, proportion of persons in low-income families | Mean (SD): 7.37 (2.60); 75th: 9.07; 95th: 11.97; Max: 20.00 | Correlation (r): NA; Copollutant models with: NA
Pappin et al. (2019); Canada; PM_2.5_: 1988−2015; Follow-up: 1991−2016 | CanCHEC (1991, 1996, and 2001); n = 8.5 million; deaths = 1.5 million; person-years = 150,996,500; 25−89 yr of age | Nonaccidental | PM_2.5_ estimates at 1 km over 3-yr average (3-yr/1-km model) with single-year lag assigned to postal code of residence for years 1998−2012. As detailed in van Donkelaar et al. (2015) PM_2.5_ exposures derived from AOD retrievals using GEOS-Chem calibrated to surface measurements by GWR. For PM_2.5_ concentrations prior to 1998, back casting method employed that applied observed trends in ground monitoring data for PM_2.5_ to adjust pre-gridded PM_2.5_ estimates (Meng et al., 2019). | Age, sex, immigrant status; Contextual: CAN-Marg Index, population size of home community/city, urban form, regional airshed; Individual-level: income, education, occupational class, Indigenous status, visible minority status, employment status, marital status | Mean (SD):; 1991: 7.95 (3.28); 1996: 7.18 (2.70); 2001: 6.68 (2.24); 99th Percentile:; 1991: 17.26; 1996: 15.00; 2001: 12.30; Range (min−max):; 1991: 0.37−20.00; 1996: 0.37−20.00; 2001: 0.37−18.50 | Correlation (r): NA; Copollutant models with: O_3_, NO_2_, O_x_
Christidis et al. (2019); Canada; PM_2.5_: 1998−2015; Follow-up: 2000−2012; (linked to postal code history 1981−2016) | mCCHS; n = 452,700; deaths = 50,700; person-years = 4,452,700 | Nonaccidental | PM_2.5_ estimates at 1 km^2^ over 3-yr average (3-yr/1-km model) with single-year lag assigned to postal code of residence. As detailed in van Donkelaar et al. (2015) PM_2.5_ exposures derived from AOD retrievals using GEOS-Chem calibrated to surface measurements by GWR. Spatial variation from modeled surface used with simulate PM_2.5_ and constrained with local ground-based monitors to estimate PM_2.5_ concentrations through 2015 as detailed in Meng et al. (2019). | Age, sex, immigrant status, visible minority identity, Indigenous identity, marital status, educational attainment, employment status, income quintile, alcohol consumption, smoking behavior, fruit and vegetable consumption, leisure exercise frequency, BMI, CAN-Marg Index, ethnic concentration, community/city size, urban form, airshed | Mean (SD): 5.9 (2.0); 75th: 7.1; 95th: 9.7; Max: 17.2 | Correlation (r): NA; Copollutant models with: O_3_, NO_2_, O_x_
Erickson et al. (2020); Canada; PM_2.5_: 1998−2106; Follow-up: May 15, 2001−Dec 31, 2016 | CanCHEC (2001); n = 3,101,605; immigrants (n) = 684,400; deaths (non-immigrants) = 323,430; deaths (immigrants) = 87,775 | Nonaccidental; Cardiovascular; Cardiometabolic; IHD; Cerebrovascular; Respiratory; COPD; Lung cancer | PM_2.5_ estimates at 1 km^2^ over 3-yr average (3-yr/1-km model) with single-year lag assigned to postal code of residence for years 1998−2012. As detailed in van Donkelaar et al. (2015) PM_2.5_ exposures derived from AOD retrievals using GEOS-Chem calibrated to surface measurements by GWR. Spatial variation from modeled surface used with simulate PM_2.5_ and constrained with local ground-based monitors to estimate PM_2.5_ concentrations through 2015 as detailed in Meng et al. (2019). PM_2.5_ concentrations extended back to 1998 by applying interannual variation of a published PM_2.5_ data set (Boys et al., 2014). | Age, sex, visible minority status, Aboriginal identity, marital status, educational attainment, income adequacy quintiles, employment status, occupational classification, age at immigration, geographic region of birth, CAN-Marg Index, community size, urban form, regional airshed | Mean (SD); Non-immigrant: 7.53 (2.65); Immigrant:; Pre-1971: 9.13 (2.53); 1971−1980: 9.28 (2.28); 1981−1990: 9.54 (2.13); 1991−2001: 9.69 (2.02) | Correlation (r): NA; Copollutant models with: NA
Erickson et al. (2019); Canada; PM_2.5_: 1998−2012; Follow-up: 2001−2011 | CanCHEC (2001); n = 2,468,190; CCHS; n = 80,630 | Nonaccidental; Cardiovascular; IHD; Lung cancer | PM_2.5_ estimates at 1 km over 3-yr average (3-yr/1-km model) with single-year lag assigned to postal code of residence for years 1998−2012. As detailed in van Donkelaar et al. (2015). PM_2.5_ exposures derived from AOD retrievals using GEOS-Chem calibrated to surface measurements by GWR. | Age, sex, visible minority status, Aboriginal status, marital status, educational attainment, income quintile, labor force status, CMA-size, airshed, CAN-Marg Index | CanCHEC; Mean: 8.40; CCHS:; Mean: 6.70 | Correlation (r): NA; Copollutant models with: NA
Zhang et al. (2021); Ontario, Canada; PM_2.5_: 2000−2016; Follow-up: 2009−2017 | Ontario Health Study; n = 88,615; deaths = 7,488; 30+ yr of age | Nonaccidental; Cardiovascular; Respiratory | PM_2.5_ estimates at 1 km^2^ over 3-yr average (5-yr/1-km model) with single-year lag assigned to postal code of residence. As detailed in van Donkelaar et al. (2015) PM_2.5_ exposures derived from AOD retrievals using GEOS-Chem calibrated to surface measurements by GWR. Additional methodological changes including treating topographical changes and urban land cover as separate predictors improved R2 to 0.80. | Age, sex, ethnicity, place of birth, educational level, marital status, annual household income, BMI, daily intake of fruits and vegetables, physical activity, smoking habit, drinking habit, environmental exposure to smoke, urban residency, percentage of recent immigrants, percentage of population ≥ 15 with educational attainment lower than high school, and percentage of population ≥ 15 unemployed and income quintile | Mean (SD): 7.8 (1.5); 75th: 8.8 | Correlation (r): NO_2_ = 0.63; Copollutant models with: NO_2_
Cakmak et al. (2018); Canada; PM_2.5_:1998−2011; Follow-up: 1991−2011 | CanCHEC (1991); n = 2,291,250; deaths = 522,305; ≥25 yr of age | IHD; COPD; Lung cancer | PM_2.5_ estimates from median satellite-derived concentrations from 1998 to 2011 at 10 km × 10 km resolution as detailed in van Donkelaar et al. (2010). Changes in PM_2.5_ from 1998 to 2005 inferred from MISR and SeaWiFS satellites (Boys et al., 2014). Seven-year average exposures applied to each participant. | Age, sex, Aboriginal ancestry, visible minority status, marital status, education level, occupational level, immigrant status, income quintile; Smoking data and BMI from CCHS | Mean (Range) (SD):; 3.8 (1.2)–7.4 (2.2) | Correlation (r): O_3_: −0.007 to 0.698; Copollutant models with: O_3_
Hayes et al. (2020); U.S.; PM_2.5_: 1980−2010; Follow-up: 1995−2011 | NIH-AARP Diet and Health Study; n = 565,477; deaths = 135,289; 50−71 yr of age | Nonaccidental; Cardiovascular; Respiratory | Spatiotemporal prediction model detailed in Kim et al. (2017) that provided mean annual estimates of PM_2.5_ for each census tract. PM_2.5_ data prior to 1999 estimated using extrapolation based on PM_2.5_ data in FRM/IMPROVE; PM_2.5_ sulfate data in Clean Air Status and Trends Network; and visibility data across the Weather-Bureau-Army-Navy network. Annual average PM_2.5_ concentrations assigned at census tract level lagged by 1 yr in time-dependent manner.; Sensitivity analyses: (1) Follow-up period starting in 2000; and (2) distance to residence from AQS PM_2.5_ monitoring site. | Age, race/ethnicity, education level, marital status, BMI, alcohol consumption, smoking status, city/state, characteristics of census tract at enrollment (median income, percentage not completing high school) | Median: 13.3; Range: 2.9−28.0 | Correlation (r): NA; Copollutant models with: NA
Chen et al. (2020); Ontario, Canada; PM_2.5_: 2000−2016; Follow-up: 2001−2016 | ONPHEC; n = 5,264,985; deaths = 305,335; 35−85 yr of age | Cardiovascular | Annual average PM_2.5_ estimated at 1 km2 from multiple satellite retrievals of AOD combined with geophysical relationship between AOD and PM_2.5_ simulated by GEOS-Chem, which were then calibrated with surface measurements by GWR as detailed in van Donkelaar et al. (2019). Annual estimates closely agree with ground measurements across North America (R2 = 0.76). | Age, sex, urban/rural residency, north/south, percentage of population ≥ 15 with educational attainment lower than high school, percentage of recent immigrants, unemployment rate, income quintile, urban vs. other areas | Mean: 8.61 | Correlation (r):; Organic mass: 0.62; Sulfate: 0.73; Ammonium: 0.85; Nitrate: 0.9; Sea salt: 0.87; Mineral dust: 0.92; Black carbon: 0.97; Copollutant models with: NA
Pinault et al. (2018); Canada; CanCHEC; PM_2.5_:1998−2012; Follow-up: May 15, 2001− Dec 31, 2011; mCCHS; PM_2.5_:1998−2012; Follow-up: 2001−2008 | CanCHEC (2001); n = 2,448,500; CVD deaths = 123,500; mCCHS; n = 270,600; CVD deaths = 12,400 | Cardiovascular | PM_2.5_ estimates at 1 km2 over 3-yr average (3-yr/1-km model) with single-year lag assigned to postal code of residence for years 1998 – 2012. As detailed in van Donkelaar et al. (2015) PM_2.5_ exposures derived from AOD retrievals using GEOS-Chem calibrated to surface measurements by GWR. PM_2.5_ concentrations extended back to 1998 by applying interannual variation of a publishing PM_2.5_ data set (Boys et al., 2014). Estimates were correlated with ground measurements, R2 = 0.82. | Age, sex, population center size, airshed, Aboriginal identity, visible minority status, educational attainment, labor force status, income adequacy quintile, percentage of persons ≥ 25 unemployed or had not graduated from high school, overall percentage of people in low-income families | 2001 CanCHEC; Mean (SE): 7.37 (2.60); mCCHS; Mean (SE): 6.37 (2.65) | Correlation (r): NA; Copollutant models with: NA
Lim et al. (2018); U.S.; PM_2.5_: 2002−2010; Follow-up: 1995−2011 | NIH-AARP Diet and Health Study; n = 549,735; Diabetes deaths = 3,597; 50−71 yr of age | Diabetes | Long-term exposure to PM_2.5_ was estimated using annual average concentrations for the Years 2002 to 2010 from a spatiotemporal prediction model as described in Kim et al. (2017). Average PM_2.5_ concentrations were assigned based on residential census tract centroids. | Age, sex, region, race/ethnicity, education level, marital status, BMI, alcohol consumption, smoking status, diet, median census tract household income, percent of census tract population less than high school education | Mean (SD): 11.0 (2.7); Range: 2.8−21.2 | Correlation (R2):; NO_2_: 0.6; O_3_: 0.01; Copollutant models with: NA
Ward-Caviness et al. (2020); North Carolina, U.S.; PM_2.5_: 2003−2016; Follow-up: Jul 2004−Dec 2016 | North Carolina hospital-based cohort of individuals diagnosed with heart failure; using electronic health records n = 23,302 contributed to analyses (out of total of 35, 084 HF patients); Deaths = 4,496; Mean age = 66.9 yr (SD = 15.2 years; IQR = 22.2 yr) | All cause | Exposures are estimated using nearest PM_2.5_ monitor and using Harvard’s 1 km × 1 km modeled PM_2.5_ surface.; Monitors: Daily PM_2.5_ values were obtained from EPA National Ambient Air Quality Standards (NAAQS) ground-based monitoring network (July 1, 2003−December 31, 2016). Annual average PM_2.5_ concentration assigned to nearest monitor of geocoded address for the 365 days preceding the time of initial heart failure, based on the patient’s electronic health records. Sensitivity analyses were restricted to participants < 30 km from a monitor.; Modeled: An ensemble-based prediction model was used to estimate daily PM_2.5_ concentrations for a 1-km^2^ grid network across the contiguous U.S.; (model validation: r2 = 0.89 for Middle Atlantic region of U.S. for 2000−2015) [discussed in Di et al. (2019)]. Daily PM_2.5_ estimates for North Carolina were extracted for the years 2003−2016 and annual averages were calculated. | Age, sex, race, distance to nearest monitor, neighborhood-level socioeconomic variables (household below federal poverty line, median home value, median household income, urbanicity, households receiving public assistance) | Monitors:; Mean: 10.2; SD: 2.11; IQR: 3.36; Modeled:; Mean: 10.3; SD: 1.70; IQR: 2.45 | Correlation (r): NA; Copollutant models with: NA
Malik et al. (2019); U.S. (31 hospitals); PM_2.5_: 2002−2007; Follow-up: 2003−2013 | TRIUMPH and PREMIER cohorts; n = 5,640; deaths = NA; Mean age = 59.9; (SD = 12.7) | All cause | Daily average PM_2.5_ concentration estimated at census tract centroid of patient using U.S. EPA’s downscaled CMAQ, which is a Bayesian space-time fusion model that bias corrects modeled output data with monitored data as detailed in (Berrocal et al., 2012). Annual average PM_2.5_ concentrations estimated for year prior to myocardial infarction. | Age, sex, race, smoking status, date of enrollment, SES (patients’ education, insurance status, history of avoiding care because of costs, end-of-the-month financial resources) | Mean: 11.96; SD: 2.11; Range: 4.3−20.5 | Correlation (r): O_3_: −0.02; Copollutant models with: O_3_
Bennett et al. (2019); U.S. (1,339 county units); PM_2.5_: 1999−2015; Follow-up: NA | Vital Registration data from NCHS; Deaths = 41.9 million | All cause | Annual average PM_2.5_ estimated from integrated geographic model described in Kim et al. (2020). PM_2.5_ modeled through application of universal kriging approach to monitoring data and geographic variables, and satellite-derived estimates of PM_2.5_. PM_2.5_ concentrations predicted to 2010 census block centroids in contiguous U.S. and aggregated by population-weighting to county level. | Per capita income; percentage of population Black/African American, graduated from high school, live in urban areas, unemployed; proxy for cumulative smoking, mean temperature and RH | 1999; Median: 12.7; 75h: 14.6; 99th: 19.7; 2015; Median: 7.7; 75th: 8.5; 99th: 10.1 | Correlation (r):; NO_2_: 0.50; O_3_: 0.55; Copollutant models with: NA

AOD = aerosol optical depth; AQS = Air Quality System; BMI = body mass index; CanCHEC = Canadian Census Health and Environment Cohort; CAN-Marg = Canadian Marginalization Index; CCHEC = Canadian Census Health and Environment Cohort; CMA = census metropolitan area size; CMAQ = Community Multiscale Air Quality model; EPA = Environmental Protection Agency; FRM = Federal Reference Method; GEOS-Chem = Goddard Earth Observing System-Chem; GWR = geographically weighted regression; HF = heart failure; IMPROVE = Interagency Monitoring of Protected Visual Environments; IQR = interquartile range; mCCHS = Canadian Community Health Survey―Mortality cohort; NA = not applicable; NAAQS = National Ambient Air Quality Standards; NCHS = National Center for Health Statistics; NHIS = National Health Interview Survey; ONPHEC = Ontario Population Health and Environment Cohort; Ox = redox weighted average of NO2 and O3; PM = particulate matter; PM_2.5_ = particulate matter with a nominal mean aerodynamic diameter less than or equal to 2.5; PM_10_ = particulate matter with a nominal mean aerodynamic diameter less than or equal to 10; PREMIER = Prospective Registry Evaluating Myocardial Infarction: Events and Recovery; r = correlation coefficient; RH = relative humidity; SD = standard deviation; SE = standard error; SES = socioeconomic status; TRIUMPH = Translational Research Investigating Underlying Disparities in Acute Myocardial Infarction; yr = year(s).

Table A-8 Study-specific details for epidemiologic studies using accountability analyses or alternative methods for confounder control to examine long-term PM_2.5_ exposure and mortality

Study/Location Years | Population (Cohort) | Outcome | Exposure Assessment | PM_2.5_ Concentrations (µg/m^3^) | Confounders | Copollutant Examination
Peterson et al. (2020); U.S.; 1990−2010 | National Center for Health Statistics; n = 2,132 counties | Cardiovascular mortality | Estimated annual average PM_2.5_-total and component concentrations (sulfates, nitrates, elemental carbon, and organic carbon) between 1990 and 2010 from CMAQ | Weighted annual trend mass concentration (standard error): 0.134 (0.001) | County: median household income, percent of non-White population, and population; age-standardized annual COPD mortality rates (to account for the cumulative burden of smoking and annual smoking rates) | Correlation (r): NA; Copollutant models with: NA
Wei et al. (2020); Massachusetts; 2000−2012 | Medicare; n = 1,503,572 | All-cause mortality | Used predicted daily ambient PM_2.5_, ozone, and nitrogen dioxide levels in each 1-km × 1-km grid cell across the contiguous U.S. using well-validated ensemble models | Mean (SD): 9.0 (1.9); Range: 3.3−16.4 | Temperature―air and dew point; Individual: sex; race/ethnicity; age; Medicaid eligibility; ZIP code level: annual median household income; median value of owner-occupied housing units; percentage of population living in poverty; percentage of the population with less than a high school education; population density; home ownership rate; County level: annual percentage of ever smokers; percentage of obese people | Correlation (r): NA; Copollutant models with: O_3_, NO_2_
Wei et al. (2021b); Massachusetts; 2000−2012 | Medicare; n = 1,503,572 | All-cause mortality | Daily concentrations of ambient PM_2.5_, ozone, and nitrogen dioxide levels at 1 km × 1 km grid cells were predicted using geographically weighted regressions that ensembled predictions from ensemble methods | Mean (SD): 9.0 (1.9); Range: 3.3−16.4 | Air surface temperature, dew point temperature, and relative humidity; Individual: sex, race, age, Medicaid eligibility; ZIP code level: median household income, median house value, percent of owner-occupied homes, percent of population living in poverty, percent of population below high school education, population density, percent of Blacks, and percent of Hispanics, percent of persons over age 65 with an annual hemoglobin A1c test, an annual low-density lipoprotein test, and an annual eye exam in each hospital catchment area; County level: percent of ever smokers, lung cancer rate, and average BMI | Correlation (r): NA; Copollutant models with: O_3_, NO_2_
Wu et al. (2020a); U.S.; 2000−2016 | Medicare; n = 68,503,979 | Mortality | Estimated daily PM_2.5_ levels at a high spatiotemporal resolution using a 1-km^2^ grid network across the contiguous U.S. and a well-validated ensemble-based prediction model | Mean (SD): 9.8 (3.2) | Meteorologic variables: ZIP code level summer and winter averages of maximum daily temperatures; relative humidity; Individual: age, race/ethnicity, sex, Medicare eligibility; ZIP code level: proportion of Hispanic residents; proportion of Black resident; median household income; median home value; proportion of residents in poverty; proportion of residents with a high school diploma; population density; proportion of residents that own their house; County level: average BMI and smoking rate; Indicator variables: four census geographic regions (Northeast, South, Midwest, and West); calendar years (2000−2016) | Correlation (r): NA; Copollutant models with: NA
Wu et al. (2019); New England (Vermont, New Hampshire, Connecticut, Massachusetts, Rhode Island, and Maine); 2000−2012 | Medicare; n = 3,300,000 | All-cause mortality | PM_2.5_ exposures are determined at each 1 km × 1 km grid cell using a spatiotemporal prediction model which uses multiple different sources as input | Mean: 9.35 | Individual: Age, sex, race, and Medicare eligibility; Area-level: BMI; percent ever smoke; percent Hispanic population; percent Black population; median household income; median value of housing; percent below poverty level; percent below high school education; percent of owner-occupied housing; population density; percent with LDL-c test; percent with one ambulatory visit; percent with hemoglobin A1c test; temperature; relative humidity | Correlation (r): NA; Copollutant models with: O_3_
Corrigan et al. (2018); U.S.; 2000−2010 | National Center for Health Statistics; n = 619 counties (total); n = 486 counties (attainment); n = 133 counties (non-attainment) | Cardiovascular mortality | U.S. EPA’s Air Quality System (AQS) sites―calculated annual average PM_2.5_ concentrations at (3.3) each monitoring site for each year between 2000 and 2010; then averaged the annual means across the monitors located in the same county to calculate annual averages for counties | Before (2000−2004); Mean (IQR): 12.0 monitoring (3.9); After (2005−2010); Mean (IQR): 10.8 | Temperature; County: total income, percent with at least a high school diploma (of population 25 yr and older), percent Hispanic (of total population), and percent Black (of total population) | Correlation (r): NA; Copollutant models with: NA
Yitshak-Sade et al. (2019b); Maine, New Hampshire, Vermont, Massachusetts, Rhode Island, Connecticut, New York, New Jersey, Delaware, Pennsylvania, Maryland, Washington, DC, Virginia, and West Virginia; 2000−2013 | Medicare; n = 15,401,064 | Mortality | Highly spatially resolved PM_2.5_ data (1 × 1 km spatial resolution) from a hybrid satellite-based model incorporating daily satellite remote sensing Aerosol Optic Depth data and classic land-use regression methodologies | Range of Mean Annual PM_2.5_ Concentrations: 6.5−14.5 | Temperature; Individual: age, race/ethnicity, sex, Medicare eligibility | Correlation (r): NA; Copollutant models with: NA
Henneman et al. (2019); U.S.; 2005−2012 | Medicare | All-cause mortality | Modeled national PM_2.5_ concentrations estimated by combining GEOS-Chem chemical transport model-simulated PM_2.5_, satellite-retrieved aerosol optical depth, and observed PM_2.5_ concentrations. Estimated monthly 0.1 longitude × 0.1 latitude PM_2.5_ concentrations were averaged to annual concentrations and spatially overlayed on U.S. ZIP codes; Coal exposure: HYSLPLIT air parcel trajectory and dispersion model | Mean (IQR):; 2005: 10.0 (4.5); 2012: 7.2 (2.6); Difference between 2012 and 2005: −3.2 (2.4) | Median age; median household income; per-capita income; sex; race; fraction of population by county that smoked in 2000; temperature; specific humidity | Correlation (r): NA; Copollutant models with: NA
Sanders et al. (2020); U.S.; 2000−2013 | Medicare; n = 137 counties (non-attainment); n = 467 counites (attainment) | Mortality | Daily 24-h average PM_2.5_ was calculated for each county as a simple average of all monitors within a county (if multiple monitors exist) | Mean (SD): 10.84 (3.06); Mean for; Non-attainment < 2006: 15.29; Attainment < 2006: 10.99; Mean for; Non-attainment ≥ 2006: 11.96; Attainment ≥ 2006: 9.33 | Temperature (daily minimum and maximum); Total precipitation; Income per capita, share of population employed, migration | Correlation (r): NA; Copollutant models with: NA
Fan and Wang (2020); U.S.; 1999−2013 | Medicare; n = 770 county-month observation for treated; n = 7504 county-month observation for controls | Mortality | Ambient PM_2.5_ monitoring data from EPA AQS and power plants were selected from a list of coal-fired power plants from Clean Air Watch | Mean (SD): 12.04 (3.78) | Temperature, dew point, barometric pressure; County: median household income, poverty rate, percentage of non-Hispanic Whites in the population, and percentage of population with college degree | Correlation (r): NA; Copollutant models with: NA
Schwartz et al. (2021); U.S.; 2000−2016 | Medicare; n = 623,036,820 person-years of follow-up | Mortality | Used a validated prediction model calibrated to measurements at almost 2000 U.S. EPA AQS monitoring stations using an ensemble of machine learners that provided daily estimates for a 1 km grid of the contiguous U.S. | Mean (SD): 10.3 (3.1); Median: 9.8; IQR: 7.9, 12.0 | Individual: age, sex, ZIP code, Medicaid eligibility; ZIP code: percent of people ≥ 65 living in poverty, median household income, median house value, percent of owner occupied homes, percent Black, percent Hispanic, population density, and education, percentage of Medicare participants who had a hemoglobin A1c test, a low-density lipoprotein cholesterol (LDL-c) test, a mammogram, an eye exam, and a visit to an annual checkup for each year in each hospital catchment area, distance from each ZIP code centroid to the nearest hospital, hospitalization rate for lung cancer (proxy for long-term smoking); County: percentage of people who ever smoked and BMI; Meteorologic: average temperature in the warm months (April−September) and in the cold months (October−March) | Correlation (r): NA; Copollutant models with: NA
Schwartz et al. (2018b); Northeastern and mid-Atlantic States (Maine, New Hampshire, Vermont, Massachusetts, Rhode Island, Connecticut, New York, New Jersey, Delaware, Pennsylvania, Maryland, Washington, DC, Virginia, and West Virginia); 2000−2013 | Medicare; n = 129,341,959 person-years; n = 6,334,905 deaths | Life expectancy | Estimate annual average concentrations of PM_2.5_ at each ZIP code, which uses a hybrid model that integrates land use, meteorological, and satellite remote sensing data | Mean: 10.3; Median: 10.4; 25th Percentile: 9.2; 75th Percentile: 11.4 | Individual: age, sex, race, ZIP code of residence for that year, Medicaid eligibility; ZIP code: percentage of the population that was Black, Hispanic, ≥ 65 yr of age living in poverty, living in owner-occupied housing, and with less than a high school education as well as median household income, median value of owner-occupied housing, and population density; hospitalization rate for lung cancer (to capture long-term smoking); percentage of Medicare participants who had a hemoglobin A1c test, a low-density lipoprotein cholesterol (LDL-c) test, a mammogram, and a visit to a primary care physician for each year in each hospital catchment area; County: percentage of people who ever smoked and BMI scores | Correlation (r): NA; Copollutant models with: NA
Awad et al. (2019); U.S.; 2000−2012 | Medicare; n = 12,095,504 | Mortality | Mean annual exposure to PM_2.5_ for each enrollee at his/her residential ZIP code for each year between 2000 and 2012 was estimated using a neural network-based hybrid prediction mode. Daily predictions were generated and then averaged over the calendar year for the four grids closest to the centroid of the ZIP code of residence | Mean in the year of move: 11.88 for Whites and 13.02 for Blacks; Mean in second year after move: 11.15 for Whites and 12.12 for Blacks | Individual: age, sex, race, ZIP code of residence, Medicaid eligibility; hospitalizations for Alzheimer’s disease, acute myocardial infarction, diabetes Mellitus, heart failure, Parkinson’s disease, pneumonia, other respiratory diseases, ischemic stroke, unstable angina, vascular dementia, chronic obstructive pulmonary disease, and lung cancer; ZIP code: median household income, population density, percentage Black, percentage of owner-occupied housing units, median value of owner-occupied housing, percentage above age 65 living below the poverty level, and percentage above age of 65 with less than high school education | Correlation (r): NA; Copollutant models with: NA
Zigler et al. (2018); Eastern U.S.; 2000-2012 | Medicare; N=3,892,984 Medicare fee-for-service beneficiaries and N=1,620,778 Medicare managed-care beneficiaries | All-cause mortality | U.S. EPA Air Quality System: Ambient PM_2.5_ measurements in operation between 1997 and 2012 and enumerated which were in areas designated as nonattainment for PM_2.5_ in 2005. Monitors were only included each year if the annual percentage of valid measurements for that year was at least 67%. | Mean (SD) for 2002-2004 in attainment areas: 11.59 (1.88); Mean (SD) for 2002-2004 in non-attainment areas: 14.48 (1.39); Mean (SD) for 2010-2012 in attainment areas: 9.39 (1.65); Mean (SD) for 2010-2012 in non-attainment areas: 11.13 (1.35) | Temperature, relative humidity, dew point, which were measured from climate monitors located within 150 km of the monitoring site; Age, sex, race, rural/urban, education, income, occupied housing, migration rate, house value among zip codes with controls located within 6 miles of the monitoring station Smoking rate from the surrounding county | Correlation (r): NA; Copollutant models with: NA
Higbee et al. (2020); U.S.; 1986−2015 | National Center for Health Statistics; n = 635,539 | All-cause mortality; Cardiopulmonary mortality | Annual pollution exposures were estimated for each census block using national regulatory monitoring data from 1999 to 2015 within a universal kriging model employing land use regression methods and hundreds of variables | Mean (SD): 10.7 (2.4); Range: 2.5−19.2 | Individual: age, sex, race/ethnicity, educational attainment, marital status, income level, urban–rural designation, census tract, interview date, mortality status, smoking status, BMI, and date of death | Correlation (r): NA; Copollutant models with: NA
Wei et al. (2021a); U.S.; 2000−2016 | Medicare; n = 74,537,533 | All-cause mortality | The daily concentrations of ambient PM_2.5_, O_3_, and NO_2_ at 1 km × 1 km grid cells across the contiguous U.S. were predicted and validated using hybrid models that ensembled predictions from random forest, gradient boosting, and neural network | Mean (SD): 9.85 (3.17) | Meteorologic: Air temperature, humidity, average temperature in warm (April−September) and cold seasons (January−March, plus October−December); Individual: sex, race, age, Medicaid eligibility; ZIP code: percentage of Blacks, percentage of Hispanics, median household income, median value of owner occupied housing, percentage of Americans aged 65 and older living below the poverty threshold, percentage of Americans with less than high school education, percentage of owner occupied housing units, and population density; percentage of Medicare participants who had a hemoglobin A1c test, a low-density lipoprotein cholesterol (LDL-c) test, a mammogram, and an eye exam to a primary care physician for each year in each hospital catchment area; County: BMI and percentage of ever smokers | Correlation (r): NA; Copollutant models with: O_3_ and NO_2_

AQS = Air Quality System; BMI = body mass index; EPA = Environmental Protection Agency; GEOS-Chem = Goddard Earth Observing System with global chemical transport model; HYSLPLIT = HYbrid Single-Particle Lagrangian Integrated Trajectory; IQR = interquartile range; km = kilometer; NA = not applicable; PM_2.5_ = particulate matter with a nominal mean aerodynamic diameter less than or equal to 2.5; r = correlation coefficient; SD = standard deviation; yr = year(s).

Table A-9 Study-specific details for epidemiologic studies of short-term PM_2.5_ exposure and COVID-19 outcomes

Study/Location Years | Outcome | Exposure Assessment and Long-Term Mean and Upper Percentile Concentrations (µg/m^3^) | Covariates in Statistical Model | Copollutant Examination
Adhikari and Yin (2020); Queens County, NY; Mar 1, 2020−Apr 20, 2020 | Daily confirmed COVID-19 cases and deaths | Daily average PM_2.5_ collected and averaged from two stationary monitors.; Mean (SD): 4.73 (2.39); Median: 4.1; Range: 0.65 to 11.15 | Lagged outcome and day trend | Correlation (r): O_3_ = −0.82; Copollutant models with: NA

AQS = Air Quality System; BMI = body mass index; EPA = Environmental Protection Agency; GEOS-Chem = Goddard Earth Observing System with global chemical transport model; HYSLPLIT = HYbrid Single-Particle Lagrangian Integrated Trajectory; IQR = interquartile range; km = kilometer(s); LDL = low-density lipoprotein; NA = not applicable; PM_2.5_ = particulate matter with a nominal mean aerodynamic diameter less than or equal to 2.5; r = correlation coefficient; SD = standard deviation.

Table A-10 Study-specific details for epidemiologic studies of long-term PM_2.5_ exposure and COVID-19 outcomes

Study/Location Years | Outcome | Exposure Assessment | Covariates in Statistical Model | Copollutant Examination
Chakrabarty et al. (2021); U.S. | R0 | PM_2.5_ concentrations were aggregated at the state-level using monthly estimates based on stationary monitors, model inputs, and satellite observations between the years 2012−2017. | population, population density, % of population ≤ 9, % of population 10−19, % of population 20−29 % of population 30−39, % of population 40−49, % of population 50−59, % of population 60−69, % of population 70−79, % of population ≥ 80, number of people tested, hospital beds, Intensive Care Unit beds, liquid asset poverty rate, total health care and social services workers, total essential workers, fraction of total health care and social services workers, fraction of total essential workers, average household size, average family size, number of households, number of family, households with elderly resident, renter-occupied housing units, lapse in states issuance of stay-at-home order, residents in two or more unit structures, median income for single earner household, median income for working age individuals, % White, % African American, % Asian, % Native American Indian, % Pacific Islander, % Other race, ozone, NO_2_, relative humidity, SO_2_. | Correlation (r): NA; Copollutant models with: NA
Liang et al. (2020); U.S.; (3,122 U.S. counties); Jan 22, 2020 to Jul 17, 2020 | U.S. COVID-19 deaths; n = 138,552 | Daily ambient PM_2.5_ concentrations estimated using an ensemble machine learning model at the 1 km × 1 km grid level for 2010−2016. Annual mean concentrations were aggregated to county level.; 5th percentile: 3.8; 95th percentile: 10.4 | County-level number of cases per 1,000 people, social deprivation index, population density, % of residents > 60, % males, % race and ethnicity, body mass index, smoking rate, number of regular hospital beds per 1,000 people, number of intensive unit beds per 1,000 people, number of medical doctors per 1,000 people, average mobility (March and July 17, 2020), average temperature and humidity, state-level COVID-19 test positive rate as of July 17, 2020, and spatial smoother with 5 degrees of freedom for both latitude and longitude. | Correlation (r): NA; Copollutant models with: NO_2_, O_3_
Mendy et al. (2021); University of Cincinnati Hospital System; Mar 13, 2020−Jul 5, 2020 | COVID-19 hospitalizations; n =1,128 COVID cases; n = 310 hospitalizations | 10-yr average and 10-yr maximum concentrations of PM_2.5_ were aggregated for each ZIP code between 2008 and 2017 within the study area.; Average Mean ± SD: 11.34 ± 0.70; Maximal Mean ± SD: 13.83 ± 1.03 | Age, race, sex, median household income, smoking status, obesity, diabetes, asthma, COPD, cardiovascular disease, chronic kidney disease, neoplasm/history of neoplasm | Correlation (r): NA; Copollutant models with: NA
Stieb et al. (2020); Canada; (111 health regions); Up to May 13, 2020 | SARS-CoV-2 infections; n = 73,390 | Annual PM_2.5_ concentrations estimated using satellite imagery, chemical transport models, and ground observations for years 2000−2016 on a 0.01° × 0.01° grid. Concentrations were aggregated to 2018 health region boundaries.; Mean (SD): 6.1 (2.1) | Temperature (minimum, maximum), population density, % ≥ 65, % with income < lowest income cutoff, % Black, % asthma, % COPD, % hypertension, % diabetes, % physically active, % overweight, % obese, % smokers, days since first case, days since peak incidence, greenspace | Correlation (r): NA; Copollutant models with: NA
Wu et al. (2020b); U.S.; (3,089 counties; Up to Jun 18, 2020 | COVID-19 deaths; n = 116,747 | Daily PM_2.5_ concentrations estimated using atmospheric chemistry and machine learning models for the years 2000−2016 on 0.01° × 0.01° grid. Daily concentrations were aggregated to county level and averaged.; Mean (SD): 8.4 (2.5) | Days since first COVID-19 case reported, population density, % of population ≥ 65, % of population 45−64, % of population 15−44, % of population in poverty, median household income, % Black residents, % Hispanic residents, % of adult population with < high school education, median house value, % owner-occupied housing, % of population with obesity, % current smokers, number of hospital beds per unit population, average daily temperature, relative humidity for summer (June to September) and winter (December to February) for each county, days since issuance of stay-at-home order for each state. | Correlation (r): NA; Copollutant models with: NA

COPD = chronic obstructive pulmonary disease; COVID-19 = coronavirus disease 2019; ICU = intensive care unit; NA = not applicable; PM_2.5_ = particulate matter with a nominal mean aerodynamic diameter less than or equal to 2.5; r = correlation coefficient; SARS-CoV-2 = severe acute respiratory syndrome coronavirus 2; SD = standard deviation.

Table A-11 Study-specific details for epidemiologic studies examining socioeconomic status and PM_2.5_ exposure

Study/Location Years | Exposure Assessment | Mean Concentration (µg/m^3^) | Copollutant Examination
Han et al. (2017); Houston, TX; Jun 2013−Nov 2013 | PM_2.5_ concentrations collected from two stationary monitors placed in a single Low SES community, and a High SES community. | Mean (SD):; Low SES: 11.3 (2.90); High SES: 9.6 (2.93) | Correlation (r): NA; Copollutant models with: NA
Lee (2019); California; 2016 | PM_2.5_ concentrations estimated from both stationary monitors and satellite | Statewide; Mean (SD): 8.09 (3.25); Poverty: High: 9.7, Low: 8.7; Education: High: 9.9, Low: 8.5 | Correlation (r): NA; Copollutant models with: NA
Lee and Park (2020); California; 2012−2014 | PM_2.5_ concentrations estimated from stationary monitors | Mean (SD):; Overall: 9.4 (8.0); High Vulnerability: 10.8 (8.0); Low Vulnerability: 6.8 (5.5) | Correlation (r): NA; Copollutant models with: NA
Richmond-Bryant et al. (2020); U.S.; 2008, 2011, 2014 | PM_2.5_ emissions from fossil-fuel Electricity Generating Units obtained from the National Emissions Inventory | NR | Correlation (r): NA; Copollutant models with: NA
Rosofsky et al. (2018); Massachusetts; 2003−2010 | PM_2.5_ concentrations estimated at 1 km × 1 km grid using a modeling approach which incorporated satellite, land use, and meteorological data aggregated to yearly averages. | Population-weighted annual average PM_2.5_ range:; Education:; Masters: 2003:11.2, 2010: 8,0; Bachelors: 2003: 11.2, 2010: 8.0; High School-Post Secondary:; 2003: 11.1, 2010: 7.9; < High School: 2003: 11.3, 2010: 8.2; Household Income:; > $75,000: 2003:11.1, 2010:7.9; $50−$75,000: 2003: 11.1, 2010: 8.0; $35−$50,000: 2003: 11.2, 2010: 8.0; $20−$35,000: 2003: 11.2, 2010: 8.1; < $20,000: 2003: 11.4, 2010: 8.2 | Correlation (r): NA; Copollutant models with: NA
Tanzer et al. (2019); Pittsburgh, PA; Apr 2017−May 2018 | PM_2.5_ measured using Met-One Neighborhood PM Monitors (NPMs) and small subset measured using PurpleAir PA-II, as part of a Real-time Affordable Multi-Pollutant (RAMP) package | Annual average range: 7.5 to 25.8; EJ Communities: 10.6 (1.0); Non-EJ Communities: 10.3 (1.5) | Correlation (r): 0.32 (0.16−0.56) SO_2_; Copollutant models with: NA
Weaver et al. (2019); 2001−2010; Duke University Medical Center Wake, Durham, and Orange Counties in NC | Daily average PM_2.5_ concentrations were estimated using a hybrid model on a 1 × 1 km grid | Mean (SD): 12.7 (1.1); Cluster 1: 12.9 (1.1); Cluster 2: 13.2 (1.0); Cluster 3: 12.8 (1.1); Cluster 4: 12.8 (1.1); Cluster 5: 12.2 (1.2); Cluster 6: 11.9 (1.0) | Correlation (r): NA; Copollutant models with: NA

EJ = environmental justice; km = kilometer(s); NA = not applicable; NR = nor reported; NPMs = Neighborhood PM Monitors; PM = particulate matter; PM_2.5_ = particulate matter with a nominal mean aerodynamic diameter less than or equal to 2.5; r = correlation coefficient; RAMP = Real-time Affordable Multi-Pollutant; SD = standard deviation; SES = socioeconomic status.

Table A-12 Study-specific details for epidemiologic studies examining short-term PM_2.5_ exposure and health risk disparity by socioeconomic status

Study/Location Years | Population (Cohort) | Outcome | Exposure Assessment and Mean Concentration (µg/m^3^) | Select Results | Covariates in Statistical Model | Copollutant Examination
Yitshak-Sade et al. (2019a); Massachusetts; 2001−2011; Case-crossover | Massachusetts Department of Public Health; n = 179,986 | Cardiovascular mortality | Daily average PM_2.5_ estimated from a model incorporating aerosol optical depth and monitored PM_2.5_ at a 1 × 1 km grid; Mean: 10.2; Max: 17.4 | Change in CV Mortality; High % High School Educated; Green: 2.64% (0.46, 4.68); Less Green: 1.42% (0.72, 3.62); High % without high school diploma; Green: 2.64% [0.60, 4.72]; Less Green: 3.31% [1.26, 5.41]; High % White; Green: 2.80% (0.62, 5.02); Less Green: 1.14% (−1.00, 3.33); Low % White; Green: 2.47% (0.43, 4.56); Less Green: 3.55% (1.49, 5.65) | Temperature and day of the week | Correlation (r): NA; Copollutant models with: NA
Son et al. (2020); North Carolina; 2002−2013 | Death Records; n = 775,338 | Total Mortality | Daily average PM_2.5_ concentrations estimated from the CMAQ downscaler model on a 12 × 12 grid; Mean (SD): 11.4 (5.7); Max: 70.8 | OR (95% CI):; Income; < $41,500: 1.01 (1.01, 1.01); ≥ $41,500: 1.01 (1.00, 1.01); Education; < 12 yr: 1.01 (1.01, 1.02); High School: 1.01 (1.00, 1.01); 1−4 yr of college: 1.01 (1.00, 1.01); ≥ 5 yr of college: 1.01 (0.99, 1.02); Unknown: 1.00 (0.98, 1.03) | Residential greenness, proximity to water bodies, median household income, and classification of urbanicity | Correlation (r): O_3_: 0.48; Copollutant models with: NA

CI = confidence interval; CMAQ = Community Multi-Scale Air Quality; CV = cardiovascular; km = kilometer(s); NA = not applicable; PM_2.5_ = particulate matter with a nominal mean aerodynamic diameter less than or equal to 2.5; r = correlation coefficient; SD = standard deviation.

Table A-13 Study-specific details for epidemiologic studies examining long-term PM_2.5_ exposure and health risk disparity by socioeconomic status

Study/Location Years | Population (Cohort) | Outcome | Exposure Assessment and Long-Term Mean and Upper Percentile Concentrations (µg/m^3^) | Select Results | Covariates in Statistical Model | Copollutant Examination
Bai et al. (2019); Ontario, Canada; 2001-2015 | Canadian Ontario Population and Health Cohort | Congestive Heart Failure; (n = 5,062,146); Acute Myocardial Infarction; (n = 5,141,172) | Annual average PM_2.5_ concentrations estimated using the GEOS-Chem CTM model and a geographically weighted regression model; Mean (SD): 9.6 (2.8); Max: 20.0 | Income; HR (95% CI); CHF; Lowest: 1.12 (1.10, 1.13); Lower: 1.09 (1.06, 1.10); Middle: 1.03 (1.01, 1.04); Upper: 1.04 (1.03, 1.06); Uppermost: 1.01 (1.00, 1.04); AMI; Lowest: 1.12 (1.09, 1.15); Lower: 1.09 (1.06, 1.12); Middle: 1.04 (1.03, 1.07); Upper: 1.03 (1.01, 1.06); Uppermost: 1.03 (1.00, 1.06) | Age, sex, area level risk factors including SES, and geographic indicator variables that distinguished participants based on whether their residence in the north or south of Ontario and whether it was urban or rural | Correlation (r): NA; Copollutant models with: NA
Bennett et al. (2019); U.S.; 2015 | National Center for Health Statistics; n = 41.9 million | Life expectancy loss | Annual average PM_2.5_ concentrations estimated using an integrated geographic regression model; Median: 7.7; 99th percentile: 10.1 | PM_2.5_ associated with lower life expectancy among counties with lower income, higher percent poverty, and those with a low % who graduated from high school. | Income, % in poverty, Black race, ≥ high school, urbanization, unemployment, cumulative smoking, mean temperature, relative humidity, county-specific random intercepts | Correlation (r): NA; Copollutant models with: NA
Bevan et al. (2021); U.S.; 2000−2016 | National Center for Health and Statistics; n = 5,769,315 | Cardiovascular Mortality | Annual zip-level average PM_2.5_ concentrations estimated using aerosol optical depth calibrated to ground-based observations; Mean (SD):; 6.51 (1.54) | Social Deprivation Index (SDI) (1−100); No. deaths/100,000 (95% CI); SDI 1−25: 39.1; (32.1, 46.1); SDI 26−50: 48.2; (38.5, 57.9); SDI 51−75: 71.0; (57.6, 84.4); SDI 76−100: 52.0; (30.9, 73.1) | Smoking, diabetes obesity, physical inactivity, and urbanization | Correlation (r): NA; Copollutant models with: NA
Crouse et al. (2019); Canada; 2001−2011 | Canadian Census Health Environment Cohort | Nonaccidental Mortality; Cardio-metabolic Mortality; Cardiovascular Mortality | Annual average PM_2.5_ concentrations estimated from satellite derived annual estimates on a 1 × 1 km grid; Mean (SD): 8.4 (2.7); 95th percentile: 13.3 | For all mortality outcomes, the strongest associations were among the group with the lowest amount of deprivation and the lowest amount of greenspace. | Aboriginal identity, visible minority status, marital status, highest level of education, employment status, and household income adequacy quintiles | Correlation (r): NA; Copollutant models with: O_3_
Jorgenson et al. (2020); U.S.; 2000−2014 | U.S. Mortality Database | Life expectancy at birth | PM_2.5_ concentrations estimated from stationary monitors, averaged at the state level; Mean: 10.55; Max: 19.02 | PM_2.5_ more detrimental in states with high percent of income inequality. | Income share of top 10%, % Black, total population, median household income, median age, % college degree or higher | Correlation (r): NA; Copollutant models with: NA
Schulz et al. (2018); Detroit Metropolitan Area; 2013 | n = 171,000 | Cardiopulmonary Mortality | Annual average PM_2.5_ concentrations estimated from downscaler and CMAQ by census tract; Mean: 9.6; Max: 10 | Both PM_2.5_ and social vulnerability were independently related to CV mortality in the same model. | Age, gender, race/ethnicity, educational attainment, death attributable to smoking, and marital status | Correlation (r): NA; Copollutant models with: NA
Shin et al. (2019); Ontario, Canada; April 1, 2001 – March 31, 2015 | Canadian Ontario Population and Health Cohort; n = 5,071,956 | Atrial Fibrillation; Stroke | Annual average PM_2.5_ concentrations estimated using AOD and PM_2.5_ simulated by the GEOS-Chem CTM at a 1 × 1 km grid; Mean (SD):; 9.8 (2.9); IQR: 4.0; Max: 20 | Income; HR (95% CI); Atrial Fibrillation; Lowest: 1.06 (1.04, 1.08); Lower: 1.05 (1.03, 1.07); Middle: 1.02 (1.00, 1.04); Upper: 1.02 (1.01, 1.04); Uppermost: 0.99 (0.97, 1.02); Stroke; Lowest: 1.08 (1.04, 1.13); Lower: 1.08 (1.05, 1.11); Middle: 1.04 (1.00, 1.08); Upper: 1.01 (0.99, 1.04); Uppermost: 1.01 (0.99, 1.04) | Age, sex, area-level SES (education, recent immigrants, unemployment rate, and income quintile), urban/rural area, and northern/southern Ontario | Correlation (r):; NO_2_: 0.65; O_3_ 0.275; Ox: 0.668; Copollutant models: with NO_2_, O_3_, Ox
Wang et al. (2020); U.S.; 2000−2008 | Medicare, ≥ 65; n = 52,954,845 | Mortality | Daily average PM_2.5_ concentrations estimated from a validated spatiotemporal generalized additive model on a 6 km grid; Mean (SD):; 10.32 (3.15) | Associations were null by income. | Age, sex, race, and ZIP code with additional control for ZIP code and state SES | Correlation (r):; NO_2_: 0.59, O_3_: 0.24; Copollutant models with: O_3_
Weaver et al. (2019); NC, U.S.; Duke University Medical Center Wake, Durham, and Orange Counties; 2001−2010 | Catheterizati on Genetics (CATHGEN) study | Coronary Artery Disease, Myocardial Infarction, hypertension, Diabetes Mellitus | Daily average PM_2.5_ concentrations were estimated using a hybrid model on a 1 × 1 km grid; Mean (SD):; 12.7 (1.1) | Hypertension; OR (95% CI); Cluster 1: 2.70 (0.95, 7.59); Cluster 2: 11.86 (2.10, 67.21); Cluster 3: 0.70 (0.86, 1.07) | Odds ratios were adjusted for age, sex, BMI, race, and smoking status | Correlation (r): NA; Copollutant models with: NA
Wyatt et al. (2020b); U.S.; 3,132 counties; 1990−2010 | National Center for Health Statistics | Cardiovascular mortality | Annual average PM_2.5_ concentrations were estimated using CMAQNR | In the 1990s, counties with highest social deprivation benefited least, but by 2010, counties with highest social deprivation benefited the most by a reduction in PM_2.5_. | Age, baseline year PM_2.5_ and CMR for each county | Correlation (r): NA; Copollutant models with: NA
Zhang et al. (2021); Ontario, Canada; 2009−2017 | Ontario Health Study; n = 88,615 | Total nonaccidental mortality, cardiovascular mortality, respiratory mortality | Annual average PM_2.5_ estimated from model incorporating satellite, chemical transport, and ground-level observation data at a 1 × 1 km grid; Mean: 7.8; 75th percentile: 8.8 | Household Income; Hazard Ratio; (95% CI); Nonaccidental; < $25,000: 1.61 (1.23, 2.12); $25,000−$49,999: 1.42 (1.18, 1.72); $50,000−$74,999: 1.14 (0.94, 1.38); $75,000−$99,999: 1.24 (0.97, 1.60); ≥ $100,000: 1.00 (0.82, 1.21); Cardiovascular; < $25,000: 4.58 (2.48, 8.47); $25,000−$49,999: 1.34 (0.91, 1.97); $50,000−$74,999: 1.10 (0.73, 1.68); $75,000−$99,999: 1.11 (0.63, 1.98); ≥ $100,000: 1.46 (0.94, 2.25); Respiratory; < $25,000: 3.20 (1.40, 7.34); $25,000−$49,999: 0.84 (0.45, 1.57); $50,000−$74,999: 1.33 (0.63, 2.79); $75,000−$99,999: 1.47 (0.45, 4.74); ≥ $100,000: 4.48 (1.69, 11.83) | Age, sex, ethnicity, survey year, Canadian born, educational level, marital status, BMI, fruit and vegetable intake, smoking, alcohol drinking, physical activity, environmental exposure to tobacco smoke at home or in the workplace, urban/rural, south/north, and neighborhood SES characteristics (percent recent immigrants, percent population ≥ 15 unemployed, percent population ≥ 15 with educational level lower than high school, and income quintile) | Correlation (r): NA; Copollutant models with: NO_2_

AMI = acute myocardial infarction; AOD = aerosol optical depth; BMI = body mass index; CATHGEN = Catheterization Genetics study; CHF = congestive heart disease; CI = confidence interval; CMAQ = Community Multi-Scale Air Quality; CTM = chemical transport model; GEOS-Chem = Goddard Earth Observing System with global chemical transport model; hr = hazard ratio; IQR = interquartile range; km = kilometer(s); PM_2.5_ = particulate matter with a nominal mean aerodynamic diameter less than or equal to 2.5; r = correlation coefficient; SD = standard deviation; SDI = social deprivation index; SES = socioeconomic status.

Table A-14 Study-specific details for epidemiologic studies examining race/ethnicity and PM_2.5_ exposure

Study/Location Years | Exposure Assessment | Mean Concentration (µg/m^3^) | Copollutant Examination
Awad et al. (2019); U.S.; 2000−2012 | Annual average PM_2.5_ concentrations estimated using a neural network-based hybrid model between 2000 and 2012 on a 1 × 1 km grid | White; Mean: pre-move: 11.88, post-move: 11.15; 99th Percentile: pre-move: 20.24, post-move: 18.08; Black; Pre-move: 13.02, post-move: 12.12; 99th Percentile: pre-move: 20.68, post-move: 18.95 | Correlation (r): NA; Copollutant models with: NA
Erqou et al. (2018); Pittsburg, PA; 2001−2014 | PM_2.5_ concentrations estimated using land use regression models for the 300 m buffer surrounding an individual’s residence for the year prior to enrollment in the study | Mean (SE); Overall: 15.7 (0.77); Black: 16.1 (0.75); White: 15.7 (0.73) | Correlation (r): NA; Copollutant models with: NA
Kelly et al. (2020); U.S.; 2011 | PM_2.5_ concentrations estimated from nine different exposure models which can be described as either geophysical process, interpolation-based, Bayesian statistical regression, satellite-AOD-based, or machine learning models | Population-weighted average (range from models); NH-White: 9−10.3; Hispanic: 9.8−11.4; NH-Other: 9.4−11.5; NH-Black: 10.1−12.1 | Correlation (r): NA; Copollutant models with: NA
Lee (2019); California; 2016 | PM_2.5_ concentrations estimated from both stationary monitors and satellite | Mean (SD): 8.09 (3.25); 25th−75th percentiles = 5.77−9.76 | Correlation (r): NA; Copollutant models with: NA
Liévanos (2019); California; 2009−2011 | PM_2.5_ concentrations estimated from stationary monitors for each census tract centroid using kriging | Annual mean concentrations percentile ranges:; ≤ 20th: 2.30−7.71; 20−40th: 7.71−9.11; 40−60th: 9.11−10.86; 60−80th: 10.86−12.52; > 80th: 12.54−17.04 | Correlation (r): NA; Copollutant models with: NA
Lim et al. (2018); U.S.; 1995−2011 | Annual average PM_2.5_ concentrations estimated using a spatiotemporal prediction model at the census tract | Mean (SD); Overall: 11.0 (2.7); White: 10.9 (2.7); Black: 12.3 (2.4); Hispanic: 11.4 (3.5); Asian, Pacific Islander, or American Indian/Alaska Native: 11.9 (3.0); Max: 21.2 | Correlation (r): NO_2_ = 0.60, O_3_ = 0.01; Copollutant models with: NA
Lipfert and Wyzga (2020); U.S.; 1976−2001 | Average PM_2.5_ concentrations estimated from stationary monitors, averaged at the county level | Mean at cohort entry:; White: 13.9; Black: 15.7 | Correlation (r):; White:; SO_4_^2^: 0.68, NO_2_: 0.55,; peak CO: −0.19,; peak O_3_: 0.57, peak SO_2_: 0.20, PM_10_: 0.45; Black:; SO_4_^2^: 0.50, NO_2_: 0.58,; peak CO: 0.16, peak O_3_: 0.19, peak SO_2_: 0.43, PM_10_: 0.49; Copollutant models with: NA
Parker et al. (2018); U.S.; 1997−2011 | Annual average PM_2.5_ concentrations estimated from stationary monitors | Median:11.8; 90th percentile: 14.7 | Correlation (r): NA; Copollutant models with: NA
Richmond-Bryant et al. (2020); U.S.; 2008, 2011, 2014 | PM_2.5_ emissions from fossil-fuel Electricity Generating Units obtained from the National Emissions Inventory | NR | Correlation (r): NA; Copollutant models with: NA
Rosofsky et al. (2018); Massachusetts; 2003−2010 | PM_2.5_ concentrations estimated at 1 km × 1 km grid using a modeling approach which incorporated satellite, land use, and meteorological data aggregated to yearly averages | Population-weighted annual average PM_2.5_ range:; 2003: 11.1 to 11.7; 2010: 7.8 to 8.4 | Correlation (r): NA; Copollutant models with: NA
Tessum et al. (2019); U.S.; 2002−2015 | PM_2.5_ concentrations estimated using a modeling approach based on the InMAP model and incorporating 2014 National Emissions Inventory data as well as biogenic and wildfire emission sources | Average Exposure:; Black: 6.0; Hispanic: 5.5; White: 4.6 | Correlation (r): NA; Copollutant models with: NA
Tessum et al. (2021); U.S.; 2014 | PM_2.5_ concentrations estimated using a modeling approach based on the InMAP model and incorporating 2014 National Emissions Inventory data | Population average exposure from all domestic anthropogenic sources; People of Color: 7.4; Black: 7.9; Hispanic: 7.2; Asian: 7.7; White: 5.9 | Correlation (r): NA; Copollutant models with: NA
Yitshak-Sade et al. (2020); Massachusetts; 2001−2011 | Daily average PM_2.5_ estimated from a model incorporating aerosol optical depth and monitored PM_2.5_ at a 1 × 1 km grid | NR | Correlation (r): NA; Copollutant models with: NA

AOD = aerosol optical depth; inMAP = Intervention Model for Air Pollution; km = kilometer(s); NA = not applicable; NR = not reported; PM_2.5_ = particulate matter with a nominal mean aerodynamic diameter less than or equal to 2.5; PM_10_ = particulate matter with a nominal mean aerodynamic diameter less than or equal to 10; r = correlation coefficient; SD = standard deviation.

Table A-15 Study-specific details for epidemiologic studies examining short-term PM_2.5_ exposure and health risk disparity by race/ethnicity

Study/Location Years | Population (Cohort) | Outcome | Exposure Assessment Short-term Mean Concentration (µg/m^3^) | Select Results | Covariates in Statistical Model | Copollutant Examination
Yitshak-Sade et al. (2019a); Massachusetts; 2001-2011 | Massachusetts Department of Public Health; n = 179,986 | Cardiovascular mortality | Daily average PM_2.5_ estimated from a model incorporating aerosol optical depth and monitored PM_2.5_ at a 1 × 1 km grid; Mean: 10.2; Max: 17.4 | Change in CV mortality; [underlined: High % White]; Green: 2.80% (0.62, 5.02); Less green: 1.14% (−1.00, 3.33); [underlined: Low % White]; Green: 2.47% (0.43, 4.56); Less green: 3.55% (1.49, 5.65) | Temperature and day of the week | Correlation (r): NA; Copollutant models with: NA
Yitshak-Sade et al. (2020); Massachusetts; 2001-2011 | Massachusetts Department of Public Health; n = 130,863 | Cardiovascular mortality | Daily average PM_2.5_ estimated from a model incorporating aerosol optical depth and monitored PM_2.5_ at a 1 × 1 km grid; NR | Change in CV mortality; [underlined: Individual]; Black: 4.78% (−1.99, 12.02); White: 2.25% (0.80, 3.23); [underlined: Block group]; Low % Black: 1.62% (0.05, 3.22); High % Black: 3.35% (1.57, 5.16); [underlined: Racial Residential Segregation (RRS)]; More White (RRS 0.5, 1):; 1.84% (0.31, 3.40); More Black (RRS −1, −0.5):; 15.37% (0.76, 31.99); [underlined: Index of Racial Dissimilarity (IRD)]; No difference | Temperature and day of the week | Correlation (r): NA; Copollutant models with: NA

CV = cardiovascular; km = kilometer(s); IRD = Index of Racial Dissimilarity; NA = not applicable; NR = not reported; PM_2.5_ = particulate matter with a nominal mean aerodynamic diameter less than or equal to 2.5; RRS = racial residential segregation.

Table A-16 Study-specific details for epidemiologic studies examining long-term PM_2.5_ exposure and health risk disparity by race/ethnicity

Study/Location Years | Population (Cohort) | Outcome | Exposure Assessment and Long-Term Mean and Upper Percentile Concentrations (µg/m^3^) | Select Results | Covariates | Copollutant Examination
Awad et al. (2019); U.S.; 2000−2012 | Medicare; n = 12,095,504 | All-cause mortality | Annual average PM_2.5_ concentrations estimated using a neural network-based hybrid model between 2000 and 2012 on a 1 × 1 km grid; White; Mean: pre-move: 11.88, post-move: 11.15; 99th percentile: pre-move: 20.24, post-move: 18.08; Black; Pre-move: 13.02, post-move: 12.12; 99th percentile: pre-move: 20.68, post-move: 18.95 | HR (95% CI); Black movers: 1.06 (1.04, 1.07); White movers: 1.10 (1.10, 1.10) | Age, race, sex, Medicaid eligibility, calendar year, hospitalization before move for: Alzheimer’s disease, AMI, COPD, CV disease, diabetes, heart failure, lung cancer, Parkinson’s Disease, pneumonia, any respiratory illness, stroke, unstable angina, vascular dementia and ZIP code level variables for the new ZIP code including: median household income, % Black, % Hispanic, % of owneroccupied housing units, population density, and median value of owner occupied housing | Correlation (r): NA; Copollutant models with: NA
Bennett et al. (2019); U.S.; 2015 | National Center for Health Statistics; n = 41.9 million | Life expectancy loss | Annual average PM_2.5_ concentrations estimated using an integrated geographic regression model; Median: 7.7; 99th percentile: 10.1 | PM_2.5_ associated with lower life expectancy among counties with, higher percent of Black or African Americans. | Income, % in poverty, Black race, ≥ high school, urbanization, unemployment, cumulative smoking, mean temperature, relative humidity, county-specific random intercepts | Correlation (r): NA; Copollutant models with: NA
Jorgenson et al. (2020); U.S.; 2000−2014 | U.S. Mortality Database | Life expectancy at birth | PM_2.5_ concentrations estimated from stationary monitors, averaged at the state level; Mean: 10.55; Max: 19.02 | PM_2.5_ more detrimental in states with high percent of population of Black race. | Income share of top 10%, % Black, total population, median household income, median age, % college degree or higher | Correlation (r): NA; Copollutant models with: NA
Juarez et al. (2020); Southeastern U.S.; 2002−2009 | Southern Community Cohort Study; n = 72,215 | Cardio-metabolic disease | Annual average PM_2.5_ concentrations estimated from a continuous, spatial surface model using ground-level ambient air measures and satellite-derived measurements; Mean: 13.5; 90th percentile: 15.8 | Race did not modify the relationship between PM_2.5_ and CMD. | Age, history of tobacco use/smoking status, air quality outdoors, educational level, household income, marital status, gender, residence location, race | Correlation (r): NA; Copollutant models with: NA
Honda et al. (2017); U.S.; 1993−2010 | Women’s Health Initiative; n = 23,656 | Hypertension | Mean (SD): 13.2 (3.0) | HR (95% CI); White:1.15 (0.99, 1.35); Black: 1.26 (1.06, 1.44); Non-White: 1.27 (1.17, 1.38); Asian/Pacific Islander: 1.34 (1.00, 1.64); Hispanic/Latino:; 1.18 (0.99, 1.38) | Age, BMI, education, ethnicity, smoking status, physical activity, sodium intake, neighborhood SES, household income, employment status, insurance status, history of high cholesterol, history of cardiovascular disease, history of diabetes, clinical trial study arm and WHI clinical site | Correlation (r):; PM_10_: 0.56; PM_10−2.5_: 0.03; Copollutant models with: NA
Lim et al. (2018); U.S.; 1995−2011 | NIH-AARP Diet and Health Study; n = 549,735 | Diabetes Mortality | Annual average PM_2.5_ concentrations estimated using a spatiotemporal prediction model at the census tract; Mean (SD): 11.0 (2.7); Max: 21.2 | HR (95% CI); Black: 1.27 (1.02, 1.58); White: 1.05 (0.96, 1.14) | Age sex, region, race, or ethnic group, level of education, marital status, BMI, alcohol consumption, smoking status, diet, median census tract household income, % of census tract population with < a high school education | Correlation (r): NO_2_ = 0.60, O_3_ = 0.01; Copollutant models with: NA
Lipfert and Wyzga (2020); U.S.; 1976−2001 | Veterans Cohort Mortality Study; n = 70,000 | Mortality | Average PM_2.5_ concentrations estimated from stationary monitors, averaged at the county level; White: 13.9; Black: 15.7 | RR (95% CI); 1976−2001; White: 1.05 (1.01, 1.10); Black: 0.82 (0.75, 0.89); 1997−2001; White: 1.03 (0.91, 1.17); Black: 0.96 (0.76, 1.21) | individual age, race, smoking, height, body mass index, blood pressure, county-wide climate and ZIP code level socioeconomic indicators | Correlation (r):; White:; SO_4_^2^: 0.68, NO_2_:0.55,; peak CO: −0.19,; peak O_3_: 0.57, peak SO_2_: 0.20, PM_10_: 0.45; Black:; SO_4_^2^: 0.50, NO_2_: 0.58,; peak CO: 0.16, peak O_3_: 0.19, peak SO_2_: 0.43, PM_10_: 0.49; Copollutant models with: NA
Parker et al. (2018); U.S.; 1997−2011 | National Health Interview Survey; n = 657,238 | All-cause mortality (excluding unintentional injuries), heart disease mortality | Annual average PM_2.5_ concentrations estimated from stationary monitors; Median: 11.8; 90th percentile: 14.7 | HR (95% CI); All-cause; Black: 1.05 (1.03, 1.09); White: 1.03 (1.02, 1.03); Hispanic: 0.98 (0.94, 1.03); Heart disease; Black: 1.04 (0.94, 1.15); White: 1.10 (1.05, 1.15); Hispanic: 1.03 (0.95, 1.12); Other: 0.90 (0.75, 1.07) | Sex, family income as a % of the poverty threshold, marital status, education, county-level income, region of county, urbanization, and survey year | Correlation (r): NA; Copollutant models with: NA
Son et al. (2020); North Carolina; 2002−2013 | Death Records; n = 775,338 | Total Mortality | Daily average PM_2.5_ concentrations estimated from the CMAQ downscaler model on a 12 ×12 grid; Mean (SD): 11.4 (5.7); Max: 70.8 | OR (95% CI); NH-White: 1.01 (1.01, 1.01); NH-Black: 1.01 (1.00, 1.02); Hispanic: 0.97 (0.93, 1.02); NH-Asian: 1.01 (0.97, 1.02); NH-Other 1.01 (0.97, 1.04) | Case crossover | Correlation (r): O_3_: 0.48; Copollutant models with: NA
Wang et al. (2020); U.S.; 2000−2008 | Medicare, ≥ 65; n = 52,954,845 | Mortality | Daily average PM_2.5_ concentrations estimated from a validated spatiotemporal generalized additive model on a 6 km grid; Mean (SD): 10.32 (3.15) | Associations were null by race. | Age, sex, race, and ZIP code with additional control for ZIP code and state SES | Correlation (r): NO_2_: 0.59, O_3_: 0.24; Copollutant models with: O_3_

AARP = American Association of Retired Persons; AMI = acute myocardial infarction; BMI = body mass index; CMAQ = Community Multi-Scale Air Quality; CI = confidence interval; CV = cardiovascular; km = kilometer(s); HR = hazard ratio; IRD = Index of Racial Dissimilarity; NA = not applicable; NIH = National Institutes of Health; PM_2.5_ = particulate matter with a nominal mean aerodynamic diameter less than or equal to 2.5; PM_10_ = particulate matter with a nominal mean aerodynamic diameter less than or equal to 10; PM_10-2.5_ = particulate matter with a nominal mean aerodynamic diameter greater than 2.5 and less than or equal to 10; r = correlation coefficient; RRS = racial residential segregation; SD = standard deviation; SES = socioeconomic status; WHI = Women’s Health Initiative.

## A.1 Advances in Estimating Light Extinction

Equation 4-1, which across studies has been referred to as the original IMPROVE equation was originally the basis for estimating light extinction to track progress in reducing haze in visibility protected areas for the 1999 Regional Haze Rule (Malm et al., 1994):

b_ext_ ≈ 3 × f ( R H ) × [ Ammonium Sulfate ] + 3 × f ( R H ) × [ Ammonium Nitrate ] + 4 × [ Organic Mass ] + 10 × [ Elemental Carbon ] + 1 × [ Fine Soil ] + 0.6 × [ Coarse Mass ] + Rayleigh scattering (Eq. A-1)

Light extinction (b_ext_) is in units of per Mm; [Ammonium Sulfate], [Ammonium Nitrate], [Organic Mass], [Elemental Carbon], [Fine Soil], and [Coarse Mass] are the concentrations in μg/m^3^ of ammonium sulfate, ammonium nitrate, organic matter, elemental carbon, fine soil, and coarse mass, respectively; f(RH) is the relative-humidity-dependent water growth function for both ammonium sulfate and ammonium nitrate, and the various coefficients are empirically derived mass scattering and absorption coefficients originally proposed by (Malm et al., 1994). Organic mass is derived from organic carbon measurements by multiplying measured organic carbon by a factor of 1.4 to account for the non-carbon elements that also contribute to organic mass. Details on PM size distribution assumptions, component mass scattering extinction efficiencies, hygroscopicity, and other assumptions used to develop Equation A-1 are discussed in detail by Malm et al. (1994) and reviewed in Section 9.2.2 of the 2009 PM ISA (U.S. EPA, 2009) and Section 13.2.3 of the 2019 PM ISA (U.S. EPA, 2019).

Generally good performance was attributed to Equation A-1, but it underestimated high light extinction values and overestimated low light extinction values. Over the years, changes to the original IMPROVE equation have been adopted or proposed. Equation A-2 was developed to address bias at the low and high light extinction values of Equation A-1 (Pitchford et al., 2007). Equation A-2 has been referred to as the revised IMPROVE equation.

b_ext_ ≈ 2.2 × f_S_ ( R H ) × [ Small Ammonium Sulfate ] + 4.8 × f_L_ ( R H ) × [ Large Ammonium Sulfate ] + 2.4 × f_S_ ( R H ) × [ Small Ammonium Nitrate ] + 5.1 × f_L_ ( R H ) × [ Large Ammonium Nitrate ] + 2.8 × [ Small Organic Mass ] + 6.1 × [ Large Organic Mass ] + 10 × [ Elemental Carbon ] + 1 × [ Fine Soil ] + 1.7 × f_SS_ ( R H ) × [ Sea Salt ] + 0.6 × [ Coarse Mass ] + Rayleigh Scattering ( Site Specific ) + 0.33 × [ N O_2_ ( ppb ) ] (Eq. A-2)

Term definitions are the same as for Equation A-1. f_S_ and f_L_ are the relative-humidity-dependent water growth functions of ammonium sulfate and ammonium nitrate in the small and large modes, respectively, and f_SS_ is the water growth function for sea salt. Small and large ammonium sulfate, ammonium nitrate, and organic mass are used to refer to the splitting of the concentrations of each of those three species into two size modes.

Equation A-2 is the result of five revisions to Equation A-1: (1) the addition of a sea salt term, (2) a change in the ratio of organic mass to organic carbon mass from 1.4 to 1.8, (3) a change in the Rayleigh scattering term to a site-specific term based on elevation and annual temperature, (4) introduction of split-component extinction efficiency terms to represent two particle size modes for sulfate, nitrate, and organic mass along with a new water growth term for sulfate and nitrate, and (5) addition of a NO_2_ light absorption term for monitors where NO_2_ concentration data are available. Sulfate, nitrate, and organic mass are each split into a small mode and a large mode, with the fraction of the large mode estimated by dividing the component concentration by 20 µg/m^3^ and the remaining component mass attributed to the small mode if the PM_2.5_ concentration is under 20 µg/m^3^ and attributing all component mass to the large mode if the concentration is greater than 20 µg/m^3^. This approach is consistent with an assumption that lower concentrations are associated with fresher emissions and smaller particle sizes, and higher concentrations with more aged PM and larger particle sizes. Because of this particular feature, Equation A-2 is sometimes referred to as the split-component algorithm. Further explanation of this calculation is available at (http://vista.cira.colostate.edu/Improve/the-improve-algorithm/). Light extinction and hygroscropicity are based on literature values, but component splitting between size modes is based on empirical observations (Prenni et al., 2019). Details on component mass scattering extinction efficiencies and hygroscopicities, and other assumptions used to develop Equation A-2 are discussed by Pitchford et al. (2007) and in Section 9.2.3 of the 2009 PM ISA (U.S. EPA, 2009).

Good performance of Equation A-2 was reported for a wide range of PM composition and sample loadings through 2003 (Prenni et al., 2019). However, Equation 4-2 was based on data from 1995 to 2003, when PM concentrations were higher than they are now, and PM composition and source contributions have also changed since then (Prenni et al., 2019). By the time of publication of the 2019 PM ISA, new results indicated that the Equation A-2 had not been generally successful in decreasing the bias in light extinction estimates associated with Equation A-1. For example, Equation A-2 was evaluated by Lowenthal and Kumar (2016), who recommended a further increase in the ratio of organic mass to organic carbon from 1.8 to 2.1, as well as the introduction of a relative-humidity-dependent water growth function for organic mass. The basis for these recommendations was discussed in detail by Lowenthal and Kumar (2016) and summarized in the 2019 PM ISA (U.S. EPA, 2019). Implementation of their recommendations results in Equation A-3, which is identical in form to Equation A-2, except for the insertion of the water growth terms f_S_(RH)_OM_ and f_L_(RH) for small and large organic mass, respectively:

b_ext_ ≈ 2.2 × f_S_ ( R H ) × [ Small Ammonium Sulfate ] + 4.8 × f_L_ ( R H ) × [ Large Ammonium Sulfate ] + 2.4 × f_S_ ( R H ) × [ Small Ammonium Nitrate ] + 5.1 × f_L_ ( R H ) × [ Large Ammonium Nitrate ] + 2.8 × f_S_ ( R H )_OM_ × [ Small Organic Mass ] + 6.1 × f_L_ ( R H )_OM_ × [ Large Organic Mass ] + 10 × [ Elemental Carbon ] + 1 × [ Fine Soil ] + 1.7 × f_SS_ ( R H ) × [ Sea Salt ] + 0.6 × [ Coarse Mass ] + Rayleigh Scattering ( Site Specific ) + 0.33 × [ N O_2_ ( ppb ) ] (Eq. A-3)

The 2011 IMPROVE report (Hand et al., 2011) and the 2019 PM ISA (U.S. EPA, 2019) also recognized concerns with Equation A-2, and returned to the use of Equation 4-1, but with the following changes that had been incorporated into Equation A-2: (1) the sea salt term was added, (2) the factor used to compute organic mass concentration from organic carbon measurements increased from 1.4 to 1.8, and (3) the site-specific term based on elevation and mean temperature was substituted for the constant value 10/Mm for Rayleigh scattering (U.S. EPA, 2019; Hand et al., 2011). These modifications resulted in Equation A-4, sometimes referred to as the modified original IMPROVE equation:

b_ext_ ≈ 3 × f ( R H ) × [ Ammonium Sulfate ] + 3 × f ( R H ) × [ Ammonium Nitrate ] + 4 × [ Organic Mass ] + 10 × [ Elemental Carbon ] + 1 × [ Fine Soil ] + 1.7 × f ( R H ) × [ Sea Salt ] + 0.6 × [ Coarse Mass ] + Rayleigh scattering (Eq. A-4)

More detailed discussions of Equations A-1 through A-4, as well as additional studies that have evaluated their performance are reviewed are in Sections 9.2.2 and 9.2.3 of the 2009 PM ISA (U.S. EPA, 2009) and Section 13.2.3 of the 2019 PM ISA (U.S. EPA, 2019).

The observations of persistent and potentially increasing bias in the established method for estimating light extinction from national monitoring network data are a concern and, as a result, it continues to be investigated. Since publication of the 2019 PM ISA, a comparison of direct measurements of light extinction using an integrating nephelometer with estimates of reconstructed light extinction based on Equation A-2 at 11 monitoring locations from 2002 to 2018 showed that the relationship between measured and reconstructed light extinction is changing (Prenni et al., 2019). As large decreases in sulfate and organic mass occurred over this 16-year period, the difference between measured and reconstructed light extinction increased at the five eastern monitoring locations, indicating that Equation A-2 increasingly underestimated light extinction over time. Multiple linear regressions of light extinction against PM components resulted in increasing regression coefficients over time for ammonium sulfate and particulate organic matter at these locations.

As PM concentrations have decreased, an increasingly larger portion of PM mass has been allocated to the smallest of the two size modes of Equation A-2 because, as described above, species mass is apportioned between size modes by dividing the decreasing species concentration by the same fixed factor of 20 µg/m^3^ each year (Prenni et al., 2019). Prenni et al. (2019) used particle size distribution data from intensive field studies and from model simulations to demonstrate that changes in particle size distributions have not actually occurred as PM concentrations have decreased, and they concluded that a part of the apparent decreasing trend in light extinction by ammonium sulfate and particulate organic matter is likely an artifact of Equation A-2, leading to calculations of changes in mass scattering efficiencies that have not occurred in the atmosphere. Estimating the fraction of the large size mode by dividing the component concentration by five times the annual median component mass calculated for ammonium sulfate, ammonium nitrate, and organic mass for each monitor and year instead of by the 20 µg/m^3^ factor previously used for all sites and years, reduced the bias, especially in later years (Prenni et al., 2019).

Other sources of bias associated with both Equations A-1 and A-2 that could affect reconstructed light extinction have also been documented and reviewed by Prenni et al. (2019). Among the potential sources of biases that have been investigated are (1) the assumption of a constant ratio for converting measured organic carbon mass to total organic mass, in spite of spatial and seasonal variability and observed changes during atmospheric aging; (2) the assumption that organic mass is not hygroscopic while there is increasing evidence to the contrary; and (3) the assumption that ammonium sulfate is the only form of atmospheric sulfate even though recent research provides evidence that it is not fully neutralized in many U.S. locations (Prenni et al., 2019). While these could also lead to increased bias in light extinction estimates, the results of Prenni et al. (2019) indicate that a better understanding and correction of the potential biases is necessary before additional revision of Equation A-2 could be effective.

## A.2 Quality Assurance Summary

The use of quality assurance (QA) and peer review help ensure that EPA conducts high-quality science assessments that can be used to help policymakers, industry, and the public make informed decisions. Quality assurance activities performed by EPA ensure that environmental data are of sufficient quantity and quality to support the Agency’s intended use. The ISA for Particulate Matter is classified as a Highly Influential Scientific Assessment (HISA), which is defined by the Office of Management and Budget (OMB) as a scientific assessment that is novel, controversial, or precedent-setting, or has significant interagency interest. OMB requires a HISA to be peer reviewed before dissemination. To meet this requirement, EPA engages the Clean Air Scientific Advisory Committee (CASAC) as an independent federal advisory committee to conduct peer reviews. Both peer-review comments provided by the CASAC panel and public comments submitted to the panel during its deliberations about the external review draft were considered in the development of this ISA. Agency-wide, EPA Quality System provides the framework for planning, implementing, documenting, and assessing work performed by the Agency, and for carrying out required quality assurance and quality control (QA/QC) activities. Additionally, the Quality System covers the implementation of EPA Information Quality Guidelines. This ISA follows all Agency guidelines to ensure a high-quality document. Within EPA, Quality Assurance Project Plans (QAPPs) are developed to ensure that all Agency materials meet a high standard for quality. U.S. EPA has developed a Program-level QAPP (PQAPP) for the ISA Program to describe the technical approach and associated QA/QC procedures associated with the ISA Program (PQAPP ID# L-HEEAD-0030253-QP-1-5). In addition, QAPP (L-HEEAD-0030768-QP-1-0) was applied to the PM ISA Project. All QA objectives and measurement criteria detailed in the PQAPP and QAPP have been employed in developing this ISA. Quality assurance checks were conducted on numerical entries used in the appendices, and at a minimum, the numbers obtained from every tenth reference cited in the appendices were verified against the original source by an independent scientist for accuracy. Furthermore, publicly available databases (e.g., National Emissions Inventory, Air Quality System database) from which data were used in analyses were verified to have their own QA processes in place. U.S. EPA QA staff are responsible for the review and approval of all quality-related documentation. Because this is a HISA, U.S. EPA QA staff performed a Technical System Audit on the 2019 PM ISA in August 2019 and September 2020, and the Supplement to the 2019 PM ISA in March 2022. These audits verified that the appropriate QA/QC procedures and reviews were adequately performed and documented.