# ACRONYMS AND ABBREVIATIONS

Acronym/Abbreviation: Meaning
AARP: American Association of Retired Persons
ABI: ankle-brachial index
ACS: American Cancer Society
adj: adjustment
AF: atrial fibrillation
Ag Health: Agricultural Health Study
AHSMOG: Adventist Health Study and Smog
AIC: Akaike information criterion
AL: Alabama
AMI: acute myocardial infarction
AN: ammonium nitrate
AOD: aerosol optical depth
APPROACH: Alberta Provincial Project for Outcome Assessment in Coronary Heart Disease
AQCD: Air Quality Criteria Document
AQS: Air Quality System
AS: ammonium sulfate
ASD: autism spectrum disorder
avg: average
BAD: bronchial artery diameter
BASIC: Brain Attack Surveillance in Corpus Christi
BC: black carbon
b _ext_: light extinction coefficient
BME: Bayesian maximum entropy
BMI: body mass index
BP: blood pressure
BRFSS: Behavioral Risk Factor Surveillance System
CA: California
CAC: coronary artery calcification
CAD: coronary artery disease
Cancer Prev: cancer prevention
CanCHEC: Canadian Census Health and Environment Cohort
CAN-Marg: Canadian Marginalization Index
CAPs: concentrated ambient particles
CASAC: Clean Air Scientific Advisory Committee
CATHGEN: Catheterization Genetics study
CBSA: core-based statistical area
CBVD: cerebrovascular disease
CCHEC: Canadian Census Health and Environment Cohort
CCHS: Canadian Community Health Survey
CFR: case fatality rate
CHD: coronary heart disease
CHF: congestive heart failure
CI: confidence interval
cIMT: carotid intima-media thickness
CM: coarse mass
CMA: census metropolitan area size
CMAQ: Community Multiscale Air Quality model
CMR: cardiovascular mortality rate
CO: carbon monoxide
COPD: chronic obstructive pulmonary disease
COVID-19: coronavirus disease 2019
C-R: concentration-response
CSN: Chemical Speciation Network
CTM: chemical transport model
CTS: California Teachers Study
C-V: cross-validation
CVD: cardiovascular disease
DBP: diastolic blood pressure
DC: District of Columbia
DE: diesel exhaust
df: degrees of freedom
DID: difference-in-difference
DNA: deoxyribonucleic acid
DOW: day of week
DRAM: doubly robust additive model
DVT: deep vein thrombosis
EC: elemental carbon
ECG: electrocardiogram
ED: emergency department
EFFECT: Enhanced Feedback for Effective Cardiac Treatment
EJ: environmental justice
EPA: Environmental Protection Agency
ESCAPE: European Study of Cohorts for Air Pollution Effects
ESRD: end-stage renal disease
exp: exposure
FA: filtered air; fatty acid
FD: find dust
FEV_1_: forced expiratory volume in 1 second
FMD: flow-mediated dilation
FVC: forced vital capacity
GA: Georgia
GAM: generalized additive model
GLM: generalized linear model
GEOS-Chem: Goddard Earth Observing System-Chem
GP: general practitioner
GPS: generalized propensity score
GWR: geographically weighted regression
h: hour(s)
HA: hospital admission
HDL-c: High-density lipoprotein cholesterol
Health Prof: health professionals
HeartSCORE: Heart Strategies Concentration on Risk Evaluation
HEI: Health Effects Institute
HEPA: high efficiency particle filter
HF: heart failure; high frequency
HHD: hypertensive heart disease
HISA: Highly Influential Scientific Assessment
HNR: Heinz Nixdorf Recall (study)
HPFU: Health Professionals Follow-Up Study
HR: hazard ratio
HRV: heart rate variability
HS: hemorrhagic stroke
HSC: Harvard Six Cities
HYSLPLIT: HYbrid Single-Particle Lagrangian Integrated Trajectory
IAD: inter-adventitial diameter
ICD-10: International Classification of Disease version 10
ICD-9: International Classification of Disease version 9
ICU: intensive care unit
IDW: inverse distance weighting
IHD: ischemic heart disease
IL: Illinois
IMPROVE: Interagency Monitoring of Protected Visual Environments
InMAP: Intervention Model for Air Pollution
IPTW: inverse probability of treatment weighting
IPW: inverse probability weighting
IQR: interquartile range
IRD: Index of Racial Dissimilarity
IRP: Integrated Review Plan
IRR: incidence rate ratio
IS: ischemic stroke
IV: instrumental variable
JHS: Jackson Heart Study
km: kilometer(s)
km2: square kilometer(s)
LDH: lactate dehydrogenase
LDL-c: low-density lipoprotein cholesterol
LF: low frequency
LUR: land use regression
LUR-BME: land use regression—Bayesian maximum entropy
LV: left ventricular
m^2^: Square meter(s)
MAP: mean arterial pressure
MAPLE: mortality-air pollution associations in low-exposure environments
max: maximum
MCAPS: Medicare Cohort Air Pollution Study
MCC: Multi-City Multi-Country Collaborative Research Network
mCCHS: Canadian Community Health Survey―mortality cohort
MCM: multi-cause multicity
MD: Maryland
MESA: Multi-Ethnic Study of Atherosclerosis
mg: milligram(s)
MI: myocardial infarction
min: minimum
MINAP: Myocardial Ischemia National Audit Project
MISR: Multiangle Imaging Spectroradiometer
MISS: monotonically increasing smoothing splines
mm Hg: millimeters of mercury
mo: month(s)
MO: Missouri; month
MR: mortality ratio
MRR: mortality risk ratio
NAAQS: National Ambient Air Quality Standards
NAPS: National Air Pollution Surveillance System
NC: number concentration; North Carolina
NCHS: National Center for Health Statistics
NEI: National Emissions Inventory
NH: non-Hispanic
NHIS: National Health Interview Survey
NHS: Nurses’ Health Study
NIH: National Institutes of Health
NIH-AARP: National Institutes of Health–American Association of Retired Persons (diet and health cohort)
NMMAPS: National Morbidity, Mortality, and Air Pollution Study
NN: Normal-to-Normal
NO_2_: nitrogen dioxide
NO_3_: nitrate
NO_X_: oxides of nitrogen (NO + NO_2_)
NPMs: neighborhood PM monitors
NR: not reported
NSTEMI: non-ST segment elevation MI
O_3_: ozone
OC: organic carbon
OHCA: out-of-hospital cardiac arrest
OLS: ordinary least squares
OM: organic matter
OMB: Office of Management and Budget
ONPHEC: Ontario Population Health and Environment Cohort
OR: odds of recurrent
Ox: Redox weighted average of NO_2_ and O_2_
PA: Pennsylvania
PAH: polycyclic aromatic hydrocarbon(s)
PE: prediction error
PEF: peak expiratory flow
PM: particulate matter
PM_10_: particulate matter with a nominal mean aerodynamic diameter less than or equal to 10 um
PM_10–2.5_: particulate matter with a nominal mean aerodynamic diameter greater than 2.5 um and less than or equal to 10 um
PM_2.5_: particulate matter with a nominal mean aerodynamic diameter less than or equal to 2.5 um
POM: particulate organic matter
ppb: parts per billion
ppm: parts per million
PQAPP: Program-level Quality Assurance Project Plan
PREMIER: Prospective Registry Evaluating Myocardial Infraction: Events and Recovery
QA: quality assurance
QAPP: quality assurance project plans
QRS: time interval between the beginning of the Q wave and the peak of the S wave
r: correlation coefficient
R^2^: coefficient of determination
RAMP: Real-time Affordable Multi-Pollutant
RC: regression calibration
RCS: restricted cubic splines
redox: reduction-oxidation
REGARDS: REasons for Geographic and Racial Differences in Stroke
re-HA: Readmission to the hospital
RF: radiative forcing
RH: relative humidity
RMSS: root mean square standardized
RR: relative risks
RRS: racial residential segregation
RV: right ventricular
SARS: severe acute respiratory syndrome
SARS-CoV-2: severe acute respiratory syndrome coronavirus 2
SBP: systolic blood pressure
SC: surface area concentration
SCHIF: Shape Constrained Health Impact Function
SD: standard deviation
SDI: social deprivation index
SDNN: standard deviation of NN
SE: standard error
SED: socioeconomic deprivation
SEIR: susceptible-exposed-infected-rec overed
SES: socioeconomic status
SHS: second-hand smoke
SHV: Social and Health Vulnerability
sICAM: soluble intercellular adhesion molecule 1
SO_2_: sulfur dioxide
SO_4_: sulfate
SPARCS: New York State Department of Health Statewide Planning and Research Cooperative System
SPE: standardized prediction error
ST: beginning of S wave to end of T wave
STEMI: ST elevated myocardial infarction
sVCAM: Soluble vascular cell adhesion molecule 1
SHV: Social Health Vulnerability
SWAN: Study of Women’s Health Across the Nation
TRAP: traffic-related air pollution
TrIPS: Trucking Industry Particle Study
TRIUMPH: Translational Research Investigating Underlying Disparities in Acute Myocardial Infarction
TX: Texas
UFIREG: Ultrafine Particles—An Evidence-Based Contribution to the Development of Regional and European Environmental and Health Policy
UFP: ultrafine particle
U.S.: United States of America
U.S. EPA: U.S. Environmental Protection Agency
USRDS: U.S. Renal Data System
W: west
WHI: Women’s Health Initiative
WHO: World Health Organization
WS Fe: water-soluble iron
yr: year(s)
ZIP: Zone Improvement Plan