# REFERENCES

Abrass, CK. (2000). The nature of chronic progressive nephropathy in aging rats [Review]. Advances in Renal Replacement Therapy 7: 4–10. 10.1016/S1073-4449(00)70001-X 10672913
Amberg, A; Rosner, E; Dekant, W. (1999). Biotransformation and kinetics of excretion of methyl-tert-butyl ether in rats and humans. Toxicological Sciences 51: 1–8.10496672
Amberg, A; Rosner, E; Dekant, W. (2000). Biotransformation and kinetics of excretion of ethyl tert-butyl ether in rats and humans. Toxicological Sciences 53: 194–201. 10.1093/toxsci/53.2.194 10696767
ARCO (ARCO Chemical Company). (1983). Toxicologist’s report on metabolism and pharmacokinetics of radiolabeled TBA 534 tertiary butyl alcohol with cover letter dated 03/24/1994. (8EHQ86940000263). Newton Square, PA.
Asano, Y; Ishikura, T; Kudoh, K; Haneda, R; Endoh, T. (2011). Prenatal developmental toxicity study of ethyl tertiary-butyl ether in rabbits. Drug and Chemical Toxicology 34: 311–317. 10.3109/01480545.2010.532501 21649486
Aso, S; Miyata, K; Takakura, S; Hoshuyama, S; Muroi, T; Kusune, Y, . (2014). Prenatal developmental toxicity study of ethyl tertiary-butyl ether in rats. Drug and Chemical Toxicology 37: 17–24. 10.3109/01480545.2013.806527 23841892
ATSDR (Agency for Toxic Substances and Disease Registry). (1996). Toxicological profile for methyl-tert-butyl ether [ATSDR Tox Profile]. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service. http://www.atsdr.cdc.gov/ToxProfiles/tp91.pdf
Bailey, SA; Zidell, RH; Perry, RW. (2004). Relationships between organ weight and body/brain weight in the rat: What is the best analytical endpoint? Toxicologic Pathology 32: 448–466. 10.1080/01926230490465874 15204968
Banton, MI; Peachee, VL; White, KL; Padgett, EL. (2011). Oral subchronic immunotoxicity study of ethyl tertiary butyl ether in the rat. Journal of Immunotoxicology 8: 298–304. 10.3109/1547691X.2011.598480 21827378
Berger, T; Horner, CM. (2003). In vivo exposure of female rats to toxicants may affect oocyte quality. Reproductive Toxicology 17: 273–281. 10.1016/S0890-6238(03)00009-1 12759095
Bernauer, U; Amberg, A; Scheutzow, D; Dekant, W. (1998). Biotransformation of 12C- and 2-13C-labeled methyl tert-butyl ether, ethyl tert-butyl ether, and tert-butyl alcohol in rats: Identification of metabolites in urine by 13C nuclear magnetic resonance and gas chromatography/mass spectrometry. Chemical Research in Toxicology 11: 651–658. 10.1021/tx970215v 9625733
Blanck, O; Fowles, J; Schorsch, F; Pallen, C; Espinasse-Lormeau, H; Schulte-Koerne, E, . (2010). Tertiary butyl alcohol in drinking water induces phase I and II liver enzymes with consequent effects on thyroid hormone homeostasis in the B6C3F1 female mouse. Journal of Applied Toxicology 30: 125–132. 10.1002/jat.1478 19760798
Bond, JA; Medinsky, MA; Wolf, DC; Cattley, R; Farris, G; Wong, B, . (1996). Ethyl tertiary butyl ether (ETBE): ninety-day vapor inhalation toxicity study in CD-1(R) mice. Bond, JA; Medinsky, MA; Wolf, DC; Cattley, R; Farris, G; Wong, B; Janszen, D; Turner, MJ; Sumner, SCJ.
Borghoff, SJ; Parkinson, H; Leavens, TL. (2010). Physiologically based pharmacokinetic rat model for methyl tertiary-butyl ether; comparison of selected dose metrics following various MTBE exposure scenarios used for toxicity and carcinogenicity evaluation. Toxicology 275: 79–91. 10.1016/j.tox.2010.06.003 20561556
Borghoff, SJ; Prescott, JS; Janszen, DB; Wong, BA; Everitt, JI. (2001). alpha2u-Globulin nephropathy, renal cell proliferation, and dosimetry of inhaled tert-butyl alcohol in male and female F-344 rats. Toxicological Sciences 61: 176–186. 10.1093/toxsci/61.1.176 11294988
Borghoff, SJ; Ring, C; Banton, MI; Leavens, TL. (2016). Physiologically based pharmacokinetic model for ethyl tertiary-butyl ether and tertiary-butyl alcohol in rats: Contribution of binding to α2u-globulin in male rats and high-exposure nonlinear kinetics to toxicity and cancer outcomes. Journal of Applied Toxicology 37: 621–640. 10.1002/jat.3412 27885692
Brennan, P. (2002). Gene-environment interaction and aetiology of cancer: what does it mean and how can we measure it? Carcinogenesis 23: 381–387.11895852
Brennan, P; Lewis, S; Hashibe, M; Bell, DA; Boffetta, P; Bouchardy, C, . (2004). Pooled analysis of alcohol dehydrogenase genotypes and head and neck cancer: a HuGE review. American Journal of Epidemiology 159: 1–16.14693654
CalEPA (California Environmental Protection Agency). (2016). GeoTracker. Available online at http://geotracker.waterboards.ca.gov/
Capen, CC; Dybing, E; Rice, JM; Wilbourn, JD. (1999). Species differences in thyroid, kidney and urinary bladder carcinogenesis. In CC Capen; E Dybing; JM Rice; JD Wilbourn (Eds.), (pp. 1–225). Lyon, France: International Agency for Research on Cancer.
Cederbaum, AI; Cohen, G. (1980). Oxidative demethylation of t-butyl alcohol by rat liver microsomes. Biochemical and Biophysical Research Communications 97: 730–736. 10.1016/0006-291X(80)90325-3 7470124
Chernoff, N; Rogers, JM; Turner, CI; Francis, BM. (1991). Significance of supernumerary ribs in rodent developmental toxicity studies - postnatal persistence in rats and mice. Fundamental and Applied Toxicology 17: 448–453. 10.1016/0272-0590(91)90196-B 1794649
Cohen, SM; Hard, GC; Regan, KS; Seely, JC; Bruner, RH. (2011). Pathology working group review of selected histopathologic changes in the kidneys of rats assigned to toxicology and carcinogenicity studies of ethyl tertiary butyl ether (ETBE): Japan Bioassay Research Center studies no.: 0065 and 0691 [Unpublished report] (pp. 1–30). Research Triangle Park, NC: Research Pathology Associates under contract to Lyondell Chemical Company.
Craig, EA; Yan, Z; Zhao, QJ. (2014). The relationship between chemical-induced kidney weight increases and kidney histopathology in rats. Journal of Applied Toxicology 35: 729–736. 10.1002/jat.3036 25092041
de Peyster, A. (2010). Ethyl t-butyl ether: Review of reproductive and developmental toxicity [Review]. Birth Defects Research, Part B: Developmental and Reproductive Toxicology 89: 239–263. 10.1002/bdrb.20246 20544807
de Peyster, A; Stanard, B; Westover, C. (2009). Effect of ETBE on reproductive steroids in male rats and rat Leydig cell cultures. Toxicology Letters 190: 74–80. 10.1016/j.toxlet.2009.06.879 19595749
Dekant, W; Bernauer, U; Rosner, E; Amberg, A. (2001). Toxicokinetics of ethers used as fuel oxygenates [Review]. Toxicology Letters 124: 37–45. 10.1016/s0378-4274(00)00284-8 11684356
Doi, AM; Hill, G; Seely, J; Hailey, JR; Kissling, G; Bucher, JR. (2007). α2u-Globulin Nephropathy and Renal Tumors in National Toxicology Program Studies. Toxicologic Pathology 35: 533–540.17562486
Dorman, DC; Struve, MF; Wong, BA; Morgan, KT; Janszen, DB; Gross, EB, . (1997). Neurotoxicological evaluation of ethyl tertiary-butyl ether following subchronic (90-day) inhalation in the Fischer 344 rat. Journal of Applied Toxicology 17: 235–242. 10.1002/(sici)1099-1263(199707)17:4<235::aid-jat435>3.0.co;2-4 9285536
Drogos, DL; Diaz, AF. (2001). Appendix A: Physical properties of fuel oxgenates and addititves. In Oxygenates in Gasoline. Washington, DC: American Chemical Society. 10.1021/bk-2002-0799.ch018
Elcombe, CR; Peffer, RC; Wolf, DC; Bailey, J; Bars, R; Bell, D, . (2014). Mode of action and human relevance analysis for nuclear receptor-mediated liver toxicity: A case study with phenobarbital as a model constitutive androstane receptor (CAR) activator [Review]. Critical Reviews in Toxicology 44: 64–82. 10.3109/10408444.2013.835786 24180433
Eriksson, CJ. (2015). Genetic-epidemiological evidence for the role of acetaldehyde in cancers related to alcohol drinking [Review]. Advances in Experimental Medicine and Biology 815: 41–58. 10.1007/978-3-319-09614-8_3 25427900
Faulkner, TP; Wiechart, JD; Hartman, DM; Hussain, AS. (1989). The effects of prenatal tertiary butanol administration in CBA/J and C57BL/6J mice. Life Sciences 45: 1989–1995.2601562
Frazier, KS; Seely, JC; Hard, GC; Betton, G; Burnett, R; Nakatsuji, S, . (2012). Proliferative and nonproliferative lesions of the rat and mouse urinary system. Toxicologic Pathology 40: 14S–86S. 10.1177/0192623312438736 22637735
Fujii, S; Yabe, K; Furukawa, M; Matsuura, M; Aoyama, H. (2010). A one-generation reproductive toxicity study of ethyl tertiary butyl ether in rats. Reproductive Toxicology 30: 414–421. 10.1016/j.reprotox.2010.04.013 20438832
Fukami, T; Nakajima, M; Yoshida, R; Tsuchiya, Y; Fujiki, Y; Katoh, M, . (2004). A novel polymorphism of human CYP2A6 gene CYP2A6*17 has an amino acid substitution (V365M) that decreases enzymatic activity in vitro and in vivo. Clinical Pharmacology & Therapeutics 76: 519–527. 10.1016/j.clpt.2004.08.014 15592323
Gaoua, W. (2004a). Ethyl tertiary butyl ether (ETBE): Prenatal developmental toxicity study by the oral route (gavage) in rats (pp. 1–280). (CIT Study No. 24860 RSR). unpublished study for Totalfinaelf on behalf of the ETBE Producers’ Consortium.
Gaoua, W. (2004b). Ethyl tertiary butyl ether (ETBE): Two-generation study (reproduction and fertility effects) by the oral route (gavage) in rats. (CIT Study No. 24859 RSR). unpublished study for Totalfinaelf on behalf of the ETBE Producers’ Consortium.
Gehlhaus, MW, III; Gift, JS; Hogan, KA; Kopylev, L; Schlosser, PM; Kadry, AR. (2011). Approaches to cancer assessment in EPA’s Integrated Risk Information System [Review]. Toxicology and Applied Pharmacology 254: 170–180. 10.1016/j.taap.2010.10.019 21034767
Gross, ER; Zambelli, VO; Small, BA; Ferreira, JC; Chen, CH; Mochly-Rosen, D. (2015). A personalized medicine approach for Asian Americans with the aldehyde dehydrogenase 2*2 variant [Review]. Annual Review of Pharmacology and Toxicology 55: 107–127. 10.1146/annurev-pharmtox-010814-124915
Guyton, KZ; Chiu, WA; Bateson, TF; Jinot, J; Scott, CS; Brown, RC, . (2009). A reexamination of the PPAR-alpha activation mode of action as a basis for assessing human cancer risks of environmental contaminants [Review]. Environmental Health Perspectives 117: 1664–1672. 10.1289/ehp.0900758 20049115
Hagiwara, A; Doi, Y; Imai, N; Nakashima, H; Ono, T; Kawabe, M, . (2011). Medium-term multi-organ carcinogenesis bioassay of ethyl tertiary-butyl ether in rats. Toxicology 289: 160–166. 10.1016/j.tox.2011.08.007 21864636
Hagiwara, A; Doi, Y; Imai, N; Suguro, M; Kawabe, M; Furukawa, F, . (2015). Promotion of liver and kidney carcinogenesis by ethyl tertiary-butyl ether (ETBE) in male Wistar rats. Journal of Toxicologic Pathology 28: 189–195. 10.1293/tox.JTP-2015-0023 26538808
Hagiwara, A; Imai, N; Doi, Y; Suguro, M; Kawabe, M; Furukawa, F, . (2013). No Promoting Effect of Ethyl Tertiary-butyl Ether (ETBE) on Rat Urinary Bladder Carcinogenesis Initiated with N-Butyl-N-(4-hydroxybutyl)nitrosamine. Journal of Toxicologic Pathology 26: 351–357. 10.1293/tox.2013-0027 24526807
Hard, GC; Banton, MI; Bretzlaff, RS; Dekant, W; Fowles, JR; Mallett, AK, . (2013). Consideration of rat chronic progressive nephropathy in regulatory evaluations for carcinogenicity. Toxicological Sciences 132: 268–275. 10.1093/toxsci/kfs305 23104430
Hard, GC; Johnson, KJ; Cohen, SM. (2009). A comparison of rat chronic progressive nephropathy with human renal disease-implications for human risk assessment [Review]. Critical Reviews in Toxicology 39: 332–346. 10.1080/10408440802368642 19514917
Hard, GC; Khan, KN. (2004). Invited review: A contemporary overview of chronic progressive nephropathy in the laboratory rat, and its significance for human risk assessment [Review]. Toxicologic Pathology 32: 171–180. 10.1080/01926230490422574 15200155
Hattis, D; Goble, R; Russ, A; Chu, M; Ericson, J. (2004). Age-related differences in susceptibility to carcinogenesis: A quantitative analysis of empirical animal bioassay data. Environmental Health Perspectives 112: 1152–1158. 10.1289/ehp.6871 15289159
HSDB (Hazardous Substances Data Bank). (2021). Tert-Butyl ethyl ether CASRN: 637-92-3. Washington D.C. https://pubchem.ncbi.nlm.nih.gov/compound/Tert-Butyl-ethyl-ether https://pubchem.ncbi.nlm.nih.gov/compound/6386
IARC (International Agency for Research on Cancer). (1999a). Acetaldehyde [IARC Monograph]. In Re-evaluation of some organic chemicals, hydrazine and hydrogen peroxide (pp. 319–335). Lyon, France. http://monographs.iarc.fr/ENG/Monographs/vol71/mono71-88.pdf
IARC (International Agency for Research on Cancer). (1999b). IARC monographs on the evaluation of carcinogenic risks to humans: Re-evaluation of some organic chemicals, hydrazine and hydrogen peroxide [IARC Monograph]. Lyon, France: World Health Organization.
IARC (International Agency for Research on Cancer). (1999c). Methyl tert-butyl ether. In Some chemicals that cause tumours of the kidney or urinary bladder in rodents and some other substances. Lyon, France: World Health Organization.
IARC (International Agency for Research on Cancer). (2010). Alcohol consumption and ethyl carbamate [IARC Monograph]. Lyon, France. http://monographs.iarc.fr/ENG/Monographs/vol96/mono96.pdf
IARC (International Agency for Research on Cancer). (2012). Consumption of Alcoholic Beverages [IARC Monograph]. Lyon, France. http://monographs.iarc.fr/ENG/Monographs/vol100E/
Johanson, G; Nihlén, A; Löf, A. (1995). Toxicokinetics and acute effects of MTBE and ETBE in male volunteers. Toxicology Letters 82/83: 713–718. 10.1016/0378-4274(95)03589-3 8597131
JPEC (Japan Petroleum Energy Center). (2007a). 13-Week toxicity test of 2-ethoxy-2-methylpropane in F344 rats (drinking water study) [Preliminary study for the carcinogenicity test]. (Study No. 0665). Kanagawa, Japan: Japan Industrial Safety and Health.
JPEC (Japan Petroleum Energy Center). (2007b). Micronucleus test of ETBE using bone marrow of rats of the 13-week toxicity study of 2-ethoxy-2-methylpropane in F344 rats (drinking water study) [preliminary carcinogenicity study]. (Study Number: 7046). Japan Bioassay Research Center, Japan Industrial Safety and Health Association.
JPEC (Japan Petroleum Energy Center). (2008a). [28-day ETBE repeated dose full-body inhalation toxicity test in rats (preliminary test)]. (Study No. B061828). Japan: Mitsubishi Chemical Safety Institute Ltd.
JPEC (Japan Petroleum Energy Center). (2008b). A 90-day repeated dose toxicity study of ETBE by whole-body inhalation exposure in rats. (Study Number: B061829). Mitsubishi Chemical Safety Institute Ltd.
JPEC (Japan Petroleum Energy Center). (2008c). A 180-Day repeated dose oral toxicity study of ETBE in rats. (Study Number: D19-0002). Japan: Hita Laboratory, Chemicals Evaluation and Research Institute (CERI).
JPEC (Japan Petroleum Energy Center). (2008d). Medium-term mutli-organ carcinogenesis bioassay of 2-ethoxy-2-methylpropane (ETBE) in rats. (Study Number: 0635). Ichinomiya, Japan: DIMS Institute of Medical Science.
JPEC (Japan Petroleum Energy Center). (2008e). A one-generation reproduction toxicity study of ETBE in rats. (Study Number: SR07060). Safety Research Institute for Chemical Compounds.
JPEC (Japan Petroleum Energy Center). (2008f). Pharmacokinetic study in rats treated with [14c] ETBE repeatedly for 14 days. (P070497). Japan: Kumamoto Laboratory, Mitsubishi Chemical Safety Institute Ltd.
JPEC (Japan Petroleum Energy Center). (2008g). Pharmacokinetic study in rats treated with single dose of [14C] ETBE. (P070496). Japan: Kumamoto Laboratory, Mitsubishi Chemical Safety Institute Ltd.
JPEC (Japan Petroleum Energy Center). (2008h). A prenatal developmental toxicity study of ETBE in rats. (Study Code Number E09-0006). Hita Research Laboratories, Chemicals Evaluation and Research Institute (CERI).
JPEC (Japan Petroleum Energy Center). (2008i). Study for effects on embryo-fetal development in rabbits treated orally with ETBE. (Study No. R-965). Shizuoka, Japan: Kannami Laboratory, Bozo Research Center Inc.
JPEC (Japan Petroleum Energy Center). (2010a). Carcinogenicity test of 2-Ethoxy-2-methylpropane in rats (Drinking water study). (Study No: 0691). Japan Industrial Safety and Health Association, Japan Bioassay Research Center.
JPEC (Japan Petroleum Energy Center). (2010b). Carcinogenicity test of 2-Ethoxy-2-methylpropane in rats (Inhalation study). (Study No: 0686). Japan: Japan Industrial Safety and Health Association.
Kakehashi, A; Hagiwara, A; Imai, N; Nagano, K; Nishimaki, F; Banton, M, . (2013). Mode of action of ethyl tertiary-butyl ether hepatotumorigenicity in the rat: evidence for a role of oxidative stress via activation of CAR, PXR and PPAR signaling pathways. Toxicology and Applied Pharmacology 273: 390–400. 10.1016/j.taap.2013.09.016 24090815
Kakehashi, A; Hagiwara, A; Imai, N; Wei, M; Fukushima, S; Wanibuchi, H. (2015). Induction of cell proliferation in the rat liver by the short-term administration of ethyl tertiary-butyl ether. Journal of Toxicologic Pathology 28: 27–32. 10.1293/tox.2014-0056 26023258
Kaneko, T; Wang, PY; Sato, A. (2000). Partition coefficients for gasoline additives and their metabolites. Journal of Occupational Health 42: 86–87. 10.1539/joh.42.86
Kanerva, RL; Ridder, GM; Stone, LC; Alden, CL. (1987). Characterization of spontaneous and decalin-induced hyaline droplets in kidneys of adult male rats. Food and Chemical Toxicology 25: 63–82.2434396
Klaunig, JE; Babich, MA; Baetcke, KP; Cook, JC; Corton, JC; David, RM, . (2003). PPARalpha agonist-induced rodent tumors: modes of action and human relevance [Review]. Critical Reviews in Toxicology 33: 655–780. 10.1080/713608372 14727734
Leavens, TL; Borghoff, SJ. (2009). Physiologically based pharmacokinetic model of methyl tertiary butyl ether and tertiary butyl alcohol dosimetry in male rats based on binding to alpha2u-globulin. Toxicological Sciences 109: 321–335. 10.1093/toxsci/kfp049 19270017
Li, Q; Kobayashi, M; Inagaki, H; Hirata, Y; Hirata, K; Shimizu, T, . (2011). Effects of subchronic inhalation exposure to ethyl tertiary butyl ether on splenocytes in mice. International Journal of Immunopathology and Pharmacology 24: 837–847. 10.1177/039463201102400403 22230391
Liau, SS; Qureshi, MS; Praseedom, R; Huguet, E. (2013). Molecular pathogenesis of hepatic adenomas and its implications for surgical management [Review]. 17: 1869–1882. 10.1007/s11605-013-2274-6
Lusco, MA; Fogo, AB; Najafian, B; Alpers, CE. (2016). AJKD Atlas of Renal Pathology: Tubular Atrophy. American Journal of Kidney Diseases 67: e33–e34. 10.1053/j.ajkd.2016.04.007 27211375
Malarkey, DE; Bucher, JR. (2011). Summary report of the National Toxicology Program and Environmental Protection Agency-sponsored review of pathology materials from selected Ramazzini Institute rodent cancer bioassays [NTP]. Research Triangle Park: National Toxicology Program. http://ntp.niehs.nih.gov/ntp/about_ntp/partnerships/international/summarypwg_report_ri_bioassays.pdf
Maltoni, C; Belpoggi, F; Soffritti, M; Minardi, F. (1999). Comprehensive long-term experimental project of carcinogenicity bioassays on gasoline oxygenated additives: plan and first report of results from the study on ethyl-tertiary-butyl ether (ETBE). European Journal of Oncology 4: 493–508.
Maryland Department of the Environment. (2016). Oil Control Program Remediation Sites. Available online at http://www.mde.state.md.us/programs/Land/OilControl/RemediationSites/Pages/Programs/LandPrograms/Oil_Control/RemediationSites/index.aspx
McConnell, EE; Solleveld, HA; Swenberg, JA; Boorman, GA. (1986). Guidelines for combining neoplasms for evaluation of rodent carcinogenesis studies. Journal of the National Cancer Institute 76: 283–289. 10.1093/jnci/76.2.283 3456066
Mcgregor, D. (2007). Ethyl tertiary-butyl ether: a toxicological review [Review]. Critical Reviews in Toxicology 37: 287–312. 10.1080/10408440601177723 17453936
Medinsky, MA; Wolf, DC; Cattley, RC; Wong, B; Janszen, DB; Farris, GM, . (1999). Effects of a thirteen-week inhalation exposure to ethyl tertiary butyl ether on Fischer-344 rats and CD-1 mice. Toxicological Sciences 51: 108–118. 10.1093/toxsci/51.1.108 10496682
Melnick, R; Burns, K; Ward, J; Huff, J. (2012). Chemically exacerbated chronic progressive nephropathy not associated with renal tubule tumor induction in rats: An evaluation based on 60 carcinogenicity studies by the National Toxicology Program. Toxicological Sciences 128: 346–356. 10.1093/toxsci/kfs156 22539614
Miyata, K; Koga, T; Aso, S; Hoshuyama, S; Ajimi, S; Furukawa, K. (2013). A subchronic (180-day) oral toxicity study of ethyl tertiary-butyl ether, a bioethanol, in rats. Drug and Chemical Toxicology. 10.3109/01480545.2013.851690
NEIWPCC (New England Interstate Water Pollution Control Commission). (2003). Summary Report on a Survey of State Experiences with MtBE and Other Oxygenate Contamination at LUST Sites. Lowell, Massachusetts: NEIWPCC. http://www.neiwpcc.org/neiwpcc_docs/2003mtbesum.pdf
NIEHS (National Institute of Environmental Health Sciences). (2019). NTP pathology consult for ETBE and tBA. Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health.
Nihlén, A; Johanson, G. (1999). Physiologically based toxicokinetic modeling of inhaled ethyl tertiary-butyl ether in humans. Toxicological Sciences 51: 184–194. 10.1093/toxsci/51.2.184 10543020
Nihlén, A; Löf, A; Johanson, G. (1995). Liquid/air partition coefficients of methyl and ethyl t-butyl ethers, t-amyl methyl ether, and t-butyl alcohol. Journal of Exposure Analysis and Environmental Epidemiology 5: 573–582.8938250
Nihlén, A; Löf, A; Johanson, G. (1998a). Controlled ethyl tert-butyl ether (ETBE) exposure of male volunteers: I Toxicokenetics. Toxicological Sciences 46: 1–10. 10.1006/toxs.1998.2516 9928663
Nihlén, A; Löf, A; Johanson, G. (1998b). Controlled ethyl tert-butyl ether (ETBE) exposure of male volunteers: II. Acute effects. Toxicological Sciences 46: 143–150. 10.1006/toxs.1998.2517 9928677
Nihlén, A; Löf, A; Johanson, G. (1998c). Experimental exposure to methyl tertiary-butyl ether: I Toxicokinetics in humans. Toxicology and Applied Pharmacology 148: 274–280. 10.1006/taap.1997.8333 9473535
NRC (National Research Council). (2011). Review of the Environmental Protection Agency’s draft IRIS assessment of formaldehyde (pp. 1–194). Washington, DC: The National Academies Press. 10.17226/13142
NSF International. (2003). t-Butanol: Oral Risk Assessment Document (CAS 75-65-0) (pp. 81). Ann Arbor, MI: National Science Foundation.
NTP (National Toxicology Program). (1995). Toxicology and carcinogenesis studies of t-butyl alcohol (CAS no 75-65-0) in F344/N rats and B6C3F1 mice (Drinking water studies). (NTPTR436). Research Triangle Park, NC: U.S. Department of Health, Public Health Service, National Institutes of Health. https://ntp.niehs.nih.gov/ntp/htdocs/lt_rpts/tr436.pdf
NTP (National Toxicology Program). (1997). NTP technical report on toxicity studies of t-butyl alcohol (CAS no 75-65-0) administered by inhalation to F344/N rats and B6C3F1 mice. (NIH Pub 97-3942). Research Triangle Park, NC: U.S. Department of Health, Public Health Service, National Institutes of Health. http://ntp.niehs.nih.gov/ntp/htdocs/ST_rpts/tox053.pdf
NTP (National Toxicology Program). (2011). NTP historical controls report: All routes and vehicles: F 344/N rats. Washington, DC. http://ntp.niehs.nih.gov/ntp/historical_controls/ntp2000_2010/2010-03-22-hist-ratsallroutes.pdf
NTP (National Toxicology Program). (2015). Handbook for conducting a literature-based health assessment using OHAT approach for systematic review and evidence integration. U.S. Dept. of Health and Human Services, National Toxicology Program. https://ntp.niehs.nih.gov/ntp/ohat/pubs/handbookjan2015_508.pdf
OECD (Organisation for Economic Co-operation and Development). (2001). Test no. 414: Prenatal development toxicity study: 2001 version. In OECD guidelines for the testing of chemicals, Section 4: Health effects. Paris, France.
Peter, CP; Burek, JD; van Zwieten, MJ. (1986). Spontaneous nephropathies in rats. Toxicologic Pathology 14: 91–100.3715332
Peterson, RO; Sesterhenn, IA; Davis, CJ. (2009). Urologic pathology. In RO Peterson; IA Sesterhenn; CJ Davis (Eds.), Renal Pelvis and ureter (3rd ed., pp. 133174). Philadelphia, PA: Lippincott Williams and Wilkins.
Poet, TS; Valentine, JL; Borghoff, SJ. (1997). Pharmacokinetics of tertiary butyl alcohol in male and female Fischer 344 rats. Toxicology Letters 92: 179–186. 10.1016/S0378-4274(97)00056-8 9334828
Saito, A; Sasaki, T; Kasai, T; Katagiri, T; Nishizawa, T; Noguchi, T, . (2013). Hepatotumorigenicity of ethyl tertiary-butyl ether with 2-year inhalation exposure in F344 rats. Archives of Toxicology 87: 905–914. 10.1007/s00204-012-0997-x 23389738
Salazar, KD; Brinkerhoff, CJ; Lee, JS; Chiu, WA. (2015). Development and application of a rat PBPK model to elucidate kidney and liver effects induced by ETBE and tert-butanol. Toxicology and Applied Pharmacology 288: 439–452. 10.1016/j.taap.2015.08.015 26341290
Satirapoj, B; Nast, CC; Adler, SG. (2012). Novel insights into the relationship between glomerular pathology and progressive kidney disease [Review]. Advances in Chronic Kidney Disease 19: 93–100. 10.1053/j.ackd.2011.12.001 22449346
Seely, JC; Brix, A. (2014a). Kidney nephropathy, chronic progressive. In National Toxicology Program Nonneoplastic Lesion Atlas. Research Triangle Park, NC: National Toxicology Program. https://ntp.niehs.nih.gov/nnl/urinary/kidney/necp/index.htm
Seely, JC; Brix, A. (2014b). Kidney, urothelium hyperplasia. Available online at https://ntp.niehs.nih.gov/nnl/urinary/kidney/urhyp/index.htm
Setshedi, M; Wands, JR; de la Monte, SM. (2010). Acetaldehyde adducts in alcoholic liver disease [Review]. Oxidative Medicine and Cellular Longevity 3: 178–185. 10.4161/oxim.3.3.12288 20716942
Short, BG; Burnett, VL; Swenberg, JA. (1986). Histopathology and cell proliferation induced by 2,2,4-trimethylpentane in the male rat kidney. Toxicologic Pathology 14: 194–203. 10.1177/019262338601400208 3764317
Smith, MT; Guyton, KZ; Gibbons, CF; Fritz, JM; Portier, CJ; Rusyn, I, . (2016). Key characteristics of carcinogens as a basis for organizing data on mechanisms of carcinogenesis [Review]. Environmental Health Perspectives 124: 713–721. 10.1289/ehp.1509912 26600562
Suzuki, M; Yamazaki, K; Kano, H; Aiso, S; Nagano, K; Fukushima, S. (2012). No carcinogenicity of ethyl tertiary-butyl ether by 2-year oral administration in rats. Journal of Toxicological Sciences 37: 1239–1246.23208438
Swenberg, JA; Lehman-McKeeman, LD. (1999). Alpha 2-urinary globulin-associated nephropathy as a mechanism of renal tubule cell carcinogenesis in male rats. In CC Capen; E Dybing; JM Rice; JD Wilbourn (Eds.), Species Differences in Thyroid, Kidney, and Urinary Bladder Carcinogenesis (pp. 95–118). Lyon, France: International Agency for Research on Cancer. http://apps.who.int/bookorders/anglais/detart1.jsp?sesslan=1&codlan=1&codcol=73&codcch=147
Tiesjema, B; Baars, AJ. (2009). Re-evaluation of some human-toxicological Maximum Permissible Risk levels earlier evaluated in the period 1991-2001. (RIVM Report 711701092). Bilthoven, the Netherlands: National Institute for Public Health and the Environment (Netherlands). http://www.rivm.nl/bibliotheek/rapporten/711701092.pdf
Travlos, GS; Hard, GC; Betz, LJ; Kissling, GE. (2011). Chronic progressive nephropathy in male F344 rats in 90-day toxicity studies: its occurrence and association with renal tubule tumors in subsequent 2-year bioassays. Toxicologic Pathology 39: 381–389. 10.1177/0192623310388432 21422264
U.S. EPA (U.S. Environmental Protection Agency). (1988). Recommendations for and documentation of biological values for use in risk assessment [EPA Report] (pp. 1–395). (EPA/600/6-87/008). Cincinnati, OH: U.S. Environmental Protection Agency, Office of Research and Development, Office of Health and Environmental Assessment. http://cfpub.epa.gov/ncea/cfm/recordisplay.cfm?deid=34855
U.S. EPA (U.S. Environmental Protection Agency). (1991a). Alpha-2u-globulin: Association with chemically induced renal toxicity and neoplasia in the male rat (pp. 1–136). (EPA/625/3-91/019F). Washington, DC: U.S. Environmental Protection Agency, National Center for Environmental Assessment. https://ntrl.ntis.gov/NTRL/dashboard/searchResults.xhtml?searchQuery=PB92143668
U.S. EPA (U.S. Environmental Protection Agency). (1991b). Guidelines for developmental toxicity risk assessment (pp. 1–71). (EPA/600/FR-91/001). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. http://cfpub.epa.gov/ncea/cfm/recordisplay.cfm?deid=23162
U.S. EPA (U.S. Environmental Protection Agency). (1994). Methods for derivation of inhalation reference concentrations and application of inhalation dosimetry [EPA Report] (pp. 1–409). (EPA/600/8-90/066F). Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Research and Development, Office of Health and Environmental Assessment, Environmental Criteria and Assessment Office. https://cfpub.epa.gov/ncea/risk/recordisplay.cfm?deid=71993&CFID=51174829&CFTOKEN=25006317
U.S. EPA (U.S. Environmental Protection Agency). (1996). Guidelines for reproductive toxicity risk assessment (pp. 1–143). (EPA/630/R-96/009). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. https://www.epa.gov/sites/production/files/2014-11/documents/guidelines_repro_toxicity.pdf
U.S. EPA (U.S. Environmental Protection Agency). (1997). Support: Ethyl tertiary butyl ether (ETBE): Ninety-day vapor inhalation toxicity study with neurotoxicity evaluations in Fischer 344 rats [TSCA Submission] (pp. 1–90). (89970000047). Newtown Square, PA: ARCO Chemical Company. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS05585301.xhtml
U.S. EPA (U.S. Environmental Protection Agency). (1998a). Guidelines for neurotoxicity risk assessment [EPA Report] (pp. 1–89). (EPA/630/R-95/001F). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. http://www.epa.gov/risk/guidelines-neurotoxicity-risk-assessment
U.S. EPA (U.S. Environmental Protection Agency). (1998b). Health effects test guidelines OPPTS 870.3700 prenatal developmental toxicity study [EPA Report]. (EPA 712C98207). Washington, DC.
U.S. EPA (U.S. Environmental Protection Agency). (2000). Science policy council handbook: Risk characterization handbook [EPA Report]. (EPA/100/B-00/002). Washington, D.C.: U.S. Environmental Protection Agency, Science Policy Council. https://www.epa.gov/risk/risk-characterization-handbook
U.S. EPA (U.S. Environmental Protection Agency). (2002). A review of the reference dose and reference concentration processes (pp. 1–192). (EPA/630/P-02/002F). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. http://www.epa.gov/osa/review-reference-dose-and-reference-concentration-processes
U.S. EPA (U.S. Environmental Protection Agency). (2005a). Guidelines for carcinogen risk assessment [EPA Report]. (EPA/630/P-03/001B). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. https://www.epa.gov/sites/production/files/2013-09/documents/cancer_guidelines_final_3-25-05.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2005b). Supplemental guidance for assessing susceptibility from early-life exposure to carcinogens (pp. 1–125). (EPA/630/R-03/003F). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum.
U.S. EPA (U.S. Environmental Protection Agency). (2006). Approaches for the application of physiologically based pharmacokinetic (PBPK) models and supporting data in risk assessment (Final Report) [EPA Report] (pp. 1–123). (EPA/600/R-05/043F). Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development, National Center for Environmental Assessment. http://cfpub.epa.gov/ncea/cfm/recordisplay.cfm?deid=157668
U.S. EPA (U.S. Environmental Protection Agency). (2011). Recommended use of body weight 3/4 as the default method in derivation of the oral reference dose (pp. 1–50). (EPA/100/R-11/0001). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum, Office of the Science Advisor. https://www.epa.gov/sites/production/files/2013-09/documents/recommended-use-of-bw34.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2012). Benchmark dose technical guidance (pp. 1–99). (EPA/100/R-12/001). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum.
U.S. EPA (U.S. Environmental Protection Agency). (2014). Guidance for applying quantitative data to develop data-derived extrapolation factors for interspecies and intraspecies extrapolation. (EPA/100/R-14/002F). Washington, DC: Risk Assessment Forum, Office of the Science Advisor. http://www.epa.gov/raf/DDEF/pdf/ddef-final.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2017). PK/PBPK model evaluation for the IRIS assessments of ethyl tertiary butyl ether (CASRN 637-92-3) and tert-butyl alcohol (CAS No. 75-65-0) (Draft) [EPA Report]. Washington, DC: U.S. Environmental Protection Agency, Pharmacokinetics Working Group.
USDA (U.S. Department of Agriculture). (2012). Japan focuses on next generation biofuels. Tokyo, Japan: Global Agricultural Information Network, USDA Foreign Agricultural Service. Prepared by Midori Iijima. http://gain.fas.usda.gov/Recent%20GAIN%20Publications/Biofuels%20Annual_Tokyo_Japan_7-2-2012.pdf
USGS (U.S. Geological Survey). (2006). Volatile Organic Compounds in the Nation’s Ground Water and Drinking-Water Supply Wells: Supporting Information. Available online at http://water.usgs.gov/nawqa/vocs/national_assessment/index.html
Venkata, NG; Aung, CS; Cabot, PJ; Monteith, GR; Roberts-Thomson, SJ. (2008). PPARalpha and PPARbeta are differentially affected by ethanol and the ethanol metabolite acetaldehyde in the MCF-7 breast cancer cell line. Toxicological Sciences 102: 120–128. 10.1093/toxsci/kfm281 18003597
Vetrano, KM. (1993). Final report to ARCO Chemical Company on the odor and taste threshold studies performed with methyl tertiary-butyl ether (MTBE) and ethyl tertiary-butyl ether (ETBE). Vetrano, KM.
Wang, RS; Ohtani, K; Weng, ZQ; Yanagiba, Y; Suda, M. (2012). Enhanced reproductive effects of exposure to ETBE in Aldh2 knockout mice [Abstract]. Toxicology Letters 211: S183. 10.1016/j.toxlet.2012.03.661
Weaver, LW; Exum, LR; Prieto, LM. (2010). Gasoline Composition Regulations Affecting LUST Sites. GRA and I: 39.
Webb, DR; Kanerva, RL; Hysell, DK; Alden, CL; Lehman-Mckeeman, LD. (1990). Assessment of the subchronic oral toxicity of d-limonene in dogs. Food and Chemical Toxicology 28: 669–675. 10.1016/0278-6915(90)90142-A 2276695
Weng, Z; Ohtani, K; Suda, M; Yanagiba, Y; Kawamoto, T; Nakajima, T, . (2014). Assessment of the reproductive toxicity of inhalation exposure to ethyl tertiary butyl ether in male mice with normal, low active and inactive ALDH2. Archives of Toxicology 88: 1007–1021. 10.1007/s00204-014-1192-z 24448831
Weng, Z; Shi, Y; Suda, M; Yanagiba, Y; Kawamoto, T; Nakajima, T, . (2019). Inhalation exposure to low levels of ethyl tertiary butyl ether: Its genetic effects were significantly modified by ALDH2 activity. Environmental and Molecular Mutagenesis 60: 145–153. 10.1002/em.22256 30474146
Weng, Z; Suda, M; Ohtani, K; Mei, N, an; Kawamoto, T; Nakajima, T, . (2013). Subchronic exposure to ethyl tertiary butyl ether resulting in genetic damage in Aldh2 knockout mice. Toxicology 311: 107–114. 10.1016/j.tox.2013.06.005 23810710
Weng, Z; Suda, M; Ohtani, K; Mei, N; Kawamoto, T; Nakajima, T, . (2012). Differential genotoxic effects of subchronic exposure to ethyl tertiary butyl ether in the livers of Aldh2 knockout and wild-type mice. Archives of Toxicology 86: 675–682. 10.1007/s00204-011-0779-x 22102104
Weng, ZQ; Suda, M; Ohtani, K; Mei, N; Kawamoto, T; Nakajima, T, . (2011). Aldh2 Knockout Mice Were More Sensitive to DNA Damage in Leukocytes due to Ethyl Tertiary Butyl Ether Exposure. Industrial Health 49: 396–399. 10.2486/indhealth.MS1188 21372431
White, RD; Daughtrey, WC; Wells, MS. (1995). Health effects of inhaled tertiary amyl methyl ether and ethyl tertiary butyl ether. Toxicology Letters 82/83: 719–724. 10.1016/0378-4274(95)03590-7 8597132
Williams, TM; Borghoff, SJ. (2001). Characterization of tert-butyl alcohol binding to “alpha”2u-globulin in F-344 rats. Toxicological Sciences 62: 228–235. 10.1093/toxsci/62.2.228 11452135
Zoja, C; Abbate, M; Remuzzi, G. (2015). Progression of renal injury toward interstitial inflammation and glomerular sclerosis is dependent on abnormal protein filtration [Review]. Nephrology, Dialysis, Transplantation 30: 706–712. 10.1093/ndt/gfu261