# PREFACE

This Toxicological Review critically reviews the publicly available studies on ethyl tertiary butyl ether (ETBE) to identify its adverse health effects and to characterize exposure-response relationships. The assessment examined all effects by oral and inhalation routes of exposure and includes a noncancer oral reference dose (RfD), a noncancer inhalation reference concentration (RfC), a cancer weight-of-evidence descriptor, and a cancer dose-response assessment. It was prepared under the auspices of the U.S. Environmental Protection Agency’s (EPA’s) Integrated Risk Information System (IRIS) program.

ETBE was named in the Energy Policy Act of 2005 (Section 1505). This law directs the Administrator to conduct an assessment of ETBE along with other alkylates, ethers, and heavy alcohols. ETBE was nominated for IRIS assessment by the Office of Transportation and Air Quality (OTAQ) within the Office of Air and Radiation (OAR). Assessment of ETBE is also relevant to the Office of Land and Emergency Management/Office of Underground Storage Tanks (OLEM/OUST) and the Office of Water (OW) due to concerns over groundwater contamination from leaking storage containers.

This assessment updates a previous IRIS draft assessment of ETBE that went to peer review in 2010. The previous draft assessment was suspended pending completion of several new studies that were identified during the peer review and are now included in this document.

The Toxicological Reviews for ETBE and tert-butyl alcohol (tert-butanol) were developed simultaneously because they have overlapping scientific aspects:

- tert-butanol and acetaldehyde are the primary metabolites of ETBE, and some of the toxicological effects of ETBE are likely attributed to tert-butanol. Therefore, data on tert-butanol are considered informative for the hazard identification and dose-response assessment of ETBE, and vice versa.
- The scientific literature for the two chemicals includes data on alpha 2u-globulin-related nephropathy; therefore, a common approach was used to evaluate the data as they relate to the mode of action for kidney effects.
- A combined physiologically based pharmacokinetic (PBPK) model for ETBE and tert-butanol in rats was applied to support the dose-response assessments for these chemicals (Borghoff et al., 2016).

Before developing the IRIS assessment, EPA held a public meeting in December 2013 to obtain input on preliminary materials for ETBE, including draft literature searches and associated search strategies, evidence tables, and exposure-response arrays. In June 2016, EPA convened a public science meeting to discuss the public comment draft Toxicological Review of tert-Butyl Alcohol (tert-Butanol) during which time the Agency heard comments on “disentangling mechanisms of kidney toxicity and carcinogenicity,” an issue relevant to both tert-butanol and ETBE. The complete set of public comments, including the slides presented at the June 2016 public science meeting, is available on the docket at http://www.regulations.gov (Docket ID No. EPA-HQ-ORD-2013-1111 (https://www.regulations.gov/docket?D=EPA-HQ-ORD-2013-0111)). In October 2016, a public science meeting was held to give the public an opportunity to engage in early discussions on the draft IRIS Toxicological Review of ETBE and the draft charge to the peer-review panel prior to release for external peer review. The complete set of public comments, including the slides, is available on the docket at http://www.regulations.gov (Docket ID No. EPA-HQ-ORD-2009-0229 (https://www.regulations.gov/docket?D=EPA-HQ-ORD-2009-0229)).

Organ/system-specific reference values are calculated where feasible (in this case for kidney toxicity only). These reference values could be useful for cumulative risk assessments that consider the combined effect of multiple agents acting on the same biological system.

This assessment was conducted in accordance with EPA guidance, which is cited and summarized in the Preamble to IRIS Toxicological Reviews. Appendices for toxicokinetic information, PBPK modeling, genotoxicity study summaries, dose-response modeling, and other information are provided as Supplemental Information to this Toxicological Review. For additional information about this assessment or for general questions regarding IRIS, please contact EPA’s IRIS Hotline at 202-566-1676 (phone), 202-566-1749 (fax), or hotline.iris@epa.gov.

## Uses

ETBE has been used as a fuel oxygenate in the United States to improve combustion efficiency and reduce pollutants in exhaust. From about 1990 to 2006, ETBE was periodically added to gasoline at levels up to approximately 20%, but methyl tert-butyl ether (MTBE) and other oxygenates were more commonly used. In 2006, use of ETBE and other ether fuel additives ceased in the United States, and the use of ethanol as an additive increased dramatically (Weaver et al., 2010). ETBE is still registered with EPA for use as a fuel additive, but it is not used currently in the United States. Several states have banned or limited the use of ether fuel additives, largely in response to groundwater contamination concerns.

The United States is a major exporter of ETBE, producing 25% of the world’s ETBE in 2012. Worldwide consumption of ETBE is concentrated in Western Europe (~70%). Use in Eastern Europe and Japan also is relatively high. Japan’s use increased dramatically in 2010 to fulfill its 2010 Kyoto Accord obligations (USDA, 2012).

## Fate and Transport

ETBE is expected to be highly mobile in soil due to its high carbon-water partitioning coefficient (HSDB, 2012 (https://hero.epa.gov/hero/index.cfm?action=search.view&reference_id=3230466)). ETBE is not predicted to adsorb onto suspended particles and is unlikely to undergo anaerobic biodegradation in water (HSDB, 2012 (https://hero.epa.gov/hero/index.cfm?action=search.view&reference_id=3230466)). ETBE is estimated to have a half-life of 2 days in air (HSDB, 2012 (https://hero.epa.gov/hero/index.cfm?action=search.view&reference_id=3230466)).

## Occurrence in the Environment

ETBE can be released to the environment by gasoline leaks, evaporation, spills, and other releases. ETBE degrades slowly in the environment and can move with the water percolating through soils. Monitoring studies targeting groundwater near areas where petroleum contamination likely occurred detected ETBE. For instance, a survey of states reported an average detection rate of 18% for ETBE in groundwater samples associated with gasoline contamination (NEIWPCC, 2003). Nontargeted studies, such as a 2006 U.S. Geological Survey (USGS) study (USGS, 2006) measuring volatile organic compounds (VOCs) in general, show lower detection rates of ETBE. The 2006 USGS study showed detections of ETBE above 0.2 μg/L in five samples from two public drinking water wells, corresponding to a 0.0013 rate of detection. The USGS study, which measured several VOCs, did not focus on sites that would be most vulnerable to ETBE contamination.

Fuel contamination cleanup is done largely by states, and information on the number of private contaminated drinking water wells is not consistently available. California maintains an online database of measurements from contaminated sites (CalEPA, 2016). From 2010 to 2013, ETBE has been detected in California at 607 and 73 sites in groundwater and air, respectively. Most of the contamination is attributed to leaking underground storage tanks, and some contamination is associated with refineries and petroleum transportation. The contamination was noted in approximately 48 counties, with higher-population counties (e.g., Los Angeles and Orange) having more contaminated sites.

The occurrence of ETBE in other states was found using fewer and less standardized data. Currently, only 13 states routinely analyze for ETBE at fuel-contaminated sites (NEIWPCC, 2003). Monitoring data associated with leaking storage tanks in Maryland show contamination in groundwater affecting multiple properties (Maryland Department of the Environment, 2016).

## General Population Exposure

ETBE exposure can occur in many different settings. Releases from underground storage tanks could result in exposure to individuals who obtain their drinking water from wells. Due to its environmental mobility and resistance to biodegradation, ETBE has the potential to contaminate and persist in groundwater and soil (HSDB, 2012 (https://hero.epa.gov/hero/index.cfm?action=search.view&reference_id=3230466)); therefore, exposure through ingestion of contaminated drinking water is possible.

Other human exposure pathways of ETBE include inhalation and, to a lesser extent, dermal contact. ETBE inhalation exposure can occur owing to the chemical’s volatility and release from industrial processes and contaminated sites (HSDB, 2012 (https://hero.epa.gov/hero/index.cfm?action=search.view&reference_id=3230466)).

## Assessments by Other National and International Health Agencies

Toxicity information on ETBE has been evaluated by the National Institute for Public Health and the Environment [Bilthoven, The Netherlands; Tiesjema and Baars (2009)]. The results of this assessment are presented in Appendix A of the Supplemental Information to this Toxicological Review. Of importance to recognize is that earlier assessments were prepared for different purposes and used different methods. In addition, more recent studies are included and evaluated in this IRIS assessment.