# LITERATURE SEARCH STRATEGY | STUDY SELECTION AND EVALUATION

A literature search and screening strategy consisted of a broad search of online scientific databases and other sources to identify all potentially pertinent studies. In subsequent steps, references were screened to exclude papers not pertinent to an assessment of the health effects of ethyl tertiary butyl ether (ETBE), and remaining references were sorted into categories for further evaluation. The original chemical-specific search was conducted in four online scientific databases, PubMed, Toxline, Web of Science, and Toxic Substances Control Act Test Submissions (TSCATS), through December 2016, using the keywords and limits described in Table LS-1. The overall literature search approach is shown graphically in Figure LS-1. Another 114 citations were obtained using additional search strategies described in Table LS-2. After electronically eliminating duplicates from the citations retrieved through these databases, 847 unique citations were identified. The resulting 847 citations were screened for pertinence and separated into categories as presented in Figure LS-1 using the title and either abstract or full text, or both, to examine the health effects of ETBE exposure. The inclusion and exclusion criteria used to screen the references and identify sources of health effects data are provided in Table LS-3.

- 33 references were identified as potential “Sources of Health Effects Data” and were considered for data extraction to evidence tables and exposure-response arrays.
- 70 references were identified as “Supporting Studies.” These included 31 studies describing physiologically based pharmacokinetic (PBPK) models and other toxicokinetic information; 25 studies providing genotoxicity and other mechanistic information; 9 acute, short-term, or preliminary toxicity studies; and 5 direct administration (e.g., dermal) studies of ETBE. Although still considered sources of health effects information, studies investigating the effects of acute and direct chemical exposures are generally less pertinent for characterizing health hazards associated with chronic oral and inhalation exposures. Therefore, information from these studies was not considered for extraction into evidence tables. Nevertheless, these studies were still evaluated as possible sources of supplementary health effects information.
- 29 references were identified as “Secondary Literature and Sources of Contextual Information” (e.g., reviews and other agency assessments); these references were retained as additional resources for development of the Toxicological Review.
- 715 references were identified as being not pertinent (not on topic) for evaluating health effects for ETBE and were excluded from further consideration (see Figure LS-1 for exclusion categories and Table LS-3 for exclusion criteria). For example, health-effect studies of gasoline and ETBE mixtures were not considered pertinent to the assessment because the separate effects of gasoline components could not be determined. Retrieving numerous references that are not on topic is a consequence of applying an initial search strategy designed to cast a wide net and to minimize the possibility of missing potentially relevant health effects data.

The complete list of references as sorted above can be found on the ETBE project page of the Health and Environmental Research Online (HERO) website at https://hero.epa.gov/hero/index.cfm/project/page/project_id/1376.

## LS.1 POSTPEER-REVIEW LITERATURE SEARCH UPDATE

A post-peer-review literature search update was conducted in PubMed, Toxline, TSCATS, and Defense Technical Information Center (DTIC) for the period December 2016 to July 2019 using a search strategy consistent with previous literature searches (see Table LS-1). The documentation and results for the literature search and screen, including the specific references identified using each search strategy and tags assigned to each reference based on the manual screen, can be found on the HERO website on the ETBE project page at: (https://hero.epa.gov/hero/index.cfm/project/page/project_id/1376).

Consistent with the Integrated Risk Information System (IRIS) Stopping Rules (https://www.epa.gov/sites/production/files/2014-06/documents/iris_stoppingrules.pdf), manual screening of the literature search update focused on identifying new studies that might change a major conclusion of the assessment. The last formal literature search was in 2019 while the draft was in external peer review, after which the literature was monitored in PubMed through January 2021. No animal bioassays or epidemiological studies were identified in the post-peer-review literature searches that would change any major conclusions in the assessment.

## LS.2 SELECTION OF STUDIES FOR INCLUSION IN EVIDENCE TABLES

To summarize the important information systematically from the primary health effects studies in the ETBE evidence base, evidence tables were constructed in a standardized tabular format as recommended by NRC (2011). Studies were arranged in evidence tables by route of exposure and then alphabetized by author. Of the studies retained after the literature search and screen, 33 were identified as “Sources of Health Effects Data” and considered for extraction into evidence tables for the hazard identification in Section 1. An initial review of studies examining neurotoxic endpoints did not find consistent effects to warrant a comprehensive hazard evaluation; thus, the one subchronic study (Dorman et al., 1997) that examined only neurotoxic endpoints (functional observational battery, motor activity, and terminal neuropathology) was not included in evidence tables. Data from the remaining 32 studies were extracted into evidence tables.

Supplementary studies that contain pertinent information for the Toxicological Review and augment hazard identification conclusions, such as genotoxic and mechanistic studies, studies describing the kinetics and disposition of ETBE absorption and metabolism, and pilot studies, were not included in the evidence tables. One controlled human exposure toxicokinetic study was identified, which is discussed in Appendix Section B.2 (Toxicokinetics). Short-term and acute studies did not differ qualitatively from the results of the longer term studies (i.e., ≥90-day exposure studies). These were grouped as supplementary studies, however, because the evidence base of chronic and subchronic rodent studies was considered sufficient for evaluating chronic health effects of ETBE exposure. Additionally, studies of effects from chronic exposure are most pertinent to lifetime human exposure (i.e., the primary characterization provided by IRIS assessments) and are the focus of this assessment. Such supplementary studies can be discussed in the narrative sections of Section 1 and are described, for example, in sections such as “Mode-of-Action Analysis” to augment the discussion or are presented in appendices, if they provide additional information.

Figure LS-1 Summary of literature search and screening process for ETBE

ADME = absorption, distribution, metabolism, excretion; QSAR = quantitative structure-activity relationship.

Table LS-1 Details of the search strategy employed for ETBE

Database; (search date) | Keywords | Limits
PubMed; (03/31/2014); Updated (12/2016) | “ETBE” OR “Ethyl tert-butyl ether” OR “2-ethoxy-2-methyl-propane” OR “ethyl tertiary butyl ether” OR “ethyl tert-butyl oxide” OR “tert-butyl ethyl ether” OR “ethyl t-butyl ether” OR “637-92-3” | None
Web of Science; (03/31/2014); Updated (12/2016) | “ETBE” OR “ethyl tert-butyl ether” OR “2-ethoxy-2-methyl-propane” OR “ethyl tertiary butyl ether” OR “ethyl tert-butyl oxide” OR “tert-butyl ethyl ether” OR “ethyl t-butyl ether” OR “637-92-3” | Lemmatization only (e.g., the search term is reduced to its lexical root)
Toxline (includes TSCATS); (03/31/2014); Updated (12/2016) | “ETBE” OR “Ethyl tert-butyl ether” OR “2-Ethoxy-2-methyl-propane” OR “ethyl tertiary butyl ether” OR “ethyl tert-butyl oxide” OR “tert-butyl ethyl ether” OR “ethyl t-butyl ether” OR “637-92-3” | Not PubMed
TSCATS2; (3/31/2014); Updated (12/2016) | 637-92-3 | 01/2004 to 7/2019

Table LS-2 Summary of additional search strategies for ETBE

Approach used | Source(s) | Date performed | Number of additional references identified
Electronic backward search through Web of Science | Review article: Mcgregor (2007). “Ethyl tertiary-butyl ether: a toxicological review.” Critical Reviews in Toxicology 37(4): 287–312 17453936 17453936 | 3/2014 | 68 references
Electronic backward search through Web of Science | Review article: de Peyster (2010). “Ethyl t-butyl ether: Review of reproductive and developmental toxicity.” Birth Defects Research, Part B: Developmental and Reproductive Toxicology 89(3): 239–263 20544807 | 3/2014 | 26 references
Personal communication | Japan Petroleum Energy Center | 3/2014; Updated (12/2016) | 21 references

Table LS-3 Inclusion-exclusion criteria

| Inclusion criteria | Exclusion criteria/supplemental material^a^
Population | - Humans; - Standard mammalian animal models, including rat, mouse, rabbit, guinea pig, monkey, dog | - Ecological species; - Nonmammalian species
Exposure | - Exposure is to ETBE; - Exposure is measured in an environmental medium (e.g., air, water, diet); - Exposure via oral or inhalation routes; for supporting health effect studies, exposure via oral or inhalation routes | - Study population is not exposed to ETBE; - Exposure to a mixture only (e.g., gasoline containing ETBE); - Exposure via injection (e.g., intravenous); - Exposure paradigm not relevant (e.g., acute, dermal, or ocular)
Outcome | - Study includes a measure of one or more health effect endpoints, including effects on the nervous, kidney/urogenital, musculoskeletal, cardiovascular, immune, and gastrointestinal systems; reproduction; development; liver; eyes; and cancer | - Odor threshold studies
Other | | - Not on topic, including:; - Abstract only, editorial comments, policy papers, were not considered further because study was not potentially relevant; - Bioremediation, biodegradation, or environmental fate of ETBE, including evaluation of wastewater treatment technologies and methods for remediation of contaminated water and soil; - Chemical, physical, or fuel chemistry studies; - Analytical methods for measuring/detecting/remotely sensing ETBE; - Not chemical specific: studies that do not involve testing of ETBE; - Quantitative structure activity relationship studies; - Exposure studies without health effect evaluation

a Studies that met this exclusion criterion were considered supplemental (i.e., not considered a primary source of health effects data, but were retained as potential sources of contextual information).

## LS.3 EVIDENCE BASE EVALUATION

For this draft assessment, 33 experimental animal studies were the primary sources of health effects data; no studies were identified that evaluated humans exposed to ETBE (e.g., cohort studies, case reports, ecological studies). The animal studies were evaluated by considering aspects of design, conduct, or reporting that could affect the interpretation of results, overall contribution to the synthesis of evidence, and determination of hazard potential as noted in various EPA guidance documents (U.S. EPA, 2005a, 1998a, 1996, 1991b). The objective was to identify the stronger, more informative studies based on a uniform evaluation of quality characteristics across studies of similar design. Studies were evaluated to identify their suitability based on:

- Study design;
- Nature of the assay and validity for its intended purpose;
- Characterization of the nature and extent of impurities and contaminants of ETBE administered, if applicable;
- Characterization of dose and dosing regimen (including age at exposure) and their adequacy to elicit adverse effects, including latent effects;
- Sample sizes to detect dose-related differences or trends;
- Ascertainment of survival, vital signs, disease or effects, and cause of death; and
- Control of other variables that could influence the occurrence of effects.

Additionally, several general considerations, presented in Table LS-4, were used in evaluating the animal studies (see Table LS-5). Much of the key information for conducting this evaluation can be determined based on study methods and how the study results were reported. Importantly, the evaluation at this stage does not consider the direction or magnitude of any reported effects.

EPA considered statistical tests to evaluate whether the observations might be due to chance. The standard for determining statistical significance of a response is a trend test or comparison of outcomes in the exposed groups against those of concurrent controls. Studies that did not report statistical testing were identified, and when appropriate, statistical tests were conducted by EPA.

Information on study features related to this evaluation is reported in evidence tables and documented in the synthesis of evidence. Discussions of study strengths and limitations are included in the text where relevant. If EPA’s interpretation of a study differs from that of the study authors, the draft assessment discusses the basis for the difference.

### LS.3.1 Experimental Animal Studies

The 33 experimental animal studies, all of which were performed on rats, mice, and rabbits, were associated with drinking water, gavage, or inhalation exposures to ETBE. Many of these studies were conducted according to Organisation for Economic Co-operation and Development Good Laboratory Practice (GLP) guidelines and used well-established methods, were well reported, and evaluated an extensive range of endpoints and histopathological data. For the body of available studies, detailed discussion of any identified methodological concerns precedes each endpoint evaluated in the hazard identification section. Overall, the experimental animal studies of ETBE involving repeated oral or inhalation exposure were considered acceptable in quality, and whether yielding positive, negative, or null results, were considered in assessing the evidence for health effects associated with chronic exposure to ETBE.

Table LS-4 Considerations for evaluating experimental animal studies

Methodological feature | Considerations; (relevant information extracted into evidence tables)
Test animal | Suitability of species, strain, sex, and source of test animals
Experimental design | Suitability of animal age/lifestage at exposure and endpoint testing; periodicity and duration of exposure (e.g., h/d, d/wk); timing of endpoint evaluations; and sample size and experimental unit (e.g., animals, dams, litters)
Exposure | Characterization of test article source, composition, purity, and stability; suitability of control (e.g., vehicle control); documentation of exposure techniques (e.g., route, chamber type, gavage volume); verification of exposure levels (e.g., consideration of homogeneity, stability, analytical methods)
Endpoint evaluation | Suitability of specific methods for assessing endpoint(s) of interest
Results presentation | Data presentation for endpoint(s) of interest (including measures of variability) and for other relevant endpoints needed for results interpretation (e.g., maternal toxicity, decrements in body weight relative to organ weight)

Table LS-5 Summary of experimental animal evidence base

Study category | Study duration, species/strain, and administration method
Chronic | 2-yr study in F344 rats (drinking water) JPEC (2010a);^a^ Suzuki et al. (2012); 2-yr study in F344 rats (inhalation) JPEC (2010b);^a^ Saito et al. (2013); 2-yr study in S-D rats (gavage) Maltoni et al. (1999)
Subchronic | 13-wk study in F344 rats (inhalation) Medinsky et al. (1999); U.S. EPA (1997); 26-wk study in S-D rats (gavage) JPEC (2008c);^a^ Miyata et al. (2013) Fujii et al. (2010); JPEC (2008e); 13-wk study in S-D rats (inhalation) JPEC (2008b)^a^; 23-wk study in F344 rats (gavage) Hagiwara et al. (2011); JPEC (2008d); 13-wk study in CD-1 mice (inhalation) Medinsky et al. (1999); Bond et al. (1996); 23-wk study in Wistar rats (gavage) Hagiwara et al. (2015); 31-wk study in F344/DuCrlCrlj rats (drinking water) Hagiwara et al. (2013); 13-wk study in C57BL/6 mice (inhalation) Weng et al. (2012)
Reproductive | Two-generation reproductive toxicity study on S-D rats (gavage) Gaoua (2004b)^a^; One-generation reproductive toxicity study on S-D rats (gavage) Fujii et al. (2010); JPEC (2008e); 2-wk study on Simonsen albino rats (drinking water) Berger and Horner (2003); 9-wk study on C57BL/6 mice (inhalation) Weng et al. (2014); 14-d study on F344 rats (gavage) de Peyster et al. (2009); Two-generation reproductive toxicity study in S-D rats (gavage) Gaoua (2004b)^a^
Developmental | Developmental study (GD 6–27) on New Zealand White rabbits (gavage) Asano et al. (2011); JPEC (2008i); Developmental study (GD 5–19) on S-D rats (gavage) Aso et al. (2014); JPEC (2008h); Developmental study (GD 5–19) on S-D rats (gavage) Gaoua (2004b)^a^; Developmental study (GD 5–19) on S-D rats (gavage) Gaoua (2004a)^a^
Pharmacokinetic | Single-dose study on S-D rats (gavage) JPEC (2008g); 14-d study on S-D rats (gavage) JPEC (2008f); Single-dose study on S-D rats (gavage) JPEC (2008g)^a^; 14-d study on S-D rats (gavage) JPEC (2008f)^a^

GD = gestation day; S-D = Sprague-Dawley.

a The IRIS program had this study peer reviewed.