# AUTHORS | CONTRIBUTORS | REVIEWERS

Assessment Team
Kathleen Newhouse, M.S. (Chemical Manager); Andre Weaver, Ph.D. (Co-Chemical Manager); Janice Lee, Ph.D. | U.S. EPA; Office of Research and Development; Center for Public Health and Environmental Assessment
Keith Salazar, Ph.D. | Former Chemical Manager; EPA/ORD/NCEA; Currently with U.S. EPA, Office of Chemical Safety and Pollution Prevention, Office of Pollution Prevention and Toxics
Christopher Brinkerhoff, Ph.D. | Former ORISE Postdoctoral Fellow at U.S. EPA/ORD/NCEA Currently with U.S. EPA, Office of the Administrator, Office of Children’s Health Protection
Contributors
Brandy Beverly, Ph.D.; Christine Cai, M.S.; Jeff Gift, Ph.D.; Karen Hogan, M.S.; Andrew Hotchkiss, Ph.D.; Channa Keshava, Ph.D.; Susan Makris, Ph.D.; Alan Sasso, Ph.D.; Paul Schlosser, Ph.D.; Erin Yost, Ph.D. | U.S. EPA; Office of Research and Development; Center for Public Health and Environmental Assessment
Vincent Cogliano, Ph.D.; Jason Fritz, Ph.D. | (previously with) U.S. EPA National Center for Environmental Assessment
Charles Wood, Ph.D. | (previously with) U.S. EPA National Health and Environmental Effects Research Lab
Production Team
Maureen Johnson; Dahnish Shams; Vicki Soto | U.S. EPA; Office of Research and Development; Center for Public Health and Environmental Assessment
Contractor Support
Robyn Blain, Ph.D.; Ami Gordon, M.P.H.; Pam Ross, M.S.P.H. | ICF; 9300 Lee Highway; Fairfax, VA
Executive Direction
Wayne E. Cascio, M.D. (CPHEA Director); Samantha Jones, Ph.D. (CPHEA Associate Director); Andrew Kraft, Ph.D. (CPAD Senior Science Advisor); Ravi Subramaniam, Ph.D. (CPAD Branch Chief); Kristina Thayer, Ph.D. (CPAD Director); Paul White, Ph.D. (CPAD Senior Science Advisor) | U.S. EPA; Office of Research and Development; Center for Public Health and Environmental Assessment
Internal Review Team
General Toxicology Workgroup; Inhalation Workgroup; Neurotoxicity Workgroup; PharmacoKinetic Workgroup; Reproductive and Developmental; Toxicology Workgroup; Statistical Workgroup; Toxicity Pathways Workgroup; Executive Review Committee | U.S. EPA; Office of Research and Development; Center for Public Health and Environmental Assessment

## Reviewers

This assessment was provided for review to scientists in EPA’s Program and Regional Offices. Comments were submitted by:

- Office of Children’s Health Protection, Washington, DC
- Office of Policy, Washington, DC
- Office of Solid Waste and Emergency Response, Washington, DC
- Office of Air and Radiation, Washington, DC
- Region 2, New York, NY
- Region 8, Denver, CO

This assessment was provided for review to other federal agencies and the Executive Office of the President. Comments were submitted by:

- Department of Health and Human Services/Agency for Toxic Substances and Disease Registry,
- Department of Health and Human Services/National Institute of Environmental Health Sciences/National Toxicology Program
- Executive Office of the President/Office of Management and Budget

This assessment was released for public comment on September 1, 2016 for a 60-day public comment period. The public comments are available on Regulations.gov. A summary and EPA’s disposition of the comments from the public is available in the revised external review draft assessment on the IRIS website. Comments were received from the following entities:

- American Chemistry Council
- American Petroleum Institute
- Exponent, Inc. on behalf of LyondellBasell
- Japan Petroleum Energy Center
- LyondellBasell
- Tox Strategies on behalf of LyondellBasell

This assessment was peer reviewed by independent, expert scientists external to EPA convened by EPA’s Science Advisory Board (SAB). A peer-review meeting was held on August 15–17, 2017. The report of the SAB’s review of the EPA’s Draft Toxicological Review of ETBE, dated February 27, 2019, is available on the SAB website. A summary and EPA’s disposition of the comments received from the SAB is included in Appendix E.

Janice E. Chambers, Ph.D. (chair) | Mississippi State University, MS
Hugh A. Barton, Ph.D. | Pfizer, Inc., Groton, CT
Janet Benson, Ph.D. | Lovelace Biomedical, Albuquerque, NM
Trish Berger, Ph.D. | University of California, Davis, Davis, CA
John Budroe, Ph.D. | Office of Environmental Health Hazard Assessment, Oakland, CA
James V. Bruckner, Ph.D. | University of Georgia, Athens, GA
Karen Chou, Ph.D. | Michigan State University, East Lansing, MI
Harvey Clewell, Ph.D. | Ramboll Environment and Health, Research Triangle Park, NC
Deborah Cory-Slechta, Ph.D. | University of Rochester, Rochester, NY
Bevin Engelward, Ph.D. | Massachusetts Institute of Technology, Cambridge, MA
Jeffrey Fisher, Ph.D. | U.S. Food and Drug Administration, Jefferson, AR
William Michael Foster, Ph.D. | Independent Consultant, Durham, NC
Alan Hoberman, Ph.D. | Charles River Laboratories, Inc., Horsham, PA
Tamarra James-Todd, Ph.D. | Harvard University, Boston, MA
Lawrence Lash, Ph.D. | Wayne State University, Detroit, MI
Marvin Meistrich, Ph.D. | Anderson Cancer Center, University of Texas, Houston, TX
Maria Morandi, Ph.D. | Independent Consultant, Houston, TX
Isaac Pessah, Ph.D. | University of California, Davis, CA
Lorenz Rhomberg, Ph.D. | Gradient, Cambridge, MA
Stephen M. Roberts, Ph.D. | University of Florida, Gainesville, FL
Alan Stern, Ph.D. | New Jersey Department of Environmental Protection/University of Medicine and Dentistry of New Jersey-Robert Wood Johnson Medical School, Trenton, NJ

The postexternal review draft of the assessment was provided for review to scientists in EPA’s Program and Regional Offices, and to other federal agencies and the Executive Office of the President (EOP). A summary and EPA’s disposition of major comments from the other federal agencies and EOP is available on the IRIS website. Comments were submitted by:

- EPA, Office of Air Quality Planning and Standards
- EPA, Office of Water
- EPA, Office of Children’s Health Protection
- EPA, Office of Land and Emergency Management
- EPA, Region 2

- Department of Health and Human Services/The National Institute for Occupational Safety and Health (NIOSH)
- Executive Office of the President/Office of Management and Budget