# 2 DOSE-RESPONSE ANALYSIS

## 2.1 ORAL REFERENCE DOSE FOR EFFECTS OTHER THAN CANCER

The oral reference dose (RfD) (expressed in units of mg/kg-day) is defined as an estimate (with uncertainty spanning perhaps an order of magnitude) of a daily exposure to the human population (including sensitive subgroups) that is likely to be without an appreciable risk of deleterious effects during a lifetime. It can be derived from a no-observed-adverse-effect level (NOAEL), lowest-observed-adverse-effect level (LOAEL), or the 95% lower bound on the benchmark dose (BMDL), with uncertainty factors (UFs) generally applied to reflect limitations of the data used.

### 2.1.1 Identification of Studies and Effects for Dose-Response Analysis

Studies were evaluated using general study quality characteristics as discussed in Section 1.1.1; see also U.S. EPA (2002) to help inform the selection of studies from which to derive toxicity values.

Human studies are preferred over animal studies when quantitative measures of exposure are reported and when the reported effects are determined to be associated with exposure. No human occupational or epidemiological studies of oral exposure to ethyl tertiary butyl ether (ETBE), however, are available.

Animal studies were evaluated to determine which studies provided (1) the most relevant routes and durations of exposure, (2) multiple exposure levels that informed the shape of the dose-response curve, and (3) sufficient sample size to detect effects at low exposure levels (U.S. EPA, 2002). The database for ETBE includes several chronic and subchronic studies, mostly in rats, showing effects in the kidney that are suitable for use in deriving oral reference values. In general, lifetime exposures are preferred over subchronic exposures.

#### Kidney Toxicity

Kidney effects were identified as a potential human hazard of ETBE-induced toxicity based on findings in male and female rats (summarized in Section 1.3.1). Kidney toxicity was observed across several chronic and subchronic studies following oral and inhalation exposure, based on findings of organ-weight changes, histopathology (urothelial hyperplasia in males), and altered serum biomarkers (cholesterol, creatinine, blood urea nitrogen [BUN]) in rats. The strongest and most consistent findings across oral exposure routes and durations were for absolute kidney-weight changes and urothelial hyperplasia in male rats; thus, only these endpoints were analyzed for dose-response. Kidney effects, such as urothelial hyperplasia, observed after chronic exposure could affect the ability of the kidney to filter waste, and changes in kidney weight could serve as a general indication of renal toxicity. In the case of kidney-weight changes, numerous chronic and subchronic studies investigated this endpoint following oral and inhalation exposure (Miyata et al., 2013; Saito et al., 2013; Suzuki et al., 2012; Hagiwara et al., 2011; Fujii et al., 2010; JPEC, 2010b, 2008b, c; Gaoua, 2004b; Medinsky et al., 1999). Chronic studies of oral exposure reported urothelial hyperplasia to be increased with treatment in male rats (Saito et al., 2013; Suzuki et al., 2012; JPEC, 2010a, b).

Hagiwara et al. (2011) used only one dose group, so was not considered further given its concordance with several other rat studies that had multiple groups. Additionally, as discussed in Section 1.1.1, 2-year organ-weight data in male rats were not considered suitable because of the prevalence of age-associated confounders (e.g., chronic progressive nephropathy [CPN]-related early deaths in male rats). Therefore, the urothelial hyperplasia data (observed in male rats only) and absolute kidney weight (female rats, only) were the only endpoints from the 2-year studies [(JPEC, 2010a); with selected data published as Suzuki et al. (2012)]. Absolute kidney weight was the only endpoint from the 13- to 26-week studies considered for dose-response analysis. These data and the absolute kidney weights from the remaining studies, JPEC (2008c) [with selected data published as Miyata et al. (2013)], Gaoua (2004b), and Fujii et al. (2010), are discussed further below.

In the 2-year drinking water study (Suzuki et al., 2012; JPEC, 2010a), male and female F344 rats (50/sex/dose group) were exposed to doses of 0, 28, 121, or 542 mg/kg-day. Increased incidence of urothelial hyperplasia was observed only in males and reached statistical significance at 121 and 542 mg/kg-day.

In the JPEC (2008c) 26-week gavage study, male and female Crl:CD(SD) rats (15/sex/dose group) were exposed to daily doses of 0, 5, 25, 100, or 400 mg/kg-day. Absolute kidney weight was significantly increased in males and females treated with 400 mg/kg-day. Abnormal histopathological findings in the kidney (basophilic tubules and hyaline droplets) were observed in male rats, but not in female rats.

In the Gaoua (2004b) two-generation reproductive toxicity study, Sprague Dawley (S-D) rats (25/sex/dose group) were exposed via gavage to doses of 0, 250, 500, or 1,000 mg/kg-day; treatment commenced 10 weeks before mating and continued throughout the 2-week mating period, gestation, and the end of lactation (Postnatal Day [PND] 21) for 18 weeks. Absolute kidney weight were significantly increased in all dose groups in F0 males (but not in F0 females) and was associated with the presence of acidophilic globules in renal tissue from 5/6 males examined. In addition, tubular basophilia (4/6), peritubular fibrosis (3/6), and proteinaceous casts (1/6) were observed in kidneys of male rats at the high dose. Similar microscopic effects in females were not observed, so F0 female kidney weights were not modeled. Absolute kidney weights were also increased in F1 animals, but the F1 animals appeared to be less affected than the F0 animals.

In the Fujii et al. (2010) one-generation reproductive toxicity study, male and female Crl:CD(SD) rats (24/sex/dose group) were exposed via gavage to doses of 0, 100, 300, or 1,000 mg/kg-day beginning 10 weeks prior to F0 mating and continuing throughout the reproductive period (mating, gestation, lactation). Treatment durations were stated to be approximately 16 weeks for males and 17 weeks for females but ranged up to 20 weeks in animals that took longer to mate. Kidney weights were significantly increased in F0 males and females at 1,000 mg/kg-day.

### 2.1.2 Methods of Analysis

No biologically based dose-response models are available for ETBE. In this situation, a range of dose-response models was evaluated to determine how best to model the dose-response relationship empirically in the range of the observed data. The models in the U.S. Environmental Protection Agency’s (EPA’s) Benchmark Dose Software (BMDS) were applied. Consistent with EPA’s Benchmark Dose Technical Guidance Document (U.S. EPA, 2012), the benchmark dose (BMD) and the BMDL are estimated using a benchmark response (BMR) to represent a minimal, biologically significant level of change. In the absence of information regarding what level of change is considered biologically significant, a BMR of 10% change from the control mean (relative deviation [RD]) for kidney weight and a BMR of 10% extra risk on incidences of urothelial hyperplasia data were used to estimate the BMD and BMDL and to facilitate a consistent basis of comparison across endpoints, studies, and assessments. When modeling was feasible, the estimated BMDLs were used as points of departure (PODs); which are summarized in Table 2-1. Details, including the modeling output and graphical results for the model selected for each endpoint, are presented in Appendix C of the Supplemental Information to this Toxicological Review.

Human equivalent doses (HEDs) for oral exposures were derived from the PODs according to the hierarchy of approaches outlined in EPA’s Recommended Use of Body Weight^3/4^ as the Default Method in Derivation of the Oral Reference Dose (U.S. EPA, 2011). The preferred approach is physiologically based pharmacokinetic (PBPK) modeling. Other approaches include using chemical-specific information in the absence of a complete PBPK model. As discussed in Appendix B of the Supplemental Information, several rat PBPK models for ETBE have been developed and published, but a validated human PBPK model for ETBE for extrapolating doses from animals to humans is not available. In lieu of chemical-specific models or data to inform the derivation of human equivalent oral exposures, body-weight scaling to the 3/4 power (BW^3/4^) is applied to extrapolate toxicologically equivalent doses of orally administered agents from adult laboratory animals to adult humans to derive an oral RfD. BW^3/4^ scaling was not used for deriving human equivalent doses (HEDs) from studies in which doses were administered directly to early postnatal animals because of the absence of information on whether allometric (i.e., body weight) scaling holds when extrapolating doses from neonatal animals to adult humans due to presumed toxicokinetic or toxicodynamic differences between lifestages (U.S. EPA, 2011; Hattis et al., 2004).

Table 2-1 Summary of derivation of points of departure following oral exposure for up to 2 years

Endpoint and reference | Species/sex | Model^a^ | BMR | BMD mg/kg-d | BMDL mg/kg-d | POD_ADJ_^b^ mg/kg-d | POD_HED_^c^ mg/kg-d
Kidney
Increased urothelial hyperplasia; 2-yr; Suzuki et al. (2012); JPEC (2010a) | F344 rat/M | Quantal-Linear | 10% ER | 79.3 | 60.5 | 60.5 | 14.5
Increased absolute kidney weight; 2-yr; Suzuki et al. (2012); JPEC (2010a) | F344 rat/M | NOAEL^d,e^ 121 mg/kg-d; 5% ↑ in kidney weight | | | | 121 | 29.0
Increased absolute kidney weight; 2-yr; Suzuki et al. (2012); JPEC (2010a) | F344 rat/F | Exponential (M4) | 10% RD | 204 | 120 | 120 | 28.8
Increased absolute kidney weight; 26-wk; JPEC (2008c); Miyata et al. (2013) | S-D rat/M | Linear | 10% RD | 176 | 115 | 115 | 27.6
Increased absolute kidney weight; 26-wk; JPEC (2008c); Miyata et al. (2013) | S-D rat/F | Exponential (M4) | 10% RD | 224 | 57 | 57 | 13.7
Increased absolute kidney weight (F0 generation); 18-wk; Gaoua (2004b) | S-D rat/M | Hill | 10% RD | 244 | 94 | 94 | 22.6
Increased absolute kidney weight (F0 generation); 16-wk; Fujii et al. (2010) | S-D rat/M | Hill | 10% RD | 435 | 139 | 139 | 33.4
Increased absolute kidney weight (F0 generation); 17-wk; Fujii et al. (2010) | S-D rat/F | Polynomial (2 degree) | 10% RD | 1,094 | 905 | 905 | 217

ER = extra risk, F = female; M = male; RD = relative deviation; TWA = time-weighted average.

a For modeling details, see Appendix C of the Supplemental Information.

b For studies in which animals were not dosed daily, administered doses were adjusted to calculate the TWA daily doses prior to BMD modeling. This adjustment, however, was not required for the studies evaluated.

c HED PODs were calculated using BW^3/4^ scaling (U.S. EPA, 2011).

d NOAEL was used because of the lack of suitable model fit (see Appendix C).

e 18% increase in kidney weight at LOAEL.

Consistent with EPA guidance (U.S. EPA, 2011), the PODs estimated based on effects in adult animals, are converted to HEDs using a standard dosimetric adjustment factor (DAF) derived as follows:

DAF = ( BW_a^1 / 4^_ ÷ BW_h^1 / 4^_ ) where BW_a_ = animal body weight BW_h_ = human body weight (2-1)

Using a standard BW_a_ of 0.25 kg for rats and a BW_h_ of 70 kg for humans (U.S. EPA, 1988), the resulting DAF for rats is 0.24. Applying the DAF to the POD identified for effects in adult rats yields a POD_HED_ as follows (see Table 2-1):

POD_HED_ = Duration-adjusted laboratory animal dose ( mg/kg-day ) × DAF (2-2)

Table 2-1 summarizes the sequence of calculations leading to the derivation of a human-equivalent POD for each data set discussed above.

### 2.1.3 Derivation of Candidate Values

Consistent with EPA’s A Review of the Reference Dose and Reference Concentration Processes (U.S. EPA, 2002; Section 4.4.5 (https://hero.epa.gov/hero/index.cfm?action=search.view&reference_id=88824)), five possible areas of uncertainty and variability were considered when determining the application of UF values to the PODs presented in Table 2-1. An explanation follows.

An intraspecies uncertainty factor, UF_H_, of 10 was applied to all PODs to account for potential differences in toxicokinetics and toxicodynamics in the absence of information on the variability of response in the human population following oral exposure to ETBE (U.S. EPA, 2002).

An interspecies uncertainty factor, UF_A_, of 3 (10^0.5^ = 3.16, rounded to 3) was applied to PODs that used BW^3/4^ scaling to extrapolate oral doses from laboratory animals to humans. Although BW^3/4^ scaling addresses some aspects of cross-species extrapolation of toxicokinetic and toxicodynamic processes, some residual uncertainty remains. In the absence of chemical-specific data to quantify this uncertainty, EPA’s BW^3/4^ guidance (U.S. EPA, 2011) recommends using an uncertainty factor of 3. For PODs that did not use BW^3/4^ such as early-life effects, a UF_A_ of 10 was applied (U.S. EPA, 2011).

A subchronic-to-chronic uncertainty factor, UF_S_, differs depending on the exposure duration. For studies of 16- to 26-week duration, the magnitude of change observed in kidney weights was similar to the effect observed at 104 weeks. This suggests a maximum effect could have been reached by 16−26 weeks. The 104-week kidney data, however, are confounded due to age-associated factors, so this comparison might not be completely reliable. Additionally, some but not all markers of kidney toxicity appear more severely affected by ETBE at 2 years compared with observations at 16−26 weeks [e.g., histopathology, BUN; Suzuki et al. (2012); JPEC (2010a)]. Thus, a UF_S_ of 3 was applied for studies of 16- to 26-week duration to account for this uncertainty, and a UF_S_ of 1 was applied to 2-year studies.

A LOAEL-to-NOAEL uncertainty factor, UF_L_, of 1 was applied to all PODs derived because the current approach is to address this factor as one of the considerations in selecting a BMR for benchmark dose modeling. In this case, BMRs of a 10% change in absolute kidney weight and a 10% extra risk of urothelial hyperplasia were selected assuming that they represent minimal biologically significant response levels.

A database uncertainty factor, UF_D_, of 1 was applied to all PODs. The ETBE oral toxicity data set includes a 2-year toxicity study in rats (Suzuki et al., 2012; JPEC, 2010a), a 26-week toxicity study in rats (Miyata et al., 2013), prenatal developmental toxicity studies in rats and rabbits (Aso et al., 2014; Asano et al., 2011), and both single- and multigeneration reproductive studies and developmental studies in rats (Fujii et al., 2010; Gaoua, 2004a, b). As discussed in Appendix B of the Supplemental Information, the ETBE data set does not indicate immunotoxicity (Banton et al., 2011; Li et al., 2011). Additionally, the available mouse study showed less severe effects than those in rats, suggesting that mice are less sensitive than rats. Although most of the studies are in rats, the ETBE oral database adequately covers all major systemic effects, including reproductive and developmental effects, and the available evidence does not raise concern that additional studies would likely lead to identification of a more sensitive endpoint or a lower POD. Furthermore, the effects observed in inhalation studies support the noncancer effects observed in the oral studies. Therefore, an uncertainty factor for the database, UF_D_, of 1 was applied.

Figure 2-1 graphically presents the candidate values, UFs, and POD_HED_ values, with each bar corresponding to one data set described in Table 2-1 and Table 2-2.

Table 2-2 Effects and corresponding derivation of candidate values

Endpoint and reference | POD_HED_ mg/kg-d | POD type | UF_A_ | UF_H_ | UF_L_ | UF_S_ | UF_D_ | Composite UF | Candidate value mg/kg-d
Kidney
Increased urothelial hyperplasia; male rat; 2-yr; Suzuki et al. (2012); JPEC (2010a) | 14.5 | BMDL_10_ | 3 | 10 | 1 | 1 | 1 | 30 | 5 × 10^−1^
Increased absolute kidney weight; male rat; 2-yr; Suzuki et al. (2012); JPEC (2010a) | 29.0 | NOAEL | 3 | 10 | 1 | 1 | 1 | 30 | 1 × 10^0^
Increased absolute kidney weight; female rat; 2-yr; Suzuki et al. (2012); JPEC (2010a) | 28.8 | BMDL_10_ | 3 | 10 | 1 | 1 | 1 | 30 | 1 × 10^0^
Increased absolute kidney weight; male rat; 26-wk; JPEC (2008c); Miyata et al. (2013) | 27.6 | BMDL_10_ | 3 | 10 | 1 | 3 | 1 | 100 | 3 × 10^−1^
Increased absolute kidney weight; female rat; 26-wk; JPEC (2008c); Miyata et al. (2013) | 13.7 | BMDL_10_ | 3 | 10 | 1 | 3 | 1 | 100 | 1 × 10^−1^
Increased absolute kidney weight; F0 male rat; 18-wk; Gaoua (2004b) | 22.6 | BMDL_10_ | 3 | 10 | 1 | 3 | 1 | 100 | 2 × 10^−1^
Increased absolute kidney weight; male rat; 16-wk; Fujii et al. (2010) | 33.4 | BMDL_10_ | 3 | 10 | 1 | 3 | 1 | 100 | 3 × 10^−1^
Increased absolute kidney weight; female rat; 17-wk; Fujii et al. (2010) | 217 | BMDL_10_ | 3 | 10 | 1 | 3 | 1 | 100 | 2 × 10^0^

Figure 2-1 Oral candidate values with corresponding POD and composite UF

### 2.1.4 Derivation of Organ/System-Specific Reference Doses

Table 2-3 distills the candidate values from Table 2-2 into a single value for each organ or system. Organ- or system-specific RfDs are useful for subsequent cumulative risk assessments that consider the combined effect of multiple agents acting at a common site.

Table 2-3 Organ/system-specific RfDs and overall RfD for ETBE

Effect | Basis | RfD (mg/kg-d) | Study exposure description | Confidence
Kidney | Increased absolute kidney weight in female rats; Suzuki et al. (2012); JPEC (2010a) | 1 × 10^0^ | Chronic | High
Overall RfD | Kidney | 1 × 10^0^ | Chronic | High

#### Kidney Toxicity

For ETBE, candidate values were derived for increases in urothelial hyperplasia or absolute kidney weight in male or female rats. Selection of a point estimate considered multiple aspects, including study design and consistency across estimates. As stated previously, reference values based on lifetime exposure are preferred over subchronic exposures. The only candidate reference values based on data from a 2-year oral study are those for increased absolute kidney weight in female rats and urothelial hyperplasia in male rats (Saito et al., 2013; Suzuki et al., 2012; JPEC, 2010a, b). While urothelial hyperplasia in male rats was the most sensitive candidate value, this endpoint was not observed in female rats or mice of either sex, whereas increased kidney weights were observed in multiple studies in rats of both sexes and in mice. A lower candidate value based on increased kidney weights in female rats was derived from a smaller (n = 15), shorter duration study [26 weeks; JPEC (2008c)]; however, based on comparison of BMD values (204 vs. 224 mg/kg-day) and composite UFs (30 vs. 100), this lower value reflects greater variability and uncertainty in the data. The composite UF for the candidate value based on increased kidney weight in female rats treated for 2 years was the lowest uncertainty value, providing greater certainty in the selection of this candidate value. In addition, the candidate values from female rats are not potentially confounded by alpha 2u-globulin related processes.

Collectively, these observations indicate that the most appropriate basis for a kidney-specific RfD would be the increased absolute kidney weight in female rats from the 2-year oral study (Suzuki et al., 2012; JPEC, 2010a). The observed increases in kidney weight are likely a result of increased CPN severity seen with ETBE exposure as CPN is characterized by cell proliferation and chronic inflammation that results in increased kidney weight (Melnick et al., 2012; Travlos et al., 2011).

The candidate value for increased absolute kidney weight in female rats (1 × 10^0^ mg/kg-day) was selected as the kidney-specific reference dose for ETBE. Confidence in this RfD is high. The candidate value is derived from a well-conducted good laboratory practice (GLP) study, involving a sufficient number of animals per group and assessing a wide range of kidney endpoints. In addition, the POD is based on benchmark dose modeling, with the POD within the range of tested doses (e.g., not requiring extrapolation well beyond the experimental range), and the reference value is associated with less relative uncertainty (as illustrated by the smaller composite UF). Furthermore, several additional studies demonstrate quantitatively similar PODs and candidate values for kidney effects (see Table 2-2 and Figure 2-1).

### 2.1.5 Selection of the Overall Reference Dose

For ETBE, kidney effects were identified as the strongest hazard and carried forward for dose-response analysis; thus, only one organ/system-specific reference dose was derived. Therefore, the kidney-specific RfD of 1 × 10^0^ mg/kg-day is the overall RfD for ETBE. This value is based on increased absolute kidney weight in female rats exposed to ETBE.

The overall reference dose is derived to be protective of all types of effects for a given duration of exposure and is intended to protect the population as a whole, including potentially susceptible subgroups (U.S. EPA, 2002). Decisions concerning averaging exposures over time for comparison with the RfD should consider the types of toxicological effects and specific lifestages of concern. Fluctuations in exposure levels that result in elevated exposures during these lifestages could lead to an appreciable risk, even if average levels over the full exposure duration were less than or equal to the RfD. In the case of ETBE, no specific potential for early lifestage susceptibility to ETBE exposure was identified, as discussed in Section 1.3.3.

### 2.1.6 Confidence Statement

A confidence level of high, medium, or low is assigned to the study used to derive the RfD, the overall database, and the RfD, as described in Section 4.3.9.2 of EPA’s Methods for Derivation of Inhalation Reference Concentrations and Application of Inhalation Dosimetry (U.S. EPA, 1994). The overall confidence in this RfD is high. Confidence in the principal study (Suzuki et al., 2012; JPEC, 2010a) is high. This study was well conducted, complied with OECD guidelines for GLP studies, involved a sufficient number of animals per group (including both sexes), and assessed a wide range of tissues and endpoints. Confidence in the database is high. The available studies evaluated a comprehensive array of endpoints, and the existing evidence base does not raise concerns that additional studies would be likely to lead to the identification of a more sensitive endpoint. Furthermore, multiple studies demonstrate quantitatively similar PODs and candidate values for kidney effects (see Table 2-2 and Figure 2-1), providing additional support. Reflecting high confidence in the principal study and high confidence in the database, confidence in the RfD is high.

### 2.1.7 Previous IRIS Assessment

No previous oral assessment for ETBE is available in IRIS.

## 2.2 INHALATION REFERENCE CONCENTRATION FOR EFFECTS OTHER THAN CANCER

The inhalation reference concentration (RfC) (expressed in units of mg/m^3^) is defined as an estimate (with uncertainty spanning perhaps an order of magnitude) of a continuous inhalation exposure to the human population (including sensitive subgroups) that is likely to be without an appreciable risk of deleterious effects during a lifetime. It can be derived from a NOAEL, LOAEL, or the 95% lower bound on the benchmark concentration (BMCL), with UF values generally applied to reflect limitations of the data used.

### 2.2.1 Identification of Studies and Effects for Dose-Response Analysis

Kidney effects were identified as a potential human hazard of ETBE exposure based on studies in experimental animals (summarized in Section 1.3.1). These studies were evaluated using general study quality characteristics as discussed in Section 6 of the Preamble and in Section 1.1.1 [see also U.S. EPA (2002)] to help inform the selection of studies from which to derive toxicity values. Rationale for selection of studies and effects representative of this hazard is summarized below.

Human studies are generally preferred over animal studies as the basis for reference values when there are quantitative measures of exposure and reported effects that are determined to be associated with that exposure. Data on the effects of inhaled ETBE in humans is limited to a small number of 2-hour inhalation studies at concentrations up to 208.9 mg/m^3^ (Nihlén et al., 1998b; Vetrano, 1993). These studies were not considered for dose-response assessment because they are of acute duration and primarily focused on toxicokinetics.

The database for ETBE includes inhalation studies and data sets from animal studies that are potentially suitable for use in deriving inhalation reference values. Specifically, effects associated with ETBE exposure in animals include observations of organ weight and histological changes in the kidney in chronic and subchronic studies in male and female rats.

#### Kidney Toxicity

There is evidence supporting kidney effects following ETBE exposure in rats, including organ-weight changes, histopathology (urothelial hyperplasia and exacerbation of CPN), and altered clinical chemistry (creatinine, BUN, cholesterol). The most consistent, concentration-related findings across multiple studies, in both sexes, were for kidney-weight changes and increased CPN severity. In the case of kidney-weight changes, one chronic and numerous subchronic studies investigated this endpoint following inhalation exposure (Suzuki et al., 2012; Hagiwara et al., 2011; Fujii et al., 2010; JPEC, 2010b, 2008b, c; Gaoua, 2004b; Medinsky et al., 1999). A 2-year inhalation study (Saito et al., 2013; JPEC, 2010b) reported increased urothelial hyperplasia in male rats only, and increased kidney weight and CPN severity in both sexes. Increased kidney weights from the 13-week studies were also considered for dose-response analysis (Saito et al., 2013; JPEC, 2010b).

In the Saito et al. (2013) 2-year inhalation study, male and female F344 rats (50/sex/concentration group) were exposed to concentrations of 0, 2,090, 6,270, or 20,900 mg/m^3^ (JPEC, 2010b). Increased incidence of urothelial hyperplasia was only observed in males and significantly increased at 6,270 and 20,900 mg/m^3^. Increased severity of CPN was significantly increased in males and females at 20,900 mg/m^3^. Absolute kidney weight was significantly increased in males at concentrations ≥2,090 mg/m^3^ and in females at ≥6,270 mg/m^3^.

In the JPEC (2008b) 13-week whole-body inhalation study, male and female Crl:CD(SD) rats were exposed to concentrations of 0, 627, 2,090, 6,270, or 20,900 mg/m^3^ for 6 hours/day, 5 days/week. Significant increases in absolute kidney weights occurred in male rats exposed to 6,270 or 20,900 mg/m^3^ ETBE compared with controls, while changes in female rats were not statistically significant, and were not modeled.

In the Medinsky et al. (1999) 13-week whole-body inhalation study, male and female F344 rats were exposed to concentrations of 0, 2,090, 7,320, or 20,900 mg/m^3^ for 6 hours/day, 5 days/week. Kidney weights were increased at the highest two concentrations in both males and females. Slight, but statistically significant, increases in various clinical chemistry parameters were observed; however, these effects were reported to be of uncertain toxicological significance and were not modeled.

### 2.2.2 Methods of Analysis

No biologically based dose-response models are available for ETBE. In this situation, dose-response models thought to be consistent with underlying biological processes were evaluated to determine how best to model the dose-response relationship empirically in the range of the observed data. Consistent with this approach, all models available in EPA’s BMDS were evaluated. Consistent with EPA’s Benchmark Dose Technical Guidance Document (U.S. EPA, 2012), the benchmark concentration (BMC) and the 95% BMCL were estimated using BMR to represent a minimal, biologically significant level of change. As noted in Section 2.1.2, a 10% relative change from the control mean (RD) was used as a BMR for absolute kidney weight, and a BMR of 10% extra risk was considered appropriate for the quantal data on incidences of urothelial hyperplasia. When modeling was feasible, the estimated BMCLs were used as PODs; the PODs are summarized in Table 2-4. Further details including the modeling output and graphical results for the model selected for each endpoint are found in Appendix C of the Supplemental Information to this Toxicological Review.

Table 2-4 Summary of derivation of PODs following inhalation exposure

Endpoint and reference | Species/sex | Model^a^ | BMR | BMC (mg/m^3^) | BMCL (mg/m^3^) | POD_ADJ_^b^ (mg/m^3^) | POD_HEC_^c^ (mg/m^3^)
Kidney
Increased urothelial hyperplasia; 2-yr; Saito et al. (2013); JPEC (2010b) | F344 rat/M | Gamma | 10% | 2,734 | 1,498 | 268 | 265
Increased CPN severity; 2-yr; Saito et al. (2013); JPEC (2010b) | F344 rat/M and F | NOAEL:^d^ 6,270 mg/m^3^ | | | | 1,120 | 1,110
Increased absolute kidney weight; 2-yr; Saito et al. (2013); JPEC (2010b) | F344 rat/F | NOAEL:^d,e^ 6,270 mg/m^3^; 6% ↑ in kidney weight | | | | 1,120 | 1,110
Increased absolute kidney weight; 13-wk; JPEC (2008b) | S-D rat/M | NOAEL:^d^ 627 mg/m^3^; 10% ↑ in kidney weight | | | | 112 | 111
Increased absolute kidney weight; 13-wk; JPEC (2008b) | S-D rat/F | Linear | 10% RD | 28,591 | 16,628 | 2,969 | 2,946
Increased absolute kidney weight; 13-wk; Medinsky et al. (1999) | F344 rat/M | Hill | 10% RD | 6,968 | 2,521 | 450 | 447
Increased absolute kidney weight; 13-wk; Medinsky et al. (1999) | F344 rat/F | Exponential (M4) | 10% RD | 5,610 | 3,411 | 609 | 604

F = female; M = male.

a For modeling details, see Appendix C of the Supplemental Information.

b PODs were adjusted for continuous daily exposure: POD_ADJ_ = POD × (hours exposed per day ÷ 24 hours) × (days exposed per week ÷ 7 days).

c POD_HEC_ calculated by adjusting the POD_ADJ_ by the DAF (= 0.992) for a Category 3 gas (U.S. EPA, 1994).

d NOAEL was used because of the lack of a suitable model fit (see Appendix C).

e Absolute kidney weight was increased 5, 6, and 18% at 2,090, 6,270, and 20,900 mg/m^3^. A NOAEL was selected based on the concentration closest to a 10% change in order to more closely approximate a minimally biologically significant change.

Because the RfC is applicable to a continuous lifetime human exposure but is derived from animal studies featuring intermittent exposure, EPA guidance (U.S. EPA, 1994) provides mechanisms for: (1) adjusting experimental exposure concentrations to a value reflecting continuous exposure duration (ADJ) and (2) determining a human equivalent concentration (HEC) from the animal exposure data. The former employs an inverse concentration-time relationship to derive a health-protective duration adjustment to time-weight the intermittent exposures used in the studies. The modeled benchmark concentration from the animal exposures the inhalation studies (JPEC, 2010b, 2008b; Medinsky et al., 1999) were adjusted to reflect a continuous exposure by multiplying concentration by (6 hours/day) ÷ (24 hours/day) and (5 days/week) ÷ (7 days/week) as follows:

BMCL_ADJ_ = BMCL ( mg / m^3^ ) × ( 6 ÷ 24 ) × ( 5 ÷ 7 ) = BMCL ( mg / m^3^ ) × ( 0.1786 ) (2-3)

The RfC methodology provides a mechanism for deriving an HEC from the duration-adjusted POD (BMCL_ADJ_) determined from the animal data. The approach takes into account the extrarespiratory nature of the toxicological responses and accommodates species differences by considering blood:air partition coefficients for ETBE in the laboratory animal (rat or mouse) and humans. According to the RfC guidelines (U.S. EPA, 1994), ETBE is a Category 3 gas because extrarespiratory effects were observed. Therefore, the BMCL_ADJ_ is multiplied by the ratio of animal/human blood:air partition coefficients (L_A_/L_H_). As detailed in Appendix Section B.2.2 of the Supplemental Information, the values reported in the literature for these parameters include an L_A_ of 11.6 for Wistar rats (Kaneko et al., 2000) and an L_H_ in humans of 11.7 (Nihlén et al., 1995). This allowed a BMCL_HEC_ to be derived as follows:

BMCL_HEC_ = BMCL_ADJ_ ( mg / m^3^ ) × ( L_A_ ÷ L_H_ ) ( interspecies conversion ) = BMCL_ADJ_ ( mg / m^3^ ) × ( 11.6 ÷ 11.7 ) = BMCL_ADJ_ ( mg / m^3^ ) × ( 0.992 ) (2-4)

Table 2-4 summarizes the sequence of calculations leading to the derivation of a human-equivalent POD (POD_HEC_) for each inhalation data set discussed above.

### 2.2.3 Derivation of Candidate Values

In EPA’s A Review of the Reference Dose and Reference Concentration Processes (U.S. EPA, 2002; Section 4.4.5 (https://hero.epa.gov/hero/index.cfm?action=search.view&reference_id=88824)) described in the Preamble, five possible areas of uncertainty and variability were considered. An explanation follows.

An intraspecies uncertainty factor, UF_H_, of 10 was applied to all PODs to account for potential differences in toxicokinetics and toxicodynamics in the absence of information on the variability of response in the human population following inhalation exposure to ETBE (U.S. EPA, 2002).

An interspecies uncertainty factor, UF_A_, of 3 (10^0.5^ = 3.16, rounded to 3) was applied to all PODs to account for residual uncertainty in the extrapolation from laboratory animals to humans in the absence of information to characterize toxicodynamic differences between rodents and humans after inhalation exposure to ETBE. This value is adopted by convention where an adjustment from animal to a human equivalent concentration has been performed as described in EPA’s Methods for Derivation of Inhalation Reference Concentrations and Application of Inhalation Dosimetry (U.S. EPA, 1994).

The subchronic to chronic uncertainty factor, UF_S_, differs depending on the exposure duration. For rodent studies, exposure durations of 90 days (or 13 weeks) are generally considered subchronic. Furthermore, the magnitude of change in absolute kidney weights appeared to increase in male and female rats exposed for 26 weeks compared with 13−18 weeks, suggesting that toxicity would be expected to increase with exposure durations greater than 13 weeks. Therefore, a UF_S_ of 10 was applied for studies of 13 weeks, and a UF_S_ of 1 was applied to 2-year studies.

A LOAEL to NOAEL uncertainty factor, UF_L_ of 1 was applied to all PODs derived because the current approach is to address this factor as one of the considerations in selecting a BMR for benchmark dose modeling. In this case, BMRs of a 10% change in absolute kidney weight and a 10% extra risk of histological lesions were selected assuming that they represent minimal biologically significant response levels. In some cases, the data were not amenable to modeling, thus a NOAEL was selected to represent a minimal biologically significant response.

A database uncertainty factor, UF_D_ of 1 was applied to all PODs. The ETBE inhalation toxicity database includes a 2-year toxicity study in rats (Saito et al., 2013; JPEC, 2010b) and 13-week toxicity studies in mice and rats (JPEC, 2008b; Medinsky et al., 1999). Generally, if the RfD or RfC is based on animal data, a factor of 3 is often applied if either a prenatal toxicity study or a two-generation reproduction study is missing, or a factor of 10 if both are missing (U.S. EPA, 2002). There are no developmental or multigeneration reproductive studies by the inhalation route; however, the oral studies of prenatal developmental toxicity in rats and rabbits (Aso et al., 2014; Asano et al., 2011), and single- and multigeneration reproductive toxicity and developmental toxicity in rats (Fujii et al., 2010; Gaoua, 2004a, b) are available to inform the inhalation database. In addition, systemic effects are anticipated to be similar via oral or inhalation exposure to ETBE, first-pass effects are not indicated by the available data, and no evidence is available to suggest that untransformed ETBE would have a significant role in toxicity. Similarly, the oral ETBE data set does not indicate immunotoxicity and differences in outcome would not be expected for inhalation exposures (Banton et al., 2011; Li et al., 2011). Although most of the studies are in rats, the available mouse study showed effects that were less severe than those in rats, suggesting that mice are less sensitive than rats. The ETBE inhalation database, supported by the information from the oral database, adequately covers all major systemic effects, including reproductive, developmental, immunological, and neurological effects, and the available evidence does not raise concern that additional studies would likely lead to the identification of a more sensitive endpoint or a lower POD. Therefore, a database UF_D_ of 1 was applied.

Table 2-5 is a continuation of Table 2-4, and summarizes the application of UF values to each POD to derive a candidate value for each data set. The candidate values presented in the table below are preliminary to the derivation of the organ/system-specific reference values. These candidate values are considered individually in the selection of a representative inhalation reference value for a specific hazard and subsequent overall RfC for ETBE.

Figure 2-2 presents graphically the candidate values, UF values, and PODs, with each bar corresponding to one data set described in Table 2-4 and Table 2-5.

Table 2-5 Effects and corresponding derivation of candidate values

Endpoint (sex and species) and reference | POD_HEC_ (mg/m^3^) | POD type | UF_A_ | UF_H_ | UF_L_ | UF_S_ | UF_D_ | Composite UF | Candidate value (mg/m^3^)
Kidney
Increased urothelial hyperplasia; male rat; 2-yr; Saito et al. (2013); JPEC (2010b) | 265 | BMCL_10_ | 3 | 10 | 1 | 1 | 1 | 30 | 9 × 10^0^
Increased CPN severity; male and female rat; 2-yr; Saito et al. (2013); JPEC (2010b) | 1,110 | NOAEL | 3 | 10 | 1 | 1 | 1 | 30 | 4 × 10^1^
Increased absolute kidney weight; female rat; 2-yr; Saito et al. (2013); JPEC (2010b) | 1,110 | NOAEL | 3 | 10 | 1 | 1 | 1 | 30 | 4 × 10^1^
Increased absolute kidney weight; male rat; 13-wk; JPEC (2008b) | 111 | NOAEL | 3 | 10 | 1 | 10 | 1 | 300 | 4 × 10^−1^
Increased absolute kidney weight; female rat; 13-wk; JPEC (2008b) | 2,946 | BMCL_10_ | 3 | 10 | 1 | 10 | 1 | 300 | 1 × 10^1^
Increased absolute kidney weight; male rat; 13-wk; Medinsky et al. (1999) | 447 | BMCL_10_ | 3 | 10 | 1 | 10 | 1 | 300 | 2 × 10^0^
Increased absolute kidney weight; female rat; 13-wk; Medinsky et al. (1999) | 604 | BMCL_10_ | 3 | 10 | 1 | 10 | 1 | 300 | 2 × 10^0^

Figure 2-2 Inhalation candidate values with corresponding POD and composite UF

### 2.2.4 Derivation of Organ/System-Specific Reference Concentrations

Table 2-6 distills the candidate values from Table 2-5 into a single value for the kidney. Organ- or system-specific reference values can be useful for subsequent cumulative risk assessments that consider the combined effect of multiple agents acting at a common site.

#### Kidney Toxicity

As stated previously, reference values based on lifetime exposure are preferred over subchronic exposures to minimize uncertainty and extrapolation to a chronic exposure duration. The only candidate reference values based on data from a 2-year inhalation study are those for urothelial hyperplasia in male rats and increased absolute kidney weight in female rats (Saito et al., 2013; JPEC, 2010b). For ETBE, candidate values were derived for increased kidney weight in both sexes of rats and urothelial hyperplasia in males. While the increase in urothelial hyperplasia in male rats resulted in the lowest candidate value, this endpoint was observed only in male rats and thus the biological relevance of this lesion is more uncertain than the kidney endpoints observed in both sexes. Increased kidney weight was observed in both sexes of rats, however, the kidney weight changes in female rats was selected to avoid potential confounding from alpha 2u-globulin processes. The candidate RfC for increased absolute kidney weight in female rats (4 × 10^1^ mg/m^3^) was ultimately selected as the kidney-specific RfC for ETBE and is consistent with the selection of the kidney-specific RfD (see Section 2.1.4). As discussed in Section 2.1.4, this lesion is a general indicator of kidney toxicity, which has been observed in both sexes of rats (and to a lesser extent in mice). This RfC is identical to the candidate RfC for the increased severity of CPN in male and female rats. That the observed increases in kidney weight seen in male and female rats is a result of the increases in severity of CPN seen with ETBE exposure is likely, as a characteristic feature of CPN is increasing kidney size and weight (Hard et al., 2013). Confidence in this kidney-specific RfC is medium. The candidate value is derived from a well-conducted study, involving a sufficient number of animals per group, including both sexes, and assessing a wide range of kidney endpoints, but the inability to model the selected endpoint resulted in some reduction in confidence.

Table 2-6 Organ/system-specific RfCs and overall RfC for ETBE

Effect | Basis | RfC (mg/m^3^) | Study exposure description | Confidence
Kidney | Increased absolute kidney weight in female rats; Saito et al. (2013); JPEC (2010b) | 4 × 10^1^ | Chronic | Medium
Overall RfC | Kidney | 4 × 10^1^ | Chronic | Medium

### 2.2.5 Selection of the Overall Reference Concentration

For ETBE, kidney effects were identified as the primary hazard; thus, a single organ/system-specific RfC was derived. Therefore, the kidney-specific RfC of 4 × 10^1^ mg/m^3^ is selected as the overall RfC, representing an estimated exposure level below which deleterious effects from ETBE exposure are not expected to occur.

The overall RfC is derived to be protective for all types of effects for a given duration of exposure and is intended to protect the population as a whole, including potentially susceptible subgroups (U.S. EPA, 2002). Decisions concerning averaging exposures over time for comparison with the RfC should consider the types of toxicological effects and specific lifestages of concern. Fluctuations in exposure levels that result in elevated exposures during these lifestages could lead to an increased level of concern, even if average levels over the full exposure duration were less than or equal to the RfC. In the case of ETBE, no specific potential for early lifestage susceptibility to ETBE exposure was identified, as discussed in Section 1.3.3.

### 2.2.6 Confidence Statement

A confidence level of high, medium, or low is assigned to the study used to derive the RfC, the overall database, and the RfC itself, as described in Section 4.3.9.2 of EPA’s Methods for Derivation of Inhalation Reference Concentrations and Application of Inhalation Dosimetry (U.S. EPA, 1994). The overall confidence in this RfC is medium. Confidence in the principal study, Saito et al. (2013); JPEC (2010b), is medium. This study was well conducted, following GLP guidelines that involved a sufficient number of animals per group (including both sexes), and assessed a wide range of tissues and endpoints; however, the inability to model the POD resulted in some reduction in confidence. Confidence in the database is high; the available studies evaluated a comprehensive array of endpoints, and there is no indication that additional studies would lead to identification of a more sensitive endpoint. Reflecting medium confidence in the principal study and high confidence in the database, overall confidence in the RfC for ETBE is medium.

### 2.2.7 Previous IRIS Assessment

No previous inhalation assessment for ETBE is available in IRIS.

### 2.2.8 Uncertainties in the Derivation of the Reference Dose and Reference Concentration

The following discussion identifies uncertainties associated with the RfD and RfC for ETBE. To derive the RfD and RfC, the UF approach (U.S. EPA, 2000, 1994) was applied to a POD based on kidney toxicity in rats treated chronically. UFs were applied to the PODs to account for extrapolating from an animal bioassay to human exposure and for the likely existence of a diverse human population of varying susceptibility. Default approaches are used for these extrapolations, given the lack of data to inform individual steps.

The database for ETBE contains no human data on adverse health effects from subchronic or chronic exposure, and the PODs were calculated from data on the effects of ETBE reported by studies in rats. The database for ETBE exposure includes three lifetime bioassays in rats, several reproductive/developmental studies in rats and rabbits, several subchronic studies in rats and mice, and immunotoxicity assays in rats and mice.

Although the database is adequate for reference value derivation, some uncertainty associated with the database remains, such as the lack of chronic studies in a species other than rats (e.g., mice), the lack of developmental/reproductive inhalation studies, and limited or no information available regarding effects in humans or animals with deficient ALDH2 activity.

The toxicokinetic and toxicodynamic differences for ETBE between the animal species from which the POD was derived and humans are unknown. Although sufficient information is available to develop a PBPK model in rats to evaluate differences across routes of exposure, the ETBE database lacks an adequate model that would inform potential interspecies differences. Generally, male rats appear more susceptible than females to ETBE toxicity. The underlying mechanistic basis of this apparent difference, however, is not understood (except in the case of kidney effects in males which are likely exacerbated by alpha 2u-globulin nephropathy). Most importantly, it is unknown which animal species and sexes are more comparable to humans.

Overall, the ETBE data are insufficient to conclude that the alpha 2u-globulin process is operative; however, key noncancer effects related to alpha 2u-globulin (including exacerbation of CPN in male rats) were observed and considered not appropriate for hazard identification and, therefore, not suitable for dose-response consideration. Instead, candidate values in female rats were prioritized to avoid confounding by alpha 2u-globulin processes. Only one subchronic study is available in mice, which are not affected by alpha 2u-globulin. This study seemed to indicate male mice were more sensitive to kidney-weight changes than female mice, although these changes did not reach statistical significance (Medinsky et al., 1999; Bond et al., 1996). Therefore, there is uncertainty regarding whether other factors (unrelated to alpha 2u-globulin) may increase the susceptibility of male rats to ETBE-related kidney effects.

## 2.3 ORAL SLOPE FACTOR FOR CANCER

The oral slope factor (OSF) is a plausible upper bound on the estimate of risk per mg/kg-day of oral exposure. The OSF can be multiplied by an estimate of lifetime exposure (in mg/kg-day) to estimate the lifetime cancer risk.

As noted in Section 1.3.2, EPA concluded that there is inadequate information to assess carcinogenic potential for oral exposure to ETBE because the two available chronic oral bioassays for ETBE were negative in rats (Suzuki et al., 2012; JPEC, 2010a; Maltoni et al., 1999) and because no chronic oral bioassays are available in mice. Furthermore, PBPK analysis indicated the absence of a consistent dose-response relationship for liver tumors when compared across oral and inhalation exposures; therefore, a route-to-route extrapolation was not performed, and no oral slope factor is derived.

## 2.4 INHALATION UNIT RISK FOR CANCER

The carcinogenicity assessment provides information on the carcinogenic hazard potential of the substance in question, and quantitative estimates of risk from inhalation exposure can be derived by applying a low-dose extrapolation procedure. If derived, the inhalation unit risk is a plausible upper bound on the estimate of risk per μg/m^3^ air breathed.

### 2.4.1 Analysis of Carcinogenicity Data

As noted in Section 1.3.2, there is suggestive evidence of carcinogenic potential for inhalation exposure to ETBE. The Guidelines for Carcinogen Risk Assessment (U.S. EPA, 2005a) state:

When there is suggestive evidence, the Agency generally would not attempt a dose-response assessment, as the nature of the data generally would not support one; however, when the evidence includes a well-conducted study, quantitative analysis may be useful for some purposes, for example, providing a sense of the magnitude and uncertainty of potential risks, ranking potential hazards, or setting research priorities. In each case, the rationale for the quantitative analysis is explained, considering the uncertainty in the data and the suggestive nature of the weight of evidence. These analyses generally would not be considered Agency consensus estimates.

In the case of ETBE, an inhalation unit risk is derived. A description of the carcinogenicity data is presented in the discussions of biological considerations for cancer dose-response analysis (see Section 1.3.2). Briefly, a well-conducted study demonstrated a significant, positive exposure-response for hepatocellular adenomas and carcinomas in male rats. While the majority of liver tumors occurred at the high dose, statistical tests conducted by the study authors found a significant dose-response trend using both the Peto test (incidental tumor test) and the Cochran-Armitage test. The available data do not demonstrate that the liver tumors are the result of an excessively high dose (e.g., overt toxicity or altered toxicokinetics) in male rats rather than the carcinogenicity of ETBE (see discussion in Section 1.2.2). Although decreased body weight gain and survival was noted in the high dose males and females, the study authors did not detect changes to the animals’ general condition (e.g. abnormal behavior or clinical signs) associated with ETBE. In addition, the study provided no indication that altered to toxicokinetics was responsible for the significantly increased incidence of liver tumors in male rats. Considering these data, along with the uncertainty associated with the suggestive weight of evidence, quantitative analysis of the tumor data may be useful for providing a sense of the magnitude of potential carcinogenic risk (e.g., including workers and consumers). Therefore, the hepatocellular adenomas and carcinomas in male rats were considered for dose-response modeling and calculation of a quantitative risk estimate. Because of the suggestive nature of the tumorigenic response (U.S. EPA, 2005a), there is increased uncertainty in this risk estimate, and this is noted below where relevant.

### 2.4.2 Dose-Response Analysis―Adjustments and Extrapolation Methods

The EPA Guidelines for Carcinogen Risk Assessment (U.S. EPA, 2005a) recommends that the method used to characterize and quantify a chemical’s cancer risk be determined by what is known about its mode of action (MOA) and the shape of its dose-response curve. EPA uses a two-step approach that distinguishes analysis of the observed dose-response data from inferences about lower doses (U.S. EPA, 2005a). Within the observed range, the preferred approach is to use biologically based modeling to incorporate a wide range of data into the analysis, if supported by substantial data. Without a biologically based model, as in the case of ETBE, a standard model is used to curve-fit the data and to estimate a POD. EPA uses the multistage model in IRIS dose-response analyses for cancer (Gehlhaus et al., 2011) because it parallels the multistage carcinogenic process and fits a broad array of dose-response patterns.

The second step, extrapolation to lower exposures from the POD, considers what is known about the modes of action for each effect. As above, a biologically based model is preferred (U.S. EPA, 2005a). Otherwise, linear low-dose extrapolation is recommended if the MOA of carcinogenicity is mutagenic or has not been established (U.S. EPA, 2005a). For ETBE, the mode(s) of carcinogenic action for liver tumors has not been established (see Section 1.3.2). Therefore, linear low-dose extrapolation was used to estimate human carcinogenic risk.

Details of the modeling and the model selection process can be found in Appendix C of the Supplemental Information. A POD for estimating low-dose risk was identified at the lower end of the observed data, corresponding to 10% extra risk.

Because the inhalation unit risk is applicable to a continuous lifetime human exposure but derived from animal studies featuring intermittent exposure, EPA guidance (U.S. EPA, 1994) provides mechanisms for (1) adjusting experimental exposure concentrations to a value reflecting continuous exposure duration and (2) determining a HEC from the animal exposure data. The former uses an inverse concentration-time relationship to derive a health-protective duration adjustment to time weight the intermittent exposures used in the study. The animal BMCL (see Table 2-7) estimated from the inhalation study (Saito et al., 2013; JPEC, 2010b) was adjusted to reflect continuous exposure by multiplying it by (6 hours/day) ÷ (24 hours/day) and (5 days/week) ÷ (7 days/week) as follows:

BMCL_ADJ_ = BMCL ( mg / m^3^ ) × ( 6 ÷ 24 ) × ( 5 ÷ 7 ) = 7,118 mg/m^3^ × 0.25 × 0.71 = 1,271 mg/m^3^ (2-5)

The approach to determine the HEC accounts for the extrarespiratory nature of the toxicological responses and accommodates species differences by considering blood:air partition coefficients for ETBE in the laboratory animal (rat) and humans. According to the RfC guidelines (U.S. EPA, 1994), ETBE is a Category 3 gas because extrarespiratory effects were observed. The values reported in the literature for these parameters include a blood:air partition coefficient for rats (L_A_) of 11.6 (Kaneko et al., 2000) and a blood:air partition coefficient for humans (L_H_) of 11.7 (Nihlén et al., 1995). This allowed a BMCL_HEC_ to be derived as follows:

BMCL_HEC_ = BMCL_ADJ_ ( mg/m^3^ ) × ( L_A_ ÷ L_H_ ) ( interspecies conversion ) = BMCL_ADJ_ ( mg/m^3^ ) × ( 11.6 ÷ 11.7 ) = BMCL_ADJ_ ( mg/m^3^ ) × ( 0.992 ) = 1,271 mg/m^3^ × ( 0.992 ) = 1,261 mg/m^3^ (2-6)

Table 2-7 Summary of the inhalation unit risk derivation

Tumor | Species/sex | Selected model | BMR | BMC_ADJ_ (mg/m^3^) | POD = BMCL_ADJ_ (mg/m^3^) | BMCL_HEC_ (mg/m^3^) | Slope factor^a,b^ (mg/m3)−1
Hepatocellular adenomas or carcinomas; Saito et al. (2013); JPEC (2010b) | F344 rat/M | Multistage (1 degree) | 10% | 1,944 | 1,271 | 1,261 | 8 × 10^−5^

M = male.

a Human equivalent slope factor = 0.1/BMCL_10HEC_; see Appendix C of the Supplemental Information for details of the modeling results.

b This value is uncertain because it is based on a determination of suggestive evidence of carcinogenic potential.

The uncertainties in the data leading to this suggestive weight of evidence determination for carcinogenicity are detailed in Sections 1.3.2, 2.4.1, and 2.4.4.

### 2.4.3 Inhalation Unit Risk Derivation

The POD estimate based on the male rat liver tumor data (Saito et al., 2013; JPEC, 2010b) is summarized in Table 2-7. The lifetime inhalation unit risk for humans is defined as the slope of the line from the lower 95% bound on the exposure at the POD to the control response (inhalation unit risk = 0.1 ÷ BMCL_10_). This slope represents a plausible upper bound on the true risk. Using linear extrapolation from the BMCL_10_, a human-equivalent inhalation unit risk was derived as presented in Table 2-7.

A single inhalation unit risk was derived. Therefore, the recommended inhalation unit risk for providing a sense of the magnitude of potential carcinogenic risk associated with lifetime inhalation exposure to ETBE is 8 × 10^−5^ per mg/m^3^, based on the liver tumor response in male F344 rats (Saito et al., 2013; JPEC, 2010b). This value is uncertain because it is based on a determination of suggestive evidence of carcinogenic potential; however, the IUR may be useful for some decision purposes such as providing a sense of the magnitude of potential risks or ranking potential hazards (U.S. EPA, 2005a). This unit risk should not be used with continuous exposures exceeding 1,271 mg/m^3^ (the POD) because above this level the dose-response relationship is nonlinear. If risk estimates are needed for exposure corresponding to expected overall cancer risks greater than 10%, the full dose-response model should be consulted. The slope of the linear extrapolation from the central estimate^1^ BMC_10_ is (0.1 ÷ 0.992 × [1,944 mg/kg-day]) = 5 × 10^−5^ per mg/m^3^.

### 2.4.4 Uncertainties in the Derivation of the Inhalation Unit Risk

There is uncertainty when extrapolating data from animals to estimate potential cancer risks to human populations from exposure to ETBE. Table 2-8 summarizes several uncertainties that could affect the inhalation unit risk. Although the chronic studies did not report an increase in liver tumorigenesis following oral exposure in rats, no other inhalation studies are available to replicate these findings and none examined other animal models (e.g. mice). In addition, no data in humans are available to confirm a general cancer response or the specific tumors observed in the rat bioassay (Saito et al., 2013; JPEC, 2010b). An MOA for liver carcinogenicity could not be established; therefore, in the absence of data to indicate otherwise, rat liver tumors were considered relevant to humans (U.S. EPA, 2005a). Although changing the methods used to derive the inhalation unit risk could change the results, standard practices were used due to the lack of a human PBPK model, and no other data supported alternative derivation approaches.

Table 2-8 Summary of uncertainties in the derivation of the inhalation unit risk for ETBE

Consideration and impact on cancer risk value | Decision | Justification and discussion
Selection of tumor type and relevance to humans:; Rat liver tumors are the basis for estimating human cancer risk. | The liver was selected as the target organ (U.S. EPA, 2005a). | An MOA for liver carcinogenicity could not be established; in absence of data to indicate otherwise, rat liver tumors were considered relevant to humans (U.S. EPA, 2005a).
Selection of data set:; No other studies are available. | Saito et al. (2013), JPEC (2010b) was selected to derive cancer risks for humans. | Saito et al. (2013) and JPEC (2010b) was a well-conducted inhalation study which reported a positive exposure-response trend for liver tumors in male rats. Additional bioassays might add support to the findings or provide results for different (possibly lower) concentrations.
Selection of dose metric:; Alternative could ↑ inhalation unit risk. | Administered concentration was used. | Modeling based on the PBPK-derived internal dose metric of ETBE metabolism decreased the BMCL by 35%. However, PBPK modeling was not used for the dose-response because there was no human model.
Interspecies extrapolation of dosimetry and risk:; Alternatives could ↓ or ↑ inhalation unit risk. | The default approach for a Category 3 gas was used. | No data suggest an alternative approach. Although the true human correspondence is unknown, this overall approach is expected to neither overestimate nor underestimate human equivalent risks.
Dose-response modeling:; Alternatives could ↓ or ↑ slope factor. | Used multistage dose-response model to derive a BMC and BMCL | No biologically based models for ETBE were available. The multistage model has biological support and is the model most consistently used in EPA cancer assessments.
Low-dose extrapolation:; ↓ cancer risk estimate would be expected with the application of nonlinear low-dose extrapolation. | Linear extrapolation of risk in low-dose region was used. | Linear low-dose extrapolation for agents without a known MOA is supported (U.S. EPA, 2005a).
Statistical uncertainty at POD:; ↓ inhalation unit risk 1.4-fold if BMC used as the POD rather than BMCL. | BMCL (preferred approach for calculating slope factor) was used. | Limited size of bioassay results in sampling variability; lower bound is 95% CI on administered exposure at 10% extra risk of liver tumors.
Sensitive subpopulations:; ↑ inhalation unit risk to unknown extent. | Individuals deficient in ALDH2 are potentially more sensitive. | Experiments showed enhanced liver toxicity and genotoxicity in mice when ALDH2 was absent. Human subpopulations deficient in ALDH2 are known to be at enhanced risk of ethanol-induced cancer mediated by acetaldehyde, as discussed in Section 1.3.3. No chemical-specific data are available, however, to determine the extent of enhanced sensitivity due to ETBE-induced carcinogenicity. Beyond ALDH deficiency, no chemical-specific data are available to determine the range of human toxicodynamic variability or sensitivity, including the susceptibility of children. Because determination of a mutagenic MOA has not been made, an age-specific adjustment factor is not applied.

### 2.4.5 Previous IRIS Assessment

No previous cancer assessment for ETBE is available in IRIS.

## 2.5 APPLICATION OF AGE-DEPENDENT ADJUSTMENT FACTORS

As discussed in the Supplemental Guidance for Assessing Susceptibility from Early-Life Exposure to Carcinogens (U.S. EPA, 2005b), either default or chemical-specific age-dependent adjustment factors (ADAFs) are recommended to account for early-life exposure to carcinogens that act through a mutagenic MOA. Because chemical-specific lifestage susceptibility data for cancer are not available, and because the MOA for ETBE carcinogenicity is not known (see Section 1.3.2), application of ADAFs is not recommended.

1 The Cancer Guidelines (U.S. EPA, 2005a) recommend that the Agency calculate and present the central estimate as well as the corresponding 95% statistical bounds on the POD. The central estimate may be useful in activities that involve formal uncertainty analysis that are required by OMB, as well as in ranking agents as to their carcinogenic hazard.