# 1 HAZARD IDENTIFICATION

## 1.1 OVERVIEW OF CHEMICAL PROPERTIES AND TOXICOKINETICS

### 1.1.1 Chemical Properties

Ethyl tertiary butyl ether (ETBE) is a liquid at a temperature range of −94 to 72.6°C. It is soluble in ethanol, ethyl ether, and water (Drogos and Diaz, 2001). ETBE has a strong, highly objectionable odor and taste at relatively low concentrations. The chemical is highly flammable and reacts with strong oxidizing agents. ETBE is stable when stored at room temperature in tightly closed containers (Drogos and Diaz, 2001). Information on the physiochemical properties for ETBE is available at U.S. Environmental Protection Agency (EPA)’s CompTox Chemicals Dashboard (https://comptox.epa.gov/dashboard/) and is summarized in Table 1-1.

### 1.1.2 Toxicokinetics

ETBE is rapidly absorbed following exposure through oral and inhalation routes (see Appendix Section B.1.1). Studies in experimental animals indicate that >90% of the compound is absorbed after oral administration within 6−10 hours (JPEC, 2008d, e). No data are available for oral absorption in humans. ETBE is moderately absorbed following inhalation exposure in both rats and humans; human blood levels of ETBE approached―but did not reach―steady-state concentrations within 2 hours, and a net respiratory uptake of ETBE was estimated to be 26% in a short-term exposure study in humans conducted during light physical activity (Nihlén et al., 1998b).

ETBE and its metabolite, tert-butanol, are distributed throughout the body following oral, inhalation, and intravenous (i.v.) exposures (JPEC, 2008d, e; Poet et al., 1997; Faulkner et al., 1989; ARCO, 1983). Following exposure to ETBE in rats, ETBE was found in the kidney, liver, and blood. Comparison of the ETBE distribution in rats and mice demonstrated that concentrations of ETBE in the rat kidney and mouse liver are proportional to the blood concentration.

Table 1-1 Chemical identity and physicochemical properties of ETBE from EPA’s CompTox Chemicals Dashboard

Characteristic or property | Value
Chemical structure | chemical structure
CASRN | 637-92-3
Synonyms | Ethyl t-butyl ether; 2-ethoxy-2-methylpropane; propane, 2-ethoxy-2-methyl; Ethyl tert-butyl ether; 2-Methyl-2-ethoxypropane; (see https://comptox.epa.gov/dashboard for additional synonyms)
Molecular formula | C_6_H_14_O
Molecular weight (g/mol) | 102.177
| Average experimental value^a^ | Average predicted value^a^
Flash point (°C) | ― | −10.9
Boiling point (°C) | 72.4 | 74.3
Melting point (°C) | −94 | −90.8
Log K_OW_ | ― | 1.72
Density (g/cm^3^) | ― | 0.768
Henry’s law constant (atm-m^3^/mole) | 1.64 × 10^−3^ | 1.66 × 10^−3^
Vapor pressure (mm Hg at 20°C) | 124 | 124

atm = atmosphere; CASRN = Chemical Abstracts Service registry number.

a Median values and ranges for physicochemical properties of ETBE are also provided on the CompTox Chemicals Dashboard at https://comptox.epa.gov/dashboard/.

A general metabolic scheme for ETBE, illustrating the biotransformation in rats and humans, is shown in Figure 1-1 (see Appendix Section B.1.3).

Human data on the excretion of ETBE was measured in several studies (Amberg et al., 2000; Nihlén et al., 1998a, c). The half-life of ETBE in urine was biphasic with half-lives of 8 minutes and 8.6 hours (Johanson et al., 1995). These studies showed urinary excretion of ETBE to be less than 0.2% of the uptake or absorption of ETBE (Nihlén et al., 1998a, c). Amberg et al. (2000) observed a similar half-life of 1−6 hours after human exposure to ETBE of 170 mg/m^3^; however, the elimination of ETBE in rats was considerably faster than in humans, and only the metabolites of ETBE were detectable in rat urine, not the parent compound itself. No studies were identified which investigated lactational transfer of ETBE in humans or animal models.

A more detailed summary of ETBE toxicokinetics is provided in Appendix Section B.1.

Figure 1-1 Proposed metabolism of ETBE

CYP450 = cytochrome P450.

Source: Adapted from Dekant et al. (2001), NSF International (2003), ATSDR (1996), Bernauer et al. (1998), Amberg et al. (1999), and Cederbaum and Cohen (1980).

### 1.1.3 Description of Toxicokinetic Models

Two physiologically based pharmacokinetic (PBPK) models have been developed specifically for predicting the adsorption, distribution, metabolism and excretion of ETBE in rats (Borghoff et al., 2016; Salazar et al., 2015). The previously available models have studied tert-butanol as the primary metabolite after oral or inhalation exposure to methyl tertiary butyl ether (MTBE) in rats and humans or ETBE in humans. Models for MTBE oral and inhalation exposure include a component for the binding of tert-butanol to alpha 2u-globulin (Borghoff et al., 2010; Leavens and Borghoff, 2009). A PBPK model for inhalation exposure of humans to ETBE has also been reported (Nihlén and Johanson, 1999).

All available PBPK models of ETBE and its principal metabolite tert-butanol were evaluated for potential use in this assessment (for extrapolation from animals to humans and for extrapolation between routes of exposure). Regarding the extrapolation from animals to humans, the existing human PBPK model was not considered adequate (see Appendix Section B.1.7); therefore, default methodologies were applied to extrapolate toxicologically equivalent exposures from adult laboratory animals to adult humans. Regarding the extrapolation between routes of exposure, extrapolation from inhalation to oral routes of exposure was not supported due to the lack of a consistent dose-response relationship for liver tumors combined across oral and inhalation studies.

A detailed summary of the toxicokinetic models is provided in Appendix Section B.1.5 (U.S. EPA, 2017).

### 1.1.4 Related Chemicals That Provide Supporting Information

ETBE is metabolized to acetaldehyde and tert-butanol, and the effects induced by these metabolites can inform the evaluation of ETBE-induced effects. Some of the noncancer kidney effects observed in ETBE have been attributed to tert-butanol (Salazar et al., 2015). Animal studies demonstrate that chronic exposure to tert-butanol is associated with noncancer kidney effects, including increased kidney weights in male and female rats accompanied by increased chronic progressive nephropathy (CPN), urothelial hyperplasia/transitional epithelial hyperplasia (in males and females), and increased suppurative inflammation in females (NTP, 1997, 1995).

Inhalation exposures to acetaldehyde have been determined to cause carcinomas of the nasal mucosa in rats and carcinomas of the larynx in hamsters (IARC, 1999b). In addition, acetaldehyde is known to be the key metabolite in the development of cancer of the esophagus and aerodigestive tract associated with ethanol consumption (IARC, 2010).

MTBE is a compound structurally related to ETBE that is metabolized to formaldehyde and tert-butanol. In 1996, the U.S. Agency for Toxic Substances and Disease Registry’s (ATSDR) Toxicological Profile for MTBE (ATSDR, 1996) identified cancer effect levels of MTBE based on carcinogenicity data in animals. ATSDR reported that inhalation exposure resulted in kidney cancer in rats and liver cancer in mice. ATSDR concluded that oral exposure to MTBE might cause liver and kidney damage and nervous system effects in rats and mice. The chronic inhalation minimal risk level was derived based on incidence and severity of chronic progressive nephropathy in female rats (ATSDR, 1996). In 1998, the International Agency for Research on Cancer (IARC) found “limited” evidence of MTBE carcinogenicity in animals and classified MTBE in Group 3 [i.e., not classifiable as to carcinogenicity in humans; IARC (1999c)]. Although some similar effects are seen with tert-butanol and ETBE, the evidence from MTBE is confounded by its metabolite formaldehyde, a known human carcinogen (as classified by IARC and National Toxicology Program [NTP]).

## 1.2 PRESENTATION AND SYNTHESIS OF EVIDENCE BY ORGAN/SYSTEM

### 1.2.1 Kidney Effects

#### Synthesis of Effects in the Kidney

This section reviews the studies that investigated whether subchronic or chronic exposure to ETBE can cause kidney toxicity in humans or animals. The evidence base examining kidney effects following ETBE exposure contains no human data and 10 animal studies, predominantly in rats. Exposures ranged from 13 weeks to 2 years and both inhalation and oral exposure routes are well represented. Studies using short-term and acute exposures that examined kidney effects are not included in the evidence tables; however, they are discussed in the text if they provided data to inform mode of action (MOA) or hazard identification. Four unpublished technical reports relevant to the kidney were externally peer reviewed at the request of EPA in August 2012 (see Table LS-5): JPEC (2010a), JPEC (2010b), JPEC (2008c), JPEC (2008b), some of which were subsequently published. These are JPEC (2010a) [published as Suzuki et al. (2012)], JPEC (2010b) [published as Saito et al. (2013)], and JPEC (2008c) [published as Miyata et al. (2013)]. Gaoua (2004b) was externally peer reviewed at the request of EPA in November 2008. Studies are arranged in evidence tables by effect and alphabetical order by author.

In an unpublished analysis by Cohen et al. (2011), a pathology working group reexamined kidney histopathology from the JPEC (2010a) and JPEC (2007a) studies. Cohen et al. (2011) reported slightly different incidences and severity of CPN, but incidences of carcinomas did not differ from the original study (Suzuki et al., 2012; JPEC, 2010a). Histopathological interpretations from both Cohen et al. (2011) and JPEC (2007b) are considered for hazard identification and are presented in Table 1-2.

The design, conduct, and reporting of each study were reviewed, and each study was considered adequate to provide information pertinent to this assessment. Interpretation of non-neoplastic kidney endpoints in rats, however, is complicated by the common occurrence of age-related spontaneous lesions characteristic of CPN [NTP (2015); Hard et al. (2013); Melnick et al. (2012); U.S. EPA (1991a); http://ntp.niehs.nih.gov/nnl/urinary/kidney/necp/index.htm]. CPN is more severe in male rats than in females and is particularly common in the Sprague-Dawley (S-D) and Fischer 344 (F344) strains. Dietary and hormonal factors play a role in modifying CPN, although the etiology is unknown (see further discussion below).

Kidney weight. Increases in kidney weight serve as a general indication of renal toxicity. Kidney weights (see Figure 1-2) exhibited strong dose-related increases with estimates of the primary ETBE metabolite, tert-butanol, in blood in male rats following oral exposures (Spearman’s rank coefficient [rho] = 0.86, p < 0.01) of 16 weeks or longer (Miyata et al., 2013; Suzuki et al., 2012; Fujii et al., 2010; JPEC, 2010a, 2008c; Gaoua, 2004b), and following inhalation exposures (rho = 0.71, p = 0.05) of 13 weeks or longer (Saito et al., 2013; JPEC, 2010b, 2008b; Medinsky et al., 1999). Kidney weight also showed strong dose-related increases following inhalation exposure (rho = 0.82, p = 0.01) and moderate dose-related increases following oral exposure (rho = 0.42, p = 0.2). Short-term inhalation studies in rats also showed increased kidney weight (JPEC, 2008a). In utero ETBE exposure induced greater increases in kidney weights in F1 male and female rats compared with parental exposure in one unpublished study (independently peer reviewed via EPA contract, see Table LS-5) but the magnitude of increases were comparable to those observed in other adult oral studies (Gaoua, 2004b). A 13-week mouse inhalation study observed small increases in kidney weight in both sexes, with a greater magnitude of effect in males, up to 10% as compared with 4−6% increases in females [see Figure 1-3 (Medinsky et al., 1999; Bond et al., 1996)].

In most of the studies with data available for relative and absolute organ weight comparisons, both relative and absolute kidney weights are increased (Miyata et al., 2013; Saito et al., 2013; Suzuki et al., 2012; JPEC, 2010b, 2008b, c; Gaoua, 2004b). For ETBE, body weight in exposed animals was consistently decreased at several doses relative to controls in the oral and inhalation studies. Thus, use of relative organ-weight change may not be a reliable measure of the kidney-weight increases for this assessment. Additionally, a recent analysis indicates that statistically significant increases in subchronic absolute, but not relative, kidney weights correlate well with chronic renal histopathology(Craig et al., 2014). Therefore, absolute weight was used as the more appropriate measure of kidney-weight change for determining ETBE hazard potential. Absolute and relative kidney-weight data are presented in Appendix B of the Supplemental Information.

Interpretation of 2-year kidney-weight data in male rats treated by inhalation is complicated by increased mortality attributed to CPN which would be expected to bias the analysis of kidney weight (toward the null) because organ weight was not assessed in animals that did not survive to study termination (Saito et al., 2013; Suzuki et al., 2012; JPEC, 2010a, b). CPN is an age-associated disease characterized by cell proliferation and chronic inflammation that results in increased kidney weight (Melnick et al., 2012; Travlos et al., 2011), thus animals severely affected by CPN, including those that died due to CPN, would be expected to have enlarged kidneys. Although mortality in female rats in the 2-year inhalation study was also significantly increased, the study authors attributed these deaths to pituitary tumors, which would not be expected to bias measurement of kidney weight (JPEC, 2010b). Mortality of male and female rats in the 2-year drinking water studies was not significantly different from controls (JPEC, 2010a).

Kidney histopathology. Kidney lesions also were observed in several studies. The incidence of nephropathy, which was characterized as CPN due to sclerosis of glomeruli, thickening of the renal tubular basement membranes, inflammatory cell infiltration, and interstitial fibrosis, was not increased in any chronic study because of ETBE exposure. However, the severity of CPN was exacerbated by ETBE in male and female rats in a 2-year inhalation study, and the number of CPN foci was increased in male rats in a 13-week drinking water study [see Table 1-2; Cohen et al. (2011); JPEC (2007a); JPEC (2010b)]. Increases in CPN graded as marked or severe were dose-related when compared on an internal dose basis across routes of exposure in male and female rats (Salazar et al., 2015).

CPN is a common and well-established constellation of age-related lesions in the kidney of rats, although the mode of action of CPN is not known. In addition, no known counterpart to CPN has been identified in the aging human kidney. However, several individual lesions noted in CPN (e.g., tubule atrophy, tubule dilation, thickening of tubular basement membranes, glomerulosclerosis) also occur in the human kidney (Lusco et al., 2016; Zoja et al., 2015; Seely and Brix, 2014a; Frazier et al., 2012; Satirapoj et al., 2012). Therefore, exacerbation of one or more of these lesions following ETBE exposure may reflect some type of cell injury or inflammatory process, which is relevant to the human kidney.

Increased incidence of urothelial hyperplasia (also known as transitional epithelial hyperplasia) of the renal pelvis (graded as slight or minimal) was observed in male rats in 2-year studies by both inhalation and oral exposure (Saito et al., 2013; Suzuki et al., 2012; JPEC, 2010a, b). However, urothelial hyperplasia was not observed in female rats following 2 years of oral or inhalation exposure (Saito et al., 2013; Suzuki et al., 2012; JPEC, 2010a, b). The histological finding of urothelial hyperplasia represents in an increase in the layers of urothelium and is typically associated with inflammation or neoplasia (Seely and Brix, 2014b; Peterson et al., 2009). The increase in urothelial hyperplasia in male rats appeared to be dose related on an internal dose basis across routes of exposure (Salazar et al., 2015). Cohen et al. (2011), however, attributed this effect to CPN rather than the “direct” result of ETBE treatment. In addition, there is some confusion regarding the terminology of “urothelial hyperplasia of the renal pelvis” as reported in the JPEC studies (JPEC, 2010a, b). Specifically, based on the pathological description of this lesion, it may represent proliferation of the papillary lining epithelium and not true “urothelial hyperplasia” (NIEHS, 2019). Hyperplasia of the epithelial lining of the renal papilla has been associated with advanced CPN (Seely and Brix, 2014a).

To determine if the severity of the hyperplasia was positively associated with the severity of CPN, contingency tables comparing the occurrence of urothelial hyperplasia with CPN in individual rats were arranged by severity and analyzed with Spearman’s rank correlation tests to determine strength of associations for each comparison (see Table 1-5, Table 1-6). Urothelial hyperplasia and severity of CPN were weakly correlated (rho = 0.36) in males following oral and inhalation exposure to ETBE. The biological significance of urothelial hyperplasia and any relationship with CPN is discussed in “Mode-of-Action Analysis” (see below).

The number and size of hyaline droplets were increased in the proximal tubules of male rats, but not in females, and the hyaline droplets tested positive for the presence of alpha 2u-globulin (Miyata et al., 2013; JPEC, 2008c, e, f; Medinsky et al., 1999). The significance of this finding, along with other potentially related histopathological effects, such as necrosis, linear tubule mineralization, and tubular hyperplasia, are discussed in “Mode-of-Action Analysis” (see below).

Serum and urinary biomarkers. The increased kidney weight and CPN in male rats is associated with several changes in urinary and serum biomarkers of renal function (see Table 1-2, Table 1-3). CPN is proposed to be associated with several changes in urinary and serum measures such as proteinuria, blood urea nitrogen (BUN), creatinine, and hypercholesterolemia (Hard et al., 2009). Chronic and subchronic studies of male rats found total cholesterol was elevated in 3 of 4 studies, BUN was elevated in 2 of 4 studies, and creatinine was elevated 1 of 4 studies (Miyata et al., 2013; Saito et al., 2013; Suzuki et al., 2012; JPEC, 2010a, b, 2008c). In F344 female rats, cholesterol and BUN were elevated at the highest dose in one chronic inhalation study; this dose corresponded with an elevated severity of CPN in females (Saito et al., 2013; JPEC, 2010b). The single reported instance of elevated proteinuria occurred in female rats following chronic inhalation exposure; thus, no correlation of elevated proteinuria with CPN in males was observed (Saito et al., 2013; JPEC, 2010b).

Kidney tumors. No increase in kidney tumor incidence was observed following chronic oral or inhalation exposure in either F344 rats (Saito et al., 2013; Suzuki et al., 2012; JPEC, 2010a, b) or S-D rats [Maltoni et al. (1999); see Table 1-4]. However, animals in the Maltoni et al. (1999) study had extremely low survival in the control and treated groups (approximately 25−30%) after 104 weeks, which is much lower than typical for a 2-year study, ultimately limiting the ability of this study to predict potential carcinogenicity (see discussion in Section 1.2.5).

In two-stage (“initiation, promotion”) cancer bioassays, 23 weeks of daily gavage ETBE exposure did not increase kidney tumor incidence following 4 weeks of treatment with a 5-mutagens mixture of diethylnitrosamine (DEN), N-methyl-N-nitrosourea (MNU), N-butyl-N-(4-hydroxybutyl)nitrosamine (BBN), 1,2-dimethylhydrazine dihydrochloride (DMH), and N-bis(2-hydroxypropyl)nitrosamine (DHPN) (DMBDD) in male F344 rats (Hagiwara et al., 2011;JPEC, 2008d); however, a moderate, but statistically significant dose-response trend in the incidence of renal tubular adenoma or carcinoma incidence was observed with 19 weeks of daily gavage ETBE exposure following 2 weeks of the mutagen (N-ethyl-N-hydroxyethylnitrosamine [EHEN]) administration in male Wistar rats (Hagiwara et al., 2015). In Hagiwara et al. (2011), kidney tumors were not observed following 23 weeks of ETBE exposure without mutagen exposure (n = 11). An ETBE-only exposure group was not evaluated in the later study in Wistar rats (Hagiwara et al., 2015).

Figure 1-2 Comparison of absolute kidney-weight change in male and female rats across oral and inhalation exposure based on metabolite internal blood concentration

Rho was calculated to evaluate the direction of a monotonic association (e.g., positive value = positive association) and the strength of association.

rho = Spearman’s rank coefficient.

Figure 1-3 Comparison of absolute kidney-weight change in male and female mice following 13-week inhalation exposure

Source: Medinsky et al. (1999); Bond et al. (1996). No significant relationships were observed

Table 1-2 Evidence pertaining to kidney histopathology effects in animals following exposure to ETBE

Reference and study design | Results
Cohen et al. (2011); Rat, F344/DuCrlCrlj; oral―drinking water; male (50/group): 0, 625, 2,500, or 10,000 ppm (0, 28, 121, or 542 mg/kg-d);^a^ female (50/group): 0, 625, 2,500, or 10,000 ppm (0, 46, 171, or 560 mg/kg-d)^a^; reanalysis of histopathology data from JPEC (2010a) study, for which animals were dosed daily for 104 wk | Male | | | Female
| Dose (mg/kg-d) | Average severity of CPN | Incidence of CPN | Dose (mg/kg-d) | Average severity of CPN | Incidence of CPN
| 0 | 2.08 | 49/50 | 0 | 1.14 | 45/50
| 28 | - | - | 46 | 0.98 | 41/50
| 121 | - | - | 171 | 1.2 | 46/50
| 542 | 2.72^b^ | 50/50 | 560 | 1.36 | 46/50
Cohen et al. (2011); Rat, F344/DuCrlCrlj; oral―drinking water; male (10/group): 0, 250, 1,600, 4,000, or 10,000 ppm (0, 17, 40, 101, 259, or 626 mg/kg-d)^a^; reanalysis of histopathology data from JPEC (2007a) (study No. 0665) study, for which animals were dosed daily for 13 wk | Male
| Dose (mg/kg-d) | | Number of CPN foci/rat | | Number of granular casts/rat
| 0 | | 1.2 | | 0
| 17 | | - | | -
| 40 | | - | | -
| 101 | | - | | -
| 259 | | - | | -
| 626 | | 27.2 | | 8.2
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for 180 d | Male | | | Female
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for 180 d | Dose (mg/kg-d) | Incidence of papillary mineralization | | Dose (mg/kg-d) | Incidence of papillary mineralization
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for 180 d | 0 | 0/15 | | 0 | 0/15
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for 180 d | 5 | 0/15 | | 5 | -
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for 180 d | 25 | 0/15 | | 25 | -
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for 180 d | 100 | 1/15 | | 100 | -
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for 180 d | 400 | 0/15 | | 400 | 0/15
Saito et al. (2013); JPEC (2010b); Rat, F344; inhalation―vapor; male (50/group): 0, 500, 1,500, or 5,000 ppm (0, 2,090, 6,270, or 20,900 mg/m^3^);^c^ female (50/group): 0, 500, 1,500, or 5,000 ppm (0, 2,090, 6,270, or 20,900 mg/m^3^)^c^; dynamic whole-body inhalation; 6 h/d, 5 d/wk for 104 wk; generation method, analytical concentration reported | Male
| Dose (mg/m^3^) | Average severity of CPN as calculated by EPA^d^ | Incidence of CPN | | Incidence of papillary mineralization | Incidence of urothelial hyperplasia of the renal pelvis
| 0 | 2.4 | 49/50 | | 0/50 | 2/50
| 2,090 | 2.6 | 50/50 | | 0/50 | 5/50
| 6,270 | 2.7 | 49/49 | | 1/49 | 16/49^b^
| 20,900 | 3.1^b^ | 50/50 | | 6/50^b^ | 41/50^b^
| Female
| Dose (mg/m^3^) | | Average severity of CPN as calculated by EPA^d^ | | Incidence of CPN
| 0 | | 2.4 | | 49/50
| 2,090 | | 2.6 | | 50/50
| 6,270 | | 2.7 | | 49/49
| 20,900 | | 3.1^b^ | | 50/50
| Atypical tubule hyperplasia not observed in males or females.; Papillary mineralization and urothelial hyperplasia of the renal pelvis not observed in females.
Suzuki et al. (2012); JPEC (2010a); Rat, F344; oral―water; male (50/group): 0, 625, 2,500, or 10,000 ppm (0, 28, 121, or 542 mg/kg-d);^a^ female (50/group): 0, 625, 2,500, or 10,000 ppm (0, 46, 171, or 560 mg/kg-d)^a^; daily for 104 wk | Male
| Dose (mg/kg-d) | Average severity of CPN | Average severity of CPN as calculated by EPA^d^ | | Incidence of atypical tubule hyperplasia | Incidence of CPN
| 0 | 2.1 | 2.1 | | 0/50 | 49/50
| 28 | 2.0 | 1.7 | | 0/50 | 43/50
| 121 | 2.0 | 1.8 | | 0/50 | 45/50
| 542 | 2.4^b^ | 2.3 | | 1/50 | 48/50
| Dose (mg/kg-d) | Incidence of papillary necrosis | Incidence of papillary mineralization | | Incidence of urothelial hyperplasia of the renal pelvis
| 0 | 0/50 | 0/50 | | 0/50
| 28 | 1/50 | 0/50 | | 0/50
| 121 | 0/50 | 16/50^b^ | | 10/50^b^
| 542 | 2/50 | 42/50^b^ | | 25/50^b^
| Female
| Dose (mg/kg-d) | Average severity of CPN | Average severity of CPN as calculated by EPA^d^ | | Incidence of atypical tubule hyperplasia | Incidence of CPN
| 0 | 1.2 | 1.0 | | 0/50 | 41/50
| 46 | 1.2 | 0.9 | | 0/50 | 37/50
| 171 | 1.5 | 1.1 | | 0/50 | 37/50
| 560 | 1.5^b^ | 1.2 | | 2/50 | 39/50
| Dose (mg/kg-d) | Incidence of papillary necrosis | Incidence of papillary mineralization | | Incidence of urothelial hyperplasia of the renal pelvis
| 0 | 0/50 | 0/50 | | 0/50
| 46 | 1/50 | 0/50 | | 0/50
| 171 | 1/50 | 1/50 | | 0/50
| 560 | 2/50 | 3/50 | | 0/50

a Conversion performed by the study authors.

b Result is statistically significant (p < 0.05) based on analysis of data by the study authors.

c 4.18 mg/m^3^ = 1 ppm.

d Average severity calculated as (grade × number of affected animals) ÷ total number of animals exposed.

-For controls, no response relevant; for other doses, no quantitative response reported.

Note: Percent change compared to controls calculated as 100 × [(treated value – control value) ÷ control value].

Table 1-3 Evidence pertaining to kidney biochemistry and urine effects in animals following exposure to ETBE

Reference and study design | Results
JPEC (2008b); Rat, Crl:CD(SD); inhalation―vapor; male (10/group): 0, 150, 500, 1,500, or 5,000 ppm (0, 627, 2,090, 6,270, or 20,900 mg/m^3^);^a^ female (10/group): 0, 150, 500, 1,500, or 5,000 ppm (0, 627, 2,090, 6,270, or 20,900 mg/m^3^)^a^; dynamic whole-body chamber; 6 h/d, 5 d/wk for 13 wk; generation method, analytical concentration, and method reported | Male
| Dose (mg/m^3^) | BUN (%) | | Cholesterol (%) | | Creatinine (%)
| 0 | - | | - | | -
| 627 | −9 | | 8 | | −13
| 2,090 | −5 | | 9 | | −6
| 6,270 | 4 | | 26 | | −
| 20,900 | 4 | | 15 | | −3
| Dose (mg/m^3^) | Proteinuria severity^b^ | | Proteinuria incidence | | Urinary casts
| 0 | 0.5 | | 3/6 | | 0/6
| 627 | 1.2 | | 5/6 | | 0/6
| 2,090 | 1.2 | | 5/6 | | 0/6
| 6,270 | 1.3 | | 6/6 | | 0/6
| 20,900 | 1.0 | | 4/6 | | 0/6
| Female
| Dose (mg/m^3^) | BUN (%) | | Cholesterol (%) | | Creatinine (%)
| 0 | - | | - | | -
| 627 | −5 | | 7 | | 0
| 2,090 | 3 | | 9 | | 3
| 6,270 | −8 | | 11 | | −9
| 20,900 | −4 | | 21 | | −9
| Dose (mg/m^3^) | Proteinuria severity^b^ | | Proteinuria incidence | | Urinary casts
| 0 | 0.2 | | 1/6 | | 0/6
| 627 | 0.3 | | 1/6 | | 0/6
| 2,090 | 0.2 | | 1/6 | | 0/6
| 6,270 | 0.5 | | 2/6 | | 0/6
| 20,900 | 0.3 | | 2/6 | | 0/6
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for approximately 26 wk | Male
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for approximately 26 wk | Dose (mg/kg-d) | BUN (%) | | Cholesterol (%) | | Creatinine (%)
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for approximately 26 wk | 0 | - | | - | | -
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for approximately 26 wk | 5 | 12 | | − | | 0
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for approximately 26 wk | 25 | 1 | | 21 | | −10
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for approximately 26 wk | 100 | 4 | | 12 | | −3
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for approximately 26 wk | 400 | 8 | | 53^c^ | | 0
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for approximately 26 wk | Dose (mg/kg-d) | Proteinuria incidence | | Proteinuria severity^b^ | | Urinary casts
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for approximately 26 wk | 0 | 10/10 | | 1.5 | | 0/10
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for approximately 26 wk | 5 | 10/10 | | 1.6 | | -
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for approximately 26 wk | 25 | 10/10 | | 1.6 | | -
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for approximately 26 wk | 100 | 10/10 | | 1.3 | | -
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for approximately 26 wk | 400 | 10/10 | | 1.5 | | 0/10
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for approximately 26 wk | Female
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for approximately 26 wk | Dose (mg/kg-d) | BUN (%) | | Cholesterol (%) | | Creatinine (%)
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for approximately 26 wk | 0 | - | | - | | -
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for approximately 26 wk | 5 | −5 | | −7 | | −19
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for approximately 26 wk | 25 | −7 | | −7 | | −12
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for approximately 26 wk | 100 | −1 | | −2 | | −16
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for approximately 26 wk | 400 | 4 | | 3 | | −16
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for approximately 26 wk | Dose (mg/kg-d) | Proteinuria incidence | | Proteinuria severity^b^ | | Urinary casts
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for approximately 26 wk | 0 | 8/10 | | 1.2 | | 0/10
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for approximately 26 wk | 5 | 9/10 | | 1.3 | | -
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for approximately 26 wk | 25 | 7/10 | | 1.0 | | -
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for approximately 26 wk | 100 | 9/10 | | 1.3 | | -
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for approximately 26 wk | 400 | 7/10 | | 1.0 | | 0/10
Saito et al. (2013); JPEC (2010b); Rat, F344; inhalation―vapor; male (50/group): 0, 500, 1,500, or 5,000 ppm (0, 2,090, 6,270, or 20,900 mg/m^3^);^a^ female (50/group): 0, 500, 1,500, or 5,000 ppm (0, 2,090, 6,270, or 20,900 mg/m^3^)^a^; dynamic whole-body inhalation; 6 h/d, 5 d/wk for 104 wk; generation method, analytical concentration, and method reported | Response relative to control:
| Male
| Dose (mg/m^3^) | BUN (%) | Cholesterol (%) | Creatinine (%) | Proteinuria incidence | Proteinuria severity^b^
| 0 | - | - | - | 44/44 | 3.7
| 2,090 | 41^c^ | 10 | 14 | 38/38 | 3.5
| 6,270 | 45^c^ | 29^c^ | 29^c^ | 40/40 | 3.6
| 20,900 | 179^c^ | 52^c^ | 71^c^ | 31/31 | 3.6
| Female
| Dose (mg/m^3^) | BUN (%) | Cholesterol (%) | Creatinine (%) | Proteinuria incidence | Proteinuria severity^b^
| 0 | - | - | - | 33/38 | 2.8
| 2,090 | 10 | −3 | 0 | 39/39 | 3.1
| 6,270 | 4 | −4 | 0 | 30/30 | 3.3
| 20,900 | 30^c^ | 53^c^ | 0 | 30/30 | 3.4^c^
Suzuki et al. (2012); JPEC (2010a); Rat, F344; oral―drinking water; male (50/group): 0, 625, 2,500, or 10,000 ppm (0, 28, 121, or 542 mg/kg-d);^d^ female (50/group): 0, 625, 2,500, or 10,000 ppm (0, 46, 171, or 560 mg/kg-d)^d^; daily for 104 wk | Response relative to control:
| Male
| Dose (mg/kg-d) | BUN (%) | Cholesterol (%) | Creatinine (%) | Proteinuria incidence | Proteinuria severity^b^
| 0 | - | - | - | 39/39 | 3.0
| 28 | 3 | −11 | 0 | 37/37 | 3.1
| 121 | 20^c^ | 10 | 17 | 34/34 | 3.1
| 542 | 43^c^ | 31^c^ | 17 | 35/35 | 3.1
| Female
| Dose (mg/kg-d) | BUN (%) | Cholesterol (%) | Creatinine (%) | Proteinuria incidence | Proteinuria severity^b^
| 0 | - | - | - | 37/37 | 2.8
| 46 | −8 | −2 | 0 | 37/37 | 3.0
| 171 | −5 | 12 | −17 | 38/38 | 3.0
| 560 | −5 | 8 | 0 | 38/38 | 3.1

a 4.18 mg/m^3^ = 1 ppm.

b Severity of proteinuria = [(1 × number of animals with “1+”) + (2 × number of animals with “2+”) + (3 × number of animals with “3+”) + (4 × number of animals with “4+”)] ÷ total number of animals in group.

c Result is statistically significant (p < 0.05) based on analysis of data by study authors.

d Conversion performed by study authors.

-For controls, no response relevant; for other doses, no quantitative response reported.

Note: Percent change compared to controls calculated as 100 × [(treated value – control value) ÷ control value].

Table 1-4 Evidence pertaining to kidney tumor effects in animals following exposure to ETBE

Reference and study design | Results
Saito et al. (2013); JPEC (2010b); Rat, F344; inhalation―vapor; male (50/group): 0, 500, 1,500, or 5,000 ppm (0, 2,090, 6,270, or 20,900 mg/m^3^);^a^ female (50/group): 0, 500, 1,500, or 5,000 ppm (0, 2,090, 6,270, or 20,900 mg/m^3^)^a^ | Male | | Female
| Dose (mg/m^3^) | Renal cell carcinoma | Dose (mg/m^3^) | Renal cell carcinoma
| 0 | 0/50 | 0 | 0/50
| 2,090 | 1/50 | 2,090 | 0/50
| 6,270 | 0/49 | 6,270 | 0/50
| 20,900 | 0/50 | 20,900 | 0/50
Suzuki et al. (2012); JPEC (2010a); Rat, F344; oral―drinking water; male (50/group): 0, 625, 2,500, or 10,000 ppm (0, 28, 121, or 542 mg/kg-d);^b^ female (50/group): 0, 625, 2,500, or 10,000 ppm (0, 46, 171, or 560 mg/kg-d)^c^; daily for 104 wk | Male | | Female
| Dose (mg/kg-d) | Renal cell carcinoma | Dose (mg/kg-d) | Renal cell carcinoma
| 0 | 0/50 | 0 | 0/50
| 28 | 0/50 | 46 | 0/50
| 121 | 0/50 | 171 | 0/50
| 542 | 1/50 | 560 | 1/50
Hagiwara et al. (2011); JPEC (2008d); Rat, F344; oral―gavage; male (12/group): 0 or 1,000 mg/kg-d; daily for 23 wk | Male
Hagiwara et al. (2011); JPEC (2008d); Rat, F344; oral―gavage; male (12/group): 0 or 1,000 mg/kg-d; daily for 23 wk | Dose (mg/kg-d) | | Renal transitional cell carcinoma | Renal tubular adenoma or carcinoma
Hagiwara et al. (2011); JPEC (2008d); Rat, F344; oral―gavage; male (12/group): 0 or 1,000 mg/kg-d; daily for 23 wk | 0 | | 0/12 | 0/12
Hagiwara et al. (2011); JPEC (2008d); Rat, F344; oral―gavage; male (12/group): 0 or 1,000 mg/kg-d; daily for 23 wk | 1,000 | | 0/12 | 0/12
Initiation Promotion Studies
Hagiwara et al. (2011); JPEC (2008d); Rat, F344; oral―gavage; male (30/group): 0, 300, or 1,000 mg/kg-d; daily for 23 wk following a 4-wk tumor initiation by DMBDD^d^ | Male
Hagiwara et al. (2011); JPEC (2008d); Rat, F344; oral―gavage; male (30/group): 0, 300, or 1,000 mg/kg-d; daily for 23 wk following a 4-wk tumor initiation by DMBDD^d^ | Dose (mg/kg-d) | | Renal tubular adenoma or carcinoma | Renal transitional cell carcinoma
Hagiwara et al. (2011); JPEC (2008d); Rat, F344; oral―gavage; male (30/group): 0, 300, or 1,000 mg/kg-d; daily for 23 wk following a 4-wk tumor initiation by DMBDD^d^ | 0 | | 11/30 | 1/30
Hagiwara et al. (2011); JPEC (2008d); Rat, F344; oral―gavage; male (30/group): 0, 300, or 1,000 mg/kg-d; daily for 23 wk following a 4-wk tumor initiation by DMBDD^d^ | 300 | | 6/30 | 0/30
Hagiwara et al. (2011); JPEC (2008d); Rat, F344; oral―gavage; male (30/group): 0, 300, or 1,000 mg/kg-d; daily for 23 wk following a 4-wk tumor initiation by DMBDD^d^ | 1,000 | | 13/30 | 2/30
Hagiwara et al. (2015); Rat, Wistar; oral―gavage; male (30/group): 0,100, 300, 500, or 1,000 mg/kg-d; daily for 19 wk following a 2-wk tumor initiation by; N-ethyl-N-hydroxyethylnitrosamine (EHEN) | Male
Hagiwara et al. (2015); Rat, Wistar; oral―gavage; male (30/group): 0,100, 300, 500, or 1,000 mg/kg-d; daily for 19 wk following a 2-wk tumor initiation by; N-ethyl-N-hydroxyethylnitrosamine (EHEN) | Dose (mg/kg-d) | | Renal tubular adenoma or carcinoma^c^
Hagiwara et al. (2015); Rat, Wistar; oral―gavage; male (30/group): 0,100, 300, 500, or 1,000 mg/kg-d; daily for 19 wk following a 2-wk tumor initiation by; N-ethyl-N-hydroxyethylnitrosamine (EHEN) | 0 | | 18/30
Hagiwara et al. (2015); Rat, Wistar; oral―gavage; male (30/group): 0,100, 300, 500, or 1,000 mg/kg-d; daily for 19 wk following a 2-wk tumor initiation by; N-ethyl-N-hydroxyethylnitrosamine (EHEN) | 100 | | 23/30
Hagiwara et al. (2015); Rat, Wistar; oral―gavage; male (30/group): 0,100, 300, 500, or 1,000 mg/kg-d; daily for 19 wk following a 2-wk tumor initiation by; N-ethyl-N-hydroxyethylnitrosamine (EHEN) | 300 | | 25/30
Hagiwara et al. (2015); Rat, Wistar; oral―gavage; male (30/group): 0,100, 300, 500, or 1,000 mg/kg-d; daily for 19 wk following a 2-wk tumor initiation by; N-ethyl-N-hydroxyethylnitrosamine (EHEN) | 500 | | 26/30
Hagiwara et al. (2015); Rat, Wistar; oral―gavage; male (30/group): 0,100, 300, 500, or 1,000 mg/kg-d; daily for 19 wk following a 2-wk tumor initiation by; N-ethyl-N-hydroxyethylnitrosamine (EHEN) | 1,000 | | 26/30

a 4.18 mg/m^3^ = 1 ppm.

b Conversion performed by study authors.

c Authors report significant trend.

d Diethylnitrosamine (DEN), N-butyl-N-(4-hydroxybutyl)nitrosamine (BBN), N-methyl-N-nitrosourea (MNU), 1,2-dimethylhydrazine dihydrochloride (DMH), and N-bis(2-hydroxypropyl)nitrosamine (DHPN).

Table 1-5 Comparison of nephropathy and urothelial hyperplasia in individual male rats from 2-year oral exposure (JPEC, 2010a)

Urothelial hyperplasia | CPN
Urothelial hyperplasia | None | Minimal | Mild | Moderate | Marked
None | 15 | 21 | 105 | 23 | 1
Minimal | 0 | 0 | 17 | 16 | 2
Mild | 0 | 0 | 0 | 0 | 0
Moderate | 0 | 0 | 0 | 0 | 0
Marked | 0 | 0 | 0 | 0 | 0

Spearman’s rank correlation test (1-sided), p < 0.0001, rho= 0.36.

Table 1-6 Comparison of nephropathy and urothelial hyperplasia in individual male rats from 2-year inhalation exposure (JPEC, 2010b)

Urothelial hyperplasia | CPN
Urothelial hyperplasia | None | Minimal | Mild | Moderate | Marked
None | 1 | 3 | 59 | 68 | 4
Minimal | 0 | 0 | 14 | 29 | 21
Mild | 0 | 0 | 0 | 0 | 0
Moderate | 0 | 0 | 0 | 0 | 0
Marked | 0 | 0 | 0 | 0 | 0

Spearman’s rank correlation test (1-sided), p < 0.0001, rho = 0.36.

Figure 1-4 Exposure-response array of kidney effects following oral exposure to ETBE

Figure 1-5 Exposure-response array of kidney effects following inhalation exposure to ETBE

#### Mode-of-Action Analysis—Kidney Effects

##### Toxicokinetic considerations relevant to kidney toxicity

ETBE is metabolized by cytochrome P450 (CYP450) enzymes to an unstable hemiacetal that decomposes spontaneously into tert-butanol and acetaldehyde (Bernauer et al., 1998). Acetaldehyde is further metabolized in the liver. The main circulating breakdown product of ETBE metabolism is tert-butanol, which is filtered from the blood by the kidneys and excreted in urine. Thus, following ETBE exposure, the kidney is exposed to significant concentrations of tert-butanol, and kidney effects caused by tert-butanol (described in more detail in the draft IRIS assessment of tert-butanol) also are relevant to evaluating the kidney effects observed after ETBE exposure. In particular, tert-butanol, like ETBE, has been reported to cause nephrotoxicity in rats, including effects associated with alpha 2u-globulin nephropathy (https://cfpub.epa.gov/ncea/iris_drafts/recordisplay.cfm?deid=262086). Unlike ETBE, however, increased renal tumors, in the absence of an initiator, were reported following chronic drinking water exposure to tert-butanol.

##### Alpha 2u-globulin-associated renal tubule nephropathy

One disease process to consider when interpreting kidney effects in rats is related to the accumulation of alpha 2u-globulin protein. Alpha 2u-globulin, a member of a large superfamily of low-molecular-weight proteins, was first characterized in male rat urine. Such proteins have been detected in various tissues and fluids of most mammals (including humans), but the particular isoform of alpha 2u-globulin commonly detected in male rat urine and associated with renal tubule nephropathy is considered specific to that sex and species. Exposure to chemicals that induce alpha 2u-globulin accumulation can initiate a sequence of histopathological events leading to kidney tumorigenesis. Because alpha 2u-globulin-related renal tubule nephropathy and carcinogenicity occurring in male rats are presumed not relevant for assessing human health hazards (U.S. EPA, 1991a), evaluating the data to determine whether alpha 2u-globulin plays a role is important. The role of alpha 2u-globulin accumulation in the development of renal tubule nephropathy and carcinogenicity observed following ETBE exposure was evaluated using the U.S. EPA (1991b) Risk Assessment Forum Technical panel report, Alpha 2u-Globulin: Association with Chemically Induced Renal Toxicity and Neoplasia in the Male Rat, as well as the IARC alpha 2u-globulin criteria (Capen et al., 1999). These frameworks provide specific guidance for evaluating renal tubule tumors that are related to chemical exposure for the purpose of risk assessment, based on an examination of the potential involvement of alpha 2u-globulin accumulation. The IARC alpha 2u-globulin criteria (Capen et al., 1999) are discussed following the EPA criteria (U.S. EPA, 1991a).

The hypothesized sequence of alpha 2u-globulin renal tubule nephropathy, as described by U.S. EPA (1991a), is as follows. Chemicals that induce alpha 2u-globulin accumulation do so rapidly. Alpha 2u-globulin accumulating in hyaline droplets is deposited in the S2 (P2) segment of the proximal tubule within 24 hours of exposure. Hyaline droplets are a normal constitutive feature of the mature male rat kidney; they are particularly evident in the S2 (P2) segment of the proximal tubule and contain alpha 2u-globulin (U.S. EPA, 1991a). Abnormal increases in hyaline droplets have more than one etiology and can be associated with the accumulation of different proteins. As hyaline droplet deposition continues, single cell necrosis occurs in the S2 (P2) segment, which leads to exfoliation of these cells into the tubule lumen within 5 days of chemical exposure. In response to the cell loss, cell proliferation occurs in the S2 (P2) segment after 3 weeks and continues for the duration of the exposure. After 2 or 3 weeks of exposure, the cell debris accumulates in the S3 (P3) segment of the proximal tubule to form granular casts. Continued chemical exposure for 3 to 12 months leads to the formation of calcium hydroxyapatite in the papilla, which results in linear mineralization. After 1 or more years of chemical exposure, these lesions can result in the induction of renal tubule adenomas and carcinomas (see Figure 1-6).

U.S. EPA (1991a) identified two questions that must be addressed to determine the extent to which alpha 2u-globulin-mediated processes induce renal tubule nephropathy and carcinogenicity. The first question is whether the alpha 2u-globulin process is occurring in male rats and influencing renal tubule tumor development. The second question is whether the renal effects in male rats exposed to ETBE are due solely to the alpha 2u-globulin process.

U.S. EPA (1991a) stated that the criteria for answering the first question in the affirmative are as follows:

1) Hyaline droplets are larger and more numerous in treated male rats;
2) The protein present in the hyaline droplets in treated male rats is alpha 2u-globulin (i.e., immunohistochemical evidence); and
3) Several (but not necessarily all) additional steps in the pathological sequence appear in treated male rats as a function of time, dose, and progressively increasing severity consistent with the understanding of the underlying biology, as described above, and illustrated in Figure 1-6.

The available data relevant to this first question are summarized in Table 1-7, Table 1-8, Figure 1-7, and Table 1-11, and are evaluated below.

Figure 1-6 Temporal pathogenesis of alpha 2u-globulin-associated nephropathy in male rats

Alpha 2u-globulin synthesized in the livers of male rats is delivered to the kidney, where it can accumulate in hyaline droplets and be retained by epithelial cells lining the S2 (P2) segment of the proximal tubules. Renal pathogenesis following continued exposure and increasing droplet accumulation can progress stepwise from increasing epithelial cell damage, death, and dysfunction, leading to the formation of granular casts in the corticomedullary junction, and linear mineralization of the renal papilla, in parallel with carcinogenesis of the renal tubular epithelium.

TBA = tert-butanol.

Source: Adapted from Swenberg and Lehman-McKeeman (1999); U.S. EPA (1991a).

Table 1-7 Additional kidney effects potentially relevant to mode of action in animals exposed to ETBE

Reference and study design | Results
JPEC (2008b); Rat, Crl:CD(SD); inhalation―vapor; male (10/group): 0, 150, 500, 1,500, or 5,000 ppm (0, 627, 2,090, 6,270, or 20,900 mg/m^3^);^a^ female (10/group): 0, 150, 500, 1,500, or 5,000 ppm (0, 627, 2,090, 6,270, or 20,900 mg/m^3^)^a^; dynamic whole-body chamber; 6 h/d, 5 d/wk for 13 wk; generation method, analytical concentration, and method reported | Male
| Dose (mg/m^3^) | | Incidence of hyaline droplets in the proximal tube epithelium
| 0 | | 0/10
| 627 | | 3/10
| 2,090 | | 8/10^b^
| 6,270 | | 8/10^b^
| 20,900 | | 8/10^b^
| Unspecified representative samples reported as “weakly positive” for alpha 2u-globulin in males; no hyaline droplets observed in proximal tubule of females; hyaline droplets positive for alpha 2u-globulin not examined in females.
JPEC (2008c); Miyata et al. (2013); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for 180 d | Male | | | Female
JPEC (2008c); Miyata et al. (2013); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for 180 d | Dose mg/kg-d | Incidence of hyaline droplets | Incidence of hyaline droplets positive for alpha 2u-globulin | Dose (mg/kg-d) | Incidence of hyaline droplets
JPEC (2008c); Miyata et al. (2013); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for 180 d | 0 | 0/15 | 0/1 | 0 | 0/15
JPEC (2008c); Miyata et al. (2013); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for 180 d | 5 | 0/15 | - | 5 | -
JPEC (2008c); Miyata et al. (2013); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for 180 d | 25 | 0/15 | - | 25 | -
JPEC (2008c); Miyata et al. (2013); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for 180 d | 100 | 4/15 | 2/2 | 100 | -
JPEC (2008c); Miyata et al. (2013); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for 180 d | 400 | 10/15^b^ | 1/1 | 400 | 0/15
Medinsky et al. (1999); U.S. EPA (1997); Rat, F344; inhalation―vapor; male (48/group): 0, 500, 1,750, or 5,000 ppm (0, 2,090, 7,320, or 20,900 mg/m^3^);^a^ female (48/group): 0, 500, 1,750, or 5,000 ppm (0, 2,090, 7,320, or 20,900 mg/m^3^)^a^; dynamic whole-body chamber; 6 h/d, 5 d/wk for 13 wk; generation method, analytical concentration, and method reported | Male
| | | Proximal tubule proliferation (%)
| Dose mg/m^3^ | Hyaline droplet severity | 1 wk | 4 wk | 13 wk
| 0 | 1.8 | - | - | -
| 2,090 | 3.0 | 39 | 24 | 137^b^
| 7,320 | 3.2 | 23 | −14 | 27^b^
| 20,900 | 3.8 | 102^b^ | 175^b^ | 171^b^
| Female
| | | Proximal tubule proliferation (%)
| Dose (mg/m^3^) | | 1 wk | 4 wk | 13 wk
| 0 | | - | - | -
| 2,090 | | 60^b^ | 3 | 73
| 7,320 | | 88^b^ | 15 | 64
| 20,900 | | 49^b^ | 31^b^ | 47
Saito et al. (2013); JPEC (2010b); Rat, F344; inhalation―vapor; male (50/group): 0, 500, 1,500, or 5,000 ppm (0, 2,090, 6,270, or 20,900 mg/m^3^);^a^ female (50/group): 0, 500, 1,500, or 5,000 ppm (0, 2,090, 6,270, or 20,900 mg/m^3^)^a^; dynamic whole-body inhalation; 6 h/d, 5 d/wk for 104 wk; generation method, analytical concentration, and method reported | Male
| No hyaline droplets observed.
| Female
| No hyaline droplets observed.
Suzuki et al. (2012); JPEC (2010a); Rat, F344; oral―water; male (50/group): 0, 625, 2,500, 10,000 ppm (0, 28, 121, 542 mg/kg-d);^c^ female (50/group): 0, 625, 2,500, 10,000 ppm (0, 46, 171, 560 mg/kg-d)^c^; daily for 104 wk | Male
| No hyaline droplets observed.
| Female
| No hyaline droplets observed.

a 4.18 mg/m^3^ = 1 ppm.

b Result is statistically significant (p < 0.05) based on analysis of data by the study authors.

c Conversion performed by the study authors.

-For controls, no response relevant; for other doses, no quantitative response reported.

Table 1-8 Summary of data informing whether the alpha 2u-globulin process is occurring in male rats exposed to ETBE

Criterion | Duration | Results | Reference
(1) Hyaline droplets are increased in size and number | 1 wk | (+)^a^ | Medinsky et al. (1999)
(1) Hyaline droplets are increased in size and number | 4 wk | (+)^a^ | Medinsky et al. (1999)
(1) Hyaline droplets are increased in size and number | 13 wk | (+)^a^ | Medinsky et al. (1999)
(1) Hyaline droplets are increased in size and number | 13 wk | + | JPEC (2008b)
(1) Hyaline droplets are increased in size and number | 26 wk | + | Miyata et al. (2013); JPEC (2008c)
(1) Hyaline droplets are increased in size and number | 104 wk | – | Suzuki et al. (2012)
(1) Hyaline droplets are increased in size and number | 104 wk | – | Saito et al. (2013); JPEC (2010b)
(2) The protein in the hyaline droplets is alpha 2u-globulin | 1 wk | (+)^b^ | JPEC (2008b)
(2) The protein in the hyaline droplets is alpha 2u-globulin | 4 wk | (+)^b^ | Medinsky et al. (1999)
(2) The protein in the hyaline droplets is alpha 2u-globulin | 13 wk | (+)^b^ | Medinsky et al. (1999)
(2) The protein in the hyaline droplets is alpha 2u-globulin | 13 wk | (+)^b^ | JPEC (2008b)
(2) The protein in the hyaline droplets is alpha 2u-globulin | 26 wk | (+)^c^ | Miyata et al. (2013); JPEC (2008c)
(3) Several (but not necessarily all) additional steps in the pathological sequence are present in male rats, such as:
(a) Single-cell necrosis | 13 wk | – | JPEC (2008b)
(a) Single-cell necrosis | 13 wk | – | Medinsky et al. (1999)
(a) Single-cell necrosis | 26 wk | – | Miyata et al. (2013); JPEC (2008c)
(a) Single-cell necrosis | 104 wk | – | Suzuki et al. (2012); JPEC (2010a)
(a) Single-cell necrosis | 104 wk | – | Saito et al. (2013); JPEC (2010b)
(b) Exfoliation of epithelial cells into the tubular lumen | 13 wk | – | JPEC (2008b)
(b) Exfoliation of epithelial cells into the tubular lumen | 13 wk | – | Medinsky et al. (1999)
(b) Exfoliation of epithelial cells into the tubular lumen | 26 wk | – | Miyata et al. (2013); JPEC (2008c)
(b) Exfoliation of epithelial cells into the tubular lumen | 104 wk | – | Suzuki et al. (2012); JPEC (2010a)
(b) Exfoliation of epithelial cells into the tubular lumen | 104 wk | – | Saito et al. (2013); JPEC (2010b)
(c) Granular casts | 13 wk | – | JPEC (2008b)
(c) Granular casts | 13 wk | (+) | Cohen et al. (2011); JPEC (2007a)
(c) Granular casts | 13 wk | – | Medinsky et al. (1999)
(c) Granular casts | 26 wk | – | Miyata et al. (2013); JPEC (2008c)
(c) Granular casts | 104 wk | – | Suzuki et al. (2012); JPEC (2010a)
(c) Granular casts | 104 wk | – | Saito et al. (2013); JPEC (2010b)
(d) Linear mineralization of tubules in the renal papilla | 13 wk | – | JPEC (2008b)
(d) Linear mineralization of tubules in the renal papilla | 13 wk | – | Medinsky et al. (1999)
(d) Linear mineralization of tubules in the renal papilla | 26 wk | – | Miyata et al. (2013); JPEC (2008c)
(d) Linear mineralization of tubules in the renal papilla | 104 wk | + | Suzuki et al. (2012); JPEC (2010a), Cohen et al. (2011)
(d) Linear mineralization of tubules in the renal papilla | 104 wk | + | Saito et al. (2013); JPEC (2010b)
(e) Proliferation and foci of tubular hyperplasia | 13 wk | – | JPEC (2008b)
(e) Proliferation and foci of tubular hyperplasia | 13 wk | +/−^d^ | Medinsky et al. (1999)
(e) Proliferation and foci of tubular hyperplasia | 26 wk | – | Miyata et al. (2013); JPEC (2008c)
(e) Proliferation and foci of tubular hyperplasia | 104 wk | – | Suzuki et al. (2012); JPEC (2010a)
(e) Proliferation and foci of tubular hyperplasia | 104 wk | – | Saito et al. (2013); JPEC (2010b)

+ = Statistically significant change reported in one or more treated groups.

(+) = Effect reported in one or more treated groups, but statistics not reported.

– = No statistically significant change reported in any of the treated groups.

a Droplet severity.

b Unspecified “representative samples” examined.

c Three samples from highest two dose groups examined.

d Labeling index statistically significantly increased, but no hyperplasia reported.

Figure 1-7 ETBE oral exposure array of alpha 2u-globulin data in male rats

Figure 1-8 ETBE inhalation exposure array of alpha 2u-globulin data in male rats

###### Question One: is the alpha 2u-globulin process occurring in male rats exposed to ETBE?^7^

(1) The first criterion to consider is whether hyaline droplets are larger and more numerous in male rats. The accumulation of hyaline droplets was observed in all three subchronic ETBE exposure studies, but was not observed in two chronic ETBE studies (see Table 1-7 and Table 1-8). Failure to observe alpha 2u-globulin and increased droplet accumulation in the 2-year studies is not unusual because alpha 2u-globulin naturally declines in males around 5 months of age (U.S. EPA, 1991a). Accumulation of hyaline droplets in the proximal tubular epithelium of the kidney was observed in male rats following 90-day inhalation exposure to 627, 2,090, 6,270, or 20,900 mg ETBE/m^3^ (JPEC, 2008b). The increases at the three highest concentrations were statistically significant; however, none of the animals had hyaline droplet grades over 1 (JPEC, 2008b). Severity grade of the hyaline droplets exhibited a dose-response after a 1-week exposure, as indicated by scores of 1.2, 3.4, 4.0, and 4.6 at 0, 2,090, 7,320, and 20,900 mg ETBE/m^3^, respectively, and 90 days of ETBE inhalation exposure increased the severity grades of hyaline droplets from 1.8 in the control to 3.0, 3.2, and 3.8 (Medinsky et al., 1999). In addition, the incidence of hyaline droplets statistically significantly increased in a dose-related manner after 26 weeks of gavage exposure to 100 and 400 mg ETBE/kg-day (Miyata et al., 2013; JPEC, 2008c). These data indicate consistent evidence of hyaline droplets increasing both in a dose-responsive manner and within the expected time frame. Therefore, the available data are sufficient to fulfill the first criterion that hyaline droplets are increased in size and number in male rats.

(2) The second criterion to consider is whether the protein in the hyaline droplets in male rats is alpha 2u-globulin. Immunohistological staining to ascertain the protein composition in the hyaline droplets was performed only in ETBE exposure studies that observed accumulation of hyaline droplets. At the two highest doses, Miyata et al. (2013); JPEC (2008c) identified hyaline droplets as positive for alpha 2u-globulin in 2/2 and 1/1 animals that were tested for the presence of alpha 2u-globulin. The other two studies also reported that unspecified samples were positive for alpha 2u-globulin (JPEC, 2008b; Medinsky et al., 1999). JPEC (2008b) reported that the samples stained weakly positive for alpha 2u-globulin and that positive alpha 2u-globulin staining was observed only in male rats. No statistical tests were performed on these results. The available studies that tested for alpha 2u-globulin in hyaline droplets did not test a sufficient number of samples within a dose group nor were enough dose groups tested for alpha 2u-globulin to perform dose-response analysis. Therefore, the available data are minimally sufficient to fulfill the second criterion for alpha 2u-globulin present in the hyaline droplets but do suggest that ETBE is a weak inductor of alpha 2u-globulin.

(3) The third criterion considered is whether several (but not necessarily all) additional steps in the histopathological sequence associated with alpha 2u-globulin nephropathy appear in male rats in a manner consistent with the understanding of alpha 2u-globulin pathogenesis (refer to Table 1-8). Of the remaining five endpoints in the pathological sequence, only linear papillary mineralization and granular casts were observed. Papillary mineralization typically appears at chronic time points, occurring after exposures of 3 months up to 2 years (U.S. EPA, 1991a). Statistically significant increases in the incidence of papillary mineralization was observed in both 2-year studies. In male rats, papillary mineralization increased in a dose-related manner following oral ETBE exposure at concentrations of 0, 28, 121, and 542 mg/kg-day, respectively (Suzuki et al., 2012; JPEC, 2010a) and at ETBE inhalation concentrations of 0, 2,090, 6,270, and 20,900 mg/m^3^ (Saito et al., 2013; JPEC, 2010b). Hyaline droplet deposition was observed at a similar frequency as mineralization following oral ETBE exposure (Miyata et al., 2013; Suzuki et al., 2012; JPEC, 2010a, 2008c); however, hyaline droplet deposition was observed in 80% of animals at all three inhalation exposure concentrations (JPEC, 2008b) compared with papillary mineralization rates of only 0, 2, and 12% [lowest to highest exposure concentration; Saito et al. (2013); JPEC (2010b)]. A detailed evaluation and analysis of all the evidence relevant to this criterion follows.

###### Detailed evaluation of the available evidence supporting the third criterion

a) Single cell death, exfoliation into the renal tubules, and necrosis were not observed in any study (JPEC, 2008b, c; Medinsky et al., 1999). This observation might not be inconsistent with the hypothesized MOA because cell death and exfoliation has been observed to occur as early as 5 days post exposure, peak at 3 weeks, and then decline to near background levels by 4−5 weeks (Kanerva et al., 1987); this endpoint was not examined in any study evaluating ETBE exposures less than 13 weeks. Thus, the lack of exfoliation observations could be due to weak induction of alpha 2u-globulin and a lack of appropriately timed examinations.
b) Granular cast formation was observed in one study. The JPEC (2007a) study reported that, at 13 weeks, granular casts were observed in high-dose males, while none were observed in controls (no statistical tests performed). Other studies at similar time points did not report the presence of granular casts (JPEC, 2008b, c; Medinsky et al., 1999) despite using similar exposure concentrations. Granular cast formation, however, might not occur with weak inducers of alpha 2u-globulin (Short et al., 1986), which is consistent with the weak staining of alpha 2u-globulin, as discussed above (JPEC, 2008b).
c) Linear mineralization of tubules within the renal papilla was consistently observed in male rats after 2 years (Saito et al., 2013; Suzuki et al., 2012). This lesion typically appears at chronic time points, occurring after exposures of 3 months up to 2 years (U.S. EPA, 1991a).
d) Cellular proliferation was increased after 1, 4, and 13 weeks in males and females; however, the magnitude of effect was less in females than in males. Observation of proliferation in both sexes suggests that this effect is not male specific, and thus not solely due to alpha 2u-globulin. Furthermore, renal tubule hyperplasia was not observed in any 2-year study, suggesting that ETBE does not induce sustained proliferation (Saito et al., 2013; Suzuki et al., 2012). Renal tubule hyperplasia is the preneoplastic lesion associated with alpha 2u-globulin nephropathy in chronic exposures that leads to renal tubule tumors (U.S. EPA, 1991a).

The progression of histopathological lesions for alpha 2u-globulin nephropathy is predicated on the initial response of excessive hyaline droplet accumulation (containing alpha 2u-globulin) leading to cell necrosis and cytotoxicity, which in turn causes the accumulation of granular casts, linear mineralization, and tubular hyperplasia resulting from sustained cellular proliferation. Therefore, observations of temporal and dose-response concordance for these effects are informative for drawing conclusions on causation.

As mentioned above (see Table 1-8), some steps in the sequence of alpha 2u-globulin nephropathy are observed at the expected time points following exposure to ETBE. Accumulation of hyaline droplet severity was observed early, at 1 week following inhalation exposure (Medinsky et al., 1999), and increased incidence was subsequently observed at 90 days (JPEC, 2008b) or 26 weeks (JPEC, 2008c); alpha 2u-globulin was identified as the protein in these droplets (Borghoff et al., 2001; Williams and Borghoff, 2001). Observations of the subsequent linear mineralization of tubules fall within the expected timeframe of the appearance of these lesions. Granular cast formation was reported in one oral study (Cohen et al., 2011) but not in three other oral and inhalation studies (JPEC, 2008b, c; Medinsky et al., 1999), which also could indicate weak alpha 2u-globulin induction. Neither alpha 2u-globulin-mediated regenerative cell proliferation nor atypical renal tubule hyperplasia were observed. Lack of necrosis and exfoliation might be due to the weak induction of alpha 2u-globulin and a lack of appropriately timed examinations.

Hyaline droplets were weakly induced in all male rats in the 13-week inhalation studies (JPEC, 2008b; Medinsky et al., 1999) but did not result in increased linear mineralization at the corresponding doses. The lack of increased linear mineralization at low doses is also consistent with weak induction of hyaline droplets.

Overall, the histopathological sequence has numerous data gaps, such as the lack of observable necrosis, cytotoxicity, and tubule hyperplasia at stages plausibly within the time frame of detectability. Furthermore, no explicit inconsistencies are present in the temporal appearance of the histopathological lesions associated with the alpha 2u-globulin nephropathy induced following ETBE exposure; however, the data set would be bolstered by measurements at additional time points to lend strength to the MOA evaluation. Therefore, the number of histopathological steps observed was insufficient to fulfill the third criterion.

###### Summary and conclusions for Question One, Is the alpha 2u-globulin process occurring in male rats exposed to ETBE?

The evidence suggests that ETBE causes hyaline droplets to increase in size and number. The documentation of alpha 2u-globulin staining is poor and provides weak evidence of alpha 2u-globulin in the hyaline droplets. Only one of the additional steps in the pathological sequence was consistently observed (linear papillary mineralization), and the ETBE database lacks evidence of renal tubule hyperplasia and adenomas or carcinomas, despite multiple chronic bioassays, exposure routes, and durations ranging from 13 weeks to 2 years. Overall, the available data were insufficient to conclude that the alpha 2u-globulin process is exclusively operative.

###### Consideration of additional IARC (1999 (https://hero.epa.gov/hero/index.cfm?action=search.view&reference_id=699905)) criteria

An alpha 2u-globulin framework was published by IARC in 1999 (Capen et al., 1999). See Table 1-9 for the criteria laid out in the IARC consensus document.

Table 1-9 IARC criteria for an agent causing kidney tumors through an alpha 2u-globulin associated response in male rats

- Lack of genotoxic activity (agent and/or metabolite) based on an overall evaluation of in vitro and in vivo data.; - Male rat specificity for nephropathy and renal tumorigenicity.; - Induction of the characteristic sequence of histopathological changes in shorter term studies, of which protein droplet accumulation is obligatory.; - Identification of the protein accumulating in tubule cells as alpha 2u-globulin.; - Reversible binding of the chemical or metabolite to alpha 2u-globulin.; - Induction of sustained increased cell proliferation in the renal cortex.; - Similarities in dose-response relationship of the tumor outcome with the histopathological endpoints (protein droplets, alpha 2u-globulin accumulation, cell proliferation).

The EPA and IARC criteria differ in a few minor ways. The EPA framework requires the observation of several (but not necessarily all) additional steps in the histopathological sequence associated with alpha 2u-globulin nephropathy, whereas IARC requires the “induction of the characteristic sequence of histopathological changes in shorter term studies, of which protein droplet accumulation is obligatory,” but IARC doesn’t specify which or how many of the additional histopathological changes must be observed to consider this criteria met. In addition, the IARC criteria have specific criteria pertaining to lack of genotoxicity of parent compound/metabolite and male rat specificity for nephropathy and renal tumorigenicity whereas the EPA framework considers these data as supplemental information (see Part 4, XVII B. Additional Information Useful for the Analysis). These additional criteria required by IARC (Capen et al., 1999) are discussed below.

###### Lack of genotoxic action

As discussed in Appendix Section B.2.2, limited data are available to help inform the genotoxic potential of ETBE. Most studies indicate that ETBE does not induce genotoxicity in the systems tested, although several key types of assays are missing (e.g., studies investigating chromosomal aberrations and deoxyribonucleic acid [DNA] adducts). While some data suggest the major metabolite of ETBE, tert-butanol, could be genotoxic, the overall evidence is inadequate to establish a conclusion. However, ETBE’s metabolite acetaldehyde has induced sister chromatid exchanges in Chinese hamster ovary cells, gene mutations in mouse lymphomas, and DNA strand breaks in human lymphocytes (IARC, 1999a). In addition, increased genotoxicity of ETBE is noted when tested in animals with polymorphisms in the acetaldehyde dehydrogenase gene ALDH2, which decreases the ability to metabolize acetaldehyde (Weng et al., 2019; Weng et al., 2014; Weng et al., 2013; Wang et al., 2012; Weng et al., 2012; Weng et al., 2011). Approximately 8% of the world’s population carries this variant (Gross et al., 2015). Overall, the IARC criterion for lack of genotoxic activity has been weakly met for nonsusceptible populations but not met for the subset of the population that cannot efficiently detoxify acetaldehyde.

###### Male rat specificity for nephropathy

Evidence is limited for ETBE-mediated kidney effects in other species. Only one subchronic study in wild-type (WT) mice evaluated kidney effects (Medinsky et al., 1999; Bond et al., 1996). No chronic studies are available that evaluated kidney effects in mice.

Increased absolute kidney weight and increased severity of chronic nephropathy was noted in both sexes of rats exposed chronically to ETBE through inhalation and in drinking water (JPEC, 2010a, b). Changes in clinical chemistry suggestive of kidney toxicity (e.g., increased BUN, cholesterol, and protein urea) were also noted in both male and female rats. However, dose-related increased incidence of urothelial hyperplasia of the renal pelvis was observed in male rats in chronic oral and inhalation bioassays but was not found in female rats by either route of exposure. In summary, while male rats appear to be more sensitive to ETBE-meditated kidney toxicity, indications of nephropathy were also observed in female rats. Therefore, this criterion has not been met.

###### Comparison of ETBE and tert-butanol alpha 2u-globulin data

Both EPA and IARC have accepted the biological plausibility of the alpha 2u-globulin-mediated hypothesis for inducing nephropathy and cancer in male rats (Swenberg and Lehman-McKeeman, 1999; U.S. EPA, 1991a), and those rationales will not be repeated here. A more recent retrospective analysis has demonstrated that several steps in the sequence of pathological events are not required for tumor development. The study showed that several alpha 2u-globulin-inducing chemicals fail to induce many of the pathological sequences in the alpha 2u-globulin pathway (Doi et al., 2007). For instance, dose-response concordance was not observed for several endpoints, such as linear mineralization, tubular hyperplasia, granular casts, and hyaline droplets, following exposure to chemicals that induce the alpha 2u-globulin process. These chemicals included d-limonene, decalin, propylene glycol mono-t-butyl ether, and Stoddard Solvent IICA (SS IICA). Although some of these chemicals induced dose-response effects for a few endpoints, all failed to induce a dose-response for all of the endpoints in the sequence. Furthermore, no endpoint in the pathological sequence was predictive for tumor incidence when considering either the dose responsiveness or the severity. Tumor incidence was not affected in a dose-related manner following either d-limonene or decalin exposure. Tumor incidence was not correlated with the severity of any one effect in the alpha 2u-globulin sequence, as demonstrated by SS IICA, which induced some of the most severe nephropathy relative to the other chemicals, but did not significantly increase kidney tumors (Doi et al., 2007). Thus, this analysis suggests that another MOA could be operative for inducing kidney tumors in male rats.

As described above, ETBE is metabolized to tert-butanol, so kidney data following tert-butanol exposure are also potentially relevant to evaluating the MOA of ETBE. In particular, the effects of tert-butanol on the alpha 2u-globulin process are relevant for evaluating the coherence of the available data on ETBE-induced nephropathy.

Hyaline droplet deposition and linear mineralization were both observed following similar exposure durations to tert-butanol and ETBE. After 13 weeks of exposure to tert-butanol or ETBE, hyaline droplets increased in a dose-response manner. ETBE exposure increased hyaline droplets at lower internal concentrations than did direct tert-butanol administration.

Tubule hyperplasia and renal tumors were both observed following 2-year exposure to tert-butanol but not to ETBE, despite similar internal concentrations of tert-butanol following ETBE exposure (Saito et al., 2013; Suzuki et al., 2012; JPEC, 2010b). The failure of ETBE to induce several histopathological lesions in the alpha 2u-globulin pathological sequence, including renal tubule hyperplasia and tumors, at similar internal tert-butanol concentrations (as predicted by the Salazar PBPK model) as those that induced hyperplasia and tumorigenesis following exposure to tert-butanol suggests remaining uncertainty regarding toxicokinetic or toxicodynamic differences, or both, across the two chemicals.

##### Chronic progressive nephropathy (CPN)

Exacerbation of CPN has been proposed as another rat-specific mechanism of nephrotoxicity that is not relevant to humans (Hard et al., 2009). CPN is an age-related renal disease that occurs in rats of both sexes (NTP, 2015; Seely and Brix, 2014a; Hard et al., 2013; Melnick et al., 2012; U.S. EPA, 1991a). CPN is more severe in males than in females and is particularly common in the S-D and F344 strains. Dietary and hormonal factors play a role in modifying CPN, though its etiology is unknown.

CPN has been suggested as a key event in the onset of renal tubule tumors, and a sequence of key events in the MOA is as follows: (1) metabolic activation, (2) chemically exacerbated CPN, (3) increased tubule cell proliferation, (4) tubule hyperplasia, and (5) adenomas (Hard et al., 2013). However, an analysis of 60 NTP carcinogenicity studies did not find an association between chemically exacerbated CPN and renal tubule tumor induction in rats (Melnick et al., 2012). ETBE exposure increased CPN severity following 2-year inhalation and 13-week oral exposure but, unlike tert-butanol, did not affect tubule hyperplasia or increase renal tubule tumor incidence.

Additional markers associated with CPN include elevated proteinuria and albumin in the urine and increased BUN, creatinine, and cholesterol in the serum, of which proteinuria is the major urinary effect and a very sensitive measure of CPN (Hard et al., 2009). In the case of ETBE exposure, however, increased severity or incidence of proteinuria was not correlated with increased severity of CPN in male rats possibly due to high background severity of CPN. In female rats, background severity of CPN was much milder; thus, increased proteinuria was observable only when CPN was increased as in the 2-year inhalation exposure study (Saito et al., 2013). Elevated BUN and creatinine typically are not observed until very late in CPN progression. This was true for ETBE, as most of these markers were elevated only after 2-year exposures.

Several of the CPN pathological effects are similar to—and can obscure the lesions characteristic of—alpha 2u-globulin-related hyaline droplet nephropathy (Webb et al., 1990). Additionally, renal effects of alpha 2u-globulin accumulation can exacerbate the effects associated with CPN (Travlos et al., 2011; U.S. EPA, 1991a).

CPN is often more severe in males than in females. While background severity of CPN in controls was higher in male rats, increased severity of CPN was reported in both male and female rats with ETBE exposure and was statistically significant at the highest exposure groups of both sexes following chronic inhalation (see Table 1-2). Some of the observed renal lesions in male rats following exposure to ETBE are effects commonly associated with CPN. A strong, statistically significant, treatment-related relationship was observed between chronic ETBE exposure and increased incidence of urothelial hyperplasia in male (but not female) rats in both the inhalation and oral studies (Saito et al., 2013; Suzuki et al., 2012; JPEC, 2010a, b). Urothelial hyperplasia is both increased by dose and weakly correlated with CPN, which is also dose-related (see Table 1-5 and Table 1-6). Thus, disentangling the contributions of dose and nephropathy in the development of urothelial hyperplasia is not possible with the currently available information. Moreover, no evidence is available to support that urothelial hyperplasia is not related to ETBE treatment, given the robust dose-response relationship in male rats treated with ETBE.

Finally, because tert-butanol is a major metabolite of ETBE and both chemicals induce similar noncancer kidney effects, tert-butanol could be the active toxic moiety responsible for these effects. The three noncancer kidney endpoints (kidney weights, urothelial hyperplasia, CPN) were evaluated on an internal dose basis using PBPK modeling to compare these data from ETBE and tert-butanol studies (Salazar et al., 2015). The results demonstrate that noncancer kidney effects, including kidney-weight changes, urothelial hyperplasia, and exacerbated CPN, yielded consistent dose-response relationships across routes of exposure and across ETBE and tert-butanol studies using tert-butanol blood concentration as the dose metric. These results are consistent with the hypothesis that tert-butanol mediates the noncancer kidney effects following ETBE administration; however, contributing toxicity from the parent compound and other metabolites cannot be ruled out.

#### Overall Conclusion on Mode of Action (MOA) for Kidney Effects

ETBE increases alpha 2u-globulin deposition and hyaline droplet accumulation in male rat kidneys, but only one of the five additional steps in the pathological sequence (linear mineralization) was consistently observed (see Table 1-8). These data are insufficient to conclude that ETBE induces alpha 2u-globulin nephropathy; however, the observation of alpha 2u-globulin accumulation in hyaline droplets with ETBE exposure makes the human relevance of the associated nephropathy in male rat CPN uncertain, and the exacerbation of CPN could play a role in the observed nephropathy. Currently, the MOA for the observed ETBE-induced exacerbation of CPN is unknown, especially in female rats and in male and female mice, which are not affected by alpha 2u-globulin nephropathy. Collectively, the evidence indicates other, unknown processes contribute to the observed nephrotoxicity following ETBE exposure, particularly in female rats.

#### Integration of Kidney Effects

Kidney effects (increases in severity of nephropathy, increased kidney weight, alterations in clinical chemistry, hyaline droplets, linear mineralization, and urothelial hyperplasia of the renal pelvis) were observed across multiple studies, predominantly in rats; chronic bioassays found no treatment-related increases in renal tumors. The available evidence indicates that multiple processes induce the noncancer kidney effects.

Some endpoints in male rats (hyaline droplets, linear mineralization) are components of the alpha 2u-globulin process. U.S. EPA (1991a) states that “[i]f a compound induces alpha 2u-globulin accumulation in hyaline droplets, the associated nephropathy in male rats is not an appropriate endpoint to determine noncancer (systemic) effects potentially occurring in humans.” Therefore, in the case of ETBE exposure, endpoints directly associated with alpha 2u-globulin processes were not considered an indication of human health hazard for noncancer kidney toxicity. Because alpha 2u-globulin nephropathy is strictly a male rat phenomenon, dose-related kidney effects in female rats and mice are not confounded by alpha 2u-globulin nephropathy.

It has been observed that chemicals that bind to alpha 2u-globulin can lead to increased incidence and/or severity of CPN (Frazier et al., 2012; Travlos et al., 2011; U.S. EPA, 1991a). CPN is a common and well-established constellation of age-related lesions in the kidney of male and female rats, with no known counterpart to in aging humans. However, CPN is not a specific diagnosis on its own but an aggregate term describing a spectrum of effects, employed to reduce the time and effort required to grade each component of the disease. The individual lesions associated with CPN (e.g., tubular degeneration, thickening of basement membranes, glomerular sclerosis, etc.) also occur in the human kidney (Lusco et al., 2016; Zoja et al., 2015; Frazier et al., 2012; Abrass, 2000). Although CPN has no known analogue in the aging human kidney (NIEHS, 2019; Hard et al., 2009), the etiology is unknown (NIEHS, 2019; Hard and Khan, 2004; Peter et al., 1986). Given that there is no definitive pathogenesis for CPN, it cannot be ruled out that a chemical which exacerbates CPN in rats could also exacerbate existing disease processes in the human kidney (NIEHS, 2019). Therefore, increased incidence of kidney effects with ETBE exposure in the female rat (including increased kidney weight and increased severity of CPN) are considered relevant to humans.

Several noncancer endpoints were concluded to result from ETBE exposure including increased absolute kidney weight, histopathological changes, and alterations in clinical chemistry in male and female rats, with the effects in males tending to be more severe than in females (potentially due to confounding by alpha 2u-globulin processes). A PBPK model-based analysis yielded consistent dose-response relationships between kidney weight, urothelial hyperplasia, and chronic progressive nephropathy (CPN) using tert-butanol blood concentration as the dose metric, consistent with the hypothesis that tert-butanol mediates the noncancer kidney effects following ETBE administration (Salazar et al., 2015). Based on dose-related increases in these noncancer endpoints in rats, kidney effects are a potential human hazard of ETBE exposure. The hazard and dose-response conclusions regarding these noncancer endpoints associated with ETBE exposure are discussed further in Section 1.3.1.

### 1.2.2 Liver Effects

#### Synthesis of Effects in the Liver

This section reviews the studies that investigated whether exposure to ETBE can cause liver noncancer or cancer effects in humans or animals. The database for ETBE-induced liver effects includes nine studies conducted in animals, all but two of which were performed in rats. A description of the studies comprising the database is provided in Section 1.2.1. Briefly, exposures ranged from 13 weeks to 2 years and both inhalation and oral exposure routes are represented. Studies using short-term and acute exposures that examined liver effects are not included in the evidence tables; however, they are discussed in the text if they provide data informative of the MOA or hazard identification. Studies are arranged in evidence tables first by effect and then in alphabetical order by author. The design, conduct, and reporting of each study were reviewed, and each study was considered adequate to provide information pertinent to this assessment.

Liver weight. Increased liver weight was observed with ETBE exposure in male and female rats treated for various durations orally or by inhalation. Several factors associated with the 2-year organ-weight data could confound consideration for hazard identification. Proliferative lesions (altered hepatocellular foci) were observed in rat livers, especially males, in both 2-year oral and inhalation studies, which complicates interpretation of changes in organ weight. Furthermore, inhalation exposure significantly increased liver adenomas and carcinomas in male rats at the highest dose, corresponding to increased liver weights in those dose groups (Saito et al., 2013; JPEC, 2010b). Organ-weight data obtained from studies of shorter duration, however, are less complicated by these age-associated factors (e.g., tumors, mortality), and therefore, could be appropriate for hazard identification.

Chronic and subchronic studies by both oral and inhalation routes reported consistent, statistically significant, dose-related increases in liver weights (see Figure 1-9, Figure 1-10, Table 1-10). Liver weight and body weight have been demonstrated to be proportional, and liver weight normalized to body weight was concluded to be optimal for data analysis (Bailey et al., 2004); thus, only relative liver weight is considered in determining hazard. Relative liver weights were consistently increased at similar exposure concentrations in four of five studies for males and three of four studies for females; however, statistically significant increases often occurred only at the highest tested concentration, with increases in relative liver weight ranging from 17 to 27% in males and 8 to 18% in females. Relative liver weights in rats were increased at only the highest dose following oral exposures of 16 weeks or longer (Miyata et al., 2013; Fujii et al., 2010; JPEC, 2008c; Gaoua, 2004b). In utero exposure yielded similar effects on F1 liver weights, in terms of the magnitude of percent change, from adult exposure (Gaoua, 2004b). Inhalation exposure increased liver weight at the highest dose in female rats, but not in males, following 13-week exposure (JPEC, 2008b). Following a 28-day recovery period, male but not female liver weights were increased (JPEC, 2008b). Short-term studies observed similar effects on liver weight (JPEC, 2008a; White et al., 1995).

Liver histopathology. Centrilobular hypertrophy and acidophilic (eosinophilic) and basophilic focal lesions were the only dose-related types of pathological lesions observed in the liver. Centrilobular hypertrophy was inconsistently increased throughout the evidence base but was also observed at the same concentrations that induced liver-weight changes in rats of both sexes after 13-week inhalation and 26-week oral exposures (see Table 1-11; Figure 1-9, Figure 1-10). A 26-week gavage study (Miyata et al., 2013; JPEC, 2008c) in rats and three 13-week inhalation studies in mice and rats (Weng et al., 2012; JPEC, 2008b; Medinsky et al., 1999) showed a statistically significant increase in centrilobular hypertrophy at the highest dose. In addition, 2-year oral and inhalation studies in rats reported increased liver weight in males and females.

Acidophilic (eosinophilic) and basophilic preneoplastic lesions were increased in male, but not female, rats at the highest tested dose following a 2-year inhalation exposure to ETBE (Saito et al., 2013; JPEC, 2010b). Following 2-year drinking water exposure to ETBE, an increasing, but not statistically significant incidence in basophilic preneoplastic lesions (14/50, 18/50, 20/50, 22/50) was observed in the liver of male rats, whereas incidence of these lesions decreased in female rats (Suzuki et al., 2012; JPEC, 2010a).

Serum liver enzymes. Serum liver enzymes were inconsistently affected across exposure routes (see Table 1-12; Figure 1-9, Figure 1-10). No enzyme levels were affected in studies of exposure durations less than 2 years (Miyata et al., 2013; JPEC, 2008b). γ-Glutamyl transpeptidase (GGT) was significantly increased in male rats at one intermediate dose following oral exposure and at the two highest doses following inhalation exposure in 2-year studies (JPEC, 2010a, b). GGT levels were not significantly affected in female rats in any study. No consistent dose-related changes were observed in aspartate aminotransferase (AST), alanine aminotransferase (ALT), or alkaline phosphatase (ALP) liver enzymes following either oral or inhalation exposure of any duration. With the exception of a dose-related increase in serum GGT in male rats and an increase in AST at the highest dose in females, no other dose-related changes in liver enzyme levels were observed that were directionally consistent with the liver weight and hypertrophy effects.

Liver tumors. Data on liver tumor induction by ETBE are presented in Table 1-13. Liver tumors were statistically significantly increased in male F344 rats at the high dose, but not in females, following 2-year inhalation exposure (Saito et al., 2013; JPEC, 2010b). The incidence of combined adenomas and carcinomas of 0/50, 2/50, 1/50, and 10/50 at 0, 2,090, 6,270, and 20,900 mg/m^3^, respectively, also resulted in a statistically significant, positive exposure-response trend (Peto’s test p < 0.001). In this study, preneoplastic lesions, acidophilic (eosinophilic) and basophilic foci, were also increased in male rats following a similar exposure pattern.

At the highest exposure dose in male rats, the dose at which the majority of liver tumors were observed, a 25% reduction in body weight was seen, raising some question as to whether the liver tumors observed in the highest exposure group in male rats are solely the result of excessive toxicity rather than carcinogenicity of the tested agent. EPA’s 2005 Cancer Guidelines discuss the determination of an “excessively high dose” as compared to an “adequately high dose” and describe the process as one of expert judgment which requires that “…adequate data demonstrate that the effects are solely the result of excessive toxicity rather than carcinogenicity of the tested agent” (U.S. EPA, 2005a). In the case of the 2-year inhalation study, the study authors did not report any overt toxicity or altered toxicokinetics at the high dose (JPEC, 2010b). In addition, the high-dose female rats had a similar reduction in body weight (22%) with no liver tumors (or increase in preneoplastic foci) observed.

No significant increase in tumors was observed following two chronic oral bioassays (Suzuki et al., 2012; JPEC, 2010a; Maltoni et al., 1999). However, one bioassay (Maltoni et al., 1999) was confounded by extremely low survival in the controls (25−28% at 2 years), potentially due to widespread respiratory infections (see discussion in Section 1.2.5). This extreme reduction in survival likely affects this study’s power to detect potential carcinogenicity. The other available 2-year oral cancer bioassay, which was well designed, conducted, and reported, did not show significant increases in liver tumors; however, it did show an increased, but not statistically significant, trend in basophilic preneoplastic lesions in the liver of male rats, with the incidence of these lesions being less in female rats (Suzuki et al., 2012; JPEC, 2010a).

Two-stage “initiation, promotion” studies in male F344 and Wistar rats administered mutagens for 2−4 weeks reported statistically significant increases in liver adenomas, carcinomas, or total neoplasms after 19−23 weeks of ETBE exposure via gavage (Hagiwara et al., 2015; Hagiwara et al., 2011). Liver tumors were not observed in male F344 rats exposed to ETBE for 23 weeks (n = 12) without prior mutagen exposure (Hagiwara et al., 2011). Liver tumorigenesis without prior mutagen exposure was not evaluated in Wistar rats (Hagiwara et al., 2015).

Table 1-10 Evidence pertaining to liver weight effects in animals exposed to ETBE

Reference and study design | Results
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; P0, male (24/group): 0, 100, 300, or 1,000 mg/kg-d; daily for 16 wk beginning 10 wk prior to mating; P0, female (24/group): 0, 100, 300, or 1,000 mg/kg-d; daily for 17 wk beginning 10 wk prior to mating to LD 21 | Response relative to control:
| P0, Male | | P0, Female
| Dose (mg/kg-d) | Relative weight (%) | Dose (mg/kg-d) | Relative weight (%)
| 0 | - | 0 | -
| 100 | 1 | 100 | −1
| 300 | 2 | 300 | 3
| 1,000 | 21^a^ | 1,000 | 9^a^
Gaoua (2004b); Rat, S-D; oral―gavage; P0, male (25/group): 0, 250, 500, or 1,000 mg/kg-d; daily for a total of 18 wk beginning 10 wk before mating until after weaning of the pups; P0, female (25/group): 0, 250, 500, or 1,000 mg/kg-d; daily for a total of 18 wk beginning 10 wk before mating until PND 21; F1, male (25/group): 0, 250, 500, or 1,000 mg/kg-d; F0 dams dosed daily through gestation and lactation, then F1 doses beginning PND 22 until weaning of the F2 pups; F1, female (24–25/group): 0, 250, 500, or 1,000 mg/kg-d; F0 dams dosed daily through gestation and lactation, then F1 dosed beginning PND 22 until weaning of F2 pups | Response relative to control:
| P0, Male | | P0, Female
| Dose (mg/kg-d) | Relative weight (%) | Dose (mg/kg-d) | Relative weight (%)
| 0 | - | 0 | -
| 250 | 3 | 250 | 10
| 500 | 6 | 500 | 8
| 1,000 | 24^a^ | 1,000 | 4
| F1, Male | | F1, Female
| Dose (mg/kg-d) | Relative weight (%) | Dose (mg/kg-d) | Relative weight (%)
| 0 | - | 0 | -
| 250 | 0 | 250 | 3
| 500 | 11^a^ | 500 | 6
| 1,000 | 25^a^ | 1,000 | 9^a^
Hagiwara et al. (2011); JPEC (2008d); Rat, F344; oral―gavage; male (12/group): 0 or 1,000 mg/kg-d; daily for 23 wk | Response relative to control:
Hagiwara et al. (2011); JPEC (2008d); Rat, F344; oral―gavage; male (12/group): 0 or 1,000 mg/kg-d; daily for 23 wk | Male
Hagiwara et al. (2011); JPEC (2008d); Rat, F344; oral―gavage; male (12/group): 0 or 1,000 mg/kg-d; daily for 23 wk | Dose (mg/kg-d) | | Relative weight (%)
Hagiwara et al. (2011); JPEC (2008d); Rat, F344; oral―gavage; male (12/group): 0 or 1,000 mg/kg-d; daily for 23 wk | 0 | | -
Hagiwara et al. (2011); JPEC (2008d); Rat, F344; oral―gavage; male (12/group): 0 or 1,000 mg/kg-d; daily for 23 wk | 1,000 | | 27^a^
JPEC (2008b); Rat, Crl:CD(SD); inhalation―vapor; male (NR): 0, 150, 500, 1,500, or 5,000 ppm (0, 627, 2,090, 6,270, or 20,900 mg/m^3^);^b^ female (NR): 0, 150, 500, 1,500, or 5,000 ppm (0, 627, 2,090, 6,270, or 20,900 mg/m^3^); dynamic whole-body chamber; 6 h/d, 5 d/wk for 13 wk; generation method, analytical concentration, and method reported | Response relative to control:
| Male | | Female
| Dose (mg/m^3^) | Relative weight (%) | Dose (mg/m^3^) | Relative weight (%)
| 0 | - | 0 | -
| 627 | 5 | 627 | 4
| 2,090 | 5 | 2,090 | −1
| 6,270 | 5 | 6,270 | 6
| 20,900 | 10 | 20,900 | 18^a^
JPEC (2008b); Rat, Crl:CD(SD); inhalation―vapor; male (6/group): 0 or 5,000 ppm (0 or 20,900 mg/m^3^);^b^ female (6/group): 0 or 5,000 ppm (0 or 20,900 mg/m^3^)^b^; dynamic whole-body chamber; 6 h/d, 5 d/wk for 13 wk followed by a 28-d recovery period; generation method, analytical concentration, and method reported | Response relative to control:
| Male | | Female
| Dose (mg/m^3^) | Relative weight (%) | Dose (mg/m^3^) | Relative weight (%)
| 0 | - | 0 | -
| 20,900 | 9^a^ | 20,900 | 7
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for 26 wk | Response relative to control:
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for 26 wk | Male | | Female
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for 26 wk | Dose (mg/kg-d) | Relative weight (%) | Dose (mg/kg-d) | Relative weight (%)
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for 26 wk | 0 | - | 0 | -
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for 26 wk | 5 | 5 | 5 | 1
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for 26 wk | 25 | 7 | 25 | 1
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for 26 wk | 100 | 9 | 100 | 4
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for 26 wk | 400 | 17^a^ | 400 | 12^a^

LD = lactation day; NR = not reported.

a Result is statistically significant (p < 0.05) based on analysis of data by the study authors.

b 4.18 mg/m^3^ = 1 ppm.

-For controls, no response relevant; for other doses, no quantitative response reported.

Note: Percent change compared with controls calculated as 100 × [(treated value – control value) ÷ control value].

Table 1-11 Evidence pertaining to liver histopathology effects in animals exposed to ETBE

Reference and study design | Results
Gaoua (2004b); Rat, S-D; oral―gavage; P0, male (25/group): 0, 250, 500, or 1,000 mg/kg-d; daily for a total of 18 wk beginning 10 wk before mating until after weaning of the pups; P0, female (25/group): 0, 250, 500, or 1,000 mg/kg-d; daily for a total of 18 wk beginning 10 wk before mating until PND 21 | P0, Male | | P0, Female
| Dose (mg/kg-d) | Incidence of centrilobular hypertrophy | Dose (mg/kg-d) | Incidence of centrilobular hypertrophy
| 0 | 0/25 | 0 | 0/25
| 250 | 0/25 | 250 | 0/25
| 500 | 0/25 | 500 | 0/25
| 1,000 | 3/25 | 1,000 | 0/25
JPEC (2008b); Rat, Crl:CD(SD); inhalation―vapor; male (NR): 0, 150, 500, 1,500, or 5,000 ppm (0, 627, 2,090, 6,270, or 20,900 mg/m^3^);^a^ female (NR): 0, 150, 500, 1,500, or 5,000 ppm (0, 627, 2,090, 6,270, or 20,900 mg/m^3^); dynamic whole-body chamber; 6 h/d, 5 d/wk for 13 wk; generation method, analytical concentration, and method reported | Male | | Female
| Dose (mg/m^3^) | Incidence of centrilobular hypertrophy | Dose (mg/m^3^) | Incidence of centrilobular hypertrophy
| 0 | 0/10 | 0 | 0/10
| 627 | 0/10 | 627 | 0/10
| 2,090 | 0/10 | 2,090 | 0/10
| 6,270 | 0/10 | 6,270 | 0/10
| 20,900 | 4/10^b^ | 20,900 | 6/10^b^
JPEC (2008b); Rat, Crl:CD(SD); inhalation―vapor; male (6/group): 0 or 5,000 ppm (0 or 20,900 mg/m^3^);^a^ female (6/group): 0 or 5,000 ppm (0 or 20,900 mg/m^3^)^a^; dynamic whole-body chamber; 6 h/d, 5 d/wk for 13 wk followed by a 28-d recovery period; generation method, analytical concentration, and method reported | Male | | Female
| Dose (mg/m^3^) | Incidence of centrilobular hypertrophy | Dose (mg/m^3^) | Incidence of centrilobular hypertrophy
| 0 | 0/6 | 0 | 0/6
| 20,900 | 0/6 | 20,900 | 0/6
Medinsky et al. (1999); U.S. EPA (1997); Rat, F344; inhalation―vapor; male (48/group): 0, 500, 1,750, or 5,000 ppm (0, 2,090, 7,320, or 20,900 mg/m^3^);^a^ female (48/group): 0, 500, 1,750, or 5,000 ppm (0, 2,090, 7,320, or 20,900 mg/m^3^);^a^; dynamic whole-body chamber; 6 h/d, 5 d/wk for 13 wk; generation method, analytical concentration, and method reported | Male | | Female
| Dose (mg/m^3^) | Incidence of centrilobular hypertrophy | Dose (mg/m^3^) | Incidence of centrilobular hypertrophy
| 0 | 0/11 | 0 | 0/10
| 2,090 | 0/11 | 2,090 | 0/11
| 7,320 | 0/11 | 7,320 | 0/11
| 20,900 | 0/11 | 20,900 | 0/11
Medinsky et al. (1999); Bond et al. (1996); Mice, CD-1; inhalation―vapor; male (40/group): 0, 500, 1,750, or 5,000 ppm (0, 2,090, 7,320, or 20,900 mg/m^3^);^a^ female (40/group): 0, 500, 1,750, or 5,000 ppm (0, 2,090, 7,320, or 20,900 mg/m^3^)^a^; dynamic whole-body chamber; 6 h/d, 5 d/wk for 13 wk; generation method, analytical concentration, and method reported | Male | | Female
| Dose (mg/m^3^) | Incidence of centrilobular hypertrophy | Dose (mg/m^3^) | Incidence of centrilobular hypertrophy
| 0 | 0/15 | 0 | 0/13
| 2,090 | 0/15 | 2,090 | 2/15
| 7,320 | 2/15 | 7,320 | 1/15
| 20,900 | 8/10^b^ | 20,900 | 9/14^b^
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for 26 wk | Male | | Female
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for 26 wk | Dose (mg/kg-d) | Incidence of centrilobular hypertrophy | Dose (mg/kg-d) | Incidence of centrilobular hypertrophy
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for 26 wk | 0 | 0/15 | 0 | 0/15
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for 26 wk | 5 | 0/15 | 5 | 0/15
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for 26 wk | 25 | 0/15 | 25 | 0/15
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for 26 wk | 100 | 0/15 | 100 | 0/15
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for 26 wk | 400 | 6/15^b^ | 400 | 6/15^b^
Saito et al. (2013); JPEC (2010b); Rat, F344; inhalation―vapor; male (50/group): 0, 500, 1,500, or 5,000 ppm (0, 2,090, 6,270, or 20,900 mg/m^3^);^a^ female (50/group): 0, 500, 1,500, or 5,000 ppm (0, 2,090, 6,270, or 20,900 mg/m^3^)^a^; dynamic whole-body inhalation; 6 h/d, 5 d/wk for 104 wk; generation method, analytical concentration, and method reported | Male
| Dose (mg/m^3^) | Acidophilic foci in liver | Basophilic foci in liver | Bile duct hyperplasia | Centrilobular hypertrophy
| 0 | 31/50 | 18/50 | 48/50 | 0/50
| 2,090 | 28/50 | 10/50 | 44/50 | 0/50
| 6,270 | 36/49 | 13/49 | 46/49 | 0/49
| 20,900 | 39/50^b^ | 33/50^b^ | 41/50 | 0/50
| Female
| Dose (mg/m^3^) | Acidophilic foci in liver | Basophilic foci in liver | Bile duct hyperplasia | Centrilobular hypertrophy
| 0 | 2/50 | 36/50 | 5/50 | 0/50
| 2,090 | 1/50 | 31/50 | 8/50 | 0/50
| 6,270 | 4/50 | 32/50 | 7/50 | 0/50
| 20,900 | 2/50 | 28/50 | 6/50 | 0/50
Suzuki et al. (2012); JPEC (2010a); Rat, F344; oral―water; male (50/group): 0, 625, 2,500, or 10,000 ppm (0, 28, 121, or 542 mg/kg-d);^c^ female (50/group): 0, 625, 2,500, or 10,000 ppm (0, 46, 171, or 560 mg/kg-d)^c^; daily for 104 wk | Male
| Dose (mg/kg-d) | Acidophilic foci in liver | Basophilic foci in liver | Bile duct hyperplasia | Centrilobular hypertrophy
| 0 | 14/50 | 14/50 | 49/50 | 0/50
| 28 | 12/50 | 18/50 | 47/50 | 0/50
| 121 | 17/50 | 20/50 | 48/50 | 0/50
| 542 | 13/50 | 22/50 | 47/50 | 0/50
| Female
| Dose (mg/kg-d) | Acidophilic foci in liver | Basophilic foci in liver | Bile duct hyperplasia | Centrilobular hypertrophy
| 0 | 2/50 | 36/50 | 1/50 | 0/50
| 46 | 2/50 | 25/50^b^ | 4/50 | 0/50
| 171 | 1/50 | 31/50 | 4/50 | 0/50
| 560 | 0/50 | 30/50^b^ | 3/50 | 0/50
Weng et al. (2012); Mice, C57BL/6; inhalation―vapor; male (5/group): 0, 500, 1,750, or 5,000 ppm (0, 2,090, 7,320, or 20,900 mg/m^3^);^a^ female (5/group): 0, 500, 1,750, or 5,000 ppm (0, 2,090, 7,320, or 20,900 mg/m^3^)^a^; dynamic whole-body chamber, 6 h/d, 5 d/wk for 13 wk; generation methods not reported, but analytical methods (gas chromatograph) and concentration reported | Male | | Female
| Dose (mg/m^3^) | Incidence of centrilobular hypertrophy | Dose (mg/m^3^) | Incidence of centrilobular hypertrophy
| 0 | 1/5 | 0 | 0/5
| 2,090 | 0/5 | 2,090 | 0/5
| 7,320 | 0/5 | 7,320 | 1/5
| 20,900 | 5/5^b^ | 20,900 | 5/5^b^
Weng et al. (2012); Mice, Aldh2 KO; inhalation―vapor; male (5/group): 0, 500, 1,750, or 5,000 ppm (0, 2,090, 7,320, or 20,900 mg/m^3^);^a^ female (5/group): 0, 500, 1,750, or 5,000 ppm (0, 2,090, 7,320, or 20,900 mg/m^3^)^a^; dynamic whole-body chamber, 6 h/d, 5 d/wk for 13 wk; generation methods were not reported, but analytical methods (gas chromatograph) and concentration reported | Male | | Female
| Dose (mg/m^3^) | Incidence of centrilobular hypertrophy | Dose (mg/m^3^) | Incidence of centrilobular hypertrophy
| 0 | 0/5 | 0 | 0/5
| 2,090 | 3/5 | 2,090 | 0/5
| 7,320 | 2/5 | 7,320 | 0/5
| 20,900 | 5/5^b^ | 20,900 | 4/5^b^

NR = not reported; PND = postnatal day.

a 4.18 mg/m^3^ = 1 ppm.

b Result is statistically significant (p < 0.05) based on analysis of data by the study authors.

c Conversion performed by study authors.

-For controls, no response relevant; for other doses, no quantitative response reported.

Table 1-12 Evidence pertaining to liver biochemistry effects in animals exposed to ETBE

Reference and study design | Results
JPEC (2008b); Rat, Crl:CD(SD); inhalation―vapor; male (NR): 0, 150, 500, 1,500, or 5,000 ppm (0, 627, 2,090, 6,270, or 20,900 mg/m^3^);^a^ female (NR): 0, 150, 500, 1,500, or 5,000 ppm (0, 627, 2,090, 6,270, or 20,900 mg/m^3^); dynamic whole-body chamber; 6 h/d, 5 d/wk for 13 wk; generation method, analytical concentration, and method reported | Response relative to control:
| Male
| Dose (mg/m^3^) | ALT (%) | ALP (%) | AST (%) | GGT (%)
| 0 | - | - | - | -
| 627 | 9 | 13 | 3 | 11
| 2,090 | 0 | 12 | 1 | 0
| 6,270 | 5 | −12 | −7 | 11
| 20,900 | 12 | −9 | 4 | −100
| Female
| Dose (mg/m^3^) | ALT (%) | ALP (%) | AST (%) | GGT (%)
| 0 | - | - | - | -
| 627 | − | −3 | 2 | 25
| 2,090 | 11 | −12 | −95 | 12
| 6,270 | −5 | −7 | 12 | 25
| 20,900 | 26 | 5 | 0 | 25
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for 180 d | Response relative to control:
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for 180 d | Male
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for 180 d | Dose (mg/kg-d) | ALT (%) | ALP (%) | AST (%) | GGT (%)
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for 180 d | 0 | - | - | - | -
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for 180 d | 5 | 10 | 2 | 1 | 25
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for 180 d | 25 | 48 | 12 | 19 | 50
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for 180 d | 100 | 13 | −7 | 20 | 25
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for 180 d | 400 | 35 | 27 | 23 | 100
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for 180 d | Female
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for 180 d | Dose (mg/kg-d) | ALT (%) | ALP (%) | AST (%) | GGT (%)
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for 180 d | 0 | - | - | - | -
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for 180 d | 5 | 11 | 6 | 10 | 40
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for 180 d | 25 | 21 | −21 | 13 | 20
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for 180 d | 100 | 46 | −18 | 19 | 0
Miyata et al. (2013); JPEC (2008c); Rat, Crl:CD(SD); oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for 180 d | 400 | 21 | −19 | 4 | −20
Saito et al. (2013); JPEC (2010b); Rat, F344; inhalation―vapor; male (50/group): 0, 500, 1,500, or 5,000 ppm (0, 2,090, 6,270, or 20,900 mg/m^3^);^a^ female (50/group): 0, 500, 1,500, or 5,000 ppm (0, 2,090, 6,270, or 20,900 mg/m^3^)^a^; dynamic whole-body inhalation; 6 h/d, 5 d/wk for 104 wk; generation method, analytical concentration, and method reported | Response relative to control:
| Male
| Dose (mg/m^3^) | ALT (%) | ALP (%) | AST (%) | GGT (%)
| 0 | - | - | - | -
| 2,090 | 53 | 0 | 29 | 33
| 6,270 | −3 | −21^b^ | −16 | 50^b^
| 20,900 | 24 | −5 | −2^b^ | 200^b^
| Female
| Dose (mg/m^3^) | ALT (%) | ALP (%) | AST (%) | GGT (%)
| 0 | - | - | - | -
| 2,090 | 2 | 12 | 22 | 50
| 6,270 | −5 | −4 | 10 | 0
| 20,900 | 4^b^ | 4 | 18^b^ | 150
Suzuki et al. (2012); JPEC (2010a); Rat, F344; oral―water; male (50/group): 0, 625, 2,500, or 10,000 ppm (0, 28, 121, 542 mg/kg-d);^c^ female (50/group): 0, 625, 2,500, or 10,000 ppm (0, 46, 171, 560 mg/kg-d);^c^; daily for 104 wk | Response relative to control:
| Male
| Dose (mg/kg-d) | ALT (%) | ALP (%) | AST (%) | GGT (%)
| 0 | - | - | - | -
| 28 | −17 | −5 | −21 | 0
| 121 | 2 | 3 | −3 | 43^b^
| 542 | −4 | 0 | −1 | 29
| Female
| Dose (mg/kg-d) | ALT (%) | ALP (%) | AST (%) | GGT (%)
| 0 | - | - | - | -
| 46 | −10 | −16 | −19 | 0
| 171 | −15 | 2 | −1 | 0
| 560 | −26 | −15 | −46^b^ | 33

NR = not reported.

a 4.18 mg/m^3^ = 1 ppm.

b Result is statistically significant (p < 0.05) based on analysis of data by the study authors.

c Conversion performed by the study authors.

-For controls, no response relevant; for other doses, no quantitative response reported.

Note: Percent change compared to controls calculated as 100 × [(treated value – control value) ÷ control value].

Figure 1-9 Exposure-response array of noncancer liver effects following oral exposure to ETBE

Figure 1-10 Exposure-response array of noncancer liver effects following inhalation exposure to ETBE

Table 1-13 Evidence pertaining to liver tumor effects in animals exposed to ETBE

Reference and study design | Results
Hepatocellular adenoma and carcinoma
Suzuki et al. (2012); JPEC (2010a); Rat, F344; oral―drinking water; male (50/group): 0, 625, 2,500, or 10,000 ppm (0, 28, 121, or 542 mg/kg-d);^a^ female (50/group): 0, 625, 2,500, or 10,000 ppm (0, 46, 171, or 560 mg/kg-d)^a^; daily for 104 wk | Male
| Dose (mg/kg-d) | Adenoma | Carcinoma | Adenoma or carcinoma
| 0 | 2/50 | 2/50 | 4/50
| 28 | 0/50 | 0/50 | 0/50
| 121 | 0/50 | 0/50 | 0/50
| 542 | 0/50 | 0/50 | 0/50
| Female
| Dose (mg/kg-d) | Adenoma | Carcinoma | Adenoma or carcinoma
| 0 | 0/50 | 0/50 | 0/50
| 46 | 0/50 | 0/50 | 0/50
| 171 | 0/50 | 0/50 | 0/50
| 560 | 1/50 | 0/50 | 1/50
Maltoni et al. (1999); Rat, S-D; oral―gavage in olive oil; male (60/group): 0, 250, or 1,000 mg/kg-d; female (60/group): 0, 250, or 1,000 mg/kg-d 4 d/wk for 104 wk; observed until natural death (depressed survival 25−28% seen in controls at 104 wk); Note: Tumor data not reanalyzed by Malarkey and Bucher (2011). | Male | | Female
| Dose (mg/kg-d) | Adenoma or carcinoma | Dose (mg/kg-d) | Adenoma or carcinoma
| 0 | 0/60 | 0 | 0/60
| 250 | 0/60 | 250 | 0/60
| 1,000 | 0/60 | 1,000 | 0/60
Saito et al. (2013); JPEC (2010b); Rat, F344; inhalation―vapor; male (50/group): 0, 500, 1,500, or 5,000 ppm (0, 2,090, 6,270, or 20,900 mg/m^3^);^b^ female (50/group): 0, 500, 1,500, or 5,000 ppm (0, 2,090, 6,270, or 20,900 mg/m^3^)^b^; dynamic whole-body inhalation; 6 h/d, 5 d/wk for 104 wk; generation method, analytical concentration, and method reported | Male
| Dose (mg/m^3^) | Adenoma | Carcinoma | Adenoma or carcinoma
| 0 | 0/50 | 0/50 | 0/50
| 2,090 | 2/50 | 0/50 | 2/50
| 6,270 | 1/50 | 0/50 | 1/50
| 20,900 | 9/50^c^ | 1/50 | 10/50^c^
| Female
| Dose (mg/m^3^) | Adenoma | Carcinoma | Adenoma or carcinoma
| 0 | 1/50 | 0/50 | 1/50
| 2,090 | 0/50 | 0/50 | 0/50
| 6,270 | 1/50 | 0/50 | 1/50
| 20,900 | 1/50 | 0/50 | 1/50
Initiation-promotion studies
Hagiwara et al. (2011); JPEC (2008d); Rat, F344; oral―gavage in olive oil; male (30/group): 0, 300, or 1,000 mg/kg-d; daily for 23 wk following a 4-wk tumor initiation by DMBDD^d^ | Male
Hagiwara et al. (2011); JPEC (2008d); Rat, F344; oral―gavage in olive oil; male (30/group): 0, 300, or 1,000 mg/kg-d; daily for 23 wk following a 4-wk tumor initiation by DMBDD^d^ | Dose (mg/kg-d) | Adenoma | Carcinoma
Hagiwara et al. (2011); JPEC (2008d); Rat, F344; oral―gavage in olive oil; male (30/group): 0, 300, or 1,000 mg/kg-d; daily for 23 wk following a 4-wk tumor initiation by DMBDD^d^ | 0 | 0/30 | 1/30
Hagiwara et al. (2011); JPEC (2008d); Rat, F344; oral―gavage in olive oil; male (30/group): 0, 300, or 1,000 mg/kg-d; daily for 23 wk following a 4-wk tumor initiation by DMBDD^d^ | 300 | 1/30 | 0/30
Hagiwara et al. (2011); JPEC (2008d); Rat, F344; oral―gavage in olive oil; male (30/group): 0, 300, or 1,000 mg/kg-d; daily for 23 wk following a 4-wk tumor initiation by DMBDD^d^ | 1,000 | 6/30^c^ | 0/30
Hagiwara et al. (2011); JPEC (2008d); Rat, F344; oral―gavage in olive oil; male (30/group): 0, 300, or 1,000 mg/kg-d; daily for 23 wk following a 4-wk tumor initiation by DMBDD^d^ | 0^e^ | 0/12 | 0/12
Hagiwara et al. (2011); JPEC (2008d); Rat, F344; oral―gavage in olive oil; male (30/group): 0, 300, or 1,000 mg/kg-d; daily for 23 wk following a 4-wk tumor initiation by DMBDD^d^ | 1,000^e^ | 0/12 | 0/12
Hagiwara et al. (2015); Rat, Wistar; oral―gavage in olive oil; male (30/group): 0,100, 300, 500, or 1,000 mg/kg-d; daily for 19 wk following 2-wk tumor initiation by; N-ethyl-N-hydroxyethylnitrosamine (EHEN) | Male
| Dose (mg/kg-d) | Adenoma | Carcinoma | Adenoma or carcinoma
| 0 | 4/30 | 0/30 | 4/30
| 100 | 5/30 | 2/30 | 7/30
| 300 | 8/30 | 0/30 | 8/30
| 500 | 8/30 | 3/30 | 10/30
| 1,000 | 15/30^c^ | 5/30^c^ | 17/30^c^

a Conversion performed by the study authors.

b 4.18 mg/m^3^ = 1 ppm.

c Result is statistically significant (p < 0.05) based on analysis of data by study authors.

d DMBDD = diethylnitrosamine (DEN), N-butyl-N-(4-hydroxybutyl)nitrosamine (BBN), N-methyl-N-nitrosourea (MNU), 1,2-dimethylhydrazine dihydrochloride (DMH), and N-bis(2-hydroxypropyl)nitrosamine (DHPN).

e No DMBDD initiation.

-For controls, no response relevant; for other doses, no quantitative response reported.

#### Mode-of-Action Analysis―Liver Effects

##### Key characteristics of carcinogens

Mechanistic information was grouped into 10 “key characteristics” useful for summarizing and organizing the mechanistic data relevant to carcinogens (Smith et al., 2016). The evidence available for each characteristic is summarized in Table 1-14. Altogether, experimental evidence informing several of the key characteristics of carcinogens was identified in the available literature. ETBE was found to have the potential to form electrophilic metabolites, but it was concluded that there was inadequate evidence that ETBE induces any of the remaining key characteristics.

Table 1-14 Evidence of key characteristics of carcinogens for ETBE

Characteristic | Evidence
1. Is electrophilic or can be metabolically activated to electrophiles | Metabolized to acetaldehyde in the liver^a,b^
2. Is genotoxic | Inadequate evidence to draw a conclusion from 12 studies examining micronucleus, DNA strand breaks, chromosomal aberration, and gene mutation assays^b,c^
3. Alters DNA repair or causes genomic instability | No pertinent studies identified
4. Induces epigenetic alterations | No pertinent studies identified
5. Induces oxidative stress | Inadequate evidence to draw a conclusion from three studies examining 8-OHdG, 8-hOGG1 formation^b,d^
6. Induces chronic inflammation | No pertinent studies identified
7. Is immunosuppressive | No pertinent studies identified
8. Modulates receptor-mediated effects | Inadequate evidence to draw a conclusion from two studies examining PPAR, CAR, and PXR activation^e^
9. Causes immortalization | No pertinent studies identified
10. Alters cell proliferation, cell death, or nutrient supply | Inadequate evidence to draw a conclusion from three studies examining basophilic, acidophilic foci, and cellular proliferation^e^

CAR = constitutive androstane receptor; PPAR = peroxisome proliferator-activated receptor; PXR = pregnane X receptor.

a See Supplemental Information Section B.1.3.

b See Acetaldehyde-mediated liver toxicity and genotoxicity in this section.

c See Supplemental Information Section B.2.2.

d See Oxidative stress in this section.

e See Receptor-mediated effects in this section.

##### Toxicokinetic considerations relevant to liver toxicity and tumors

ETBE is metabolized by CYP450 enzymes to an unstable hemiacetal that decomposes spontaneously into tert-butanol and acetaldehyde (Bernauer et al., 1998). Acetaldehyde is further metabolized in the liver by ALDH2, while tert-butanol undergoes systemic circulation and ultimate excretion in urine. Thus, following ETBE exposure, the liver is exposed to both acetaldehyde and tert-butanol, so the liver effects caused by tert-butanol (described in more detail in the IRIS assessment of tert-butanol) and acetaldehyde are relevant to evaluating the MOA for liver effects observed after ETBE exposure.

tert-Butanol induces thyroid tumors in mice and kidney tumors in male rats but has not been observed to affect the incidence of rodent liver tumors following a 2-year oral exposure. Although some data suggest tert-butanol could be genotoxic, the overall evidence is inadequate to establish a conclusion. One study reported that tert-butanol might induce centrilobular hypertrophy in mice after 2 weeks (Blanck et al., 2010), but no related liver pathology was observed in other repeat-exposure rodent studies, including both subchronic and 2-year bioassays. Although Blanck et al. (2010) reported some limited induction of mouse liver enzymes following short-term tert-butanol exposure, no corresponding evidence exists in rats following any exposure duration. Therefore, a role for tert-butanol in liver carcinogenesis of ETBE appears unlikely.

In comparison, acetaldehyde associated with the consumption of alcoholic beverages is genotoxic and mutagenic (IARC, 1999a), and acetaldehyde produced in the liver as a result of ethanol metabolism has been suggested to be a contributor to ethanol-related liver toxicity and cancer (Setshedi et al., 2010). Additional discussion on the potential role of acetaldehyde in the liver carcinogenesis of ETBE is provided below.

##### Receptor-mediated effects

ETBE exposure consistently increased relative liver weights in male and female rats and increased hepatocellular adenomas and carcinomas in males (Saito et al., 2013; JPEC, 2010b). In addition to the increased centrilobular hypertrophy, which is one possible indication of liver enzyme induction, chronic-exposure-induced focal proliferative lesions (including basophilic and acidophilic foci) could be more directly related to tumorigenesis. The centrilobular hypertrophy was increased in rats of both sexes via both oral and inhalation exposure at subchronic time points; but not at 2 years, although significantly increased liver weight was observed. However, liver tumors were only observed in one sex (males) following one route of exposure (inhalation), indicating that subchronic hypertrophy may not be associated with later tumor development. This process was investigated in several studies to determine whether nuclear receptor activation is involved.

Centrilobular hypertrophy is induced through several possible mechanisms, some of which occur by activating nuclear hormone receptors such as peroxisome proliferator-activated receptor α (PPARα), pregnane X receptor (PXR), and the constitutive androstane receptor (CAR). The sequence of key events hypothesized for PPARα induction of liver tumors is as follows: activation of PPARα, upregulation of peroxisomal genes, induction of gene expression driving PPARα-mediated growth and apoptosis, disrupted cell proliferation and apoptosis, peroxisome proliferation, preneoplastic foci, and tumors (Klaunig et al., 2003). The sequence of key events hypothesized for CAR-mediated liver tumors is as follows: CAR activation, altered gene expression as a result of CAR activation, increased cell proliferation, clonal expansion leading to altered foci, and liver adenomas and carcinomas (Elcombe et al., 2014). PXR, which has no established MOA, is hypothesized to progress from PXR activation to liver tumors in a similar manner as CAR. This progression would include PXR activation, cell proliferation, hypertrophy, CYP3A induction, and clonal expansion resulting in foci development. One study that orally exposed male rats to low and high concentrations of ETBE reported that several key sequences in the PPARα, PXR, and CAR pathways were affected (Kakehashi et al., 2013).

###### PPAR

Limited evidence suggests that ETBE could activate PPAR-mediated events (Kakehashi et al., 2013). For instance, messenger ribonucleic acid (mRNA) expression was significantly elevated for PPARα and PPARγ after 1 week of exposure but not after 2 weeks. In addition, several PPARα-mediated proteins, such as ACOX1, CYP4A2, and ECH1, involved in lipid and xenobiotic metabolism were upregulated in the liver after 2 weeks of exposure. Additional effects in the PPAR pathway such as DNA damage (8-OHdG) and apoptosis (ssDNA) also were significantly increased after 2 weeks at the highest concentration of ETBE. Cell proliferation was increased after 3 days (Kakehashi et al., 2015), unchanged after 1 week, significantly decreased after 2 weeks (Kakehashi et al., 2013), and increased after 28 days (Kakehashi et al., 2015). The number of peroxisomes per hepatocyte was increased greater than fivefold after 2 weeks of treatments. Finally, the incidences of preneoplastic basophilic and acidophilic foci were significantly increased in males after 2 years of inhalation exposure to ETBE (Saito et al., 2013; JPEC, 2010b).

PPARα-mediated genes were investigated in one study (Kakehashi et al., 2013). The high dose of ETBE (2,000 mg/kg-day), which induced the most consistent changes in PPARα, Cyp4a, Cyp1a, and Cyp3a in the gavage study (Kakehashi et al., 2013) yielded a higher internal metabolic rate in the liver (3.98 mg ETBE/hr) than from the 20,700 mg ETBE/m^3^ inhalation dose (3.34 mg ETBE/hr) that increased liver tumors in the 2-year inhalation study (Saito et al., 2013; JPEC, 2010b). Only Cyp2b genes associated with PPARα expression were affected at the low gavage dose (300 mg/kg-day), thus demonstrating poor dose-response relationships between PPAR-mediated genes and downstream effects. Finally, PPAR agonists typically decrease rates of apoptosis early in the process, which is in contrast to the increased rate of apoptosis observed after 2 weeks of ETBE exposure (Kakehashi et al., 2013). However, several measures required for a full evaluation of the PPAR MOA were absent. Selective clonal expansion and gap junction intercellular communication were not examined in any study. No evidence is available in wild-type or PPARα-null mice to demonstrate whether PPARα gene expression changes in knockout (KO) mice. Overall, these data are inadequate to conclude that ETBE induces liver tumors via a PPARα MOA.

###### CAR/PXR

Kakehashi et al. (2013) reported several CAR- and PXR-mediated events following ETBE exposure. After 2 weeks of exposure at the high dose of ETBE, CAR- and PXR-regulated xenobiotic metabolic enzymes were upregulated, including Cyp2b1, Cyp2b2, Cyp3a1, and Cyp3a2 as determined by mRNA or protein expression. Other PXR/CAR-regulated genes such as Sult1d1, Ugt2b5, and Ugt1a1 also had elevated mRNA expression after 1 and 2 weeks of exposure, which all suggest activation of CAR and PXR. However, with the exception of Cyp2b, these genes were only increased at the high dose, which yielded an internal rate of ETBE metabolism (3.98 mg/hr) that was greater than the metabolism rate (3.34 mg/hr) associated with liver tumors in the 2-year inhalation study (Saito et al., 2013; JPEC, 2010b). Histological evidence (preneoplastic foci) supporting increased liver cell proliferation is available following chronic, but not subchronic exposures (Saito et al., 2013; JPEC, 2010b). Several data gaps, such as a lack of clonal expansion and gap junction communication, were not evaluated. These data provide evidence that CAR and PXR are activated at high concentrations in the liver following acute ETBE exposure. Furthermore, the data do not provide enough information to determine dose-response relationships or temporal associations, which are helpful for establishing an MOA. Altogether, these data are inadequate to conclude that ETBE induces liver tumors via a CAR/PXR MOA.

In summary, several gaps in the receptor-mediated effects data (for PPARα, CAR, and PXR) are noted such as evidence in only one species, lack of any studies in PPAR KO mice, lack of dose response concordance between receptor-mediated gene changes and tumors, and lack of any receptor-mediated data outside of the 1 and 2 week time points, which preclude establishing temporal associations. Overall, these data are inadequate to conclude that ETBE induces liver tumors via a PPARα or CAR/PXR MOA.

##### Acetaldehyde-mediated liver toxicity and genotoxicity

Another possible MOA for increased tumors could be genotoxicity and mutagenicity resulting from the production of acetaldehyde in the liver, the primary site for ETBE metabolism. Acetaldehyde produced as a result of metabolism of alcohol consumption is considered carcinogenic to humans, although evidence is not sufficient to show that acetaldehyde formed in this manner causes liver carcinogenesis (IARC, 2012). Acetaldehyde administered directly has been shown to increase the incidence of carcinomas following inhalation exposure in the nasal mucosa and larynx of rats and hamsters. Furthermore, acetaldehyde has induced sister chromatid exchanges in Chinese hamster ovary cells, gene mutations in mouse lymphomas, and DNA strand breaks in human lymphocytes (IARC, 1999a). Acetaldehyde has been shown to have an inhibitory effect on PPARα transcriptional activity (Venkata et al., 2008), although no effect of acetaldehyde on CAR or PXR activation has been established. Additionally, the acetaldehyde metabolic enzyme aldehyde dehydrogenase 2 (ALDH2) is polymorphic in the human population, which contributes to enhanced sensitivity to the effects of acetaldehyde among some subpopulations such as people of East Asian origin (IARC, 2012; Brennan et al., 2004). IARC (2012) found that ALDH2 status was associated with increased esophageal cancer. Although IARC (2012) found inconclusive evidence for a contribution of ALDH2 to liver cancer, Eriksson (2015) concluded that reduced aldehyde metabolism is associated with liver cancer by further analyzing the ALDH2 compositions of the controls in the case-control studies.

Several studies have examined the role of acetaldehyde and the metabolizing enzyme ALDH2 in genotoxicity and centrilobular hypertrophy following ETBE exposure. Ninety-day inhalation exposure to ETBE significantly increased the incidence of centrilobular hypertrophy in male Aldh2 KO mice compared with WT, while females appeared to be less sensitive, similar to controls (Weng et al., 2012). Hepatocyte DNA damage as determined by DNA strand breaks, and oxidative base modification was increased at the highest concentration of ETBE exposure in the WT males, but not in WT females. Measures of DNA damage were all statistically significantly increased in both male and female Aldh2 KO mice (Weng et al., 2012). Further demonstrating enhanced genotoxic sensitivity in males compared with females, erythrocyte micronucleus assays and oxidative DNA damage (8-hOGG1) in leukocytes were observed to be statistically significantly increased and dose responsive only in male Aldh2 KO mice (Weng et al., 2013). Together, although these data suggest a potential role for acetaldehyde in the increased liver tumor response observed in male rats exposed to ETBE, the available data are inadequate to conclude that ETBE induces liver tumors via acetaldehyde-mediated mutagenicity.

##### Oxidative stress

Studies with pertinent information on oxidative stress are limited to several that measured oxidative DNA damage in leukocytes and hepatocytes in mice (Weng et al., 2012) and one study in the liver of rats (Kakehashi et al., 2013). Male mice had increased levels of 8-OHdG in hepatocytes after 13 weeks of inhalation exposure to the concentration of ETBE that induced liver tumors following 2 years of inhalation exposure. No significant dose response was reported. Similarly, 8-OHdG was increased after 2 weeks of gavage in rats (Kakehashi et al., 2013) at a concentration twofold greater than that inducing rat liver tumors in two-stage initiation-promotion assays (Hagiwara et al., 2015; Hagiwara et al., 2011). In addition, as discussed in the previous paragraph, oxidative DNA damage was also induced in Aldh2 KO mice (Weng et al., 2013) and Aldh2 heterozygous mice (Weng et al., 2019). Overall, these data are inadequate to conclude that ETBE induces liver tumors via oxidative stress.

#### Overall Conclusions on Mode of Action (MOA) for Liver Effects

Several reviews of the available mechanistic data suggest that the PPAR, PXR, and CAR pathways induce liver tumors in a manner not relevant to humans (Elcombe et al., 2014; Klaunig et al., 2003), although this conclusion has been questioned (Guyton et al., 2009). The database is inadequate to determine whether nuclear receptor-mediated pathways (i.e., PPAR and CAR/PXR) contribute to the tumorigenesis observed in ETBE-treated male rats. Furthermore, centrilobular hypertrophy was observed at the same concentrations that induced liver-weight changes in rats of both sexes after 13-week inhalation and 26-week oral exposure, yet liver tumors were observed only following oral exposure in male rats. This observation suggests that these effects are not associated with the observed rat liver tumorigenesis. Therefore, given the available data, ETBE-induced liver tumors in male rats are relevant to human hazard identification and are scientifically supported.

Evidence suggests that metabolism of ETBE to acetaldehyde could contribute to ETBE-induced liver carcinogenesis. For instance, enhancement of ETBE-induced liver toxicity and genotoxicity has been reported in Aldh2-deficient mice, which have an impaired ability to metabolize acetaldehyde (Weng et al., 2013; Weng et al., 2012). The database, however, is inadequate to conclude that ETBE induces liver tumors via acetaldehyde-mediated mutagenic MOA.

#### Integration of Liver Effects

Liver effects were observed in oral and inhalation studies with exposure durations of 13 weeks to 2 years. Evidence for ETBE-induced noncancer liver effects is available from rat and mouse studies, which show centrilobular hypertrophy, increased liver weight, and changes in serum liver enzyme levels. Based on dose-related increases in relative liver weight, and increases in hepatocellular hypertrophy in male and female rats, contrasted with the poor temporal correlation of serum biomarkers and pathological lesions indicative of accumulating liver damage, evidence of liver effects associated with ETBE exposure is suggestive. The hazard and dose-response conclusions regarding these noncancer endpoints associated with ETBE exposure are further discussed in Section 1.3.1.

The carcinogenic effects observed include increased hepatocellular adenomas and carcinomas in males in a 2-year bioassay and ETBE-promoted liver tumorigenesis after 23 weeks following mutagen pretreatment. Although only one carcinoma was observed, rodent liver adenomas can progress to malignancy, eventually forming carcinomas (Liau et al., 2013; McConnell et al., 1986). Mechanistic data on the role of PPAR, PXR, and CAR activation in liver tumorigenesis were inadequate to conclude that these pathways mediate tumor formation. Additional mechanistic studies in transgenic mice suggest that lack of Aldh2 enhances ETBE-induced liver toxicity and genotoxicity, which is consistent with the observed genotoxicity being mediated by the ETBE metabolite acetaldehyde, although the database is inadequate to conclude that ETBE induces liver tumors via this MOA. The hazard and dose-response conclusions regarding the liver tumors associated with ETBE exposure are further discussed as part of the overall weight of evidence for carcinogenicity in Section 1.3.2.

### 1.2.3 Reproductive Effects

#### Synthesis of Effects Related to Male Reproduction

The database examining male reproductive effects from ETBE exposure consists of data from rats and mice but not humans. Effects on male reproduction, including fertility, male reproductive organ weights, histopathology, sperm parameters, and hormone levels were evaluated in a one-generation oral study (Fujii et al., 2010), a two-generation oral study (Gaoua, 2004b), 13- and 9-week inhalation studies (Weng et al., 2014), and a 14-day oral study (de Peyster et al., 2009). Additional data on male reproductive organ weights and histopathology were obtained from two 2-year carcinogenicity studies [oral: Suzuki et al. (2012); JPEC (2010a); inhalation: Saito et al. (2013); JPEC (2010b)], a medium-term carcinogenicity study (23-week oral exposure) (Hagiwara et al., 2011; JPEC, 2008d), a 180-day oral study (Miyata et al., 2013; JPEC, 2008c), a 90-day inhalation study (JPEC, 2008b), and a 13-week inhalation study (Medinsky et al., 1999). These studies were conducted in S-D rats, F344 rats, CD-1 mice, and C57BL/6 mice, and the design, conduct, and reporting of each study were of sufficient quality to inform human health hazard assessment. Selected endpoints from these studies are summarized in Table 1-15.

The one- and two-generation reproductive toxicity studies found no effects on copulation, fertility, or sperm parameters in adult male S-D rats exposed to ETBE by gavage at concentrations up to 1,000 mg/kg-day for 10 weeks prior to mating (Fujii et al., 2010; Gaoua, 2004b), nor in F1 male offspring exposed during gestation, lactation, and postweaning in the diet (Gaoua, 2004b). No dose-related changes in testicular histopathology were observed in F0 or F1 males (Gaoua, 2004b). Furthermore, no dose-related histopathological changes or significant changes in absolute male reproductive organ weight were observed in the 2-year carcinogenicity studies in F344 rats at oral doses up to 542 mg/kg-day (Suzuki et al., 2012; JPEC, 2010a) or at inhalation exposure concentrations up to 20,900 mg/m^3^ (Saito et al., 2013; JPEC, 2010b); in the medium-term carcinogenicity study in F344 rats (Hagiwara et al., 2011; JPEC, 2008d); in the 180-day oral study in S-D rats at doses up to 400 mg/kg-day (Miyata et al., 2013; JPEC, 2008c); in the 90-day inhalation study in S-D rats at doses up to 20,900 mg/m^3^ (JPEC, 2008b); or in the 14-day oral study in F344 rats at doses up to 1,800 mg/kg-day (de Peyster et al., 2009). In some cases, dose-related increases in relative organ weights were observed, including significant increases in relative testis weight (Fujii et al., 2010; JPEC, 2010b; Gaoua, 2004b) and relative prostate weight (Gaoua, 2004b) at the highest doses tested, which may have been attributable to reduced body-weight gain in these groups.

In contrast, testicular degeneration was observed in two 13-week ETBE inhalation studies in which rats and mice were exposed to concentrations ranging from 2,090−20,900 mg/m^3^. In F344 rats, a statistically significant increase in the percentage of seminiferous tubules with spermatocyte degeneration was observed; however, there were no significant microscopic findings in CD-1 mice under these same exposure conditions and no changes in male reproductive organ weights in rats or mice (Medinsky et al., 1999). In C57BL/6 wild-type and Aldh2 KO mice, there was a dose-related increase in the incidence of atrophy of seminiferous tubules (described by the authors as “slight” or “extremely slight” atrophy), with a greater incidence of atrophy occurring in Aldh2 KO mice than in wild type (Weng et al., 2014). ETBE-exposed mice also had significant decreases in sperm head numbers and sperm mobility (expressed as the percentage of motile sperm, percentage of static sperm, and percentage of sperm with rapid movement) and a significant increase in sperm DNA damage (expressed as strand breaks and oxidative DNA damage), with effects on sperm parameters reaching statistical significance at lower exposure concentrations in Aldh2 KO mice (2,090 mg/m^3^) compared with wild type (7,320−20,090 mg/m^3^). Significantly decreased epididymis weight was observed in Aldh2 KO mice but not wild-type mice.

Weng et al. (2014) also conducted a 9-week inhalation study using lower ETBE exposure concentrations (209−2,090 mg/m^3^) and three mouse genotypes (wild type, Aldh2−/−, and Aldh2 heterozygous; n = 5/group). Wild-type mice had little to no change in male reproductive organ weights or sperm parameters at any of the tested concentrations, whereas significant effects were observed on sperm count, sperm mobility, and sperm DNA damage in Aldh2−/− and heterozygous mice at exposure concentrations as low as 836 mg/m^3^ ETBE. Aldh2 heterozygous mice had significantly decreased relative testis and epididymis weight in the 20,090 mg/m^3^ exposure group. However, for unknown reasons, several reproductive effects were noted to be more pronounced in the heterozygous mice than in the Aldh2−/− mice. Taken together, the results of Weng et al. (2014) indicated that populations with inactive Aldh2 variants may be more susceptible to male reproductive toxicity following exposure to ETBE. However, these effects are considered to be preliminary because of the small sample size (n = 5) in one species and in one study, and the unconvincing magnitude of many of the statistically significant effects (including the observation that the heterozygotes exhibited more robust changes than the knockouts).

Although testicular lesions were not found in the 14-day oral study in F344 rats (de Peyster et al., 2009), plasma estradiol levels in these animals were increased by up to 106% compared with controls. Plasma testosterone in the 1,800 mg/kg-day dose group was decreased by 34% compared with controls, but the difference was not statistically significant and was not observed in any other ETBE dose group. The authors conducted a separate in vitro experiment to evaluate testosterone production in isolated S-D rat Leydig cells and found reduced testosterone production in ETBE-treated cells compared with controls (data not shown in evidence table).

Table 1-15 Evidence pertaining to male reproductive effects in animals exposed to ETBE

Reference and study design | Results
Male fertility
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | F0 generation—parent
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | Dose (mg/kg-d) | Copulation index (%) | Absolute change from control (%) | Fertility index (%) | Absolute change from control (%)
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 0 | 100 | - | 87.5 | -
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 100 | 91.7 | -8.3 | 100 | 12.5
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 300 | 95.8 | −4.2 | 95.7 | 8.2
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 1,000 | 100 | 0 | 91.7 | 4.2
Gaoua (2004b); Rat, S-D; oral―gavage; F0, male and female (25/sex/group): 0, 250, 500, or 1,000 mg/kg-d; dosed daily for 18 wk from 10 wk premating until weaning of F1 pups; F1, male and female (24−25/group): 0, 250, 500, or 1,000 mg/kg-d; dosed daily from PND 22 until weaning of F2 pups | F0 generation—parent
| Dose (mg/kg-d) | Male mating index (%) | Absolute change from control (%) | Male fertility index (%) | Absolute change from control (%)
| 0 | 100 | - | 92 | -
| 250 | 100 | 0 | 84 | −8
| 500 | 100 | 0 | 88 | −4
| 1,000 | 100 | 0 | 100 | 8
| F1 generation—offspring
| Dose (mg/kg-d) | Male mating index^a^ (%) | Absolute change from control (%) | Male fertility index^b^ (%) | Absolute change from control (%)
| 0 | 96 | - | 92 | -
| 250 | 96 | 0 | 92 | 0
| 500 | 100 | 4 | 88 | −4
| 1,000 | 96 | 0 | 96 | 4
Testicular histopathology
Medinsky et al. (1999); U.S. EPA (1997); Rat, F344; inhalation―vapor; male (48/group): 0, 500, 1,750, or 5,000 ppm (0, 2,090, 7,320, or 20,900 mg/m^3^);^a^ f; dynamic whole-body chamber; 6 h/d, 5 d/wk for 13 wk | Dose (mg/m^3^) | | Incidence of spermatocyte degeneration | | Incidence of sloughed epithelium
| 0 | | 11/11 | | 7/11
| 2,090 | | 11/11 | | 3/11
| 7,320 | | 11/11 | | 3/11
| 20,900 | | 10/11 | | 7/11
| Dose (mg/m^3^) | | Mean seminiferous tubules with spermatocyte degeneration (%) | | Absolute change from control (%)
| 0 | | 2.1 | | -
| 2,090 | | 2.4 | | 0
| 7,320 | | 7.8^c^ | | 6
| 20,900 | | 12.7^c^ | | 11
| Dose (mg/m^3^) | | Mean seminiferous tubules with luminal debris (%) | | Absolute change from control (%)
| 0 | | 2.1 | | -
| 2,090 | | 0.7 | | −1
| 7,320 | | 2.8 | | 1
| 20,900 | | 1 | | −1
Weng et al. (2014); Mice, C57BL/6; inhalation―vapor; male (5/group): 0, 500, 1,750, or 5,000 ppm (0, 2,090, 7,320, or 20,900 mg/m^3^)^a^; dynamic whole-body inhalation; 6 h/d, 5 d/wk for 13 wk; methods described in Weng et al. (2012) | Wild-type mice; 13-wk exposure
| Dose (mg/m^3^) | Incidence of “extremely slight” atrophy | | Incidence of “slight” atrophy | Total incidence of atrophy of seminiferous tubules
| 0 | 1/5 | | 0/5 | 1/5
| 2,090 | 0/5 | | 0/5 | 0/5
| 7,320 | 2/5 | | 0/5 | 2/5
| 20,900 | 3/5 | | 0/5 | 3/5
| Knockout mice (Aldh2-/-); 13-wk exposure
| Dose (mg/m^3^) | Incidence of “extremely slight” atrophy | | Incidence of “slight” atrophy | Total incidence of atrophy of seminiferous tubules
| 0 | 2/5 | | 0/5 | 2/5
| 2,090 | 2/5 | | 3/5 | 5/5
| 7,320 | 4/5 | | 1/5 | 5/5
| 20,900 | 3/5 | | 2/5 | 5/5
Sperm parameters
Gaoua (2004b); Rat, S-D; oral―gavage; F0, male and female (25/sex/group): 0, 250, 500, or 1,000 mg/kg-d; dosed daily for 18 wk from 10 wk premating until weaning of F1 pups; F1, male and female (24−25/group): 0, 250, 500, or 1,000 mg/kg-d; dosed daily from PND 22 until weaning of F2 pups | F0 males
| Dose (mg/kg-d) | Mean epididymal spermatozoa count (n) ± SD | % Change from control | Mean epididymal sperm motility (%) ± SD | Absolute change from control (%)
| 0 | 923 ± 200 | - | 99.7 ± 1.5 | -
| 250 | 938 ± 205 | 2 | 100 ± 0 | 0
| 500 | 935 ± 159 | 1 | 98.6 ± 4 | −1
| 1,000 | 918 ± 194 | −1 | 97.6 ± 6.6 | −2
| Dose (mg/kg-d) | Mean epididymal sperm with normal morphology (%) ± SD | Absolute change from control (%) | Mean testicular sperm heads (10^6^/gram of testis) ± SD | % Change from control
| 0 | 93 ± 19 | - | 114.8 ± 18.7 | -
| 250 | 93 ±19 | 0 | 109 ± 13.1 | −5
| 500 | 97 ± 2 | 4 | 108.1 ± 18.6 | −6
| 1,000 | 96 ± 2 | 3 | 109.8 ± 16.5 | −4
| Dose (mg/kg-d) | Mean daily testicular sperm production (10^6^/gram of testis) | % Change from control | n (epididymal sperm count) | n (other sperm parameters)
| 0 | 18.8 ± 3.1 | - | 25 | 25
| 250 | 17.9 ± 2.2 | −5 | 25 | 25
| 500 | 17.7 ± 3.1 | −6 | 25 | 25
| 1,000 | 18 ± 2.7 | −4 | 24 | 25
| F1 Males
| Dose (mg/kg-d) | Mean epididymal spermatozoa count (n) ± SD | % Change from control | Mean epididymal sperm motility (%) ± SD | Absolute change from control (%)
| 0 | 725 ± 150 | - | 84.6 ± 34.1 | -
| 250 | 673 ± 197 | −7 | 87.1 ± 31.6 | 3
| 500 | 701 ± 97 | −3 | 93.3 ± 22 | 9
| 1,000 | 688 ± 177 | −5 | 88.3 ± 29.4 | 4
| Dose (mg/kg-d) | Mean epididymal sperm with normal morphology (%) ± SD | Absolute change from control (%) | Mean testicular sperm heads (10^6^/gram of testis) ± SD | % Change from control
| 0 | 84 ± 30 | - | 100.6 ± 36.7 | -
| 250 | 86 ± 28 | 2 | 97.8 ± 32.3 | −3
| 500 | 86 ± 27 | 2 | 105.3 ± 27.2 | 5
| 1,000 | 88 ± 24 | 4 | 99.8 ± 38.9 | −1
| Dose (mg/kg-d) | Mean daily testicular sperm production (10^6^/gram of testis) | % change from control | n (epididymal sperm count) | n (other sperm parameters)
| 0 | 16.5 ± 6 | - | 22 | 24
| 250 | 16 ± 5.3 | −3 | 24 | 25
| 500 | 17.3 ± 4.5 | 5 | 23 | 24
| 1,000 | 16.4 ± 6.4 | −1 | 24 | 25
Weng et al. (2014); Mice, C57BL/6; inhalation―vapor; male (5/group): 0, 500, 1,750, or 5,000 ppm (0, 2,090, 7,320, or 20,900 mg/m^3^)^a^; dynamic whole-body inhalation; 6 h/d, 5 d/wk for 13 wk; methods described in Weng et al. (2012) | Wild-type mice; 13-wk exposure
| Dose (mg/m^3^) | Mean sperm head numbers (testis) (× 10^6^/g) ± SD | % Change from control | Motile sperm (epididymal) ± SE | Absolute change from control (%)
| 0 | 166.62 ± 21.9 | - | 67.34 ± 3.45 | -
| 2,090 | 167.74 ± 28.02 | 1 | 69.64 ± 3.45 | 2
| 7,320 | 167.78 ± 25.52 | 1 | 62.73 ± 1.73 | −5
| 20,900 | 150.94 ± 23.07 | −9 | 58.13 ± 2.30 | −9
| Dose (mg/m^3^) | % Static sperm (epididymal) | Absolute change from control (%) | % Sperm with rapid movement (epididymal) | Absolute change from control (%)
| 0 | 32.57 ± 3.00 | - | 55.00 ± 3.75 | -
| 2,090 | 30.86 ± 3.86 | −2 | 56.25 ± 3.13 | 1
| 7,320 | 37.29 ± 1.71 | 5 | 49.38 ± 3.13 | −6
| 20,900 | 42.43 ± 2.57 | 10 | 46.25^c^ ± 2.50 | −9
| Dose (mg/m^3^) | Epididymal sperm DNA breaks (tail intensity in comet assay) | % Change from control | Epididymal sperm DNA damage (measurement of 8-OHdG in comet assay) | % Change from control
| 0 | 4.91 ± 0.34 | - | 3.46 ± 0.45 | -
| 2,090 | 5.91 ± 0.35 | 20 | 4.23 ± 0.22 | 23
| 7,320 | 7.60^c^ ± 0.69 | 55 | 5.16^c^ ± 0.46 | 49
| 20,900 | 7.91^c^ ± 0.52 | 61 | 6.55 ± 1.13 | 89
| Knockout mice (Aldh2-/-); 13-wk exposure
| Dose (mg/m^3^) | Mean sperm head numbers (testis) (× 10^6^/g) ± SD | % Change from control | Motile sperm (epididymal) ± SE | Absolute change from control (%)
| 0 | 169.15 ± 28.33 | - | 75.07 ± 2.88 | -
| 2,090 | 127.08 ± 17.32 | −25 | 61.23 ± 5.03 | −14
| 7,320 | 124.6^c^ ± 11.96 | −26 | 61.05^c^ ± 5.75 | −16
| 20,900 | 124.72^c^ ± 18.72 | -26 | 57.27^c^ ± 5.77 | −20
| Dose (mg/m^3^) | % Static sperm (epididymal) | Absolute change from control (%) | % Sperm with rapid movement (epididymal) | Absolute change from control (%)
| 0 | 25.46 ± 2.56 | - | 66.74 ± 2.17 | -
| 2,090 | 40.34 ± 5.14 | 15 | 51.54 ± 2.84 | −15
| 7,320 | 41.51^c^ ± 5.57 | 16 | 47.74^c^ ± 5.66 | −19
| 20,900 | 45.27^c^ ± 5.58 | 20 | 45.03^c^ ± 3.97 | −22
| Dose (mg/m^3^) | Epididymal sperm DNA breaks (tail intensity in comet assay) | % Change from control | Epididymal sperm DNA damage (measurement of 8-OHdG in comet assay) | % Change from control
| 0 | 4.90 ± 0.52 | - | 3.64 ± 0.61 | -
| 2,090 | 7.71 ± 0.69 | 58 | 5.45 ± 0.15 | 50
| 7,320 | 10.44^c^ ± 0.78 | 113 | 7.65^c^ ± 0.61 | 110
| 20,900 | 9.46^c^ ± 0.69 | 93 | 7.95^c^ ± 1.52 | 119
Weng et al. (2014); Mice, C57BL/6; inhalation―vapor; male (NR): 0, 50, 200, or 500 ppm (0, 209, 836, or 2,090 mg/m^3^)^a^; dynamic whole-body inhalation; 6 h/d, 5 d/wk for 9 wk; methods described in Weng et al. (2012) | Wild-type mice; 9-wk exposure
| Dose (mg/m^3^) | Mean sperm head numbers (testis) (× 10^6^/g) ± SD | % Change from control | Motile sperm (epididymal) ± SE | Absolute change from control (%)
| 0 | 199.62 ± 27.22 | - | 85.82 ± 4.26 | -
| 209 | 173.35 ± 23.35 | −13 | 78.72 ± 1.42 | −7
| 836 | 170.47 ± 25.37 | −15 | 82.27 ± 2.13 | −4
| 2,090 | 173.13 ± 16.28 | −13 | 80.14 ± 1.42 | −6
| Dose (mg/m^3^) | % Static sperm (epididymal) | Absolute change from control (%) | % Sperm with rapid movement (epididymal) | Absolute change from control (%)
| 0 | 13.02 ± 3.38 | - | 71.11 ± 2.78 | -
| 209 | 21.74 ± 2.96 | 9 | 65.56 ± 2.22 | −6
| 836 | 17.78 ± 2.11 | 5 | 67.22 ± 2.22 | −4
| 2,090 | 16.36 ± 1.68 | 3 | 67.22 ± 2.78 | −4
| Dose (mg/m^3^) | Epididymal sperm DNA breaks (tail intensity in comet assay) | % Change from control | Epididymal sperm DNA damage (measurement of 8-OHdG in comet assay) | % Change from control
| 0 | 4.10 ± 0.26 | - | 3.88 ± 0.30 | -
| 209 | 4.04 ± 0.10 | −2 | 3.73 ± 0.15 | −4
| 836 | 4.40 ± 0.26 | 7 | 4.25 ± 0.30 | 10
| 2,090 | 4.59 ± 0.26 | 12 | 4.48 ± 0.37 | 15
| Knockout mice (Aldh2-/-); 9-wk exposure
| Dose (mg/m^3^) | Mean sperm head numbers (testis) (× 10^6^/g) ± SD | % Change from control | Motile sperm (epididymal) ± SE | Absolute change from control (%)
| 0 | 216.19 ± 12.46 | - | 84.17 ± 2.88 | -
| 209 | 198.21 ± 20.54 | -8 | 83.45 ± 2.88 | −1
| 836 | 180.71^c^ ± 23.5 | −16 | 77.70 ± 2.88 | −6
| 2,090 | 165.8^c^ ± 43.52 | −23 | 69.06 ± 6.47 | −15
| Dose (mg/m^3^) | % Static sperm (epididymal) | Absolute change from control (%) | % Sperm with rapid movement (epididymal) | Absolute change from control (%)
| 0 | 14.57 ± 1.71 | - | 69.79 ± 2.84 | -
| 209 | 16.29 ± 4.29 | 2 | 68.65 ± 3.97 | −1
| 836 | 21.43 ± 3.00 | 7 | 63.55 ± 2.27 | −6
| 2,090 | 30.00^c^ ± 6.00 | 15 | 52.20^c^ ± 5.11 | −18
| Dose (mg/m^3^) | Epididymal sperm DNA breaks (tail intensity in comet assay) | % Change from control | Epididymal sperm DNA damage (measurement of 8-OHdG in comet assay) | % Change from control
| 0 | 4.65 ± 0.17 | - | 3.66 ± 0.30 | -
| 209 | 4.67 ± 0.09 | 0 | 3.96 ± 0.30 | 8
| 836 | 5.71^c^ ± 0.34 | 23 | 4.48 ± 0.30 | 22
| 2,090 | 7.01^c^ ± 0.26 | 51 | 4.85^c^ ± 0.22 | 33
| Haplotype mice (Aldh2 heterozygous); 9-wk exposure
| Dose (mg/m^3^) | Mean sperm head numbers (testis) (× 10^6^/g) ± SD | % Change from control | Motile sperm (epididymal) ± SE | Absolute change from control (%)
| 0 | 202.76 ± 14.59 | - | 85.61 ± 2.16 | -
| 209 | 202.26 ± 26.31 | 0 | 85.61 ± 2.16 | 0
| 836 | 109.53^c^ ± 21.56 | −46 | 73.38^c^ ± 3.60 | −12
| 2,090 | 96.31^c^ ± 33.4 | −53 | 76.98^c^ ± 3.60 | −9
| Dose (mg/m^3^) | % Static sperm (epididymal) | Absolute change from control (%) | % Sperm with rapid movement (epididymal) | Absolute change from control (%)
| 0 | 15.00 ± 1.71 | - | 70.14 ± 2.24 | -
| 209 | 15.00 ± 2.14 | 0 | 68.59 ± 2.24 | −2
| 836 | 27.43^c^ ± 3.86 | 12 | 49.42^c^ ± 6.24 | −21
| 2,090 | 24.00^c^ ± 3.00 | 9 | 58.08^c^ ± 1.69 | −12
| Dose (mg/m^3^) | Epididymal sperm DNA breaks (tail intensity in comet assay) | % Change from control | Epididymal sperm DNA damage (measurement of 8-OHdG in comet assay) | % Change from control
| 0 | 3.51 ± 0.25 | - | 4.04 ± 0.22 | -
| 209 | 3.70 ± 0.34 | 5 | 4.45 ± 0.14 | 10
| 836 | 5.32^c^ ± 0.43 | 52 | 4.86 ± 0.43 | 20
| 2,090 | 5.86^c^ ± 0.42 | 67 | 5.34^c^ ± 0.50 | 32
Organ weights
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | F0 parents—absolute organ weights
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | Dose (mg/kg-d) | Mean testis weight (g) ± SD | % Change from control | Mean epididymis weight (mg) ± SD | % Change from control
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 0 | 3.47 ± 0.31 | - | 1,371 ± 136 | -
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 100 | 3.48 ± 0.28 | 0 | 1,360 ± 83 | −1
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 300 | 3.57 ± 0.24 | 3 | 1,381 ± 73 | 1
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 1,000 | 3.57 ± 0.31 | 3 | 1,349 ± 95 | −2
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | Dose (mg/kg-d) | Mean prostate weight (mg) ± SD | % Change from control | Mean seminal vesicle weight (g) ± SD | % Change from control
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 0 | 787 ± 180 | - | 2.16 ± 0.23 | -
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 100 | 778 ± 158 | −1 | 2.1 ± 0.32 | −3
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 300 | 752 ± 172 | −4 | 2.19 ± 0.24 | 1
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 1,000 | 816 ± 136 | 4 | 2.19 ± 0.23 | 1
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | F0 parents—relative organ weights
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | Dose (mg/kg-d) | Mean testis: body weight ratio (%) ± SD | Absolute change from control (%) | Mean epididymis: body weight ratio (%) ± SD | Absolute change from control (%)
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 0 | 0.554 ± 0.065 | - | 219 ± 30 | -
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 100 | 0.572 ± 0.062 | 0.02 | 223 ± 18 | 4
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 300 | 0.589 ± 0.076 | 0.03 | 228 ± 25 | 9
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 1,000 | 0.61^c^ ± 0.074 | 0.06 | 230 ± 24 | 11
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | Dose (mg/kg-d) | Mean prostate: body weight ratio (%) ± SD | Absolute change from control (%) | Mean seminal vesicle:body weight ratio (%) ± SD | Absolute change from control (%)
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 0 | 125 ± 28 | - | 0.345 ± 0.054 | -
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 100 | 128 ± 30 | 3 | 0.343 ± 0.051 | 0.00
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 300 | 124 ± 30 | −1 | 0.361 ± 0.052 | 0.02
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 1,000 | 139 ± 23 | 14 | 0.373 ± 0.042 | 0.03
Gaoua (2004b); Rat, S-D; oral―gavage; F0, male and female (25/sex/group): 0, 250, 500, or 1,000 mg/kg-d; dosed daily for 18 wk from 10 wk premating until weaning of F1 pups; F1, male and female (24−25/group): 0, 250, 500, or 1,000 mg/kg-d; dosed daily from PND 22 until weaning of F2 pups | F0 parents—absolute organ weights
| Dose (mg/kg-d) | Mean testis weight (left) (g) ± SD | % Change from control | Mean testis weight (right) (g) ± SD | % Change from control
| 0 | 1.78 ± 0.116 | - | 1.76 ± 0.105 | -
| 250 | 1.73 ± 0.181 | −3 | 1.76 ± 0.179 | 0
| 500 | 1.78 ± 0.142 | 0 | 1.76 ± 0.13 | 0
| 1,000 | 1.75 ± 0.237 | −2 | 1.79 ± 0.126 | 2
| Dose (mg/kg-d) | Mean epididymis weight (left) (g) ± SD | % Change from control | Mean epididymis weight (right) (g) ± SD | % Change from control
| 0 | 0.77008 ± 0.054 | - | 0.78148 ± 0.053 | -
| 250 | 0.77092 ± 0.077 | 0 | 0.78698 ± 0.092 | 1
| 500 | 0.77784 ± 0.067 | 1 | 0.77492 ± 0.062 | −1
| 1,000 | 0.80988 ± 0.189 | 5 | 0.77528 ± 0.056 | −1
| Dose (mg/kg-d) | Mean prostate weight ± SD | % Change from control | Mean seminal vesicle weight ± SD | % Change from control | n
| 0 | 1.41 ± 0.272 | - | 2.06 ± 0.309 | - | 25
| 250 | 1.63 ± 0.32 | 16 | 2.26 ± 0.595 | 10 | 25
| 500 | 1.37 ± 0.285 | −3 | 2.19 ± 0.439 | 6 | 25
| 1,000 | 1.62 ± 0.396 | 15 | 2.28 ± 0.574 | 11 | 25
| F0 parents—relative organ weights
| Dose (mg/kg-d) | Mean testis weight:body weight ratio (left) (g) ± SD | Absolute change from control (%) | Mean testis weight:body weight ratio (right) (g) ± SD | Absolute change from control (%)
| 0 | 0.297488 ± 0.029 | - | 0.29488 ± 0.029 | -
| 250 | 0.29005 ± 0.025 | −0.01 | 0.29427 ± 0.025 | 0.00
| 500 | 0.307 ± 0.033 | 0.01 | 0.30321 ± 0.033 | 0.01
| 1,000 | 0.31052 ± 0.049 | 0.01 | 0.31497^c^ ± 0.029 | 0.02
| Dose (mg/kg-d) | Mean epididymis weight (left):body weight ratio (g) ± SD | Absolute change from control (%) | Mean epididymis: body weight ratio (right) (%) ± SD | Absolute change from control (%)
| 0 | 0.12886 ± 0.014 | - | 0.13072 ± 0.013 | -
| 250 | 0.12947 ± 0.013 | 0.00 | 0.13245 ± 1.014 | 0.00
| 500 | 0.13434 ± 0.016 | 0.01 | 0.13383 ± 0.015 | 0.00
| 1,000 | 0.14209 ± 0.027 | 0.01 | 0.1367 ± 0.012 | 0.01
| Dose (mg/kg-d) | Mean prostate weight:body weight ratio ± SD | Absolute change from control (%) | Mean seminal vesicle:body weight ratio ± SD | Absolute change from control (%) | n
| 0 | 0.23582 ± 0.054 | - | 0.34605 ± 0.066 | - | 25
| 250 | 0.27279 ± 0.053 | 0.04 | 0.37895 ± 0.098 | 0.03 | 25
| 500 | 0.23656 ± 0.054 | 0.00 | 0.37615 ± 0.073 | 0.03 | 25
| 100 | 0.28593^c^ ± 0.069 | 0.05 | 0.40207 ± 0.1 | 0.06 | 25
| F1 offspring—absolute organ weights
| Dose (mg/kg-d) | Mean testis weight (left) (g) ± SD | % Change from control | Mean testis weight (right) (g) ± SD | % Change from control
| 0 | 1.79 ± 0.11 | - | 1.84 ± 0.137 | -
| 250 | 1.77 ± 0.39 | −1 | 1.75 ± 0.337 | −5
| 500 | 1.84 ± 0.21 | 3 | 1.86 ± 0.226 | 1
| 1,000 | 1.84 ± 0.171 | 3 | 1.82 ± 0.255 | −1
| Dose (mg/kg-d) | Mean epididymis weight (left) (g) ± SD | % Change from control | Mean epididymis weight (right) (g) ± SD | % Change from control
| 0 | 0.71683 ± 0.11 | - | 0.75575 ± 0.041 | -
| 250 | 0.69636 ± 0.123 | −3 | 0.70512 ± 0.148 | −7
| 500 | 0.71904 ± 0.123 | 0 | 0.75008 ± 0.113 | −1
| 1,000 | 0.6898 ± 0.12 | −4 | 0.71244 ± 0.127 | −6
| Dose (mg/kg-d) | Mean prostate weight ± SD | % Change from control | Mean seminal vesicle weight ± SD | % Change from control | n
| 0 | 1.470 ± 0.311 | - | 1.71 ± 0.295 | - | 24
| 250 | 1.48 ± 0.249 | 1 | 1.94 ± 0.567 | 13 | 25
| 500 | 1.38 ± 0.23 | −6 | 1.86 ± 0.422 | 9 | 24
| 1,000 | 1.41 ± 0.279 | −4 | 1.92 ± 0.436 | 12 | 25
| F1 offspring—relative organ weights
| Dose (mg/kg-d) | Mean testis weight:body weight ratio (left) (g) ± SD | Absolute change from control (%) | Mean testis weight:body weight ratio (right) (g) ± SD | Absolute change from control (%)
| 0 | 0.30842 ± 0.065 | - | 0.31441 ± 0.036 | -
| 250 | 0.30222 ± 0.067 | −0.01 | 0.29746 ± 0.059 | −0.02
| 500 | 0.30679 ± 0.037 | 0.00 | 0.31004 ± 0.04 | 0.00
| 1,000 | 0.31198 ± 0.042 | 0.00 | 0.30958 ± 0.05 | 0.00
| Dose (mg/kg-d) | Mean epididymis weight (left): body weight ratio (g) ± SD | Absolute change from control (%) | Mean epididymis weight (right) (g) ± SD | Absolute change from control (%)
| 0 | 0.12299 ± 0.023 | - | 0.12915 ± 0.012 | -
| 250 | 0.11863 ± 0.021 | 0.00 | 0.12002 ± 0.025 | −0.01
| 500 | 0.1198 ± 0.021 | 0.00 | 0.12492 ± 0.018 | 0.00
| 1,000 | 0.11693 ± 0.021 | −0.01 | 0.12065 ± 0.022 | −0.01
| Dose (mg/kg-d) | Mean prostate weight:body weight ratio ± SD | Absolute change from control (%) | Mean seminal vesicle:body weight ratio ± SD | Absolute change from control (%) | n
| 0 | 0.25136 ± 0.057 | - | 0.29278± 0.055 | - | 24
| 250 | 0.25239 ± 0.043 | 0.00 | 0.33038 0.085 | 0.04 | 25
| 500 | 0.23059 ± 0.043 | −0.02 | 0.3165 ± 0.113 | 0.02 | 24
| 1,000 | 0.2374 ± 0.04 | −0.01 | 0.32424 ± 0.073 | 0.03 | 25
Weng et al. (2014); Mice, C57BL/6; inhalation―vapor; male (5/group): 0, 500, 1,750, or 5,000 ppm (0, 2,090, 7,320, or 20,900 mg/m^3^)^a^; dynamic whole-body inhalation; 6 h/d, 5 d/wk for 13 wk; methods described in Weng et al. (2012) | Wild type mice; 13-wk exposure
| Dose (mg/m^3^) | Mean testis:body weight ratio (%) ± SD | Absolute change from control (%) | Mean epididymis: body weight ratio (%) ± SD | Absolute change from control (%)
| 0 | 0.7 ± 0.06 | - | 0.24 ± 0.02 | -
| 2,090 | 0.74 ± 0.04 | 0.04 | 0.26 ± 0.02 | 0.02
| 7,320 | 0.67 ± 0.09 | −0.03 | 0.25 ± 0.01 | 0.01
| 20,900 | 0.7 ± 0.02 | 0.00 | 0.24 ± 0.02 | 0.00
| Knockout mice (Aldh2-/-); 13-wk exposure
| Dose (mg/m^3^) | Mean testis:body weight ratio (%) ± SD | Absolute change from control (%) | Mean epididymis: body weight ratio (%) ± SD | Absolute change from control (%)
| 0 | 0.76 ± 0.04 | - | 0.26 ± 0.01 | -
| 2,090 | 0.71 ± 0.11 | −0.05 | 0.24 ± 0.02 | −0.02
| 7,320 | 0.72 ± 0.05 | −0.04 | 0.24^c^ ± 0.02 | −0.02
| 20,900 | 0.71 ± 0.07 | −0.05 | 0.23^c^ ± 0.02 | −0.03
Weng et al. (2014); Mice, C57BL/6; inhalation―vapor; male (NR): 0, 50, 200, or 500 ppm (209, 836, or 2,090 mg/m3)^a^; dynamic whole-body inhalation; 6 h/d, 5 d/wk for 9 wk; methods described in Weng et al. (2012) | Wild type mice; 9-wk exposure
| Dose (mg/m^3^) | Mean testis:body weight ratio (%) ± SD | Absolute change from control (%) | Mean epididymis: body weight ratio (%) ± SD | Absolute change from control (%)
| 0 | 0.8 ± 0.12 | - | 0.26 ± 0.03 | -
| 209 | 0.77 ± 0.09 | −0.03 | 0.25 ± 0.03 | −0.01
| 836 | 0.77 ± 0.09 | −0.03 | 0.25 ± 0.02 | −0.01
| 2,090 | 0.78 ± 0.08 | −0.02 | 0.25 ± 0.02 | −0.01
| Knockout mice (Aldh2-/-); 9-wk exposure
| Dose (mg/m^3^) | Mean testis:body weight ratio (%) ± SD | Absolute change from control (%) | Mean epididymis: body weight ratio (%) ± SD | Absolute change from control (%)
| 0 | 0.8 ± 0.06 | - | 0.27 ± 0.02 | -
| 209 | 0.76 ± 0.05 | −0.04 | 0.26 ± 0.02 | −0.01
| 836 | 0.79 ± 0.07 | −0.01 | 0.27 ± 0.01 | 0.00
| 2,090 | 0.74 ± 0.01 | −0.06 | 0.25 ± 0.03 | −0.02
| Haplotype mice (Aldh2 heterozygous); 9-wk exposure
| Dose (mg/m^3^) | Mean testis:body weight ratio (%) ± SD | Absolute change from control (%) | Mean epididymis: body weight ratio (%) ± SD | Absolute change from control (%)
| 0 | 0.82 ± 0.07 | - | 0.26 ± 0.02 | -
| 209 | 0.8 ± 0.06 | −0.02 | 0.26 ± 0.01 | 0.00
| 836 | 0.81 ± 0.09 | −0.01 | 0.26 ± 0.02 | 0.00
| 2,090 | 0.73 ± 0.03 | −0.09 | 0.24 ± 0.01 | −0.02
de Peyster et al. (2009); Rat, F344; oral―gavage; P0, male (12/group): 0, 600, 1,200, or 1,800 mg/kg-d; daily for 14 d | Absolute organ weights
de Peyster et al. (2009); Rat, F344; oral―gavage; P0, male (12/group): 0, 600, 1,200, or 1,800 mg/kg-d; daily for 14 d | Dose (mg/kg-d) | Mean testis weight (g) ± SD | % Change from control | Mean epididymis weight (mg) ± SD | % Change from control
de Peyster et al. (2009); Rat, F344; oral―gavage; P0, male (12/group): 0, 600, 1,200, or 1,800 mg/kg-d; daily for 14 d | 0 | 2.55 ± 0.09 | - | 0.696 ± 0.016 | -
de Peyster et al. (2009); Rat, F344; oral―gavage; P0, male (12/group): 0, 600, 1,200, or 1,800 mg/kg-d; daily for 14 d | 600 | 2.53 ± 0.05 | −1 | 0.693 ± 0.027 | 0
de Peyster et al. (2009); Rat, F344; oral―gavage; P0, male (12/group): 0, 600, 1,200, or 1,800 mg/kg-d; daily for 14 d | 1,200 | 2.49 ± 0.07 | −2 | 0.701 ± 0.026 | 1
de Peyster et al. (2009); Rat, F344; oral―gavage; P0, male (12/group): 0, 600, 1,200, or 1,800 mg/kg-d; daily for 14 d | 1,800 | 2.47 ± 0.1 | −3 | 0.663 ± 0.029 | −5
de Peyster et al. (2009); Rat, F344; oral―gavage; P0, male (12/group): 0, 600, 1,200, or 1,800 mg/kg-d; daily for 14 d | Dose (mg/kg-d) | Mean prostate weight (g) ± SD | % Change from control | Mean seminal vesicle weight (g) ± SD | % Change from control
de Peyster et al. (2009); Rat, F344; oral―gavage; P0, male (12/group): 0, 600, 1,200, or 1,800 mg/kg-d; daily for 14 d | 0 | 0.238 ± 0.018 | - | 0.781 ± 0.022 | -
de Peyster et al. (2009); Rat, F344; oral―gavage; P0, male (12/group): 0, 600, 1,200, or 1,800 mg/kg-d; daily for 14 d | 600 | 0.309 ± 0.034 | 30 | 0.733 ± 0.024 | −6
de Peyster et al. (2009); Rat, F344; oral―gavage; P0, male (12/group): 0, 600, 1,200, or 1,800 mg/kg-d; daily for 14 d | 1,200 | 0.252 ± 0.018 | 6 | 0.749 ± 0.037 | −4
de Peyster et al. (2009); Rat, F344; oral―gavage; P0, male (12/group): 0, 600, 1,200, or 1,800 mg/kg-d; daily for 14 d | 1,800 | 0.269 ± 0.036 | 13 | 0.701 ± 0.041 | −10
de Peyster et al. (2009); Rat, F344; oral―gavage; P0, male (12/group): 0, 600, 1,200, or 1,800 mg/kg-d; daily for 14 d | Dose (mg/kg-d) | | Mean weight of combined accessory sex organs (g) ± SD | | % Change from control
de Peyster et al. (2009); Rat, F344; oral―gavage; P0, male (12/group): 0, 600, 1,200, or 1,800 mg/kg-d; daily for 14 d | 0 | | 1.712 ± 0.041 | | -
de Peyster et al. (2009); Rat, F344; oral―gavage; P0, male (12/group): 0, 600, 1,200, or 1,800 mg/kg-d; daily for 14 d | 600 | | 1.735 ± 0.057 | | 1
de Peyster et al. (2009); Rat, F344; oral―gavage; P0, male (12/group): 0, 600, 1,200, or 1,800 mg/kg-d; daily for 14 d | 1,200 | | 1.702 ± 0.063 | | −1
de Peyster et al. (2009); Rat, F344; oral―gavage; P0, male (12/group): 0, 600, 1,200, or 1,800 mg/kg-d; daily for 14 d | 1,800 | | 1.633 ± 0.059 | | −5
de Peyster et al. (2009); Rat, F344; oral―gavage; P0, male (12/group): 0, 600, 1,200, or 1,800 mg/kg-d; daily for 14 d | Relative organ weights
de Peyster et al. (2009); Rat, F344; oral―gavage; P0, male (12/group): 0, 600, 1,200, or 1,800 mg/kg-d; daily for 14 d | Dose (mg/kg-d) | Mean testis: body weight ratio (%) ± SD | Absolute change from control (%) | Mean epididymis: body weight ratio (%) ± SD | Absolute change from control (%)
de Peyster et al. (2009); Rat, F344; oral―gavage; P0, male (12/group): 0, 600, 1,200, or 1,800 mg/kg-d; daily for 14 d | 0 | 0.997 ± 0.036 | - | 0.272 ± 0.007 | -
de Peyster et al. (2009); Rat, F344; oral―gavage; P0, male (12/group): 0, 600, 1,200, or 1,800 mg/kg-d; daily for 14 d | 600 | 1.014 ± 0.027 | 0.02 | 0.275 ± 0.009 | 0.00
de Peyster et al. (2009); Rat, F344; oral―gavage; P0, male (12/group): 0, 600, 1,200, or 1,800 mg/kg-d; daily for 14 d | 1,200 | 1.097 ± 0.03 | 0.10 | 0.308 ± 0.009 | 0.04
de Peyster et al. (2009); Rat, F344; oral―gavage; P0, male (12/group): 0, 600, 1,200, or 1,800 mg/kg-d; daily for 14 d | 1,800 | 1.097 ± 0.045 | 0.10 | 0.294 ± 0.014 | 0.02
de Peyster et al. (2009); Rat, F344; oral―gavage; P0, male (12/group): 0, 600, 1,200, or 1,800 mg/kg-d; daily for 14 d | Dose (mg/kg-d) | Mean prostate: body weight ratio (%) ± SD | Absolute change from control (%) | Mean seminal vesicle:body wt. ratio (%) ± SD | Absolute change from control (%)
de Peyster et al. (2009); Rat, F344; oral―gavage; P0, male (12/group): 0, 600, 1,200, or 1,800 mg/kg-d; daily for 14 d | 0 | 0.092 ± 0.007 | - | 0.304 ± 0.008 | -
de Peyster et al. (2009); Rat, F344; oral―gavage; P0, male (12/group): 0, 600, 1,200, or 1,800 mg/kg-d; daily for 14 d | 600 | 0.124 ± 0.015 | 0.03 | 0.292 ± 0.012 | −0.01
de Peyster et al. (2009); Rat, F344; oral―gavage; P0, male (12/group): 0, 600, 1,200, or 1,800 mg/kg-d; daily for 14 d | 1,200 | 0.111 ± 0.076 | 0.02 | 0.328 ± 0.012 | 0.02
de Peyster et al. (2009); Rat, F344; oral―gavage; P0, male (12/group): 0, 600, 1,200, or 1,800 mg/kg-d; daily for 14 d | 1,800 | 0.123 ± 0.021 | 0.03 | 0.31 ± 0.017 | 0.01
de Peyster et al. (2009); Rat, F344; oral―gavage; P0, male (12/group): 0, 600, 1,200, or 1,800 mg/kg-d; daily for 14 d | Dose (mg/kg-d) | | Mean combined accessory sex organs:body weight ratio (%) ± SD | | Absolute change from control (%)
de Peyster et al. (2009); Rat, F344; oral―gavage; P0, male (12/group): 0, 600, 1,200, or 1,800 mg/kg-d; daily for 14 d | 0 | | 0.668 ± 0.018 | | -
de Peyster et al. (2009); Rat, F344; oral―gavage; P0, male (12/group): 0, 600, 1,200, or 1,800 mg/kg-d; daily for 14 d | 600 | | 0.691 ± 0.026 | | 0.02
de Peyster et al. (2009); Rat, F344; oral―gavage; P0, male (12/group): 0, 600, 1,200, or 1,800 mg/kg-d; daily for 14 d | 1,200 | | 0.746 ± 0.019 | | 0.08
de Peyster et al. (2009); Rat, F344; oral―gavage; P0, male (12/group): 0, 600, 1,200, or 1,800 mg/kg-d; daily for 14 d | 1,800 | | 0.727 ± 0.035 | | 0.06
Medinsky et al. (1999); U.S. EPA (1997); Rat, F344; inhalation―vapor; male (48/group): 0, 500, 1,750, or 5,000 ppm (0, 2,090, 7,320, or 20,900 mg/m^3^);^a^ female (48/group): 0, 500, 1,750, or 5,000 ppm (0, 2,090, 7,320, or 20,900 mg/m^3^)^a^; dynamic whole-body chamber; 6 h/d, 5 d/wk for 13 wk | Organ weights of F344 rats and CD-1 mice were not altered by exposure to ETBE.
Testosterone and estradiol
de Peyster et al. (2009); Rat, F344; oral―gavage; P0, male (12/group): 0, 600, 1,200, or 1,800 mg/kg-d; daily for 14 d | Dose (mg/kg-d) | n | Mean plasma testosterone (ng/mL) ± SE | | % Change from control
de Peyster et al. (2009); Rat, F344; oral―gavage; P0, male (12/group): 0, 600, 1,200, or 1,800 mg/kg-d; daily for 14 d | 0 | 12 | 2.07 ± 42 | | -
de Peyster et al. (2009); Rat, F344; oral―gavage; P0, male (12/group): 0, 600, 1,200, or 1,800 mg/kg-d; daily for 14 d | 600 | 12 | 3.1 ± 0.78 | | 50
de Peyster et al. (2009); Rat, F344; oral―gavage; P0, male (12/group): 0, 600, 1,200, or 1,800 mg/kg-d; daily for 14 d | 1,200 | 11 | 2.61 ± 0.55 | | 26
de Peyster et al. (2009); Rat, F344; oral―gavage; P0, male (12/group): 0, 600, 1,200, or 1,800 mg/kg-d; daily for 14 d | 1,800 | 10 | 1.36 ± 0.39 | | −34
de Peyster et al. (2009); Rat, F344; oral―gavage; P0, male (12/group): 0, 600, 1,200, or 1,800 mg/kg-d; daily for 14 d | Dose (mg/kg-d) | n | Mean plasma estradiol (pg/mL) | | % Change from control
de Peyster et al. (2009); Rat, F344; oral―gavage; P0, male (12/group): 0, 600, 1,200, or 1,800 mg/kg-d; daily for 14 d | 0 | 12 | 1.085 ± 0.1 | | -
de Peyster et al. (2009); Rat, F344; oral―gavage; P0, male (12/group): 0, 600, 1,200, or 1,800 mg/kg-d; daily for 14 d | 600 | 12 | 1.395 ± 0.403 | | 29
de Peyster et al. (2009); Rat, F344; oral―gavage; P0, male (12/group): 0, 600, 1,200, or 1,800 mg/kg-d; daily for 14 d | 1,200 | 11 | 2.238^c^ ± 0.377 | | 106
de Peyster et al. (2009); Rat, F344; oral―gavage; P0, male (12/group): 0, 600, 1,200, or 1,800 mg/kg-d; daily for 14 d | 1,800 | 9 | 2.224^c^ ± 0.611 | | 105

LD = lactation day; NR = not reported; SD = standard deviation; SE = standard error.

a 4.18 mg/m^3^ = 1 ppm.

b Conversion performed by the study authors.

c Result is statistically significant (p < 0.05) based on analysis of data by the study authors.

Male mating index (%) = (no. males able to mate with at least one female ÷ total males) × 100.

Male fertility index (%) = (no. males with at least one pregnant partner ÷ males that mated at least once) × 100

-For controls, no response relevant; for other doses, no quantitative response reported.

% change from control = [(treated group value – control value) ÷ control value] × 100.

Absolute change from control (%) = control value (%) – treated group value (%).

Figure 1-11 Exposure-response array of male reproductive effects following oral exposure to ETBE

Figure 1-12 Exposure-response array of male reproductive effects following inhalation exposure to ETBE

#### Mechanistic Evidence of Male Reproductive Effects

No mechanistic evidence for male reproductive effects was identified by the literature search.

#### Integration of Male Reproductive Effects

The male reproductive endpoints examined in this database were not consistently affected across studies or across doses in wild-type animals. The 13-week and 9-week inhalation studies conducted in rats and mice (Weng et al., 2014; Medinsky et al., 1999) provide suggestive evidence of ETBE-induced testicular degeneration and effects on sperm count, sperm mobility, and sperm DNA damage. In contrast, no male reproductive toxicity was observed in any of the other studies examined in this database, including one- and two-generation reproductive toxicity studies, 2-year carcinogenicity studies, and subchronic studies. For example, the 2-year inhalation carcinogenicity study (Saito et al., 2013; JPEC, 2010b) used the same rat strain, same route of exposure, and similar range of exposure concentrations as Medinsky et al. (1999) and did not observe any dose-related effects on testicular histopathology. Weng et al. (2014), however, found that Aldh2−/− and heterozygous mice had consistently reduced numbers of sperm heads and sperm motility as well as reductions in male reproductive organ weights, suggesting that populations with ALDH2 polymorphisms could be more susceptible to effects from ETBE exposure (discussed in Section 1.3.3). The 14-day study by de Peyster et al. (2009) observed increased estradiol and decreased testosterone in ETBE-exposed rats, which is a potential mechanism for testicular degeneration; however, no effects on testicular histopathology or organ weight were observed in this study. Collectively, although minimal effects were observed at otherwise toxic dose levels, the available evidence is considered insufficient to identify male reproductive effects as a potential human hazard of ETBE, so these effects are not carried forward as a hazard. While the Aldh2 KO data suggest a potential sensitive subpopulation for male reproductive effects, these findings are considered preliminary.

#### Synthesis of Effects Related to Female Reproduction

The available evidence for ETBE-induced effects on the female reproductive system includes no human data. The evidence was obtained primarily from a one-generation reproductive toxicity study (Fujii et al., 2010; JPEC, 2008e), a two-generation reproductive toxicity study (Gaoua, 2004b), and three developmental toxicity studies (Aso et al., 2014; Asano et al., 2011; JPEC, 2008h, i; Gaoua, 2004a). In addition, some evidence was obtained from two 90-day toxicity studies (JPEC, 2008b; Medinsky et al., 1999; Bond et al., 1996), one subchronic (180-day) study (Miyata et al., 2013; JPEC, 2008c), two 2-year carcinogenicity studies (Saito et al., 2013; Suzuki et al., 2012; JPEC, 2010a, b), and a short-term study evaluating ETBE-induced oocyte effects (Berger and Horner, 2003). These studies evaluated the effects of ETBE exposure on maternal body-weight change (Aso et al., 2014; Asano et al., 2011; Fujii et al., 2010; JPEC, 2008e, h, i; Gaoua, 2004a, b), fertility, mating, and pregnancy parameters (Fujii et al., 2010; JPEC, 2008e; Gaoua, 2004b; Berger and Horner, 2003), fecundity (Aso et al., 2014; Asano et al., 2011; Fujii et al., 2010; JPEC, 2008e, h, i; Gaoua, 2004a, b), estrous cyclicity (Fujii et al., 2010; JPEC, 2008e; Gaoua, 2004b), and organ weights (Aso et al., 2014; Miyata et al., 2013; Saito et al., 2013; Suzuki et al., 2012; Asano et al., 2011; Fujii et al., 2010; JPEC, 2010a, b, 2008b, c, e, h, i; Gaoua, 2004b; Medinsky et al., 1999; Bond et al., 1996). ETBE-induced effects were examined in pregnant rats and rabbits and nonpregnant female rats after oral or whole-body inhalation exposures, and the design, conduct, and reporting of each study were of sufficient quality to inform human health hazard assessment. Selected female reproductive toxicity endpoints from these studies are summarized in Table 1-16.

The one- and two-generation reproductive toxicity studies and developmental studies evaluated maternal toxicity and several endpoints related to fertility, pregnancy, and pregnancy outcomes in rats and rabbits up to 1,000 mg/kg-day ETBE. Maternal toxicity, as shown by decreased maternal body weight and corrected body weight (for the gravid uterus), was observed following gestational exposure to 1,000 mg/kg-day ETBE from Gestation Day (GD) 5−19; however, this effect was not observed in another developmental exposure study in which ETBE was administered at the same dose and duration (Aso et al., 2014; JPEC, 2008h). Further, administration of ETBE during the premating through lactation periods in parental and F1 generations (Fujii et al., 2010; JPEC, 2008e; Gaoua, 2004b) did not affect maternal body-weight parameters in rats. Maternal body weight and corrected body-weight change during the entire pregnancy (GD 0−28) were decreased in rabbits administered 1,000 mg/kg-day ETBE (Asano et al., 2011; JPEC, 2008i); however, the lack of change in body weight during the treatment period (GD 6−27), the lack of a dose-related response, and the inherent variability in body-weight parameters during pregnancy in rabbits (U.S. EPA, 1991b) complicate the interpretation of this effect. ETBE did not affect indices of mating or fertility, and precoital times and gestation lengths were similarly unaffected in rats in the parental (Fujii et al., 2010; JPEC, 2008e; Gaoua, 2004b) and the F1 generations (Gaoua, 2004b). In addition, the number of corpora lutea in pregnant rats and rabbits (Aso et al., 2014; Asano et al., 2011; JPEC, 2008h, i), the average estrous cycle length, and the percent of females with normal estrous cycles (Fujii et al., 2010; JPEC, 2008e) were not significantly affected by ETBE when compared with control values. Further supporting these findings, oocyte quality and fertilizability were shown to be unaffected by ETBE (Berger and Horner, 2003). Litter size was evaluated by Fujii et al. (2010), JPEC (2008e), Gaoua (2004b), Aso et al. (2014), JPEC (2008h), Asano et al. (2011), and JPEC (2008i), and no significant, dose-related effects were observed in rats or rabbits following ETBE exposure.

Reproductive organ weights were also reported after oral and inhalation exposures to ETBE. Gravid uterine weights were not affected during gestation in rabbits (Asano et al., 2011; JPEC, 2008i) nor were ovary and uterine weights affected after exposure during premating through lactation periods in rats (Fujii et al., 2010; JPEC, 2008e). Consistent with these findings, ovary and uterine weights in nonpregnant female rats were not affected by ETBE after 90-day inhalation (JPEC, 2008b; Medinsky et al., 1999; Bond et al., 1996), 180-day oral (Miyata et al., 2013; JPEC, 2008c), and 2-year oral (Suzuki et al., 2012; JPEC, 2010a) studies. However, a 2-year inhalation study in rats (Saito et al., 2013; JPEC, 2010b) showed a significant increase in relative (but not absolute) ovary weight at exposures of 1,500 and 5,000 ppm ETBE. It is possible the finding of increased relative ovary weight was influenced by concurrent decreases in bodyweight (9−22%) at these exposures.

Table 1-16 Evidence pertaining to female reproductive effects in animals exposed to ETBE

Reference and study design | Results
Maternal body weight
Gaoua (2004a); Rat, S-D; oral―gavage; P0, female (24/group): 0, 250, 500, or 1,000 mg/kg-d; dams exposed from GD 5 to GD 19 | Dose (mg/kg-d) | Body wt change ± SD, GD 5−20 (g) | % Change from control | Net body wt change ± SD (g) | % Change from control
Gaoua (2004a); Rat, S-D; oral―gavage; P0, female (24/group): 0, 250, 500, or 1,000 mg/kg-d; dams exposed from GD 5 to GD 19 | 0 | 132 ± 22 | - | 61.8 ± 13 | -
Gaoua (2004a); Rat, S-D; oral―gavage; P0, female (24/group): 0, 250, 500, or 1,000 mg/kg-d; dams exposed from GD 5 to GD 19 | 250 | 132 ± 12 | −2 | 59.4 ± 8.1 | −4
Gaoua (2004a); Rat, S-D; oral―gavage; P0, female (24/group): 0, 250, 500, or 1,000 mg/kg-d; dams exposed from GD 5 to GD 19 | 500 | 134 ± 19 | −1 | 60 ± 11.3 | −3
Gaoua (2004a); Rat, S-D; oral―gavage; P0, female (24/group): 0, 250, 500, or 1,000 mg/kg-d; dams exposed from GD 5 to GD 19 | 1,000 | 120^a^ ± 15 | −11 | 51.5^a^ ± 10.3 | −17
Gaoua (2004b); Rat, S-D; oral—gavage; F0, male and female (25/sex/group): 0, 250, 500, or 1,000 mg/kg-d; dosed daily for 18 wk from 10 wk premating until weaning of F1 pups; F1, male and female (24−25/group): 0, 250, 500, or 1,000 mg/kg-d; dosed daily from PND 22 until weaning of F2 pups | Dose (mg/kg-d) | F0: Body wt change ± SD (g) | % Change from control | F1: Body wt change ± SD (g) | % Change from control
| 0 | 132 ± 15 | - | 146 ± 21 | -
| 250 | 134 ± 14 | 2 | 145 ± 15 | −1
| 500 | 136 ± 25 | 3 | 141 ± 21 | −3
| 1,000 | 136 ± 12 | 3 | 137 ± 12 | −6
Aso et al. (2014); JPEC (2008h); Rat, S-D; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 5 to GD 19; C-section GD 20 | Dose (mg/kg-d) | Body wt ± SD, GD 5 (g) | Body wt ± SD, GD 20 (g) | Body wt change ± SD, GD 5−20 (g) | % Change from control
Aso et al. (2014); JPEC (2008h); Rat, S-D; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 5 to GD 19; C-section GD 20 | 0 | 280.9 ± 16.7 | 394.4 ± 26.9 | 113.5 | -
Aso et al. (2014); JPEC (2008h); Rat, S-D; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 5 to GD 19; C-section GD 20 | 100 | 273.4 ± 10.8 | 380.3 ± 23.9 | 106.9 | −6
Aso et al. (2014); JPEC (2008h); Rat, S-D; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 5 to GD 19; C-section GD 20 | 300 | 280 ± 13.4 | 389.8 ± 25.9 | 109.8 | −3
Aso et al. (2014); JPEC (2008h); Rat, S-D; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 5 to GD 19; C-section GD 20 | 1,000 | 277.7 ± 15.9 | 382.4 ± 27.1 | 104.7 | −8
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female; (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | Dose (mg/kg-d) | | F0: Body wt change ± SD, GD 5−20 (g) | | % Change from control
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female; (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 0 | | 124.9 ± 22 | | -
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female; (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 100 | | 119.6 ± 20.3 | | −4
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female; (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 300 | | 135.2 ± 21.5 | | 8
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female; (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 1,000 | | 140.2^a^ ± 19.1 | | 12
Asano et al. (2011); JPEC (2008i); Rabbit, New Zealand White; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 6 to GD 27; C-section GD 28 | Dose (mg/kg-d) | Body wt change ± SD, GD 6−28 (kg) | % Change from control | Body wt change ± SD, GD 0−28 (kg) | Adjusted body wt change ± SD (kg) | % Change from control
Asano et al. (2011); JPEC (2008i); Rabbit, New Zealand White; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 6 to GD 27; C-section GD 28 | 0 | 0.26 ± 0.12 | - | 0.40 ± 0.12 | 0.02 ± 0.14 | -
Asano et al. (2011); JPEC (2008i); Rabbit, New Zealand White; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 6 to GD 27; C-section GD 28 | 100 | 0.23 ± 0.12 | −12 | 0.35 ± 0.12 | -0.06 ± 0.12 | −400
Asano et al. (2011); JPEC (2008i); Rabbit, New Zealand White; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 6 to GD 27; C-section GD 28 | 300 | 0.28 ± 0.08 | 8 | 0.40 ± 0.08 | 0 ± 0.1 | −100
Asano et al. (2011); JPEC (2008i); Rabbit, New Zealand White; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 6 to GD 27; C-section GD 28 | 1,000 | 0.12 ± 0.19 | −54 | 0.25^a^ ± 0.21 | -0.07 ± 0.19 | −450
Fertility, mating, and pregnancy
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | Dose (mg/kg-d) | | Copulation index^b^ (%) | | Fertility index^c^ (%)
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 0 | | 100 | | 87.5
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 100 | | 95.8 | | 100
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 300 | | 100 | | 95.8
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 1,000 | | 100 | | 91.7
Gaoua (2004b); Rat, S-D; oral―gavage; F0, male and female (25/sex/group): 0, 250, 500, or 1,000 mg/kg-d; dosed daily for 18 wk from 10 wk premating until weaning of F1 pups; F1, male and female (24−25/group): 0, 250, 500, or 1,000 mg/kg-d; dosed daily from PND 22 until weaning of F2 pups | Dose (mg/kg-d) | Pregnant/mated females, F0 | Fertility index, F0 (%) | Pregnant/mated females, F1 | Fertility index, F1 (%)
| 0 | 23/25 | 92 | 22/25 | 88
| 250 | 21/25 | 84 | 22/24 | 92
| 500 | 22/25 | 88 | 22/25 | 88
| 1,000 | 25/25 | 100 | 22/23 | 96
Aso et al. (2014); JPEC (2008h); Rat, S-D; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 5 to GD 19; C-section GD 20 | Dose (mg/kg-d) | | Mean no. corpora lutea ± SD | | % Change from control
Aso et al. (2014); JPEC (2008h); Rat, S-D; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 5 to GD 19; C-section GD 20 | 0 | | 15.5 ± 1.54 | | -
Aso et al. (2014); JPEC (2008h); Rat, S-D; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 5 to GD 19; C-section GD 20 | 100 | | 14.1 ± 1.48 | | −9
Aso et al. (2014); JPEC (2008h); Rat, S-D; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 5 to GD 19; C-section GD 20 | 300 | | 14.4 ± 1.85 | | −7
Aso et al. (2014); JPEC (2008h); Rat, S-D; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 5 to GD 19; C-section GD 20 | 1,000 | | 14.6 ± 2.44 | | −6
Litter size
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | Dose (mg/kg-d) | | Mean no. pups delivered ± SD (kg) | | % Change from control
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 0 | | 11.8 ± 3.2 | | -
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 100 | | 10.4 ± 3.4 | | −12
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 300 | | 12.1 ± 2.3 | | 3
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 1,000 | | 13.0 ± 1.9 | | 10
Gaoua (2004b); Rat, S-D; oral―gavage; F0, male and female (25/sex/group): 0, 250, 500, or 1,000 mg/kg-d; dosed daily for 18 wk from 10 wk premating until weaning of F1 pups; F1, male and female (24−25/group): 0, 250, 500, or 1,000 mg/kg-d; dosed daily from PND 22 until weaning of F2 pups | Dose (mg/kg-d) | Litter size at birth, F0 | % Change from control, F0 | Pregnant/mated females, F1 | % Change from control, F1
| 0 | 14.3 | - | 13.7 | -
| 250 | 14.1 | −1 | 13.7 | 0
| 500 | 14.9 | 4 | 13.7 | 0
| 1,000 | 14.2 | −1 | 14 | 2
Aso et al. (2014); JPEC (2008h); Rat, S-D; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 5 to GD 19; C-section GD 20 | Dose (mg/kg-d) | | Mean no. live fetuses ± SD (kg) | | % Change from control
Aso et al. (2014); JPEC (2008h); Rat, S-D; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 5 to GD 19; C-section GD 20 | 0 | | 13.6 ± 1.5 | | -
Aso et al. (2014); JPEC (2008h); Rat, S-D; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 5 to GD 19; C-section GD 20 | 100 | | 12.0 ± 2.65 | | −12
Aso et al. (2014); JPEC (2008h); Rat, S-D; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 5 to GD 19; C-section GD 20 | 300 | | 12.6 ± 2.58 | | −7
Aso et al. (2014); JPEC (2008h); Rat, S-D; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 5 to GD 19; C-section GD 20 | 1,000 | | 12.3 ± 2.8 | | −10
Asano et al. (2011); JPEC (2008i); Rabbit, New Zealand White; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 6 to GD 27; C-section GD 28 | Dose (mg/kg-d) | | Mean no. live fetuses ± SD (kg) | | % Change from control
Asano et al. (2011); JPEC (2008i); Rabbit, New Zealand White; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 6 to GD 27; C-section GD 28 | 0 | | 7.8 ± 3.1 | | -
Asano et al. (2011); JPEC (2008i); Rabbit, New Zealand White; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 6 to GD 27; C-section GD 28 | 100 | | 7.9 ± 3.2 | | 1
Asano et al. (2011); JPEC (2008i); Rabbit, New Zealand White; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 6 to GD 27; C-section GD 28 | 300 | | 8.4 ± 2.0 | | 8
Asano et al. (2011); JPEC (2008i); Rabbit, New Zealand White; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 6 to GD 27; C-section GD 28 | 1,000 | | 6.9 ± 3.2 | | −12
Gestation length
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | Dose (mg/kg-d) | | Mean gestation length ± SD (d) | | % Change from control
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 0 | | 22.2 ± 0.4 | | -
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 100 | | 22.1 ± 0.4 | | 0
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 300 | | 22.2 ± 0.4 | | 0
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 1,000 | | 22.6 ± 0.5 | | 2
Gaoua (2004b); Rat, S-D; oral―gavage; F0, male and female (25/sex/group): 0, 250, 500, or 1,000 mg/kg-d; dosed daily for 18 wk from 10 wk premating until weaning of F1 pups; F1, male and female (24−25/group): 0, 250, 500, or 1,000 mg/kg-d; dosed daily from PND 22 until weaning of F2 pups | Dose (mg/kg-d) | Gestation length (d), F0 | % Change from control, F0 | Gestation length (d), F1 | % Change from control, F1
| 0 | 21.7 | - | 21.5 | -
| 250 | 21.5 | −1 | 21.6 | 0
| 500 | 21.5 | −1 | 21.6 | 0
| 1,000 | 21.8 | 0 | 21.6 | 0
Estrous cyclicity
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | Dose (mg/kg-d) | % Females w/normal estrous cycles, F0 | | Mean estrous cycle length ± SD (d) | | % Change from control
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 0 | 91.7 | | 4.03 ± 0.09 | | -
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 100 | 97.1 | | 4.1 ± 0.29 | | 2
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 300 | 97.1 | | 4.06 ± 0.17 | | 1
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 1,000 | 95.8 | | 4.29 ± 0.61 | | 6
Organ weights
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | Absolute weight
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | Dose (mg/kg-d) | Mean ovary wt ± SD (mg) | % Change from control | Mean uterus wt ± SD (mg) | % Change from control
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 0 | 98.8 ± 14.9 | - | 468 ± 68 | -
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 100 | 92.5 ± 16.6 | −6 | 513 ± 151 | 10
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 300 | 95.3 ± 11.1 | −4 | 523 ± 157 | 12
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 1,000 | 100.9 ± 16.9 | 2 | 516 ± 136 | 10
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | Relative weight
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | Dose (mg/kg-d) | Mean ovary wt ± SD (mg) | % Change from control | Mean uterus wt ± SD (mg) | % Change from control
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 0 | 30.7 ± 4.7 | - | 146 ± 27 | -
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 100 | 28.6 ± 6 | −7 | 158 ±49 | 8
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 300 | 29.3 ± 3.6 | −5 | 162 ± 53 | 11
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 1,000 | 29.9 ± 4.9 | −3 | 154 ± 46 | 5
Gaoua (2004b); Rat, S-D; oral―gavage; F0, male and female (19-25/sex/group): 0, 250, 500, or 1,000 mg/kg-d; dosed daily for 18 wk from 10 wk premating until weaning of F1 pups; F1, male and female (19−25/group): 0, 250, 500, or 1,000 mg/kg-d; dosed daily from PND 22 until weaning of F2 pups | Dose (mg/kg-d) | Mean ovary wt. ± SD (g) | % Change from control | Mean uterus wt. ± SD (g) | % Change from control
| Absolute weight, F0
| 0 | 0.168 ± 0.025 | - | 0.54 ± 0.096 | -
| 250 | 0.167 ± 0.027 | −1 | 0.587 ± 0.231 | 9
| 500 | 0.167 ± 0.022 | −1 | 0.483 ± 0.102 | −11
| 1,000 | 0.164 ± 0.023 | −2 | 0.576 ± 0.218 | 7
| Absolute weight, F1
| 0 | 0.164 ± 0.027 | - | 0.557 ± 0.13 | -
| 250 | 0.172 ± 0.028 | 5 | 0.577 ± 0.161 | 4
| 500 | 0.168 ± 0.031 | 2 | 0.538 ± 0.141 | −3
| 1,000 | 0.163 ± 0.049 | −1 | 0.547 ± 0.122 | −2
Medinsky et al. (1999); U.S. EPA (1997); Rat, F344; inhalation―vapor; male (48/group): 0, 500, 1,750, or 5,000 ppm (0, 2,090, 7,320, or 20,900 mg/m^3^);^d^ female (48/group): 0, 500, 1,750, or 5,000 ppm (0, 2,090, 7,320, or 20,900 mg/m^3^)^d^; dynamic whole-body chamber; 6 h/d, 5 d/wk for 13 wk | Dose (mg/m^3^) | | Mean ovary wt ± SD (g) | | % Change from control
| 0 | | 0.085 ± 0.022 | | -
| 2,090 | | 0.095 ± 0.016 | | 12
| 7,320 | | 0.088 ± 0.12 | | 4
| 20,900 | | 0.090 ± 0.19 | | 6
Asano et al. (2011); JPEC (2008i); Rabbit, New Zealand White oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 6 to GD 27; C-section GD 28 | Dose (mg/kg-d) | | Gravid uterus wt ± SD (g) | | % Change from control
Asano et al. (2011); JPEC (2008i); Rabbit, New Zealand White oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 6 to GD 27; C-section GD 28 | 0 | | 383 ± 98 | | -
Asano et al. (2011); JPEC (2008i); Rabbit, New Zealand White oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 6 to GD 27; C-section GD 28 | 100 | | 398 ± 128 | | 4
Asano et al. (2011); JPEC (2008i); Rabbit, New Zealand White oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 6 to GD 27; C-section GD 28 | 300 | | 403 ± 91 | | 5
Asano et al. (2011); JPEC (2008i); Rabbit, New Zealand White oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 6 to GD 27; C-section GD 28 | 1,000 | | 323 ± 128 | | −16
Miyata et al. (2013); JPEC (2008c); Rat, S-D; oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for 180 d | Dose (mg/kg-d) | | Mean absolute ovary wt ± SD (mg) | | % Change from control
Miyata et al. (2013); JPEC (2008c); Rat, S-D; oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for 180 d | 0 | | 70.0 ± 18.7 | | -
Miyata et al. (2013); JPEC (2008c); Rat, S-D; oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for 180 d | 5 | | 71.0 ± 21.7 | | 1
Miyata et al. (2013); JPEC (2008c); Rat, S-D; oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for 180 d | 25 | | 73.8 ± 16.6 | | 5
Miyata et al. (2013); JPEC (2008c); Rat, S-D; oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for 180 d | 100 | | 67.7 ± 17.7 | | −3
Miyata et al. (2013); JPEC (2008c); Rat, S-D; oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for 180 d | 400 | | 76.6 ± 18.2 | | 9
Miyata et al. (2013); JPEC (2008c); Rat, S-D; oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for 180 d | Dose (mg/kg-d) | | Mean relative ovary wt ± SD (mg/100g) | | % Change from control
Miyata et al. (2013); JPEC (2008c); Rat, S-D; oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for 180 d | 0 | | 20.4 ± 5.4 | | -
Miyata et al. (2013); JPEC (2008c); Rat, S-D; oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for 180 d | 5 | | 21.4 ± 5 | | 5
Miyata et al. (2013); JPEC (2008c); Rat, S-D; oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for 180 d | 25 | | 21.8 ± 4.8 | | 7
Miyata et al. (2013); JPEC (2008c); Rat, S-D; oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for 180 d | 100 | | 20.0 ± 4.9 | | −2
Miyata et al. (2013); JPEC (2008c); Rat, S-D; oral―gavage; male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; daily for 180 d | 400 | | 22.8 ± 5.5 | | 12
JPEC (2008b); Rat, S-D; inhalation―vapor; male (10/group): 0, 150, 500, 1,500, or 5,000 ppm (0, 627, 2,090, 6,270, or 20,900 mg/m^3^);^d^ female (10/group): 0, 150, 500, 1,500, or 5,000 ppm (0, 627, 2,090, 6,270, or 20,900 mg/m^3^)^d^; dynamic whole-body chamber; 6 h/d, 5 d/wk for 13 wk; generation method, analytical concentration, and method reported | Dose (mg/m^3^) | n | Mean ovary wt ± SD (mg) | % Change from control | Mean uterus wt ± SD (g) | % Change from control
| Absolute weight, Day 92
| 0 | 10 | 91.47 ± 10.26 | - | 0.709 ± 0.222 | -
| 627 | 10 | 87.36 ± 15.83 | 0 | 0.819 ± 0.38 | 16
| 2,090 | 10 | 84.92 ± 16.91 | 0 | 0.654 ± 0.159 | −8
| 6,270 | 10 | 78.39 ± 9.83 | 0 | 0.712 ± 0.198 | 0
| 20,900 | 10 | 91.94 ± 21.84 | 0 | 0.702 ± 0.205 | −1
| Absolute weight, Day 120
| 0 | 6 | 82.82 ± 17.89 | - | 0.965 ± 0.332 | -
| 627 | - | - | - | - | -
| 2,090 | - | - | - | - | -
| 6,270 | - | - | - | - | -
| 20,900 | 6 | 90.38 ± 15.88 | 9 | 0.818 ± 0.286 | −15
| Relative weight, Day 92
| 0 | 10 | 27.19 ± 3.8 | - | 0.21 ± 0.066 | -
| 627 | 10 | 27.58 ± 4.35 | 1 | 0.269 ± 0.151 | 28
| 2,090 | 10 | 27.03 ± 4.55 | 0 | 0.211 ± 0.055 | 0
| 6,270 | 10 | 25 ± 2.67 | −6 | 0.228 ± 0.061 | 9
| 20,900 | 10 | 30.39 ± 6.46 | 9 | 0.231 ± 0.071 | 10
| Relative weight, Day 120
| 0 | 6 | 25.02 ± 4.03 | - | 0.298 ± 0.107 | -
| 627 | - | - | - | - | -
| 2,090 | - | - | - | - | -
| 6,270 | - | - | - | - | -
| 20,900 | 6 | 26.72 ± 4.79 | 7 | 0.24 ± 0.089 | −19
JPEC (2010a); Rat, F344; oral―water; male (50/group): 0, 625, 2,500, or 10,000 ppm (0, 28, 121, or 542 mg/kg-d);^e^ female (50/group): 0, 625, 2,500, or 10,000 ppm (0, 46, 171, or 560 mg/kg-d)^e^; daily for 104 wk | Dose (mg/kg-d) | | Mean ovary wt ± SD (g) | | % Change from control
| 0 | | 0.194 ± 0.238 | | -
| 46 | | 0.18 ± 0.146 | | −7.21649
| 171 | | 0.153 ± 0.035 | | −21.134
| 560 | | 0.147 ± 0.023 | | −24.2268

LD = lactation day; PND = postnatal day; SD = standard deviation.

% change from control = [(control value – treated group value) ÷ control value] × 100.

Absolute change from control (%) = control value (%) – treated group value (%).

a Result is statistically significant (p < 0.05) based on analysis of data by study authors.

b Copulation index (%) = (no. of rats with successful copulation ÷ no. of rats paired) × 100.

c Fertility index (%) = (no. females pregnant or no. of males sired ÷ no. of rats with successful copulation) × 100.

d 4.18 mg/m^3^ = 1 ppm.

e Conversion performed by the study authors.

-For controls, no response relevant; for other doses, no quantitative response reported.

Figure 1-13 Exposure-response array of female reproductive effects following oral exposure to ETBE

Figure 1-14 Exposure-response array of female reproductive effects following inhalation exposure to ETBE

#### Mechanistic Evidence of Female Reproductive Effects

No mechanistic evidence for female reproductive effects was identified by the literature search.

#### Integration of Female Reproductive Effects

The available evidence to assess female reproductive effects consists of one- and two-generation reproductive toxicity studies, developmental toxicity studies, and 90-day through 2-year oral and inhalation exposure studies that adequately evaluate the relevant female reproductive endpoints. These studies show that ETBE does not adversely affect maternal body-weight gain, fertility, mating, pregnancy parameters, or reproductive organ weights in all but one study up to 1,000 mg/kg-day (oral exposure) or 5,000 ppm (whole-body inhalation exposure) in the female rat or rabbit. Relative, but not absolute ovary weights were significantly increased following ETBE inhalation exposure in one 2-year study but not observed in other 2-year, 180/90-day, reproductive, or developmental studies. Collectively, although minimal effects were observed at otherwise toxic dose levels, the available evidence is considered insufficient to identify female reproductive effects as a potential human hazard of ETBE, and female reproductive effects are not carried forward as a hazard.

### 1.2.4 Developmental Effects

#### Synthesis of Effects Related to Development

The database examining developmental effects following ETBE exposure includes no human data; it is composed of data from toxicology studies conducted in S-D rats or New Zealand White rabbits in which ETBE was administered via gavage. These consisted of three prenatal developmental toxicity studies [two in rats: Aso et al. (2014); JPEC (2008h); Gaoua (2004a) and one study in rabbits: Asano et al. (2011); JPEC (2008i)], a one-generation reproductive toxicity study in rats (Fujii et al., 2010; JPEC, 2008e), and a two-generation reproductive toxicity study in rats (Gaoua, 2004a). The design, conduct, and reporting of all five studies were of sufficient quality to inform human health hazard assessment. The highest dose level tested in each study was 1,000 mg/kg-day, the recommended limit dose for prenatal developmental toxicology studies (OECD, 2001; U.S. EPA, 1998b).

Developmental endpoints evaluated after ETBE exposure include prenatal and postnatal survival, growth, and morphological development. In addition, limited assessments of postnatal neurological functional development were conducted. Selected developmental toxicity data are summarized in Table 1-17.

Evidence of the effects of ETBE treatment on pre- or postnatal survival was minimal. In the developmental toxicity study in rats by Aso et al. (2014) and JPEC (2008h), increased preimplantation loss was observed in the treated groups. The percent preimplantation loss in the 1,000 mg/kg-day dams was 81.8% greater than control, while it was increased 37.9% at 100 mg/kg-day and 21.2% at 300 mg/kg-day. Statistical significance was not reported. Increased preimplantation loss was not observed in the other available developmental toxicity studies in rats or rabbits [Gaoua (2004a) and Asano et al. (2011); JPEC (2008i), respectively]. Postnatal survival was not affected by ETBE treatment in either the first or second generation of the reproductive toxicity study by Gaoua (2004b). Viability indices throughout the lactation period were similar between control and treated groups during both generations of this study. In the one-generation reproductive toxicity study (Fujii et al., 2010; JPEC, 2008e), there was evidence of a nonsignificant decrease (10.5% as compared with control) in the Postnatal Day (PND) 4 viability index at 1,000 mg/kg-day. Examination of the individual animal data indicated the majority of pup deaths occurred from the total loss of three litters from PND 0−4. For two of these litters, severe maternal toxicity had led to moribund sacrifice of the dams in early lactation; this is the only evidence in the available ETBE data in which adverse outcomes in the offspring were definitively associated with maternal toxicity. The third dam with total litter loss had no evidence of treatment-related toxicity.

Neither prenatal nor postnatal growth were affected by ETBE treatment. Mean fetal weights were comparable between the control and ETBE-treated groups in the prenatal developmental toxicity studies in rats and rabbits (Aso et al., 2014; Asano et al., 2011; JPEC, 2008h, i; Gaoua, 2004a). Similarly, pup weights from PND 0−21 were not affected by treatment in the reproductive toxicity studies (Fujii et al., 2010; JPEC, 2008e; Gaoua, 2004b). Additionally, Fujii et al. (2010) and JPEC (2008e) observed no effects in the completion rate of development landmarks in male and female F1 offspring, specifically pinna detachment on PND 3, incisor eruption on PND 11, and eye opening on PND 15. Organ weights (brain, spleen, and thymus) were evaluated in PND 21 pups in the one- and two-generation reproduction studies (Fujii et al., 2010; JPEC, 2008e; Gaoua, 2004b); no significant differences were observed between control and treated groups (not shown in evidence table). At the termination of adult animals in the reproductive toxicity studies, a number of organ weights were measured. Sections 1.2.1 and 1.2.2 discuss increased mean kidney and liver weights, respectively, that were observed in the adult F1 offspring of the two-generation reproduction study (Gaoua, 2004b). The findings in the F1 adults were similar to those in the parental (F0) adults, indicating an absence of lifestage-related susceptibility for these outcomes.

No evidence existed of treatment-related effects on postnatal morphological assessments. These assessments consisted of anogenital distance measurements in F1 and F2 pups on PND 1 (Gaoua, 2004b) and the age of sexual maturation in F1 pups (preputial separation in males and vaginal opening in females) (Fujii et al., 2010; JPEC, 2008e; Gaoua, 2004b).

In the prenatal developmental toxicity studies with ETBE (Aso et al., 2014; Asano et al., 2011; JPEC, 2008h, i; Gaoua, 2004a), there was sporadic evidence of treatment-related alterations in fetal development at 1,000 mg/kg-day but no consistent pattern of effect.

In Aso et al. (2014), a >threefold increase in the number and percent of rat fetuses with skeletal variations was noted at 1,000 mg/kg-day compared with control. Examination of the individual litter data revealed that this increase was primarily due to a statistically significant >sixfold increase in the number of fetuses (and >threefold increase in the number of litters) with rudimentary lumbar rib at that dose. The study authors dismissed the relevance of this finding, reporting that it is within a historical control range (1.1−21.2%) for the strain of rat used in the study and because the effect has sometimes been viewed as transient [e.g., Chernoff et al. (1991)]. Nevertheless, the increase in the incidence of this finding is statistically significant compared with the concurrent control, which is considered more relevant and preferable than using historical controls, and the finding might have been the result of an alteration of vertebral development; therefore, it is considered potentially treatment related.

In Gaoua (2004a), a statistically significant 37% increase in the number of fetuses with unossified 4th metacarpal as compared with control was observed at 1,000 mg/kg-day. Further evaluation of the fetuses, which were double stained with alcian blue, revealed that a cartilage precursor was present, suggesting that the finding represented a treatment-related delay in development rather than a malformation.

An increase in the number of rabbit fetuses and litters with visceral malformations at 1,000 mg/kg-day was noted in Asano et al. (2011) and JPEC (2008i). This was specifically attributed to observations of fetuses with absent right atrioventricular valve of the heart. The incidences of this finding did not achieve statistical significance. Also, in Asano et al. (2011) and JPEC (2008i), a 66% increase in the number of rabbit fetuses with skeletal variations at 1,000 mg/kg-day as compared with control was found to be primarily attributed to incidences of unossified talus (in 12 fetuses, 6 litters).

In examining reproductive toxicity, Fujii et al. (2010), JPEC (2008e), and Gaoua (2004b) conducted a limited evaluation of postnatal functional neurological development in F1 male and female offspring. No treatment-related effects were found in reflex ontogeny assessments, which included surface righting reflex on PND 5 (Fujii et al., 2010; JPEC, 2008e; Gaoua, 2004b), negative geotaxis on PND 8 (Fujii et al., 2010; JPEC, 2008e), cliff avoidance on PND 11 (Gaoua, 2004b), and air righting reflex on PND 17 (Gaoua, 2004b) or PND 18 (Fujii et al., 2010; JPEC, 2008e). Gaoua (2004b) also conducted tests in F1 males and females of acoustic startle response (Postnatal Week [PNW] 4), pupil constriction (PNW 4), and motor activity (PNW 7 and 8). The motor activity testing was performed using an automated device that measured the number of movements within the front or back of the cage, back-and-forth movements, and vertical movements. Two 10-minute trials were conducted 1 week apart. No treatment-related effects were found.

Table 1-17 Evidence pertaining to developmental effects in animals following exposure to ETBE

Reference and study design | Results
Prenatal survival
Aso et al. (2014); JPEC (2008h); Rat, S-D; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 5 to GD 19; C-section GD 20 | Dose (mg/kg-d) | No. litters | No. preimplantation loss | % Change from control | % Preimplantation loss^a^ | % Change from control
Aso et al. (2014); JPEC (2008h); Rat, S-D; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 5 to GD 19; C-section GD 20 | 0 | 21 | 22 | - | 6.6 | -
Aso et al. (2014); JPEC (2008h); Rat, S-D; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 5 to GD 19; C-section GD 20 | 100 | 22 | 25 | 13.6 | 9.1 | 37.9
Aso et al. (2014); JPEC (2008h); Rat, S-D; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 5 to GD 19; C-section GD 20 | 300 | 20 | 25 | 13.6 | 8.0 | 21.2
Aso et al. (2014); JPEC (2008h); Rat, S-D; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 5 to GD 19; C-section GD 20 | 1,000 | 22 | 39 | 77.3 | 12.0 | 81.8
Aso et al. (2014); JPEC (2008h); Rat, S-D; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 5 to GD 19; C-section GD 20 | Dose (mg/kg-d) | | No. resorptions | | % Postimplantation loss^b^
Aso et al. (2014); JPEC (2008h); Rat, S-D; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 5 to GD 19; C-section GD 20 | 0 | | 18 | | 5.8
Aso et al. (2014); JPEC (2008h); Rat, S-D; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 5 to GD 19; C-section GD 20 | 100 | | 22 | | 7.2
Aso et al. (2014); JPEC (2008h); Rat, S-D; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 5 to GD 19; C-section GD 20 | 300 | | 12 | | 4.2
Aso et al. (2014); JPEC (2008h); Rat, S-D; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 5 to GD 19; C-section GD 20 | 1,000 | | 13 | | 5
Gaoua (2004a); Rat, S-D; oral―gavage; female (24/group): 0, 250, 500, or 1,000 mg/kg-d; dosed daily from GD 5 to GD 19; C-section GD 20 | Dose (mg/kg-d) | No. litters | No. preimplantation loss | | % Preimplantation loss^a^
Gaoua (2004a); Rat, S-D; oral―gavage; female (24/group): 0, 250, 500, or 1,000 mg/kg-d; dosed daily from GD 5 to GD 19; C-section GD 20 | 0 | 21 | 48 | | 17.8
Gaoua (2004a); Rat, S-D; oral―gavage; female (24/group): 0, 250, 500, or 1,000 mg/kg-d; dosed daily from GD 5 to GD 19; C-section GD 20 | 250 | 19 | 36 | | 14.9
Gaoua (2004a); Rat, S-D; oral―gavage; female (24/group): 0, 250, 500, or 1,000 mg/kg-d; dosed daily from GD 5 to GD 19; C-section GD 20 | 500 | 20 | 38 | | 14.3
Gaoua (2004a); Rat, S-D; oral―gavage; female (24/group): 0, 250, 500, or 1,000 mg/kg-d; dosed daily from GD 5 to GD 19; C-section GD 20 | 1,000 | 22 | 47 | | 16.8
Gaoua (2004a); Rat, S-D; oral―gavage; female (24/group): 0, 250, 500, or 1,000 mg/kg-d; dosed daily from GD 5 to GD 19; C-section GD 20 | Dose (mg/kg-d) | | No. postimplantation loss | | % Postimplantation loss^b^
Gaoua (2004a); Rat, S-D; oral―gavage; female (24/group): 0, 250, 500, or 1,000 mg/kg-d; dosed daily from GD 5 to GD 19; C-section GD 20 | 0 | | 14 | | 5.2
Gaoua (2004a); Rat, S-D; oral―gavage; female (24/group): 0, 250, 500, or 1,000 mg/kg-d; dosed daily from GD 5 to GD 19; C-section GD 20 | 250 | | 16 | | 6.6
Gaoua (2004a); Rat, S-D; oral―gavage; female (24/group): 0, 250, 500, or 1,000 mg/kg-d; dosed daily from GD 5 to GD 19; C-section GD 20 | 500 | | 19 | | 7.2
Gaoua (2004a); Rat, S-D; oral―gavage; female (24/group): 0, 250, 500, or 1,000 mg/kg-d; dosed daily from GD 5 to GD 19; C-section GD 20 | 1,000 | | 21 | | 7.5
Asano et al. (2011); JPEC (2008i); Rabbit, New Zealand White; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 6 to GD 27; C-section GD 28 | Dose (mg/kg-d) | No. litters | % Preimplantation loss^a^ | | % Postimplantation loss^b^
Asano et al. (2011); JPEC (2008i); Rabbit, New Zealand White; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 6 to GD 27; C-section GD 28 | 0 | 22 | 19.6 | | 11.0
Asano et al. (2011); JPEC (2008i); Rabbit, New Zealand White; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 6 to GD 27; C-section GD 28 | 100 | 22 | 15.3 | | 11.3
Asano et al. (2011); JPEC (2008i); Rabbit, New Zealand White; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 6 to GD 27; C-section GD 28 | 300 | 20 | 10.7 | | 7.0
Asano et al. (2011); JPEC (2008i); Rabbit, New Zealand White; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 6 to GD 27; C-section GD 28 | 1,000 | 23 | 22.9 | | 8.7
Postnatal survival
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | Dose (mg/kg-d) | Viability index PND 0 ± SD | Viability index PND 4 ± SD | % Change from control (PND 4) | Total litter loss (PND 0−4)^c^
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 0 | 98.9 ± 3.7 | 97.4 ± 4.7 | - | 0
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 100 | 97.9 ± 5.6 | 96.7 ± 8.1 | −0.7 | 0
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 300 | 99.5 ± 2.6 | 99.6 ± 1.9 | 2.3 | 0
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 1,000 | 93.6 ± 15.5 | 87.2 ± 29.8 | −10.5 | 3
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | Dose (mg/kg-d) | | Viability index―PND 21 ± SD
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 0 | | 97 ± 11.1
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 100 | | 95.8 ± 11.4
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 300 | | 95.7 ± 11.1
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 1,000 | | 92.5 ± 23.1
Gaoua (2004b); Rat, S-D; oral―gavage; F0, male and female (25/sex/group): 0, 250, 500, or 1,000 mg/kg-d; dosed daily for 18 wk from 10 wk premating until weaning of F1 pups; F1, male and female (24−25/group): 0, 250, 500, or 1,000 mg/kg-d; dosed daily from PND 22 until weaning of F2 pups | Dose (mg/kg-d) | Viability index PND 0 | Viability index PND 4 | Total litter loss (PND 0−4) | Viability index PND 21
| F1
| 0 | 100 | 97.6 | 0 | 94.6
| 250 | 100 | 92.9 | 1 | 91.7
| 500 | 100 | 82.3 | 0 | 96.1
| 1,000 | 100 | 97.7 | 1 | 99.5
| F2
| 0 | 100 | 97.6 | 0 | 97.6
| 250 | 100 | 94.8 | 0 | 98.8
| 500 | 100 | 97.0 | 3 | 100
| 1,000 | 100 | 92.9 | 0 | 99.3
Prenatal growth
Aso et al. (2014); JPEC (2008h); Rat, S-D; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 5 to GD 19; C-section GD 20 | Dose (mg/kg-d) | No. litters | Mean fetal weight ± SD male (g) | | Mean fetal weight ± SD female (g)
Aso et al. (2014); JPEC (2008h); Rat, S-D; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 5 to GD 19; C-section GD 20 | 0 | 21 | 4.1 ± 0.3 | | 3.89 ± 0.25
Aso et al. (2014); JPEC (2008h); Rat, S-D; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 5 to GD 19; C-section GD 20 | 100 | 22 | 4.14 ± 0.33 | | 3.92 ± 0.23
Aso et al. (2014); JPEC (2008h); Rat, S-D; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 5 to GD 19; C-section GD 20 | 300 | 20 | 4.23 ± 0.22 | | 4.01 ± 0.22
Aso et al. (2014); JPEC (2008h); Rat, S-D; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 5 to GD 19; C-section GD 20 | 1,000 | 22 | 4.14 ± 0.34 | | 3.91 ± 0.39
Gaoua (2004b); Rat, S-D; oral―gavage; F0, male and female (25/sex/group): 0, 250, 500, or 1,000 mg/kg-d; dosed daily for 18 wk from 10 wk premating until weaning of F1 pups; F1, male and female (24−25/group): 0, 250, 500, or 1,000 mg/kg-d; dosed daily from PND 22 until weaning of F2 pups | Dose (mg/kg-d) | No. litters | Mean fetal weight ± SD male (g) | | Mean fetal weight ± SD female (g)
| 0 | 21 | 3.92 ± 0.58 | | 3.77 ± 0.5
| 250 | 19 | 4.03 ± 0.32 | | 3.82 ± 0.33
| 500 | 20 | 3.94 ± 0.35 | | 3.75 ± 0.32
| 1,000 | 22 | 3.91 ± 0.33 | | 3.66 ± 0.39
Asano et al. (2011); JPEC (2008i); Rabbit, New Zealand White; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 6 to GD 27; C-section GD 28 | Dose (mg/kg-d) | No. litters | Mean fetal weight ± SD male (g) | | Mean fetal weight ± SD female (g)
Asano et al. (2011); JPEC (2008i); Rabbit, New Zealand White; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 6 to GD 27; C-section GD 28 | 0 | 22 | 33.5 ± 4.1 | | 31.5 ± 3.7
Asano et al. (2011); JPEC (2008i); Rabbit, New Zealand White; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 6 to GD 27; C-section GD 28 | 100 | 22 | 33.4 ± 6.2 | | 31.5 ± 4.8
Asano et al. (2011); JPEC (2008i); Rabbit, New Zealand White; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 6 to GD 27; C-section GD 28 | 300 | 20 | 33.9 ± 2.5 | | 32.0 ± 3.6
Asano et al. (2011); JPEC (2008i); Rabbit, New Zealand White; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 6 to GD 27; C-section GD 28 | 1,000 | 23 | 32.3 ± 6.5 | | 30.1 ± 6.0
Postnatal growth
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | Dose (mg/kg-d) | No. litters | Mean ± SD PND 0 (g) | Mean ± SD PND 4 precull (g) | Mean ± SD PND 21 (g)
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | F1—male pup weight
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 0 | 21 | 6.9 ± 0.7 | 11.0 ± 2.0 | 61.3 ± 6.3
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 100 | 22 | 6.9 ± 0.8 | 11.0 ± 1.8 | 61.0 ± 7.0
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 300 | 23 | 6.9 ± 0.6 | 10.8 ± 1.4 | 61.6 ± 4.6
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 1,000 | 22 | 7.0 ± 0.7 | 10.4 ± 1.7 | 61.6 ± 6.4
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | F1—female pup weight
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 0 | 21 | 6.5 ± 0.7 | 10.4 ± 1.8 | 59.3 ± 6.4
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 100 | 22 | 6.5 ± 0.6 | 10.4 ± 1.6 | 58.5 ± 6.4
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 300 | 23 | 6.5 ± 0.6 | 10.2 ± 1.4 | 58.5 ± 6.4
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 1,000 | 22 | 6.6 ± 0.6 | 10.0 ± 1.8 | 59.7 ± 5.2
Gaoua (2004b); Rat, S-D; oral―gavage; F0, male and female (25/sex/group): 0, 250, 500, or 1,000 mg/kg-d; dosed daily for 18 wk from 10 wk premating until weaning of F1 pups; F1, male and female (24−25/group): 0, 250, 500, or 1,000 mg/kg-d; dosed daily from PND 22 until weaning of F2 pups | Dose (mg/kg-d) | Mean ± SD PND 1 (g) | Mean ± SD PND 4 precull (g) | | Mean ± SD PND 21 (g)
| F1—male pup weight
| 0 | 6.8 ± 0.7 | 9.1 ± 1.4 | | 50.1 ± 4.9
| 250 | 6.7 ± 0.6 | 9.0 ± 1.6 | | 51.7 ± 4.1
| 500 | 6.5 ± 0.7 | 8.7 ± 1.3 | | 50.5 ± 6.7
| 1,000 | 7.0 ± 0.7 | 9.3 ± 1.2 | | 52.4 ± 4.5
| F1—female pup weight
| 0 | 6.4 ± 0.6 | 8.6 ± 1.4 | | 48.1 ± 6.1
| 250 | 6.4 ± 0.6 | 8.5 ± 1.6 | | 49.5 ± 4.3
| 500 | 6.0 ± 0.6 | 8.1 ± 1.2 | | 48.2 ± 5.9
| 1,000 | 6.5 ± 0.6 | 8.9 ± 1.2 | | 50.6 ± 4.4
| F2—male pup weight
| 0 | 6.9 ± 0.6 | 9.5 ± 1.5 | | 51.5 ± 7.2
| 250 | 6.7 ± 0.6 | 9.3 ± 1.0 | | 52.1 ± 4.4
| 500 | 6.4 ± 0.5 | 9.2 ± 1.0 | | 50.3 ± 5.8
| 1,000 | 6.3 ± 0.6 | 9.2 ± 1.4 | | 51.2 ± 3.6
| F2—female pup weight
| 0 | 6.5 ± 0.6 | 8.9 ± 1.3 | | 49.6 ± 6.2
| 250 | 6.3 ± 0.6 | 8.8 ± 1.0 | | 49.9 ± 3.6
| 500 | 6.4 ± 0.5 | 8.9 ± 0.9 | | 49.0 ± 5.5
| 1,000 | 6.3 ± 0.6 | 8.7 ± 1.4 | | 49.1 ± 3.7
Prenatal morphology
Aso et al. (2014); JPEC (2008h); Rat, S-D; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 5 to GD 19; C-section GD 20 | Dose (mg/kg-d) | No. fetuses (litters)^d^ | No. fetuses examined for visceral anomalies | No. fetuses with visceral malformations | No. fetuses with visceral variations
Aso et al. (2014); JPEC (2008h); Rat, S-D; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 5 to GD 19; C-section GD 20 | 0 | 285 (21) | 146 | 3 (3) | 6 (6)
Aso et al. (2014); JPEC (2008h); Rat, S-D; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 5 to GD 19; C-section GD 20 | 100 | 263 (22) | 137 | 2 (2) | 8 (7)
Aso et al. (2014); JPEC (2008h); Rat, S-D; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 5 to GD 19; C-section GD 20 | 300 | 251 (20) | 132 | 2 (2) | 4 (4)
Aso et al. (2014); JPEC (2008h); Rat, S-D; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 5 to GD 19; C-section GD 20 | 1,000 | 270 (22) | 139 | 0 | 8 (7)
Aso et al. (2014); JPEC (2008h); Rat, S-D; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 5 to GD 19; C-section GD 20 | Dose (mg/kg-d) | No. fetuses examined for skeletal anomalies | No. fetuses with skeletal malformations | No. fetuses with skeletal variations | % Fetuses (litters) with skeletal variations
Aso et al. (2014); JPEC (2008h); Rat, S-D; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 5 to GD 19; C-section GD 20 | 0 | 139 | 0 | 9 (8) | 6.5 (38.1)
Aso et al. (2014); JPEC (2008h); Rat, S-D; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 5 to GD 19; C-section GD 20 | 100 | 126 | 0 | 3 (3) | 2.4 (13.6)
Aso et al. (2014); JPEC (2008h); Rat, S-D; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 5 to GD 19; C-section GD 20 | 300 | 119 | 0 | 3 (3) | 2.5 (15.0)
Aso et al. (2014); JPEC (2008h); Rat, S-D; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 5 to GD 19; C-section GD 20 | 1,000 | 131 | 0 | 29 (13) | 22.1 (59.1)
Aso et al. (2014); JPEC (2008h); Rat, S-D; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 5 to GD 19; C-section GD 20 | Dose (mg/kg-d) | | No. fetuses (litters) with rudimentary lumbar rib | | % Fetuses (litters) with rudimentary lumbar rib
Aso et al. (2014); JPEC (2008h); Rat, S-D; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 5 to GD 19; C-section GD 20 | 0 | | 4 (4) | | 2.9 (19.0)
Aso et al. (2014); JPEC (2008h); Rat, S-D; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 5 to GD 19; C-section GD 20 | 100 | | 0 | | 0 (0)
Aso et al. (2014); JPEC (2008h); Rat, S-D; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 5 to GD 19; C-section GD 20 | 300 | | 2 (2) | | 1.7 (10.0)
Aso et al. (2014); JPEC (2008h); Rat, S-D; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 5 to GD 19; C-section GD 20 | 1,000 | | 25^e^ (11) | | 19.1^e^ (50.0)
Gaoua (2004a); Rat, S-D; oral―gavage; female (24/group): 0, 250, 500, or 1,000 mg/kg-d; dosed daily from GD 5 to GD 19; C-section GD 20 | Dose (mg/kg-d) | No. fetuses (litters)^d^ | No. fetuses with external malformations | No. fetuses examined for visceral anomalies | No. fetuses with visceral malformations
Gaoua (2004a); Rat, S-D; oral―gavage; female (24/group): 0, 250, 500, or 1,000 mg/kg-d; dosed daily from GD 5 to GD 19; C-section GD 20 | 0 | 255 (21) | 0 | 120 | 0
Gaoua (2004a); Rat, S-D; oral―gavage; female (24/group): 0, 250, 500, or 1,000 mg/kg-d; dosed daily from GD 5 to GD 19; C-section GD 20 | 250 | 226 (19) | 1 (1) | 109 | 0
Gaoua (2004a); Rat, S-D; oral―gavage; female (24/group): 0, 250, 500, or 1,000 mg/kg-d; dosed daily from GD 5 to GD 19; C-section GD 20 | 500 | 246 (20) | 0 | 116 | 0
Gaoua (2004a); Rat, S-D; oral―gavage; female (24/group): 0, 250, 500, or 1,000 mg/kg-d; dosed daily from GD 5 to GD 19; C-section GD 20 | 1,000 | 258 (22) | 0 | 122 | 1 (1)
Gaoua (2004a); Rat, S-D; oral―gavage; female (24/group): 0, 250, 500, or 1,000 mg/kg-d; dosed daily from GD 5 to GD 19; C-section GD 20 | Dose (mg/kg-d) | No. fetuses with visceral variations | No. fetuses examined for skeletal anomalies | No. fetuses with skeletal malformations | No. fetuses with skeletal variations
Gaoua (2004a); Rat, S-D; oral―gavage; female (24/group): 0, 250, 500, or 1,000 mg/kg-d; dosed daily from GD 5 to GD 19; C-section GD 20 | 0 | 1 (1) | 135 | 1 (1) | 125 (21)
Gaoua (2004a); Rat, S-D; oral―gavage; female (24/group): 0, 250, 500, or 1,000 mg/kg-d; dosed daily from GD 5 to GD 19; C-section GD 20 | 250 | 2 (2) | 117 | 2 (2) | 101 (19)
Gaoua (2004a); Rat, S-D; oral―gavage; female (24/group): 0, 250, 500, or 1,000 mg/kg-d; dosed daily from GD 5 to GD 19; C-section GD 20 | 500 | 1 (1) | 130 | 1 (1) | 116 (20)
Gaoua (2004a); Rat, S-D; oral―gavage; female (24/group): 0, 250, 500, or 1,000 mg/kg-d; dosed daily from GD 5 to GD 19; C-section GD 20 | 1,000 | 3 (3) | 136 | 2 (2) | 112 (22)
Gaoua (2004a); Rat, S-D; oral―gavage; female (24/group): 0, 250, 500, or 1,000 mg/kg-d; dosed daily from GD 5 to GD 19; C-section GD 20 | Dose (mg/kg-d) | No. fetuses with unossified 4th metacarpal | | % Change from control | % Fetuses with unossified 4th metacarpal
Gaoua (2004a); Rat, S-D; oral―gavage; female (24/group): 0, 250, 500, or 1,000 mg/kg-d; dosed daily from GD 5 to GD 19; C-section GD 20 | 0 | 27 (9) | | - | 20.0 (42.9)
Gaoua (2004a); Rat, S-D; oral―gavage; female (24/group): 0, 250, 500, or 1,000 mg/kg-d; dosed daily from GD 5 to GD 19; C-section GD 20 | 250 | 21 (10) | | −22.2 | 17.9 (52.6)
Gaoua (2004a); Rat, S-D; oral―gavage; female (24/group): 0, 250, 500, or 1,000 mg/kg-d; dosed daily from GD 5 to GD 19; C-section GD 20 | 500 | 24 (9) | | −11.1 | 18.5 (45.0)
Gaoua (2004a); Rat, S-D; oral―gavage; female (24/group): 0, 250, 500, or 1,000 mg/kg-d; dosed daily from GD 5 to GD 19; C-section GD 20 | 1,000 | 43^e^ (12) | | 37.2 | 31.6 (54.5)
Asano et al. (2011); JPEC (2008i); Rabbit, New Zealand White; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 6 to GD 27; C-section GD 28 | Dose (mg/kg-d) | No. fetuses (litters)^d^ | No. fetuses with external malformations | No. fetuses with visceral malformations | No. fetuses with skeletal malformations
Asano et al. (2011); JPEC (2008i); Rabbit, New Zealand White; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 6 to GD 27; C-section GD 28 | 0 | 171 (22) | 0 | 1 (1) | 5 (4)
Asano et al. (2011); JPEC (2008i); Rabbit, New Zealand White; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 6 to GD 27; C-section GD 28 | 100 | 174 (22)^f^ | 1 (1) | 1 (1) | 4 (4)
Asano et al. (2011); JPEC (2008i); Rabbit, New Zealand White; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 6 to GD 27; C-section GD 28 | 300 | 167 (20) | 0 | 1 (1) | 3 (2)
Asano et al. (2011); JPEC (2008i); Rabbit, New Zealand White; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 6 to GD 27; C-section GD 28 | 1,000 | 159 (23)^f^ | 1 (1) | 3 (2) | 8 (5)
Asano et al. (2011); JPEC (2008i); Rabbit, New Zealand White; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 6 to GD 27; C-section GD 28 | Dose (mg/kg-d) | No. fetuses with skeletal variations | | Absent right atrioventricular valve | % Change from control
Asano et al. (2011); JPEC (2008i); Rabbit, New Zealand White; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 6 to GD 27; C-section GD 28 | 0 | 9 (7) | | 0 | -
Asano et al. (2011); JPEC (2008i); Rabbit, New Zealand White; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 6 to GD 27; C-section GD 28 | 100 | 11 (9) | | 0 | 0 (0)
Asano et al. (2011); JPEC (2008i); Rabbit, New Zealand White; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 6 to GD 27; C-section GD 28 | 300 | 6 (6) | | 1 (1) | 0.6 (5.0)
Asano et al. (2011); JPEC (2008i); Rabbit, New Zealand White; oral―gavage; female (24/group): 0, 100, 300, or 1,000 mg/kg-d; dams dosed daily from GD 6 to GD 27; C-section GD 28 | 1,000 | 15 (8) | | 3 (2) | 1.9 (8.7)
Postnatal morphology
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | Dose (mg/kg-d) | No. litters | Male preputial separation―age (d) mean ± SD | | Female vaginal opening―age (d) mean ± SD
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | F1
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 0 | 21 | 41.0 ± 1.7 | | 31.2 ± 1.4
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 100 | 22 | 41.4 ± 1.1 | | 30.9 ± 1.7
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 300 | 23 | 40.6 ± 1.5 | | 30.5 ± 2.2
Fujii et al. (2010); JPEC (2008e); Rat, S-D; oral―gavage; F0, male and female (24/sex/group): 0, 100, 300, or 1,000 mg/kg-d; dosed daily for 17 wk, from 10 wk premating to LD 21 | 1,000 | 19 | 41.2 ± 1.6 | | 30.3 ± 2.1
Gaoua (2004b); Rat, S-D; oral―gavage; F0, male and female (25/sex/group): 0, 250, 500, or 1,000 mg/kg-d; dosed daily for 18 wk from 10 wk premating until weaning of F1 pups; F1, male and female (24−25/group): 0, 250, 500, or 1,000 mg/kg-d; dosed daily from PND 22 until weaning of F2 pups | Dose (mg/kg-d) | No. litters | Anogenital distance^g^―males (PND 1) mean ± SD | | Anogenital distance^g^―females (PND 1) mean ± SD
| F1
| 0 | 21 | 2.48 ± 0.18 | | 1.53 ± 0.18
| 250 | 22 | 2.45 ± 0.17 | | 1.5 ± 0.14
| 500 | 23 | 2.4 ± 0.21 | | 1.45 ± 0.14
| 1,000 | 20 | 2.43 ± 0.15 | | 1.44 ± 0.2
| F2
| 0 | 21 | 2.41 ± 0.18 | | 1.51 ± 0.18
| 250 | 22 | 2.42 ± 0.25 | | 1.47 ± 0.19
| 500 | 23 | 2.42 ± 0.23 | | 1.51 ± 0.17
| 1,000 | 20 | 2.45 ± 0.21 | | 1.57 ± 0.22
| Dose (mg/kg-d) | No. litters | Male preputial separation―age (d)―mean ± SD | | Female vaginal opening―age (d)―mean ± SD
| F1
| 0 | 25 | 35 ± 2 | | 34 ± 3
| 250 | 25 | 34 ± 2 | | 34 ± 3
| 500 | 25 | 35 ± 2 | | 35 ± 2
| 1,000 | 25 | 35 ± 2 | | 33 ± 2

LD = lactation day; SD = standard deviation.

% change from control = ([control value – treated group value] ÷ control value) × 100.

Absolute change from control (%) = control value (%) – treated group value (%).

a Percent preimplantation loss = (no. preimplantation embryonic loss ÷ no. corpora lutea) × 100.

b Percent postimplantation loss = (no. resorptions and dead fetuses ÷ no. implantations) × 100.

c Two 1,000 mg/kg-day dams were killed in a moribund condition on PND 2 and 4, thus compromising the survival of their litters. In a third litter, all pups died between PND 1−4, although there was no evidence of maternal toxicity throughout the study.

d The parenthetical number following fetal incidence indicates the associated litter incidence for all findings.

e Result is statistically significant (p < 0.05) based on analysis of data by the study authors.

f No. of fetuses examined for visceral and skeletal anomalies at 100 and 1,000 mg/kg-day were 173 and 158, respectively, because fetuses with external malformations were excluded.

g AGD/cube root of body weight.

-For controls, no response relevant; for other doses, no quantitative response reported.

Figure 1-15 Exposure-response array of developmental effects following oral exposure to ETBE

#### Mechanistic Evidence

No mechanistic evidence for developmental effects was identified by the literature search.

#### Integration of Developmental Effects

The evidence to assess developmental toxicity for ETBE consists of two prenatal developmental toxicity studies in rats and one in rabbits, a one-generation reproductive toxicity study in rats, and a two-generation reproductive toxicity study in rats. These studies included assessments of pre- and postnatal survival, growth, morphology, and functional neurological development following oral (gavage) administration during sensitive periods of development. Slight evidence of effects of ETBE treatment on prenatal or postnatal survival consisted of preimplantation loss in a developmental toxicity study in rats and decreased PND 0−4 pup viability that was associated with severe maternal toxicity. Pre- and postnatal growth (body weights and developmental landmarks), anogenital distance, sexual maturation, and evaluation of neurological function (including reflex ontogeny and assessments of acoustic startle response, pupil constriction, and motor activity in offspring) were not affected by treatment. Evidence of incidental structural (visceral and skeletal) fetal anomalies following in utero exposures to ETBE were observed at the highest dose tested (1,000 mg/kg-day). The findings were limited to increased incidences of rudimentary lumbar rib (Aso et al., 2014; JPEC, 2008h) and unossified 4th metatarsal (Gaoua, 2004b) in two rat studies and unossified talus and absent right atrioventricular valve in a rabbit study (Asano et al., 2011; JPEC, 2008i). The fetal, but not litter, incidences of skeletal findings in rats (rudimentary lumbar rib and unossified 4th metatarsal) were statistically significant at the highest dose tested (1,000 mg/kg-day). These skeletal observations were not confirmed in other species. No inhalation prenatal developmental or reproductive toxicity studies were conducted, thus potential effects of inhalation exposure on pre- and postnatal development have not been characterized. Overall, the available evidence is considered inadequate to draw conclusions regarding the development toxicity of ETBE, and developmental effects are not carried forward as a hazard.

### 1.2.5 Carcinogenicity (Other Than in the Kidney or Liver)

#### Synthesis of Carcinogenicity Data (Other Than in the Kidney or Liver)

This section reviews the studies that investigated whether exposure to ETBE can cause cancers (other than in the kidney or liver) in humans or animals. The evidence pertaining to tumorigenicity in the kidney and liver was previously discussed in Sections 1.2.1 and 1.2.2, respectively. The database for ETBE carcinogenicity consists of animal data only: three 2-year studies (two oral, one inhalation), and two “initiation, promotion” cancer bioassays performed in rats (Hagiwara et al., 2013; Saito et al., 2013; Suzuki et al., 2012; Hagiwara et al., 2011; Malarkey and Bucher, 2011; JPEC, 2010a, b; Maltoni et al., 1999) (see Table 1-18, Table 1-19; Figure 1-16, Figure 1-17). Interpretation of the study results reported by Maltoni et al. (1999) is complicated by the nonstandard histopathological diagnoses used and the greater than expected mortality in treated groups and controls compared with other laboratories. Survival was reduced at the highest exposure in males and females after 72 weeks (data not shown) and after 104 weeks. Survival in the controls was approximately 25% in males and 28% in females—much lower survival rates than expected for a 2-year study (Maltoni et al., 1999). The high mortality in this study was potentially due to chronic respiratory infections in the controls and treated groups (Malarkey and Bucher, 2011), ultimately limiting the ability of this study to predict potential carcinogenicity.

In response to the concerns regarding high mortality and the use of nonstandard histopathological diagnoses, a pathology working group sponsored by EPA and the NTP reviewed the histopathological data (Malarkey and Bucher, 2011). In addition to recalculating tumor incidences, the working group found that the respiratory infections in the study animals confound interpretation of leukemia and lymphoma. Thus, the Malarkey and Bucher (2011) data were used when considering carcinogenicity in place of the published Maltoni et al. (1999) study, and leukemia and lymphoma incidences from this study were not considered.

Following 2-year exposure to ETBE, the incidence of leiomyomas was increased in the uterus of S-D rats in the high-dose group (Maltoni et al., 1999). Malignant schwannomas in the uterus were increased only at the lowest dose, and no significant trend was observed. These neoplasms arise from nervous tissue and are not specific to uterine tissue. Leiomyomas and a carcinomas were observed in uterine/vaginal tissue, but no significant trend was observed (Malarkey and Bucher, 2011).

Several initiation-promotion studies have been conducted with ETBE (Hagiwara et al., 2015; Hagiwara et al., 2013; Hagiwara et al., 2011). While chronic cancer bioassays are considered key data for the evaluation of carcinogenicity, other types of studies, such as initiation-promotion studies, are considered supplemental lines of information that can aid in the interpretation of more standard toxicological evidence (e.g., rodent chronic bioassays), especially regarding potential modes of action (U.S. EPA, 2005a). A statistically significant and dose-dependent increase in incidence of neoplastic lesions was observed in the thyroid of F344 male rats following subchronic exposure to ETBE after a 4-week tumor initiation exposure to DMBDD (Hagiwara et al., 2011); incidences of colon and urinary bladder neoplasms also were statistically significantly increased (Hagiwara et al., 2013). Forestomach papilloma or hyperplasia incidence was elevated statistically significantly, while no cases were reported in control animals receiving 4 weeks of mutagenic treatment. This finding is consistent with the rarity of forestomach squamous cell papillomas in untreated animals [historical control rate = 0.08% in untreated male F344/N rats after 2 years (NTP, 2011); comparability with Japan Petroleum Energy Center (JPEC) controls unknown]. While increased tumors were observed with ETBE following administration of tumor initiators, it is important to recognize the limitations of these experimental protocols. Such limitations include experimental manipulation of the carcinogenic process, a generally less than chronic exposure duration, and smaller groups of animals. Male F344 rats (n = 12), exposed to ETBE via gavage for 23 weeks (in the absence of DMBDD treatment), did not show significant tumor development in any organs evaluated (Hagiwara et al., 2011). Increased tumorigenesis in these tissues was not reported following 2 years of drinking water or inhalation exposure to ETBE alone in male or female F344 rats (Saito et al., 2013; Suzuki et al., 2012; JPEC, 2010b).

#### Mechanistic Evidence

The available mechanistic evidence was previously discussed in the context of kidney and liver tumors (Sections 1.1.1 and 1.1.2). Aside from (predominantly negative) genotoxicity testing results, which are generally relevant to tumorigenesis in any tissue location (discussed in the Supplemental Information), no further mechanistic evidence was identified relevant to uterine, thyroid, colon, forestomach, or urinary bladder carcinogenesis.

#### Integration of Carcinogenicity Evidence

The evidence for carcinogenic effects other than liver or kidney is solely from rat studies. ETBE exposure following mutagen administration (DMBDD) increased the incidence of thyroid adenomas or carcinomas, colon adenomas or carcinomas, forestomach papillomas, and urinary bladder carcinomas in male rats (Hagiwara et al., 2011; JPEC, 2008d). Confidence in the data demonstrating an increase in the incidence of schwannomas is reduced because of the lack of a dose-response in S-D rats and lack of a similar effect reported in F344 rats from two other well-conducted 2-year studies, or in F344 or Wistar rats from the two-stage subchronic cancer bioassays. The hazard and dose-response conclusions regarding these carcinomas and adenomas associated with ETBE exposure are further discussed as part of the overall weight of evidence for carcinogenicity in Section 1.3.2.

Table 1-18 Evidence pertaining to carcinogenic effects (in tissues other than liver or kidney) in animals exposed to ETBE

Reference and study design | Results
Thyroid adenomas/adenocarcinomas
JPEC (2010a); Suzuki et al. (2012); Rat, F344; oral―water; male (50/group): 0, 625, 2,500, or 10,000 ppm (0, 28, 121, or 542 mg/kg-d);^a^ female (50/group): 0, 625, 2,500, or 10,000 ppm (0, 46, 171, or 560 mg/kg-d)^a^; daily for 104 wk | Male | | | Female
| Dose (mg/kg-d) | Thyroid follicular adenocarcinoma | Thyroid follicular adenoma | Dose (mg/kg-d) | Thyroid follicular adenocarcinoma | Thyroid follicular adenoma
| 0 | 0/50 | 1/50 | 0 | 0/50 | 0/50
| 28 | 1/50 | 0/50 | 46 | 1/50 | 0/50
| 121 | 0/50 | 0/50 | 171 | 0/50 | 0/50
| 542 | 0/50 | 0/50 | 560 | 0/50 | 0/50
JPEC (2010b);Saito et al. (2013); Rat, F344; inhalation―vapor; male (50/group): 0, 500, 1,500, or 5,000 ppm (0, 2,090, 6,270, or 20,900 mg/m^3^);^b^ female (50/group): 0, 500, 1,500, or 5,000 ppm (0, 2,090, 6,270, or 20,900 mg/m^3^)^b^; dynamic whole-body inhalation; 6 h/d, 5 d/wk for 104 wk; generation method, analytical concentration, and method reported | Male | | | Female
| Dose (mg/m^3^) | Thyroid follicular adenocarcinoma | Thyroid follicular adenoma | Dose (mg/m^3^) | Thyroid follicular adenocarcinoma | Thyroid follicular adenoma
| 0 | 0/50 | 1/50 | 0 | 1/50 | 0/50
| 2,090 | 0/50 | 0/50 | 2,090 | 1/50 | 0/50
| 6,270 | 0/50 | 1/50 | 6,270 | 1/50 | 0/50
| 20,900 | 0/50 | 2/50 | 20,900 | 0/50 | 0/50
Maltoni et al. (1999); Rat, S-D; oral―gavage; male (60/group): 0, 250, or 1,000 mg/kg-d; female (60/group): 0, 250, or 1,000 mg/kg-d; 4 d/wk for 104 wk; observed until natural death; Note: Tumor data not reanalyzed by Malarkey and Bucher (2011) | Male | | | Female
| Dose (mg/kg-d) | Thyroid adenocarcinoma | | Dose (mg/kg-d) | Thyroid adenocarcinoma
| 0 | 0/60 | | 0 | 0/60
| 250 | 0/60 | | 250 | 0/60
| 1,000 | 0/60 | | 1,000 | 1/60
Endometrial/uterine carcinogenic effects
JPEC (2010a);Suzuki et al. (2012); Rat, F344; oral―water; female (50/group): 0, 625, 2,500, or 10,000 ppm (0, 46, 171, or 560 mg/kg-d)^a^; daily for 104 wk | Female
JPEC (2010a);Suzuki et al. (2012); Rat, F344; oral―water; female (50/group): 0, 625, 2,500, or 10,000 ppm (0, 46, 171, or 560 mg/kg-d)^a^; daily for 104 wk | Dose (mg/kg-d) | Endometrial stromal sarcoma | | Uterine adenocarcinoma | Uterine fibroma
JPEC (2010a);Suzuki et al. (2012); Rat, F344; oral―water; female (50/group): 0, 625, 2,500, or 10,000 ppm (0, 46, 171, or 560 mg/kg-d)^a^; daily for 104 wk | 0 | 6/50 | | 1/50 | 1/50
JPEC (2010a);Suzuki et al. (2012); Rat, F344; oral―water; female (50/group): 0, 625, 2,500, or 10,000 ppm (0, 46, 171, or 560 mg/kg-d)^a^; daily for 104 wk | 46 | 9/50 | | 0/50 | 0/50
JPEC (2010a);Suzuki et al. (2012); Rat, F344; oral―water; female (50/group): 0, 625, 2,500, or 10,000 ppm (0, 46, 171, or 560 mg/kg-d)^a^; daily for 104 wk | 171 | 3/50 | | 2/50 | 0/50
JPEC (2010a);Suzuki et al. (2012); Rat, F344; oral―water; female (50/group): 0, 625, 2,500, or 10,000 ppm (0, 46, 171, or 560 mg/kg-d)^a^; daily for 104 wk | 560 | 7/50 | | 2/50 | 0/50
JPEC (2010b);Saito et al. (2013); Rat, F344; inhalation―vapor; female (50/group): 0, 500, 1,500, or 5,000 ppm (0, 2,090, 6,270, or 20,900 mg/m^3^)^b^ dynamic whole-body inhalation; 6 h/d, 5 d/wk for 104 wk; generation method, analytical concentration, and method reported | Female
| Dose (mg/m^3^) | | Endometrial stromal sarcoma | | Uterine adenocarcinoma
| 0 | | 2/50 | | 2/50
| 2,090 | | 2/50 | | 3/50
| 6,270 | | 3/50 | | 1/50
| 20,900 | | 2/50 | | 4/50
Malarkey and Bucher (2011); Maltoni et al. (1999); Rat, S-D; oral―gavage; female (60/group): 0, 250, or 1,000 mg/kg-d; reanalysis of data from Maltoni et al. (1999) for which animals were dosed 4 d/wk for 104 wk | Female
| Dose (mg/kg-d) | Carcinoma of the uterus/vagina | Uterine leiomyoma | Uterine leiomyosarcoma | Schwannoma of the uterus/vagina | Uterine carcinoma
| 0 | 0/60 | 0/60 | 1/60 | 0/60 | 0/60
| 250 | 1/60 | 0/60 | 0/60 | 7/60 | 1/60
| 1,000 | 0/60 | 3/60 | 0/60 | 2/60 | 0/60

a Conversion performed by the study authors.

b 4.18 mg/m^3^ = 1 ppm.

Table 1-19 Supplemental evidence pertaining to ETBE promotion of mutagen-initiated tumors in animals

Reference and dosing protocol | Results by endpoint
Colon adenoma or carcinoma
Hagiwara et al. (2011); JPEC (2008d); Rat, F344; oral―gavage; male (30/group): 0, 300, or 1,000 mg/kg-d; daily for 23 wk following a 4-wk tumor initiation by DMBDD^a^ | Male
Hagiwara et al. (2011); JPEC (2008d); Rat, F344; oral―gavage; male (30/group): 0, 300, or 1,000 mg/kg-d; daily for 23 wk following a 4-wk tumor initiation by DMBDD^a^ | Dose (mg/kg-d) | Response (incidence)
Hagiwara et al. (2011); JPEC (2008d); Rat, F344; oral―gavage; male (30/group): 0, 300, or 1,000 mg/kg-d; daily for 23 wk following a 4-wk tumor initiation by DMBDD^a^ | 0 | 25/30
Hagiwara et al. (2011); JPEC (2008d); Rat, F344; oral―gavage; male (30/group): 0, 300, or 1,000 mg/kg-d; daily for 23 wk following a 4-wk tumor initiation by DMBDD^a^ | 300 | 21/30
Hagiwara et al. (2011); JPEC (2008d); Rat, F344; oral―gavage; male (30/group): 0, 300, or 1,000 mg/kg-d; daily for 23 wk following a 4-wk tumor initiation by DMBDD^a^ | 1,000 | 28/30^b^
Hagiwara et al. (2011); JPEC (2008d); Rat, F344; oral―gavage; male (30/group): 0, 300, or 1,000 mg/kg-d; daily for 23 wk following a 4-wk tumor initiation by DMBDD^a^ | 0^c^ | 0/12
Hagiwara et al. (2011); JPEC (2008d); Rat, F344; oral―gavage; male (30/group): 0, 300, or 1,000 mg/kg-d; daily for 23 wk following a 4-wk tumor initiation by DMBDD^a^ | 1,000^c^ | 0/12
Forestomach papillomas or hyperplasia
Hagiwara et al. (2011); JPEC (2008d); Rat, F344; oral―gavage; male (30/group): 0, 300, or 1,000 mg/kg-d; daily for 23 wk following a 4-wk tumor initiation by DMBDD^a^ | Male
Hagiwara et al. (2011); JPEC (2008d); Rat, F344; oral―gavage; male (30/group): 0, 300, or 1,000 mg/kg-d; daily for 23 wk following a 4-wk tumor initiation by DMBDD^a^ | Dose (mg/kg-d) | Response (incidence)
Hagiwara et al. (2011); JPEC (2008d); Rat, F344; oral―gavage; male (30/group): 0, 300, or 1,000 mg/kg-d; daily for 23 wk following a 4-wk tumor initiation by DMBDD^a^ | 0 | 0/30
Hagiwara et al. (2011); JPEC (2008d); Rat, F344; oral―gavage; male (30/group): 0, 300, or 1,000 mg/kg-d; daily for 23 wk following a 4-wk tumor initiation by DMBDD^a^ | 300 | 6/30^b^
Hagiwara et al. (2011); JPEC (2008d); Rat, F344; oral―gavage; male (30/group): 0, 300, or 1,000 mg/kg-d; daily for 23 wk following a 4-wk tumor initiation by DMBDD^a^ | 1,000 | 6/30^b^
Hagiwara et al. (2011); JPEC (2008d); Rat, F344; oral―gavage; male (30/group): 0, 300, or 1,000 mg/kg-d; daily for 23 wk following a 4-wk tumor initiation by DMBDD^a^ | 0^c^ | 0/12
Hagiwara et al. (2011); JPEC (2008d); Rat, F344; oral―gavage; male (30/group): 0, 300, or 1,000 mg/kg-d; daily for 23 wk following a 4-wk tumor initiation by DMBDD^a^ | 1,000^c^ | 0/12
Thyroid gland adenoma or carcinoma
Hagiwara et al. (2011); JPEC (2008d); Rat, F344; oral―gavage; male (30/group): 0, 300, or 1,000 mg/kg-d; daily for 23 wk following a 4-wk tumor initiation by DMBDD^a^ | Male
Hagiwara et al. (2011); JPEC (2008d); Rat, F344; oral―gavage; male (30/group): 0, 300, or 1,000 mg/kg-d; daily for 23 wk following a 4-wk tumor initiation by DMBDD^a^ | Dose (mg/kg-d) | Response (incidence)
Hagiwara et al. (2011); JPEC (2008d); Rat, F344; oral―gavage; male (30/group): 0, 300, or 1,000 mg/kg-d; daily for 23 wk following a 4-wk tumor initiation by DMBDD^a^ | 0 | 8/30
Hagiwara et al. (2011); JPEC (2008d); Rat, F344; oral―gavage; male (30/group): 0, 300, or 1,000 mg/kg-d; daily for 23 wk following a 4-wk tumor initiation by DMBDD^a^ | 300 | 17/30^b^
Hagiwara et al. (2011); JPEC (2008d); Rat, F344; oral―gavage; male (30/group): 0, 300, or 1,000 mg/kg-d; daily for 23 wk following a 4-wk tumor initiation by DMBDD^a^ | 1,000 | 20/30^b^
Hagiwara et al. (2011); JPEC (2008d); Rat, F344; oral―gavage; male (30/group): 0, 300, or 1,000 mg/kg-d; daily for 23 wk following a 4-wk tumor initiation by DMBDD^a^ | 0^c^ | 0/12
Hagiwara et al. (2011); JPEC (2008d); Rat, F344; oral―gavage; male (30/group): 0, 300, or 1,000 mg/kg-d; daily for 23 wk following a 4-wk tumor initiation by DMBDD^a^ | 1,000^c^ | 0/12
Urinary bladder carcinoma
Hagiwara et al. (2013); Rat, F344/DuCrlCrlj; oral―water; male (30/group): 0, 100, 300, 500, or 1,000 mg/kg-d; daily for 31 wk beginning 1 wk after a 4-wk exposure to BBN | Male
Hagiwara et al. (2013); Rat, F344/DuCrlCrlj; oral―water; male (30/group): 0, 100, 300, 500, or 1,000 mg/kg-d; daily for 31 wk beginning 1 wk after a 4-wk exposure to BBN | Dose (mg/kg-d) | Response (incidence)
Hagiwara et al. (2013); Rat, F344/DuCrlCrlj; oral―water; male (30/group): 0, 100, 300, 500, or 1,000 mg/kg-d; daily for 31 wk beginning 1 wk after a 4-wk exposure to BBN | 0 | 5/30
Hagiwara et al. (2013); Rat, F344/DuCrlCrlj; oral―water; male (30/group): 0, 100, 300, 500, or 1,000 mg/kg-d; daily for 31 wk beginning 1 wk after a 4-wk exposure to BBN | 100 | 7/30
Hagiwara et al. (2013); Rat, F344/DuCrlCrlj; oral―water; male (30/group): 0, 100, 300, 500, or 1,000 mg/kg-d; daily for 31 wk beginning 1 wk after a 4-wk exposure to BBN | 300 | 6/30
Hagiwara et al. (2013); Rat, F344/DuCrlCrlj; oral―water; male (30/group): 0, 100, 300, 500, or 1,000 mg/kg-d; daily for 31 wk beginning 1 wk after a 4-wk exposure to BBN | 500 | 14/30^b^
Hagiwara et al. (2013); Rat, F344/DuCrlCrlj; oral―water; male (30/group): 0, 100, 300, 500, or 1,000 mg/kg-d; daily for 31 wk beginning 1 wk after a 4-wk exposure to BBN | 1,000 | 9/26
Urinary bladder papilloma
Hagiwara et al. (2013); Rat, F344/DuCrlCrlj; oral―water; male (30/group): 0, 100, 300, 500, or 1,000 mg/kg-d; daily for 31 wk beginning 1 wk after a 4-wk exposure to N-butyl-N-(4-hydroxybutyl) (BBN) | Male
Hagiwara et al. (2013); Rat, F344/DuCrlCrlj; oral―water; male (30/group): 0, 100, 300, 500, or 1,000 mg/kg-d; daily for 31 wk beginning 1 wk after a 4-wk exposure to N-butyl-N-(4-hydroxybutyl) (BBN) | Dose (mg/kg-d) | Response (incidence)
Hagiwara et al. (2013); Rat, F344/DuCrlCrlj; oral―water; male (30/group): 0, 100, 300, 500, or 1,000 mg/kg-d; daily for 31 wk beginning 1 wk after a 4-wk exposure to N-butyl-N-(4-hydroxybutyl) (BBN) | 0 | 21/30
Hagiwara et al. (2013); Rat, F344/DuCrlCrlj; oral―water; male (30/group): 0, 100, 300, 500, or 1,000 mg/kg-d; daily for 31 wk beginning 1 wk after a 4-wk exposure to N-butyl-N-(4-hydroxybutyl) (BBN) | 100 | 13/30
Hagiwara et al. (2013); Rat, F344/DuCrlCrlj; oral―water; male (30/group): 0, 100, 300, 500, or 1,000 mg/kg-d; daily for 31 wk beginning 1 wk after a 4-wk exposure to N-butyl-N-(4-hydroxybutyl) (BBN) | 300 | 17/30
Hagiwara et al. (2013); Rat, F344/DuCrlCrlj; oral―water; male (30/group): 0, 100, 300, 500, or 1,000 mg/kg-d; daily for 31 wk beginning 1 wk after a 4-wk exposure to N-butyl-N-(4-hydroxybutyl) (BBN) | 500 | 17/30
Hagiwara et al. (2013); Rat, F344/DuCrlCrlj; oral―water; male (30/group): 0, 100, 300, 500, or 1,000 mg/kg-d; daily for 31 wk beginning 1 wk after a 4-wk exposure to N-butyl-N-(4-hydroxybutyl) (BBN) | 1,000 | 21/26
Urinary bladder papilloma or carcinoma
Hagiwara et al. (2013); Rat, F344/DuCrlCrlj; oral―water; male (30/group): 0, 100, 300, 500, or 1,000 mg/kg-d; daily for 31 wk beginning 1 wk after a 4-wk exposure to N-butyl-N-(4-hydroxybutyl) (BBN) | Male
Hagiwara et al. (2013); Rat, F344/DuCrlCrlj; oral―water; male (30/group): 0, 100, 300, 500, or 1,000 mg/kg-d; daily for 31 wk beginning 1 wk after a 4-wk exposure to N-butyl-N-(4-hydroxybutyl) (BBN) | Dose (mg/kg-d) | Response (incidence)
Hagiwara et al. (2013); Rat, F344/DuCrlCrlj; oral―water; male (30/group): 0, 100, 300, 500, or 1,000 mg/kg-d; daily for 31 wk beginning 1 wk after a 4-wk exposure to N-butyl-N-(4-hydroxybutyl) (BBN) | 0 | 24/30
Hagiwara et al. (2013); Rat, F344/DuCrlCrlj; oral―water; male (30/group): 0, 100, 300, 500, or 1,000 mg/kg-d; daily for 31 wk beginning 1 wk after a 4-wk exposure to N-butyl-N-(4-hydroxybutyl) (BBN) | 100 | 18/30
Hagiwara et al. (2013); Rat, F344/DuCrlCrlj; oral―water; male (30/group): 0, 100, 300, 500, or 1,000 mg/kg-d; daily for 31 wk beginning 1 wk after a 4-wk exposure to N-butyl-N-(4-hydroxybutyl) (BBN) | 300 | 20/30
Hagiwara et al. (2013); Rat, F344/DuCrlCrlj; oral―water; male (30/group): 0, 100, 300, 500, or 1,000 mg/kg-d; daily for 31 wk beginning 1 wk after a 4-wk exposure to N-butyl-N-(4-hydroxybutyl) (BBN) | 500 | 25/30
Hagiwara et al. (2013); Rat, F344/DuCrlCrlj; oral―water; male (30/group): 0, 100, 300, 500, or 1,000 mg/kg-d; daily for 31 wk beginning 1 wk after a 4-wk exposure to N-butyl-N-(4-hydroxybutyl) (BBN) | 1,000 | 21/26
Urinary bladder papillomatosis
Hagiwara et al. (2011); JPEC (2008d); Rat, F344; oral―gavage; male (12/group): 0 or 1,000 mg/kg-d; daily for 23 wk following a 4-wk tumor initiation by DMBDD^a^ | Male
Hagiwara et al. (2011); JPEC (2008d); Rat, F344; oral―gavage; male (12/group): 0 or 1,000 mg/kg-d; daily for 23 wk following a 4-wk tumor initiation by DMBDD^a^ | Dose (mg/kg-d) | Response (incidence)
Hagiwara et al. (2011); JPEC (2008d); Rat, F344; oral―gavage; male (12/group): 0 or 1,000 mg/kg-d; daily for 23 wk following a 4-wk tumor initiation by DMBDD^a^ | 0 | 0/30
Hagiwara et al. (2011); JPEC (2008d); Rat, F344; oral―gavage; male (12/group): 0 or 1,000 mg/kg-d; daily for 23 wk following a 4-wk tumor initiation by DMBDD^a^ | 300 | 0/30
Hagiwara et al. (2011); JPEC (2008d); Rat, F344; oral―gavage; male (12/group): 0 or 1,000 mg/kg-d; daily for 23 wk following a 4-wk tumor initiation by DMBDD^a^ | 1,000 | 10/30^b^
Hagiwara et al. (2011); JPEC (2008d); Rat, F344; oral―gavage; male (12/group): 0 or 1,000 mg/kg-d; daily for 23 wk following a 4-wk tumor initiation by DMBDD^a^ | 0^c^ | 0/12
Hagiwara et al. (2011); JPEC (2008d); Rat, F344; oral―gavage; male (12/group): 0 or 1,000 mg/kg-d; daily for 23 wk following a 4-wk tumor initiation by DMBDD^a^ | 1,000^c^ | 2/12

a Diethylnitrosamine (DEN), N-butyl-N-(4-hydroxybutyl)nitrosamine (BBN), N-methyl-N-nitrosourea (MNU), 1,2-dimethylhydrazine dihydrochloride (DMH), and N-bis(2-hydroxypropyl)nitrosamine (DHPN).

b Statistically significant (p < 0.05) based on analysis of data conducted by the study authors.

c No DMBDD initiation.

Figure 1-16 Exposure-response array of carcinogenic effects following oral exposure to ETBE

Figure 1-17 Exposure-response array of carcinogenic effects following inhalation exposure to ETBE

### 1.2.6 Other Toxicological Effects

The evidence base for other effects includes 11 rodent studies, some of which reported decreased body weight, increased adrenal weights, altered spleen weights, and increased mortality (see Supplemental Information, Appendix B). The available subchronic or chronic studies used inhalation, gavage, or drinking water routes of exposure for 90 days or more. Shorter duration, multiple-exposure studies that examined immunological endpoints were also included. The design, conduct, and reporting of each study were reviewed, and each study was considered adequate.

At this time, the available evidence is considered inadequate to draw conclusions regarding these other toxic effects following ETBE exposure. For more information, see Appendix B.

## 1.3 INTEGRATION AND EVALUATION

### 1.3.1 Effects Other Than Cancer

Kidney effects were identified as a potential human hazard of ETBE exposure based on several affected endpoints in male and female rats, including kidney-weight increases, urothelial hyperplasia (in male rats only), and—to a lesser extent—exacerbated severity of CPN and increases in serum markers of kidney function, such as cholesterol, BUN, and creatinine. These effects are similar to the kidney effects observed with the ETBE metabolite tert-butanol (e.g., CPN and transitional epithelial hyperplasia) and a related compound, MTBE [e.g., CPN and mineralization; ATSDR (1996)]. Changes in kidney parameters were consistently observed, but the magnitude of change was generally moderate, although males had greater severity of effects than females. While the ETBE metabolite tert-butanol meets the criteria for alpha 2u-globulin nephropathy (https://cfpub.epa.gov/ncea/iris_drafts/recordisplay.cfm?deid=262086), ETBE, in contrast, binds to alpha 2u-globulin and meets some but not all the criteria in the EPA and IARC alpha 2u-globulin frameworks (Capen et al., 1999; U.S. EPA, 1991a); see Section 1.2.1. U.S. EPA (1991a) noted that “[i]f a compound induces α2u-globulin accumulation in hyaline droplets, the associated nephropathy in male rats is not an appropriate endpoint to determine noncancer (systemic) effects potentially occurring in humans” (Section XVIII, page 89). However, because alpha 2u-globulin nephropathy is strictly a male rat phenomenon, dose-related kidney effects in female rats are not confounded by alpha 2u-globulin nephropathy.

It has been observed that chemicals that bind to alpha 2u-globulin also exacerbate the incidence and/or severity of background CPN in male rats (Frazier et al., 2012; Travlos et al., 2011; U.S. EPA, 1991a). CPN has no known analogue in the aging human kidney (NIEHS, 2019; Hard et al., 2009) and its etiology is unknown (NIEHS, 2019; Frazier et al., 2012; Hard and Khan, 2004; Peter et al., 1986). However, many of the same lesions observed in CPN (e.g., thickening of tubule basement membranes, tubule atrophy, tubule dilation, and glomerular sclerosis) are also observed in chronic kidney disease in humans (Lusco et al., 2016; Zoja et al., 2015; Frazier et al., 2012; Abrass, 2000). Because the mode of action is unknown, it cannot be ruled out that a chemical that exacerbates CPN in rats could also exacerbate existing disease processes in the human kidney (NIEHS, 2019). Therefore, increased incidence of kidney effects with ETBE exposure, particularly in the female rat (including increased kidney weight and increased severity of CPN), are considered relevant to humans and were carried forward for dose-response analysis. Kidney effects in male rats were also modeled and presented for comparison.

Evidence is suggestive that liver effects are associated with ETBE exposure. Increased liver weight in male and female rats was consistently observed across studies. Centrilobular hypertrophy was observed at the same concentrations that induced liver-weight changes in rats of both sexes after 13-week inhalation and 26-week oral exposures. No other histopathological findings were observed, and only one serum marker of liver toxicity (GGT) was elevated, although other markers (AST, ALT, and ALP) were not. The magnitude of change for these noncancer liver effects was considered modest and, except for organ-weight data, did not exhibit consistent dose-response relationships. Mechanistic data suggest ETBE exposure leads to activation of several nuclear receptors, but evidence that nuclear receptor-mediated pathways contribute to the tumorigenesis observed in ETBE-treated males is inadequate; thus, these data remain relevant for human noncancer hazard identification. Because of the lack of data supporting the adversity of the liver-weight increases with ETBE exposure (e.g., alterations in histology or clinical chemistry), liver effects were not considered further for dose-response analysis and the derivation of reference values.

At this time, there is inadequate information to draw conclusions regarding male reproductive, female reproductive, developmental, or other toxic effects as human hazards of ETBE exposure. While the ETBE database includes developmental, reproductive and multigenerational studies, which are generally null and do not appear to indicate an area of concern (see hazard discussions in Sections 1.2.3 and 1.2.4), this body of evidence is not sufficiently robust to conclude that ETBE is not likely to be a reproductive or developmental hazard.

### 1.3.2 Carcinogenicity

#### Summary of Evidence

In F344 rats, administration of ETBE via inhalation increased hepatocellular adenomas in males in an exposure-dependent manner, as indicated by a significant positive trend (p < 0.001 with Peto’s test). Hepatocellular tumors were not increased in female rats (Saito et al., 2013). A significantly increased incidence of hepatocellular adenomas or carcinomas (only one carcinoma observed) was observed at the highest dose tested in males, and three hepatocellular adenomas were observed at the two lower concentrations. Significant increases in preneoplastic foci (basophilic and eosinophilic foci) were also observed in male rats (Saito et al., 2013). Following 2-year gavage or drinking water exposure, the incidence of liver tumors was not increased in S-D or F344 rats of either sex (Suzuki et al., 2012; Maltoni et al., 1999), although an apparent, but statistically nonsignificant increase in preneoplastic foci (basophilic) was observed in F344 male rats (Suzuki et al., 2012). Regarding the 2-year gavage study by Maltoni et al. (1999), depressed survival (25−28% of male and female control rats survived to Week 104) may have confounded the ability to detect carcinogenicity.

Saito et al. (2013) compared the doses achieved in the 2-year drinking water bioassay with those for the 2-year inhalation bioassay (Suzuki et al., 2012; JPEC, 2010a) and calculated the highest intake in male rats to be 542 mg/kg-day as compared to the highest inhalation intake estimate of 3,015 mg/kg-day (after adjusting for 6 hours/day, 5 days a week exposure, minute volume of 561 mL/min, and 100% ETBE absorption). However, the ranges of the internal dose metrics of ETBE expressed as either metabolized ETBE or metabolized tert-butanol (one of the two primary breakdown products of ETBE) as computed by toxicokinetic modeling were similar for the oral and inhalation exposures of ETBE and the oral exposure of tert-butanol in these three studies (see the range of the internal dose variables in Figure B-3 of the Supplemental Information). Nonetheless, the incidence of liver tumors was not consistently correlated with any internal dose measure, and the lack of a consistent dose-response relationship using any of these internal metrics suggests that differences in liver tumor responses between oral and inhalation exposures are not likely due to pharmacokinetic factors alone, and additional factors besides internal dose are necessary to explain the induction of liver tumors. Statistically significant increases in liver tumor incidence were observed in the livers of male F344 and Wistar rats in supplemental initiation-promotion studies after 19−23 weeks of ETBE exposure via gavage, but only following an initial 2−4 week mutagen exposure (Hagiwara et al., 2015; Hagiwara et al., 2011) which also produced increases in colon, thyroid, forestomach, and urinary bladder tumorigenesis in male F344 rats (Hagiwara et al., 2013; Hagiwara et al., 2011). No studies have evaluated chronic ETBE exposure in mice via any route.

The cancer guidelines (U.S. EPA, 2005a) emphasize that knowledge of the biochemical and biological changes preceding tumor development could inform whether a cancer hazard exists and might help in understanding events relevant to potential mode of carcinogenic action. However, as discussed in Section 1.2.2, an MOA for liver carcinogenesis could not be established, and in the absence of information to indicate otherwise (U.S. EPA, 2005b), the liver tumors induced by ETBE following inhalation exposure are considered relevant to human hazard identification.

The cancer guidelines indicate that information on metabolites can help inform the weight of evidence for carcinogenicity. ETBE is primarily metabolized into acetaldehyde and tert-butanol. Regarding the ETBE metabolite tert-butanol, drinking water exposure in F344 rats did not cause an increase in liver tumors, but resulted in renal tubule tumors, mostly adenomas, in males; drinking water exposure also increased the incidence of thyroid follicular cell adenomas in female B6C3F_1_ mice and adenomas or carcinomas in males (NTP, 1995). Regarding the ETBE metabolite acetaldehyde, (IARC, 1999b) has concluded that inhalation exposure causes carcinomas of the nasal mucosa in rats and carcinomas of the larynx in hamsters. IARC classifies acetaldehyde as possibly carcinogenic to humans (Group 2B) based on sufficient evidence in experimental animals. Acetaldehyde produced in the liver as a result of ethanol ingestion and metabolism has been suggested to be a contributor to liver toxicity and cancer (Setshedi et al., 2010). IARC has classified acetaldehyde associated with the consumption of alcoholic beverages to be carcinogenic to humans [Group 1; IARC (1999a)] and has concluded that it is the key alcohol metabolite in causing cancer of the esophagus and aerodigestive tract (IARC, 2010).

##### Integration of evidence

The descriptor suggestive evidence of carcinogenic potential is appropriate when the evidence raises “a concern for potential carcinogenic effects in humans” but is not sufficient for a stronger conclusion; it covers a spectrum of evidence associated with varying levels of concern for carcinogenicity. Such evidence can range from a positive cancer result in the only study on an agent to a single positive cancer result in an extensive database that includes negative studies in other species. The results for ETBE raise a concern for cancer; however, the effects were limited to tumors in one tissue (liver), primarily at the high dose, by one route of exposure (inhalation) in male rats (females were negative and no ETBE bioassays are available in mice).

Regarding the animal database for carcinogenicity, EPA considers chronic bioassays as key evidence (i.e., the three chronic cancer bioassays, one inhalation and two oral), and other types of studies, including initiation promotion studies, as supplemental lines of information which can aid in the interpretation of more standard toxicological evidence, especially regarding potential modes of action (U.S. EPA, 2005a). Across three initiation-promotion studies, orally administered ETBE enhanced tumorigenesis in multiple tissues in male rats preexposed to mutagens, including kidney, liver, forestomach, thyroid, colon, and urinary bladder. Furthermore, no MOA has been identified for ETBE that could explain the potentiation of mutagen-induced carcinogenesis in the forestomach, thyroid, colon, and urinary bladder. This suggests that the available database is insufficient to determine the molecular mechanisms of ETBE carcinogenesis. The available evidence suggests that populations exposed to mutagenic agents prior to, or concomitant with, oral ETBE exposure might be more susceptible to chemically induced carcinogenesis than predicted by the results of ETBE 2-year rodent oral bioassays alone.

The carcinogenicity of ETBE appears to be route dependent, therefore multiple cancer descriptors are used in accordance with the cancer guidelines (U.S. EPA, 2005a). The evidence of carcinogenic potential for ETBE is determined to be suggestive for exposure via the inhalation route and inadequate for exposure via the oral route. This weight-of-evidence descriptor is based primarily on a positive carcinogenic response following inhalation exposure in the liver in a single animal study, along with significant increases in preneoplastic liver lesions and mechanistic data (i.e., the metabolism of ETBE to the genotoxic compound acetaldehyde in the liver) and no increased liver tumors detected in two chronic oral studies in S-D or F344 rats (Suzuki et al., 2012; JPEC, 2010a; Maltoni et al., 1999).

##### Biological considerations for dose-response analysis

This section addresses the cancer hazards to bring forward to Section 2 for dose-response analysis. The observed liver tumors in male rats following inhalation exposure are deemed relevant for estimating human cancer hazard. The Saito et al. (2013) inhalation study observed a positive exposure-response trend in the incidence of hepatocellular tumors in male rats (although the majority of tumors were observed at the highest dose). This study was considered suitable for dose-response analysis, because it is part of a well-designed GLP study that evaluated multiple dose levels (JPEC, 2010b). The study included histological examinations for tumors in many different tissues, contained three exposure levels and controls, contained adequate numbers of animals per dose group (~50/sex/group), treated animals for up to 2 years, and included detailed reporting of methods and results. Although decreased body-weight gain and survival were noted in the high-dose males and females, the study authors did not detect changes to the animals’ general condition (e.g., abnormal behavior or clinical signs) associated with ETBE. Similar decreases in body weight were observed in male (75% of control) and female animals (78% of control), although significantly increased liver tumors were only observed in male rats. Some concern exists that decreased survival in ETBE treated dose groups (primarily from CPN in the male rats) could bias the cancer findings toward the null. This study was deemed appropriate for dose-response as there is no clear indication that overt toxicity or altered toxicokinetics (as discussed in the Cancer Guidelines) are responsible for the significantly increased incidence of liver tumors in male rats.

The results from MOA analysis can potentially inform dose-response analysis and extrapolation approaches (U.S. EPA, 2005a), but no clear MOA was identified for ETBE. As discussed above, the evidence was inadequate to determine the role of nuclear receptor activation in liver carcinogenesis, due in part to a lack of coherence between nuclear receptor activation and proliferation or apoptosis, which are key events in these pathways. Evidence also was inadequate to conclude that ETBE induces liver tumors via acetaldehyde-mediated mutagenic MOA, due in part to a paucity of evidence specifically evaluating intermediate key events following ETBE exposure in rats. No other systemic cancer MOAs were identified. In the absence of MOA information to indicate otherwise, dose-response analysis should use linear extrapolation (U.S. EPA, 2005a).

### 1.3.3 Susceptible Populations and Lifestages for Cancer and Noncancer Outcomes

Genetic polymorphisms of ALDH2, the enzyme that oxidizes acetaldehyde to acetic acid, might affect potential ETBE liver toxicity. The virtually inactive form, ALDH2*2, is responsible for alcohol intolerance and is found in about one-half of East Asian populations (Brennan, 2002). This variant is associated with slow metabolism of acetaldehyde and, hence, extended exposure to a genotoxic compound. Other studies also have linked ALDH2 polymorphisms to hepatocellular cancers in humans (Eriksson, 2015). With respect to ETBE exposure, the ALDH2*2 variant should increase any type of risk associated with acetaldehyde produced by ETBE metabolism because it will prolong internal exposure to this metabolite. As demonstrated in several in vivo and in vitro genotoxic assays in Aldh2 KO mice or cells, genotoxicity was significantly increased compared with wild type controls following ETBE exposure to similar doses where both cancer and noncancer effects were observed following chronic rodent exposure bioassays (Weng et al., 2019; Weng et al., 2014; Weng et al., 2013; Weng et al., 2012; Weng et al., 2011). Studies in Aldh2 KO mice observed elevated blood concentrations of acetaldehyde following ETBE exposure compared with wild-type mice (Weng et al., 2013), increased alterations to sperm and male reproductive tissue (Weng et al., 2014), and increased incidence of centrilobular hypertrophy (Weng et al., 2013; Weng et al., 2012). Similar effects on genotoxicity and liver histopathology have also been observed in Aldh2 heterozygous animals (Weng et al., 2019). Notably, a consistent finding in these studies was increased severity of genotoxicity in males compared with females, which corresponds with increased incidence of hepatic tumors only in male rats (Saito et al., 2013; JPEC, 2010b).

No MOA information exists to account for the sex discrepancies in genotoxic effects. Finally, IARC (1999a) and IARC (2012) identified acetaldehyde produced as a result of ethanol metabolism as contributing to human carcinogenesis in the upper aerodigestive tract and esophagus following ethanol ingestion, with effects amplified by slower acetaldehyde metabolism. Altogether, these data present plausible evidence that diminished ALDH2 activity yields health effect outcomes that are more severe than those organisms with fully functional ALDH2. It is also plausible that individuals with noncoding region variants in aldh2 (which could potentially affect gene expression), as well as individuals with other variants in alcohol metabolism may also be disproportionately affected by ETBE exposure. No other specific potential polymorphic-related susceptibility issues were reported in the literature. CYP2A6 is likely to be the P450 isoenzyme in humans to cleave the ether bond in ETBE. It also exists in an array of variants, and at least one variant (2A6*4) clearly has no catalytic activity (Fukami et al., 2004); however, the effect of this variability on ETBE toxicity is unknown. In addition, the data on ETBE-induced mutagenicity are inconclusive.

Regarding lifestages particularly susceptible to ETBE exposure, while certain lifestages (e.g., development) are generally thought to have heightened vulnerability to most chemical exposures, no specific data was identified to support heightened periods of susceptibility to ETBE exposure in the available database of developmental and reproductive studies. Note that the majority of developmental and reproductive studies were performed by the oral route, so differential susceptibility from inhalation exposure cannot be ruled out, but in general, the effects observed from ETBE exposure (except for liver tumors) appeared to be consistent across routes of exposure (e.g., kidney effects, liver hypertrophy).

7 If the chemical meets the criteria for Question One, then a second question is asked: are the renal effects in male rats exposed to this chemical due solely to the alpha 2u-globulin process?