# REFERENCES

Abrass, CK. (2000). The nature of chronic progressive nephropathy in aging rats [Review]. Advances in Renal Replacement Therapy 7: 4–10. 10.1016/S1073-4449(00)70001-X 10672913
Amberg, A; Rosner, E; Dekant, W. (1999). Biotransformation and kinetics of excretion of methyl-tert-butyl ether in rats and humans. Toxicological Sciences 51: 1–8.10496672
Amberg, A; Rosner, E; Dekant, W. (2000). Biotransformation and kinetics of excretion of ethyl tert-butyl ether in rats and humans. Toxicological Sciences 53: 194–201. 10.1093/toxsci/53.2.194 10696767
Andersen, ME. (1991). Physiological modelling of organic compounds. Annals of Occupational Hygiene 35: 309–321. 10.1093/annhyg/35.3.309 1888102
ARCO (ARCO Chemical Company). (1983). Toxicologist’s report on metabolism and pharmacokinetics of radiolabeled TBA 534 tertiary butyl alcohol with cover letter dated 03/24/1994. (8EHQ86940000263). Newton Square, PA.
ATSDR (Agency for Toxic Substances and Disease Registry). (1996). Toxicological profile for methyl-tert-butyl ether [ATSDR Tox Profile]. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service. http://www.atsdr.cdc.gov/ToxProfiles/tp91.pdf
Banton, MI; Peachee, VL; White, KL; Padgett, EL. (2011). Oral subchronic immunotoxicity study of ethyl tertiary butyl ether in the rat. Journal of Immunotoxicology 8: 298–304. 10.3109/1547691X.2011.598480 21827378
Bernauer, U; Amberg, A; Scheutzow, D; Dekant, W. (1998). Biotransformation of 12C- and 2-13C-labeled methyl tert-butyl ether, ethyl tert-butyl ether, and tert-butyl alcohol in rats: Identification of metabolites in urine by 13C nuclear magnetic resonance and gas chromatography/mass spectrometry. Chemical Research in Toxicology 11: 651–658. 10.1021/tx970215v 9625733
Blancato, JN; Evans, MV; Power, FW; Caldwell, JC. (2007). Development and use of PBPK modeling and the impact of metabolism on variability in dose metrics for the risk assessment of methyl tertiary butyl ether (MTBE). Journal of Environmental Protection Science 1: 29–51.
Bond, JA; Medinsky, MA; Wolf, DC; Cattley, R; Farris, G; Wong, B, . (1996). Ethyl tertiary butyl ether (ETBE): ninety-day vapor inhalation toxicity study in CD-1(R) mice. (Final Report No. 95030). Newtown Square, PA: ARCO Chemical Co.
Borghoff, SJ. (1996). Ethyl tertiary-butyl ether: Pilot/methods development pharmacokinetic study in male F-344 rats & male cd-1 mice after single nose-only inhalation exposure, w/cvr ltr dated 7/29/96. (EPA/OTS Doc #86960000579). Chemical Industry Institute of Toxicology (CIIT).
Borghoff, SJ; Asgharian, B. (1996). Ethyl tertiary-butyl ether (ETBE): Pharmacokinetic study in male and female CD-1 mice after single inhalation exposure and male and female F-344 rats after single and repeated inhalation exposure. (CIIT Protocol 95026). La Palma, CA: ARCO Chemical Company.
Borghoff, SJ; Murphy, JE; Medinsky, MA. (1996). Development of a physiologically based pharmacokinetic model for methyl tertiary-butyl ether and tertiary-butanol in male Fischer-344 rats. Toxicological Sciences 30: 264–275. 10.1006/faat.1996.0064
Borghoff, SJ; Parkinson, H; Leavens, TL. (2010). Physiologically based pharmacokinetic rat model for methyl tertiary-butyl ether; comparison of selected dose metrics following various MTBE exposure scenarios used for toxicity and carcinogenicity evaluation. Toxicology 275: 79–91. 10.1016/j.tox.2010.06.003 20561556
Borghoff, SJ; Prescott, JS; Janszen, DB; Wong, BA; Everitt, JI. (2001). alpha2u-Globulin nephropathy, renal cell proliferation, and dosimetry of inhaled tert-butyl alcohol in male and female F-344 rats. Toxicological Sciences 61: 176–186. 10.1093/toxsci/61.1.176 11294988
Borghoff, SJ; Ring, C; Banton, MI; Leavens, TL. (2016). Physiologically based pharmacokinetic model for ethyl tertiary-butyl ether and tertiary-butyl alcohol in rats: Contribution of binding to α2u-globulin in male rats and high-exposure nonlinear kinetics to toxicity and cancer outcomes. Journal of Applied Toxicology 37: 621–640. 10.1002/jat.3412 27885692
Brown, RP; Delp, MD; Lindstedt, SL; Rhomberg, LR; Beliles, RP. (1997). Physiological parameter values for physiologically based pharmacokinetic models. Toxicology and Industrial Health 13: 407–484. 10.1177/074823379701300401 9249929
Capen, CC; Dybing, E; Rice, JM; Wilbourn, JD. (1999). Species differences in thyroid, kidney and urinary bladder carcinogenesis. In CC Capen; E Dybing; JM Rice; JD Wilbourn (Eds.), (pp. 1–225). Lyon, France: International Agency for Research on Cancer.
Carruthers, L; Reeves, K; Paul, M; Searle, A; Templeton, W; Paine, AJ. (1987). The role of “alpha”2u globulin synthesis in the production of renal hyaline droplets by iso-octane. Biochemical Pharmacology 36: 2577–2580.2440446
Cederbaum, AI; Cohen, G. (1980). Oxidative demethylation of t-butyl alcohol by rat liver microsomes. Biochemical and Biophysical Research Communications 97: 730–736. 10.1016/0006-291X(80)90325-3 7470124
Charbonneau, M; Lock, EA; Strasser, J; Cox, MG; Turner, MJ; Bus, JS. (1987). 2,2,4-trimethylpentane-induced nephrotoxicity: I metabolic disposition of TMP in male and female Fischer 344 rats. Toxicology and Applied Pharmacology 91: 171–181.2445050
Dekant, W; Bernauer, U; Rosner, E; Amberg, A. (2001). Toxicokinetics of ethers used as fuel oxygenates [Review]. Toxicology Letters 124: 37–45. 10.1016/s0378-4274(00)00284-8 11684356
Drogos, DL; Diaz, AF. (2001). Appendix A: Physical properties of fuel oxgenates and addititves. In Oxygenates in Gasoline. Washington, DC: American Chemical Society. 10.1021/bk-2002-0799.ch018
Elmore, SA. (2006). Enhanced histopathology of the spleen [Review]. Toxicologic Pathology 34: 648–655. 10.1080/01926230600865523 17067950
Frazier, KS; Seely, JC; Hard, GC; Betton, G; Burnett, R; Nakatsuji, S, . (2012). Proliferative and nonproliferative lesions of the rat and mouse urinary system. Toxicologic Pathology 40: 14S–86S. 10.1177/0192623312438736 22637735
Fujii, S; Yabe, K; Furukawa, M; Matsuura, M; Aoyama, H. (2010). A one-generation reproductive toxicity study of ethyl tertiary butyl ether in rats. Reproductive Toxicology 30: 414–421. 10.1016/j.reprotox.2010.04.013 20438832
Gaoua, W. (2004a). Ethyl tertiary butyl ether (ETBE): Prenatal developmental toxicity study by the oral route (gavage) in rats (pp. 1–280). (CIT Study No. 24860 RSR). unpublished study for Totalfinaelf on behalf of the ETBE Producers’ Consortium.
Gaoua, W. (2004b). Ethyl tertiary butyl ether (ETBE): Two-generation study (reproduction and fertility effects) by the oral route (gavage) in rats. (CIT Study No. 24859 RSR). unpublished study for Totalfinaelf on behalf of the ETBE Producers’ Consortium.
Hagiwara, A; Doi, Y; Imai, N; Nakashima, H; Ono, T; Kawabe, M, . (2011). Medium-term multi-organ carcinogenesis bioassay of ethyl tertiary-butyl ether in rats. Toxicology 289: 160–166. 10.1016/j.tox.2011.08.007 21864636
Hard, GC; Johnson, KJ; Cohen, SM. (2009). A comparison of rat chronic progressive nephropathy with human renal disease-implications for human risk assessment [Review]. Critical Reviews in Toxicology 39: 332–346. 10.1080/10408440802368642 19514917
Hard, GC; Khan, KN. (2004). Invited review: A contemporary overview of chronic progressive nephropathy in the laboratory rat, and its significance for human risk assessment [Review]. Toxicologic Pathology 32: 171–180. 10.1080/01926230490422574 15200155
Hong, JY; Wang, YY; Bondoc, FY; Lee, M; Yang, CS; Hu, WY, . (1999a). Metabolism of methyl tert-butyl ether and other gasoline ethers by human liver microsomes and heterologously expressed human cytochromes P450: Identification of CYP2A6 as a major catalyst. Toxicology and Applied Pharmacology 160: 43–48. 10.1006/taap.1999.8750 10502501
Hong, JY; Wang, YY; Bondoc, FY; Yang, CS; Gonzalez, FJ; Pan, Z, . (1999b). Metabolism of methyl tert-butyl ether and other gasoline ethers in mouse liver microsomes lacking cytochrome P450 2E1. Toxicology Letters 105: 83–88. 10.1016/s0378-4274(98)00389-0 10092060
Hong, JY; Wang, YY; Bondoc, FY; Yang, CS; Lee, M; Huang, WQ. (1997a). Rat olfactory mucosa displays a high activity in metabolizing methyl tert-butyl ether and other gasoline ethers. Toxicological Sciences 40: 205–210. 10.1093/toxsci/40.2.205
Hong, JY; Yang, CS; Lee, M; Wang, YY; Huang, WQ; Tan, Y, . (1997b). Role of cytochromes P450 in the metabolism of methyl tert-butyl ether in human livers. Archives of Toxicology 71: 266–269. 10.1007/s002040050386 9101044
Johanson, G; Nihlén, A; Löf, A. (1995). Toxicokinetics and acute effects of MTBE and ETBE in male volunteers. Toxicology Letters 82/83: 713–718. 10.1016/0378-4274(95)03589-3
JPEC (Japan Petroleum Energy Center). (2007a). Micronucleus test of 2-ethoxy-2-methylpropane (ETBE) using bone marrow in rats administered ETBE by gavage. (Study Number: 7049). Japan: Japan Industrial Safety and Health Association.
JPEC (Japan Petroleum Energy Center). (2007b). Micronucleus test of 2-ethoxy-2-methylpropane (ETBE) using bone marrow in rats administered ETBE intraperitoneally. (Study Number: 7048). Japan: Japan Bioassay Research Center, Japan Industrial Safety and Health Association.
JPEC (Japan Petroleum Energy Center). (2007c). Micronucleus test of ETBE using bone marrow of rats of the 13-week toxicity study of 2-ethoxy-2-methylpropane in F344 rats (drinking water study) [preliminary carcinogenicity study]. (Study Number: 7046). Japan Bioassay Research Center, Japan Industrial Safety and Health Association.
JPEC (Japan Petroleum Energy Center). (2007d). Micronucleus test of ETBE using bone marrow of rats of the “13-week toxicity study of 2-ethoxy-2-methylpropane in F344 rats (inhalation study) [preliminary carcinogenicity study]. (Study Number: 7047). Japan Industrial Safety and Health Association.
JPEC (Japan Petroleum Energy Center). (2008a). A 90-day repeated dose toxicity study of ETBE by whole-body inhalation exposure in rats. (Study Number: B061829). Mitsubishi Chemical Safety Institute Ltd.
JPEC (Japan Petroleum Energy Center). (2008b). A 180-Day repeated dose oral toxicity study of ETBE in rats. (Study Number: D19-0002). Japan: Hita Laboratory, Chemicals Evaluation and Research Institute (CERI).
JPEC (Japan Petroleum Energy Center). (2008c). Medium-term mutli-organ carcinogenesis bioassay of 2-ethoxy-2-methylpropane (ETBE) in rats. (Study Number: 0635). Ichinomiya, Japan: DIMS Institute of Medical Science.
JPEC (Japan Petroleum Energy Center). (2008d). A one-generation reproduction toxicity study of ETBE in rats. (Study Number: SR07060). Safety Research Institute for Chemical Compounds.
JPEC (Japan Petroleum Energy Center). (2008e). Pharmacokinetic study in rats treated with [14c] ETBE repeatedly for 14 days. (P070497). Japan: Kumamoto Laboratory, Mitsubishi Chemical Safety Institute Ltd.
JPEC (Japan Petroleum Energy Center). (2008f). Pharmacokinetic study in rats treated with single dose of [14C] ETBE. (P070496). Japan: Kumamoto Laboratory, Mitsubishi Chemical Safety Institute Ltd.
JPEC (Japan Petroleum Energy Center). (2010a). Carcinogenicity test of 2-Ethoxy-2-methylpropane in rats (Drinking water study). (Study No: 0691). Japan Industrial Safety and Health Association, Japan Bioassay Research Center.
JPEC (Japan Petroleum Energy Center). (2010b). Carcinogenicity test of 2-Ethoxy-2-methylpropane in rats (Inhalation study). (Study No: 0686). Japan: Japan Industrial Safety and Health Association.
Kaneko, T; Wang, PY; Sato, A. (2000). Partition coefficients for gasoline additives and their metabolites. Journal of Occupational Health 42: 86–87. 10.1539/joh.42.86
Kim, D; Andersen, ME; Pleil, JD; Nylander-French, LA; Prah, JD. (2007). Refined PBPK model of aggregate exposure to methyl tertiary-butyl ether. Toxicology Letters 169: 222–235. 10.1016/j.toxlet.2007.01.008 17336003
Le Gal, A; Dreano, Y; Gervaso, PG; Berthou, F. (2001). Human cytochrome P450 2A6 is the major enzyme involved in the metabolism of three alkoxyethers used as oxyfuels [Review]. Toxicology Letters 124: 47–58. 10.1016/s0378-4274(00)00286-1 11684357
Leavens, TL; Borghoff, SJ. (2009). Physiologically based pharmacokinetic model of methyl tertiary butyl ether and tertiary butyl alcohol dosimetry in male rats based on binding to alpha2u-globulin. Toxicological Sciences 109: 321–335. 10.1093/toxsci/kfp049 19270017
Li, Q; Kobayashi, M; Inagaki, H; Hirata, Y; Hirata, K; Shimizu, T, . (2011). Effects of subchronic inhalation exposure to ethyl tertiary butyl ether on splenocytes in mice. International Journal of Immunopathology and Pharmacology 24: 837–847. 10.1177/039463201102400403 22230391
Lusco, MA; Fogo, AB; Najafian, B; Alpers, CE. (2016). AJKD Atlas of Renal Pathology: Tubular Atrophy. American Journal of Kidney Diseases 67: e33–e34. 10.1053/j.ajkd.2016.04.007 27211375
Malarkey, DE; Bucher, JR. (2011). Summary report of the National Toxicology Program and Environmental Protection Agency-sponsored review of pathology materials from selected Ramazzini Institute rodent cancer bioassays [NTP]. Research Triangle Park: National Toxicology Program. http://ntp.niehs.nih.gov/ntp/about_ntp/partnerships/international/summarypwg_report_ri_bioassays.pdf
Maltoni, C; Belpoggi, F; Soffritti, M; Minardi, F. (1999). Comprehensive long-term experimental project of carcinogenicity bioassays on gasoline oxygenated additives: plan and first report of results from the study on ethyl-tertiary-butyl ether (ETBE). European Journal of Oncology 4: 493–508.
Mansouri, K; Grulke, CM; Richard, AM; Judson, RS; Williams, AJ. (2016). An automated curation procedure for addressing chemical errors and inconsistencies in public datasets used in QSAR modelling. SAR and QSAR in Environmental Research 27: 939–965. 10.1080/1062936X.2016.1253611 27885862
McComb, JA; Goldstein, DB. (1979). Quantitative comparison of physical dependence on tertiary butanol and ethanol in mice: Correlation with lipid solubility. Journal of Pharmacology and Experimental Therapeutics 208: 113–117.569697
Medinsky, MA; Kimbell, JS; Morris, JB; Gerde, P; Overton, JH. (1993). Advances in biologically based models for respiratory tract uptake of inhaled volatiles [Review]. Toxicological Sciences 20: 265–272.
Medinsky, MA; Wolf, DC; Cattley, RC; Wong, B; Janszen, DB; Farris, GM, . (1999). Effects of a thirteen-week inhalation exposure to ethyl tertiary butyl ether on Fischer-344 rats and CD-1 mice. Toxicological Sciences 51: 108–118. 10.1093/toxsci/51.1.108 10496682
Miyata, K; Koga, T; Aso, S; Hoshuyama, S; Ajimi, S; Furukawa, K. (2013). A subchronic (180-day) oral toxicity study of ethyl tertiary-butyl ether, a bioethanol, in rats. Drug and Chemical Toxicology. 10.3109/01480545.2013.851690
NIEHS (National Institute of Environmental Health Sciences). (2019). NTP pathology consult for ETBE and tBA. Washington, DC: U.S. Environmental Protection Agency.
Nihlén, A; Johanson, G. (1999). Physiologically based toxicokinetic modeling of inhaled ethyl tertiary-butyl ether in humans. Toxicological Sciences 51: 184–194. 10.1093/toxsci/51.2.184 10543020
Nihlén, A; Löf, A; Johanson, G. (1995). Liquid/air partition coefficients of methyl and ethyl t-butyl ethers, t-amyl methyl ether, and t-butyl alcohol. Journal of Exposure Analysis and Environmental Epidemiology 5: 573–582.8938250
Nihlén, A; Löf, A; Johanson, G. (1998). Controlled ethyl tert-butyl ether (ETBE) exposure of male volunteers: I Toxicokenetics. Toxicological Sciences 46: 1–10. 10.1006/toxs.1998.2516 9928663
Noguchi, T; Kamigaito, T; Katagiri, T; Kondou, H; Yamazaki, K; Aiso, S, . (2013). Lack of micronucleus induction activity of ethyl tertiary-butyl ether in the bone marrow of F344 rats by sub-chronic drinking-water treatment, inhalation exposure, or acute intraperitoneal injection. Journal of Toxicological Sciences 38: 913–924. 10.2131/jts.38.913 24213011
NSF International. (2003). t-Butanol: Oral Risk Assessment Document (CAS 75-65-0) (pp. 81). Ann Arbor, MI: National Science Foundation International.
NTP (National Toxicology Program). (1996a). Genetic toxicity evaluation of 2-methyl-2-ethoxypropane (ETBE) (637-92-3) in micronucleus study A70000 in B6C3F1 mice. Research Triangle Park, NC: National Institute of Environmental Health Sciences.
NTP (National Toxicology Program). (1996b). Genetic toxicity evaluation of 2-methyl-2-ethoxypropane (ETBE) (637-92-3) in micronucleus study A87074 in F344 rats. Research Triangle Park, NC: National Institute of Environmental Health Sciences.
Olson, MJ; Garg, BD; Murty, CV; Roy, AK. (1987). Accumulation of alpha 2u-globulin in the renal proximal tubules of male rats exposed to unleaded gasoline. Toxicology and Applied Pharmacology 90: 43–51. 10.1016/0041-008X(87)90304-8 2442852
Peter, CP; Burek, JD; van Zwieten, MJ. (1986). Spontaneous nephropathies in rats. Toxicologic Pathology 14: 91–100.3715332
Poet, TS; Valentine, JL; Borghoff, SJ. (1997). Pharmacokinetics of tertiary butyl alcohol in male and female Fischer 344 rats. Toxicology Letters 92: 179–186. 10.1016/S0378-4274(97)00056-8 9334828
Potts, RO; Guy, RH. (1992). Predicting skin permeability. Pharmaceutical Research 9: 663–669.1608900
Rao, HV; Ginsberg, GL. (1997). A physiologically-based pharmacokinetic model assessment of methyl t-butyl ether in groundwater for a bathing and showering determination. Risk Analysis 17: 583–598. 10.1111/j.1539-6924.1997.tb00899.x 9404048
Saito, A; Sasaki, T; Kasai, T; Katagiri, T; Nishizawa, T; Noguchi, T, . (2013). Hepatotumorigenicity of ethyl tertiary-butyl ether with 2-year inhalation exposure in F344 rats. Archives of Toxicology 87: 905–914. 10.1007/s00204-012-0997-x 23389738
Salazar, KD; Brinkerhoff, CJ; Lee, JS; Chiu, WA. (2015). Development and application of a rat PBPK model to elucidate kidney and liver effects induced by ETBE and tert-butanol. Toxicology and Applied Pharmacology 288: 439–452. 10.1016/j.taap.2015.08.015 26341290
Spiteri, NJ. (1982). Circadian patterning of feeding, drinking and activity during diurnal food access in rats. Physiology & Behavior 28: 139–147. 10.1016/0031-9384(82)90115-9 7200613
Stonard, MD; Phillips, PGN; Foster, JR; Simpson, MG; Lock, EA. (1986). alpha2u-Globulin: Measurement in rat kidney and relationship to hyaline droplets. Clinica Chimica Acta 160: 197–203. 10.1016/0009-8981(86)90142-7
Sun, JD; Beskitt, JL. (1995a). Ethyl tertiary-butyl ether (ETBE): Pharmacokinetics after single and repeated inhalation exposures of mice, with cover letter dated 06/21/95 [TSCA Submission]. (EPA/OTS; Doc #86950000184). Export, PA: Bushy Run Research Center, Union Carbide Corporation under contract to ARCO Chemical Company. https://ntrl.ntis.gov/NTRL/dashboard/searchResults.xhtml?searchQuery=OTS0557696
Sun, JD; Beskitt, JL. (1995b). Ethyl tertiary-butyl ether (ETBE): Pharmacokinetics after single and repeated inhalation exposures of rats [TSCA Submission]. (EPA/OTS; Doc #86950000183). Export, PA: Bushy Run Research Center, Union Carbide Corporation under contract to ARCO Chemical Company. https://ntrl.ntis.gov/NTRL/dashboard/searchResults.xhtml?searchQuery=OTS0557695
Suzuki, M; Yamazaki, K; Kano, H; Aiso, S; Nagano, K; Fukushima, S. (2012). No carcinogenicity of ethyl tertiary-butyl ether by 2-year oral administration in rats. Journal of Toxicological Sciences 37: 1239–1246.23208438
Turini, A; Amato, G; Longo, V; Gervasi, PG. (1998). Oxidation of methyl- and ethyl-tertiary-butyl ethers in rat liver microsomes: role of the cytochrome P450 isoforms. Archives of Toxicology 72: 207–214. 10.1007/s002040050490 9587015
U.S. EPA (U.S. Environmental Protection Agency). (1991). Alpha-2u-globulin: Association with chemically induced renal toxicity and neoplasia in the male rat (pp. 1–136). (EPA/625/3-91/019F). Washington, DC: U.S. Environmental Protection Agency, National Center for Environmental Assessment. https://ntrl.ntis.gov/NTRL/dashboard/searchResults.xhtml?searchQuery=PB92143668
U.S. EPA (U.S. Environmental Protection Agency). (2002). A review of the reference dose and reference concentration processes. (EPA/630/P-02/002F). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. https://www.epa.gov/sites/production/files/2014-12/documents/rfd-final.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2005). Guidelines for carcinogen risk assessment [EPA Report]. (EPA/630/P-03/001B). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. https://www.epa.gov/sites/production/files/2013-09/documents/cancer_guidelines_final_3-25-05.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2012). Benchmark dose technical guidance. (EPA/100/R-12/001). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. https://www.epa.gov/risk/benchmark-dose-technical-guidance
U.S. EPA (U.S. Environmental Protection Agency). (2015). Peer review handbook [EPA Report] (4th ed.). (EPA/100/B-15/001). Washington, DC: U.S. Environmental Protection Agency, Science Policy Council. https://www.epa.gov/osa/peer-review-handbook-4th-edition-2015
U.S. EPA (U.S. Environmental Protection Agency). (2016). Model files for tert-butanol and ETBE.
U.S. EPA (U.S. Environmental Protection Agency). (2017). PK/PBPK model evaluation for the IRIS assessments of ethyl tertiary butyl ether (CASRN 637-92-3) and tert-butyl alcohol (CAS No. 75-65-0) (Draft) [EPA Report]. Washington, DC: U.S. Environmental Protection Agency, Pharmacokinetics Working Group.
US EPA. (1997). Support: Ethyl tertiary butyl ether (ETBE): Ninety-day vapor inhalation toxicity study with neurotoxicity evaluations in Fischer 344 rats [TSCA Submission] (pp. 1–90). (89970000047). Newtown Square, PA: ARCO Chemical Company. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS05585301.xhtml
Vergnes, JS. (1995). Ethyl tertiary butyl ether: In vitro chromosome aberrations assay in Chinese hamster ovary cells. (Project ID 94N1425). Export, PA: Bushy Run Research Center, Union Carbide Corporation under contract to ARCO Chemical Company. https://ntrl.ntis.gov/NTRL/dashboard/searchResults.xhtml?searchQuery=OTS0557635
Vergnes, JS; Kubena, MF. (1995a). Ethyl tertiary butyl ether: Bone marrow micronucleus test in mice. (Project ID 94N1426). Export, PA: Bushy Run Research Center, Union Carbide Corporation under contract to ARCO Chemical Company. https://ntrl.ntis.gov/NTRL/dashboard/searchResults.xhtml?searchQuery=OTS0557636
Vergnes, JS; Kubena, MF. (1995b). Ethyl Tertiary Butyl Ether: Mutagenic Potential in the Cho/hgprt Forward Mutation Assay [TSCA Submission]. (Project ID 94N1424). Export, PA: Bushy Run Research Center, Union Carbide Corporation under contract to ARCO Chemical Company.
Weng, Z; Ohtani, K; Suda, M; Yanagiba, Y; Kawamoto, T; Nakajima, T, . (2014). Assessment of the reproductive toxicity of inhalation exposure to ethyl tertiary butyl ether in male mice with normal, low active and inactive ALDH2. Archives of Toxicology 88: 1007–1021. 10.1007/s00204-014-1192-z 24448831
Weng, Z; Suda, M; Ohtani, K; Mei, N, an; Kawamoto, T; Nakajima, T, . (2013). Subchronic exposure to ethyl tertiary butyl ether resulting in genetic damage in Aldh2 knockout mice. Toxicology 311: 107–114. 10.1016/j.tox.2013.06.005 23810710
Weng, Z; Suda, M; Ohtani, K; Mei, N; Kawamoto, T; Nakajima, T, . (2012). Differential genotoxic effects of subchronic exposure to ethyl tertiary butyl ether in the livers of Aldh2 knockout and wild-type mice. Archives of Toxicology 86: 675–682. 10.1007/s00204-011-0779-x 22102104
Weng, ZQ; Suda, M; Ohtani, K; Mei, N; Kawamoto, T; Nakajima, T, . (2011). Aldh2 Knockout Mice Were More Sensitive to DNA Damage in Leukocytes due to Ethyl Tertiary Butyl Ether Exposure. Industrial Health 49: 396–399. 10.2486/indhealth.MS1188 21372431
WHO (World Health Organization). (2012). Guidance for immunotoxicity risk assessment for chemicals. (Harmonization Project Document No. 10). Geneva, Switzerland. http://www.inchem.org/documents/harmproj/harmproj/harmproj10.pdf
Williams, AJ; Grulke, CM; Edwards, J; McEachran, AD; Mansouri, K; Baker, NC, . (2017). The CompTox Chemistry Dashboard: A community data resource for environmental chemistry. Journal of Cheminformatics 9: 61. 10.1186/s13321-017-0247-6 29185060
Zang, Q; Mansouri, K; Williams, AJ; Judson, RS; Allen, DG; Casey, WM, . (2017). In Silico Prediction of Physicochemical Properties of Environmental Chemicals Using Molecular Fingerprints and Machine Learning. Journal of Chemical Information and Modeling 57: 36–49. 10.1021/acs.jcim.6b00625 28006899
Zeiger, E; Anderson, B; Haworth, S; Lawlor, T; Mortelmans, K. (1992). Salmonella mutagenicity tests: V Results from the testing of 311 chemicals. Environmental and Molecular Mutagenesis 19: 2–141. 10.1002/em.2850190603 1541260
Zhang, YP; Macina, OT; Rosenkranz, HS; Karol, MH; Mattison, DR. (1997). Prediction of the metabolism and toxicological profiles of gasoline oxygenates. Inhalation Toxicology 9: 237–254.
Zoja, C; Abbate, M; Remuzzi, G. (2015). Progression of renal injury toward interstitial inflammation and glomerular sclerosis is dependent on abnormal protein filtration [Review]. Nephrology, Dialysis, Transplantation 30: 706–712. 10.1093/ndt/gfu261