# APPENDIX E SUMMARY OF EXTERNAL PEER-REVIEW COMMENTS AND EPA’S DISPOSITION

The Toxicological Review of ethyl tertiary butyl ether (ETBE), dated June 2017, underwent a formal external peer review in accordance with U.S. Environmental Protection Agency (EPA) guidance on peer review (U.S. EPA, 2015). This peer review was conducted by the Chemical Assessment Advisory Committee (CAAC) augmented for review of the draft Integrated Risk Information System (IRIS) ETBE assessment (SAB-CAAC ETBE panel) of EPA’s Science Advisory Board (SAB). An external peer review workshop was held on August 15−17, 2017. Public teleconferences of the SAB-CAAC ETBE panel were held on July 11, 2017, March 22, 2018, March 27, 2018, and June 6, 2018. The Chartered SAB held a public meeting on September 26, 2018 to conduct a quality review of the draft SAB-CAAC peer review report^4^. The final report of the SAB was released on February 27, 2019.

The SAB-CAAC was tasked with providing feedback in response to charge questions that addressed scientific issues related to the hazard identification and dose-response assessment of ETBE. Key recommendations of the SAB^5^ and EPA’s responses to these recommendations, organized by charge question, follow. Editorial changes and factual corrections offered by SAB were incorporated in the document as appropriate and are not discussed further.

## 1 Literature Search/Study Selection and Evaluation

### Charge Question 1 The section on Literature Search Strategy | Study Selection and Evaluation describes the process for identifying and selecting pertinent studies. Please comment on whether the literature search strategy, study selection considerations, including exclusion criteria, and study evaluation considerations, are appropriate and clearly described. Please identify additional peer-reviewed studies that the assessment should consider

[underlined: Key Recommendation]: The SAB recommended EPA should provide clarification on the rationales for several decisions that impacted how the literature search was conducted. This includes (1) the rationale for the selection of some synonyms of ETBE as key search words and not others; (2) the rationale for imposing limitations on sources in the first stage of the scientific literature search (i.e., PubMed, Web of Science); and (3) the rationale for limiting the search for additional citations to only some of the publications available in peer-reviewed literature and secondary sources, but not others.

[underlined: Response:] The literature search was developed and executed in consultation with information specialists and librarians through EPA’s Health and Environmental Research Online (HERO) database. The process includes developing, testing, and implementing a comprehensive literature search strategy in an iterative and collaborative manner. Responses to the above enumerated SAB concerns follow. (1) The most common synonyms and trade names were used as the keywords in the literature search. This included the preferred IUPAC name of 2-Methoxy-2-methylpropane. (2) PubMed, Web of Science, and Toxline are the core sources that IRIS uses for published studies. Past experience has demonstrated searching of PubMed, Web of Science and Toxline generally provides sufficient coverage for literature pertinent to human health assessments. The TSCATS2 database was included to capture submissions of health and safety data submitted to the EPA either as required or voluntarily under certain sections of TSCA. Based on the attributes of the chemical, along with input from HERO, EPA did not include supplemental databases (e.g., databases for pesticides, U.S. Department of Agriculture -related compounds or inhalation values). (3) To ensure no key studies were missed, a manual search of citations was performed on published reviews and studies identified from public comments, as well as reviews previously conducted by other international and federal agencies. Table LS-2 lists the approach and sources used in the manual searching of citations.

[underlined: Key Recommendation]: The SAB recommended that the EPA address why not all databases were updated through December 2016.

[underlined: Response]: All databases were updated through December 2016 in the external peer review draft assessment; text has been edited to ensure clarity. In addition, a literature update following SAB review was conducted through July 2019. Information on this literature update has been added to the Literature Search Section of the document.

[underlined: Key Recommendation]: The SAB recommended that the EPA address the discrepancy in the number of health effects studies reported in Table LS-1 and in the text.

[underlined: Response]: The number of studies identified has been corrected.

[underlined: Key Recommendation]: The SAB recommended that the EPA clarify why ecological/non-mammalian studies were apparently excluded from any consideration (despite the footnote in Table LS-3).

[underlined: Response]: Regarding the ETBE search strategy, ecological studies and non-mammalian studies were not “excluded” but were instead considered supplemental data. The footnote in Table LS-3 was revised to be more transparent.

## 2 Chemical Properties and Toxicokinetics

### Charge Question 2a Chemical properties. Is the information on chemical properties accurate?

[underlined: Key Recommendation]: The SAB offered several specific recommendations for improvement of the chemical properties table generally focused on increasing confidence and transparency in the values presented. The SAB also recommended the use of a template focusing on the chemical properties most relevant to the chemical and the assessment. Several recommendations focused on a preference for the citation of chemical properties from primary sources, for vetting the data in cases in which more than one value is published, and for presenting rationales for the selected values.

[underlined: Response]: In response to SAB comments, EPA has revised the ETBE chemical properties table (Table 1-1) to present average experimental and predicted chemical properties from high quality databases as curated by EPA’s CompTox Chemicals Dashboard (https://comptox.epa.gov/dashboard). The CompTox Chemicals Dashboard aggregates and presents both experimental and predicted chemical property data, with links to the source and/or model data [for details see Williams et al. (2017)]. The experimental data are sourced from publicly available databases as well PHYSPROP downloadable files (Mansouri et al., 2016). Predicted chemical property data are obtained from EPISuite, OPERA models (Mansouri et al., 2016), NICEATM models (Zang et al., 2017), and the Toxicity Estimation Software Tool (TEST) Models (https://www.epa.gov/chemical-research/toxicity-estimation-software-tool-test).

A key benefit of this aggregation of chemical properties over reporting an individual measurement is a more robust estimate than is possible from an individual study, with each study reporting measurements that are expected to have some degree of error.

### Charge Question 2b Toxicokinetic modeling. Section B.1.5 of Appendix B in the Supplemental Information describes the application and modification of a physiologically-based toxicokinetic model of ETBE in rats (Borghoff et al., 2016). Is use of the model appropriate and clearly described, including assumptions and uncertainties? Are there additional peer-reviewed studies that should be considered for modeling?

[underlined: Key Recommendation]: The SAB recommended that the EPA revise the model code to describe metabolism as a function of the free liver concentration, CVL, and that metabolic parameters (e.g., Km or first order rate constants) be re-estimated. Metabolism based upon total liver concentration, CL, is not scientifically correct.

[underlined: Response:] Model code has been revised to describe metabolism as a function of the free liver concentration and the metabolic parameters have been re-estimated. The revised final code is available on HERO (U.S. EPA, 2016).

[underlined: Key Recommendation]: The SAB recommended that the overall presentation of the PBPK modeling should be cohesive, clear, and transparent, and should provide essential information, assumptions, results, and conclusions. The SAB recommended that the text of the PBPK model evaluation report (U.S. EPA, 2017) be included in the Supplemental Information, in which case it would benefit from adding a conclusions section.

[underlined: Response]: PBPK model evaluation for the IRIS assessments of ETBE and tert-butanol has been added to the Supplemental Information to the Toxicological Review (See Appendix B.1.7).

### Charge Question 2c Choice of dose metric. Is the rate of ETBE metabolism an appropriate choice for the dose metric?

[underlined: Key Recommendation]: The SAB recommended not implementing route extrapolation for the oral cancer dose-response analysis for ETBE. Therefore, there was no need for the Agency to select a dose metric.

[underlined: Response:] Route-to-route extrapolation is not implemented, in accordance with SAB recommendation. Consequently, a dose metric wasn’t warranted. See the response to Charge Question 4d for further details.

## 3 Hazard Identification and Dose–Response Assessment

### Charge Question 3a Noncancer kidney toxicity (Sections 1.2.1, 1.3.1). The draft assessment identifies kidney effects as a potential human hazard of ETBE. EPA evaluated the evidence, including the role of α2u-globulin and chronic progressive nephropathy, in accordance with EPA guidance (U.S. EPA, 1991). Please comment on whether this conclusion is scientifically supported and clearly described

[underlined: Key Recommendation]: The SAB was unable to reach consensus on whether noncancer kidney effects should be considered a hazard relevant to humans based on the presented information in the assessment. The SAB recommended EPA strengthen the justification regarding the decision to consider the observed kidney effects as a hazard relevant to humans.

[underlined: Response:] In response to concerns regarding the human relevance of the observed kidney endpoints following ETBE exposure in rats, further expert consultation was requested from the National Toxicology Program (see Appendix D). With this additional expert consultation, the assessment has been revised to strengthen the justification regarding the human relevance of the observed kidney effects. Briefly, dose-related increases in kidney effects (increased kidney weight, increased severity of chronic progressive nephropathy, CPN) were observed in both male and female rats treated with ETBE. While ETBE binds to alpha 2u-globulin and meets some but not all the criteria in the EPA and International Agency for Research on Cancer (IARC) alpha 2u-globulin frameworks [Capen et al. (1999); U.S. EPA (1991); see Section 1.2.1], U.S. EPA (1991) noted that” [i]f a compound induces α_2u_-globulin accumulation in hyaline droplets, the associated nephropathy in male rats is not an appropriate endpoint to determine noncancer (systemic) effects potentially occurring in humans” (Section XVIII, p. 89). However, as alpha 2u-globulin nephropathy is strictly a male rat phenomenon, dose-related kidney effects in female rats are not confounded by alpha 2u-globulin nephropathy. With respect to CPN, this condition has no known analogue in the aging human kidney (NIEHS, 2019; Hard et al., 2009) and its etiology is unknown (NIEHS, 2019; Frazier et al., 2012; Hard and Khan, 2004; Peter et al., 1986). However, many of the same lesions observed in CPN (e.g., thickening of tubule basement membranes, tubule atrophy, tubule dilation, and glomerular sclerosis) are also observed in chronic kidney disease in humans (Lusco et al., 2016; Zoja et al., 2015; Frazier et al., 2012; Abrass, 2000). As summarized in the NTP pathology consultation, given that there is no definitive pathogenesis for CPN, it cannot be ruled out that a chemical which exacerbates CPN in rats could also exacerbate existing disease processes in the human kidney (NIEHS, 2019). Therefore, increased incidence of kidney effects with ETBE exposure in the female rat (including increased kidney weight and increased severity of CPN) are considered relevant to humans. See revised text in Sections 1.2.1 and 1.3.1 of the Toxicological Review.

[underlined: Key Recommendation]: The SAB acknowledged the role of alpha 2u-globulin in ETBE-induced nephropathy in male rats was thoroughly considered according to the EPA 1991 criteria, however, the SAB recommended also applying the criteria published by IARC in 1999 (Capen et al., 1999).

[underlined: Response:] The U.S. EPA (1991) and IARC criteria (Capen et al., 1999) are very similar with the IARC criteria having specific criteria pertaining to lack of genotoxicity of parent compound/metabolite and male rat specificity for nephropathy and renal tumorigenicity whereas the EPA framework considers these data as supplemental information (see Part 4, XVII B. Additional Information Useful for the Analysis). The assessment was revised in Section 1.2.1 (see Mode of Action Analysis for Kidney Effects) to provide additional discussion of the IARC criteria not explicitly required in the EPA 1991 alpha 2u-globulin framework.

### Charge Question 3b Noncancer toxicity at other sites (Sections 1.2.2, 1.2.3, 1.2.4, 1.2.6, 1.3.1). The draft assessment presents conclusions for noncancer toxicity at other sites that were not used as the basis for deriving noncancer oral reference dose or inhalation reference concentration purposes. Please comment on whether these conclusions are scientifically supported and clearly described. If there are publicly available studies to associate other health outcomes with ETBE exposure, please identify them and outline the rationale for including them in the assessment

- Liver effects: Suggestive evidence
- Developmental toxicity: Inadequate evidence
- Male and female reproductive toxicity: Inadequate evidence

[underlined: Key Recommendation]: The SAB had suggestions for better describing the overall evidence for male reproductive toxicity as “minimal effects at otherwise toxic dose levels,” rather than “inadequate evidence,” since the SAB concludes there is an adequate amount of evidence that shows minimal effects, at least in populations with normal ALDH2 function. The SAB also recommended female reproductive toxicity be characterized as “no effects even at otherwise toxic dose levels,” rather than “inadequate evidence,” since the SAB concludes there is an adequate amount of evidence, which shows minimal effects.

[underlined: Response:] The description of male and female reproductive effects in section 1.2.3 has been revised to be responsive to the SAB’s suggested language. Regarding the overall evidence for male reproductive toxicity, although minimal effects were observed at otherwise toxic dose levels, the available evidence is considered insufficient to identify male reproductive effects as a potential human hazard of ETBE exposure and male reproductive effects are not carried forward as a hazard. While the ALDH2 knock out data suggest a potential sensitive subpopulation for male reproductive effects, this evidence is considered preliminary (see discussion of these findings in Section 1.2.3, and response to Key Recommendation below).

Regarding the overall evidence for female reproductive effects, although minimal effects were observed at otherwise toxic dose levels, the available evidence is considered insufficient to identify female reproductive effects as a potential human hazard of ETBE exposure and therefore, female reproductive effects are not carried forward as a hazard.

[underlined: Key Recommendation]: The SAB recommended that male reproductive effects in genetically susceptible mice be clearly acknowledged in the assessment rather than treated as inconsistent results. The SAB also suggested that an RfC be calculated for the male reproductive effects of ETBE in ALDH2 KO mice, as this may be the most sensitive target for a sensitive subgroup.

[underlined: Response:] Based on the available mechanistic study indicating potentially increased susceptibility for reproductive effects in male mice with impaired acetaldehyde metabolism, text in Sections 1.2.3 and 1.3.3 has been revised to clarify that effects observed in the studies in ALDH2 KO mice may be indicative of increased susceptibility in a small percentage of the US population with inactive ALDH2 variations. However, these findings are considered to be preliminary due to the small sample size (n=5), single species, and the unconvincing magnitude of many of the statistically significant effects, including the observation that the heterozygotes exhibited more robust changes than the knockout mice. Thus, EPA did not calculate an RfC for these effects.

### Charge Question 3c Oral reference dose for noncancer outcomes. Section 2.1 presents an oral reference dose of 5x10^–1^ mg/kg–day, based on urothelial hyperplasia in male rats (Suzuki et al., 2012; JPEC, 2010a). Please comment on whether this value is scientifically supported and its derivation clearly described. If an alternative data set or approach would be more appropriate, please outline how such data might be used or how the approach might be developed

[underlined: Key Recommendation]: The SAB recommended that EPA carefully examine the question of the validity and applicability of the endpoints chosen and analyzed for the oral RfD, including the potential for CPN to serve as the mechanism of the kidney effects.

[underlined: Response:] CPN is not a defined mechanism or a more general MOA, rather it is a group of age-related lesions observed in rats and of unknown etiology. However, many of the lesions observed in CPN are also observed in chronic kidney disease in humans (Lusco et al., 2016; Zoja et al., 2015; Frazier et al., 2012; Abrass, 2000). In response to comments regarding the human relevance of the observed kidney endpoints following ETBE exposure in rats (e.g., related to an alpha 2u-globulin mechanism or exacerbation of CPN), further expert consultation was requested from the National Toxicology Program [(NIEHS, 2019); see also Appendix D]. With this additional expert consultation, EPA evaluated the validity and applicability of the observed kidney effects and revised the assessment to strengthen the discussion regarding the human relevance of the various kidney effects. Furthermore, to avoid the uncertainty and confounding by alpha 2u-globulin-related processes in male rats, the assessment has been revised to rely on data sets for kidney toxicity from female rats. See revised text in Sections 1.2.1, 1.3.1, 2.1.4, and 2.2.8 of the Toxicological Review. See also response to Charge Question 3a.

[underlined: Key Recommendation]: SAB recommended that the tables within this section include units for completeness and interpretability and that EPA consider a more integrated presentation of the current text, tables, and graph so as to facilitate better tracking of information without much page-flipping.

[underlined: Response:] Units have been added to the tables where missing, however, endpoints which display changes as “% change relative to control” are unitless. A more integrated presentation of text, tables, and figures is being implemented in future IRIS assessment templates.

### Charge Question 3d Inhalation reference concentration for noncancer outcomes. Section 2.2 presents an inhalation reference concentration of 9 × 10^0^ mg/m^3^, based on urothelial hyperplasia in male rats (Saito et al., 2013). Please comment on whether this value is scientifically supported and its derivation clearly described. If an alternative data set or approach would be more appropriate, please outline how such data might be used or the approach might be developed

[underlined: Key Recommendation]: SAB recommended that EPA provide statistical analysis to make clear the rationale for including or excluding studies. The SAB elaborated in the body of the final report that “there does not seem to be any reporting of statistical analysis of individual studies (trend tests or pair wise significance tests, and other statistical tests determined to be appropriate), and this omission hampers consideration of the appropriateness of inclusion and use of studies.”

The SAB also recommended the EPA provide statistical analysis to help elucidate differences in response based on sex, further observing that sex differences in response appear more marked for inhalation than for oral exposures. The SAB suggested that an evaluation of possible reasons for this (including mere statistical fluctuation which, if responsible, would suggest averaging endpoint values across sexes) would be informative.

[underlined: Response:] As discussed in the Preamble of this assessment, data analysis is part of the evaluation of study quality of the available literature. Statistical analysis of data (including pairwise tests and trend tests) is predominantly performed and reported by the study authors. Data informative for EPA evaluation of organ/system findings are reported in the evidence tables and data arrays in Section 1 (Hazard Identification) with positive statistical findings highlighted (for example, see Table 1-2, Figures 1-4 and 1-5 for kidney histological effects). When additional data analysis is deemed informative and/or is missing from the publication, further statistical tests will be conducted by EPA and noted in the assessment. For example see “average severity of CPN” from JPEC (2010a, 2010b) denoted in Table 1-2. However, it is important to note that while endpoints with statistically significant findings (especially those with significant dose response trends) inform the selection of endpoints for the derivation of candidate values, the biological significance and coherence of an outcome is more important (U.S. EPA, 2002). Decisions regarding the rationale for endpoint and study inclusion for dose response assessment for ETBE are discussed in detail in Section 1.3.1 and in Section 2.1.1 and 2.2.1 of the Toxicological Review.

Regarding the SAB recommendation for additional statistical analysis to inform averaging kidney endpoints across sex, pooling kidney endpoints across sexes is not considered appropriate due to biological considerations, specifically, the apparent increased susceptibility of male rats to ETBE-induced kidney effects, potentially related to alpha 2u-globulin binding with ETBE in male, but not female rats. Additional consideration of the human relevance of the kidney effects observed in male and female rats has been added to the assessment (see response to Charge Question 3a). Therefore, to avoid the uncertainty and confounding by alpha 2u-globulin-related processes in male rats, the assessment has been revised to rely on data sets for kidney toxicity from female rats. Please see the revised text in Sections 1.3.1, 2.2.4, and 2.2.8.

### Charge Question 4a Cancer modes-of-action in the liver. As described in section 1.2.2, the draft assessment evaluated the roles of the receptor pathways PPARα, PXR, and CAR in ETBE tumorigenesis in male rats. The analysis, conducted in accordance with EPA’s cancer guidelines (U.S. EPA, 2005), considered the liver tumors in male rats to be relevant to human hazard identification. Please comment on whether this conclusion is scientifically supported

[underlined: Key Recommendation]: The SAB recommended that EPA should clarify the evidence needed to conclude that a PPARα, CAR, and/or PXR MOA is operative and to indicate that liver tumors may not be relevant to humans. The SAB suggested that examples, if provided, would be helpful to illustrate the types of studies/information needed to satisfy each criterion, and that EPA should revisit the evaluation of information available for ETBE using these criteria.

[underlined: Response]: Text has been added to clarify additional data gaps (see Section 1.2.2). Briefly, several gaps in the receptor mediated effects data were explicitly noted such as evidence in only one species, lack of any studies in receptor knock-out or humanized mice, lack of dose response concordance between receptor mediated gene changes and tumors, and lack of any receptor mediated data outside of the 1 and 2 week time points, which preclude establishing temporal associations.

[underlined: Key Recommendation]: The SAB recommended that EPA may want to reconsider statements about transient hypertrophy.

[underlined: Response:] Statements regarding transient hypertrophy have been revised and additional information on the observation of related endpoints, such as increased liver weight, has been added for context.

[underlined: Key Recommendation]: The SAB recommended that EPA should revise Table 1-13 and accompanying narrative to be more descriptive regarding availability of information for each MOA and indicate whether studies relevant to the MOA exist, and where results are positive or negative, instead of saying “no positive studies identified”.

[underlined: Response:] The table and narrative text have been clarified to indicate the categories under which no pertinent studies were identified.

[underlined: Key Recommendation]: The SAB commented that while acetaldehyde was proposed as a strong candidate MOA for male rat liver tumors in the assessment, the plausibility of this MOA was not well explored. The SAB recommended that evidence for this MOA should be developed and presented more thoroughly; or, alternatively, encouraged the Agency to reduce emphasis on this MOA in the final assessment.

[underlined: Response:] The data for an acetaldehyde based MOA for the observed liver tumors has been evaluated in the Toxicological Review in Section 1.2.2. Although the available evidence suggests a potential role for acetaldehyde in the increased liver tumor response observed in male rats exposed to ETBE, the data are inadequate to conclude that ETBE induces liver tumors via acetaldehyde-mediated mutagenicity. Therefore, emphasis on this MOA and its effect on the assessment conclusions has been reduced throughout the document.

### Charge Question 4b Cancer characterization. As described in sections 1.2.1, 1.2.2, 1.2.5 and 1.3.2, and in accordance with EPA’s cancer guidelines (U.S. EPA, 2005), the draft assessment concludes that there is suggestive evidence of carcinogenic potential for ETBE by all routes of exposure, based on liver tumors in male F344 rats via inhalation and on promotion of liver, colon, thyroid, forestomach, and urinary bladder tumors in male rats via oral exposure. Please comment on whether the decision to include 2-stage initiation-promotion studies in the human cancer hazard characterization is sufficiently justified and if the amount of emphasis placed on the initiation promotion data in the cancer hazard characterization is scientifically supported^6^. Please comment on whether the “suggestive evidence” cancer descriptor is scientifically supported for all routes of exposure. If another cancer descriptor should be selected, please outline how it might be supported

[underlined: Key Recommendation:] The SAB recommended the use of the descriptor “Inadequate Information” for oral ETBE, and “Suggestive Evidence” for inhaled ETBE.

[underlined: Response]: The EPA agrees with the SAB recommendation and has implemented these descriptors in the revised assessment.

[underlined: Key Recommendation]: The SAB recommended that the EPA not use the initiation-promotion assay as key evidence to support a conclusion of carcinogenic potential.

[underlined: Response:] Section 1.2.5 of the Toxicological Review has been revised to clarify that initiation-promotion assays are included only as supplemental studies informing carcinogenicity. Regarding the animal database for carcinogenicity, EPA considers chronic bioassays as key evidence, and other types of studies (including initiation promotion studies, co-carcinogenicity studies, studies in genetically modified animals, etc.) as supplemental lines of information which can aid in the interpretation of more standard toxicological evidence, especially regarding potential modes of action (U.S. EPA, 2005).

[underlined: Key Recommendation]: The SAB recommended that the EPA explain within the assessment that the assigned cancer classifications are an EPA Cancer Guidelines policy-based decision.

[underlined: Response]: “Cancer classifications” or cancer weight of evidence descriptors, are used as part of the hazard narrative to express the conclusion regarding the weight of evidence for carcinogenic hazard potential. Choosing a descriptor is a matter of scientific judgement, not policy, guided by examples and considerations discussed in EPA’s Cancer Guidelines (U.S. EPA, 2005).

### Charge Question 4c Cancer toxicity values. Section 3 of EPA’s cancer guidelines (U.S. EPA, 2005) states: “When there is suggestive evidence, the Agency generally would not attempt a dose-response assessment, as the data usually would not support one. However, when the evidence includes a well-conducted study, quantitative analyses may be useful for some purposes, for example, providing a sense of the magnitude and uncertainty of potential risks, ranking potential hazards, or setting research priorities. In each case, the rationale for the quantitative analysis is explained, considering the uncertainty in the data and the suggestive nature of the weight of evidence.” Please comment on whether Sections 2.3 and 2.4 of the draft assessment adequately explain the rationale for including a quantitative analysis given the “suggestive evidence” descriptor. Also comment whether the Saito et al. (2013) study is a suitable basis for this quantitative analysis

[underlined: Key Recommendation]: The SAB recommended that the EPA refrain from conducting a quantitative analysis for ETBE carcinogenicity or explain the limitations of the analysis and clearly state that the intended purpose is to simply provide some sense of the magnitude of potential risks.

[underlined: Response]: No quantitative analysis of cancer risk is carried out for oral ETBE exposure. For inhalation exposure, additional text has been added to the assessment to discuss the strengths and limitations of a quantitative analysis of the tumor data and to clarify that the purpose is to provide a sense of the magnitude of a potential cancer risk (this is useful because when no information on the potential magnitude of risk is provided, it generally implies zero risk). See Section 1.3.2 and Section 2.4.1. The assessment also notes the increased uncertainty in this risk estimate because of the suggestive nature of the tumorigenic response (U.S. EPA, 2005).

### Charge Question 4d Oral slope factor for cancer. Section 2.3 presents an oral slope factor of 1 × 10^–3^ per mg/kg–day, based on liver tumors in male rats by inhalation (Saito et al., 2013), converted for oral exposure using a toxicokinetic model (Borghoff et al., 2016). Please comment on whether this value is scientifically supported and its derivation clearly described. If an alternative approach would be more appropriate, please outline how it might be developed

[underlined: Key Recommendation]: The SAB recommended that since the only available ETBE inhalation cancer bioassay (Saito et al., 2013; JPEC, 2010b) is not suitable for developing an oral cancer slope factor, the EPA should not derive an oral slope factor by route extrapolation absent pharmacokinetic/pharmacodynamic modeling that demonstrates consistency between the oral and inhalation study results. The SAB indicated the following concerns about the use of Saito for route to route extrapolation for developing an oral slope factor: (1) Oral studies did not demonstrate cancer (2) EPA analysis indicated that a consistent dose response relationship could not be observed when comparing across oral and inhalation exposures on the basis of any internal dose measures.

[underlined: Response:] In response to the SAB recommendation, EPA is not carrying out a route to route extrapolation for the derivation of the oral slope factor. Furthermore, there is uncertainty as to whether the liver tumors observed in male rats following inhalation would be reasonably expected following oral exposure as one high confidence oral cancer bioassay (Suzuki et al., 2012; JPEC, 2010a), and a lower confidence chronic oral cancer bioassay (Maltoni et al., 1999) did not observe elevated liver tumors.

### Charge Question 4e Inhalation unit risk for cancer. Section 2.4 presents an inhalation unit risk of 8 × 10^–5^ per mg/m^3^, based on liver tumors in male rats by inhalation (Saito et al., 2013). Please comment on whether this value is scientifically supported and its derivation clearly described. If an alternative approach would be more appropriate, please outline how it might be developed

[underlined: Key Recommendation]: The SAB had no specific recommendations; the SAB-CAAC did not reach consensus on this charge question. Some members supported use of the (Saito et al., 2013) study for dose-response assessment recognizing it as a well-designed, well-conducted, and well-reported study and also noting the liver metabolism of ETBE to acetaldehyde, a genotoxic carcinogen. Other members believed the ETBE concentration which induced liver tumors to be excessively high, with significantly elevated tumors only in one sex, at one dose, and questioned whether modeling a single positive concentration would produce a meaningful inhalation unit risk.

[underlined: Response:] Text has been added to the assessment to more clearly denote the strengths and the uncertainties in the data used to derive the inhalation unit risk (see Section 1.3.2, Biological Considerations for Dose-Response). Briefly, while liver adenomas were primarily observed at the highest dose in male rats, three liver adenomas were also observed at the lower two concentrations, resulting in a significant positive exposure-response trend (p < 0.001 with Peto’s test). The Saito et al. (2013) study was considered appropriate for the basis of a quantitative cancer estimate as it is a well-designed, conducted and reported study which included histological examinations for tumors in many different tissues, contained three exposure levels and controls, contained adequate numbers of animals per dose group (~50/sex/group), treated animals for up to 2 years, and included detailed reporting of methods and results. Decreased body weight gain and survival was noted in the high dose males and females; however, the study authors did not detect changes to the animals’ general condition (e.g., abnormal behavior or clinical signs) associated with ETBE. Similar decreases in body weight were observed in male (75% of control) and female animals (78% of control), although significantly increased liver tumors were only observed in male rats. Given the lack of overt toxicity and no apparent alterations in toxicokinetics, the ETBE concentrations were not considered to be excessively high. Additionally, text describing the suitability of the study, its utilization in deriving a cancer risk estimate, and the characterization of a cancer value considering the suggestive nature of the cancer potential are further discussed in Section 2.4.

### Charge Question 5 Question on Susceptible Populations and Lifestages Section 1.3.3 identifies individuals with diminished ALDH2 activity as a susceptible population due to an increased internal dose of acetaldehyde, a primary metabolite of ETBE. Please comment on whether this conclusion is scientifically supported and clearly described. If there are publicly available studies to identify other susceptible populations or lifestages, please identify them and outline their impact on the conclusions

[underlined: Key Recommendation]: The SAB recommends that the Agency clearly describe the uncertainty between oral exposure and other routes of exposure in the ETBE assessment and provide relevant positions with respect to differences in expected outcomes.

[underlined: Response:] Text has been added to this section to highlight the uncertainty pertaining to the fact that the available database to inform early life susceptibility of ETBE is limited to the oral route of exposure.

[underlined: Key Recommendation:] The SAB recommended the Agency identify susceptible populations and incorporate information about them into the ETBE assessment to improve the scientific concepts of the assessment. Specifically, the SAB recommended discussing individuals with noncoding region variants in adlh2, which could potentially affect gene expression, as well as discussing individuals with other variants in alcohol metabolism who may be affected by ETBE exposure.

[underlined: Response:] Increased discussion of these additional potentially susceptible populations has been added to the document.

[underlined: Key Recommendation]: The SAB recommends that information regarding lifestages should be included in the assessment.

[underlined: Response:] Discussion of data informing potential early life susceptibility to ETBE has been added to this section.

### Charge Question 6 Question on the Executive Summary The Executive Summary is intended to provide a concise synopsis of the key findings and conclusions for a broad range of audiences. Please comment on whether the executive summary clearly and appropriately presents the major conclusions of the draft assessment

[underlined: Key Recommendation]: The SAB advises that it will be important for the final Executive Summary to highlight the consequences of alternative choices for the final assessment, especially when these hinge on decisions made about the interpretation and relevance of key toxicity endpoints that have been contested.

[underlined: Response]: Text has been added to the Executive Summary to more clearly highlight the context around the interpretation and relevance of key endpoints such as the human relevance of the observed kidney effects (see Key Issues Addressed in Assessment).

Comments from two members of the Chartered SAB during the QA Review of the SAAB CAAC Peer Review Report

The Chartered SAB is tasked with conducting quality reviews of draft SAB reports to determine if they are ready for transmittal to the Administrator, reviewing whether the charge questions were adequately addressed by the CAAC, whether the report has technical errors or omissions, if the report is clear and logical, and if the CAAC recommendations in the report are supported by the body of the draft report. During this quality review of the draft SAB-CAAC report on the Draft IRIS assessments of ETBE and tert-butanol, two members of the chartered SAB (44 total members) disagreed with the CAAC regarding the recommendation for the cancer weight of evidence descriptors for ETBE and tBA. These two members provided additional comments which were included as Appendix C of the Final SAB report. A summary and response to their comments, as they pertain to ETBE, are included below.

[underlined: Comment:] Two members of the chartered SAB disagreed with the SAB-CAAC’s support of EPA’s cancer weight of evidence descriptor of “suggestive evidence” for ETBE. They stated ETBE should be characterized as “insufficient evidence” (presumably analogous to EPA’s cancer weight of evidence descriptor for “inadequate evidence”) because liver tumors were observed only in male rats at the highest exposure concentration in the JPEC (2010b) inhalation bioassay, a concentration they characterize as beyond the maximum tolerated dose (MTD) due to a 25% reduction in body weight. In addition, two chronic oral bioassays were negative for liver tumors.

[underlined: Response:] The SAB-CAAC agreed with the cancer weight of evidence descriptor of “suggestive evidence” (See Charge Question 4b) for the inhalation route of exposure, as the database was consistent with this descriptor as illustrated in the Cancer Guidelines, based on the occurrences of tumors in one sex of one species. Briefly, a statistically significant increase in liver tumors was observed in male rats exposed to ETBE by inhalation (primarily, but not exclusively at the high dose) with the incidence of combined adenomas and carcinomas of 0/50, 2/50, 1/50 and 10/50 at 0, 2,090, 6,270, 20,900 mg/m^3^, resulting in a statistically significant, positive exposure-response trend (Peto’s test p < 0.001).

Regarding the assertion that the highest inhalation dose in the Saito et al. (2013) study exceeded the MTD, EPA’s 2005 Cancer Guidelines discuss the determination of an “excessively high dose” and describe the process as one of expert judgment which requires that “…adequate data demonstrate that the effects are solely the result of excessive toxicity rather than carcinogenicity of the tested agent.” In the case of the Saito et al. (2013) inhalation study, the study authors did not report any overt toxicity or altered toxicokinetics at the high dose. In addition, the high-dose female rats had a similar reduction in body weight (22%) and no liver tumors were observed (see discussion in Section 1.2.2). Discussion regarding the cancer descriptor for the inhalation route of exposure, the rationale for deriving the inhalation unit risk (including consideration of potential excessively high dose), and the characterization of the cancer risk estimate can be found in Sections 1.3.2 and 2.4.1, and in response to comments under Charge Questions 4b, 4c, and 4e.

With regard to the comments on the cancer descriptor and the oral cancer studies, the SAB-CAAC recommended EPA’s cancer weight of evidence descriptor of “inadequate evidence of carcinogenic potential” for the oral route of exposure. EPA agreed and revised the assessment accordingly. Thus, a cancer risk estimate for the oral route was not derived. See Sections 1.3.2 and 2.3, and responses under Charge Questions 4b and 4d.

4 During the quality review by the Chartered SAB, 2 of the 44 members provided dissenting comments related to the cancer weight of evidence descriptors and the quantitative cancer risk estimates for ETBE and tBA. These comments were included as an appendix to the final SAB report and are summarized and addressed following the disposition of the SAB-CAAC recommendations below.

5 The SAB provided tiered recommendations: Tier 1 (key recommendations), Tier 2 (suggestions), and Tier 3 (future considerations).

6 This unbolded segment of the charge question was added by the SAB-CAAC