# APPENDIX C DOSE-RESPONSE MODELING FOR THE DERIVATION OF REFERENCE VALUES FOR EFFECTS OTHER THAN CANCER AND THE DERIVATION OF CANCER RISK ESTIMATES

## C.1 BENCHMARK DOSE MODELING SUMMARY

This appendix provides technical detail on dose-response evaluation and determination of points of departure (PODs) for relevant toxicological endpoints. The endpoints were modeled using EPA’s Benchmark Dose Software (BMDS, version 2.2). Section C.1.1 (noncancer) and Section C.1.2 (cancer) describe the common practices used in evaluating the model fit and selecting the appropriate model for determining the POD, as outlined in the Benchmark Dose Technical Guidance Document (U.S. EPA, 2012). In some cases, it might be appropriate to use alternative methods based on statistical judgment; exceptions are noted as necessary in the summary of the modeling results.

### C.1.1 Noncancer Endpoints

#### Evaluation of Model Fit

For each dichotomous endpoint, BMDS dichotomous models^1^ were fitted to the data using the maximum likelihood method. Each model was tested for goodness of fit using a chi-square goodness-of-fit test (χ^2^ p-value < 0.10 indicates lack of fit). Other factors were also used to assess model fit, such as scaled residuals, visual fit, and adequacy of fit in the low-dose region and in the vicinity of the benchmark response (BMR).

For each continuous endpoint, BMDS continuous models^2^ were fitted to the data using the maximum likelihood method. Model fit was assessed by a series of tests as follows. For each model, the homogeneity of the variances was tested first using a likelihood ratio test (BMDS Test 2). If Test 2 was not rejected (χ^2^ p-value ≥ 0.10), the model was fitted to the data assuming constant variance. If Test 2 was rejected (χ^2^ p-value < 0.10), the variance was modeled as a power function of the mean, and the variance model was tested for adequacy of fit using a likelihood ratio test (BMDS Test 3). For fitting models using either constant variance or modeled variance, models for the mean response were tested for adequacy of fit using a likelihood ratio test (BMDS Test 4, with χ^2^ p-value < 0.10 indicating inadequate fit). Other factors were also used to assess the model fit, such as scaled residuals, visual fit, and adequacy of fit in the low-dose region and in the vicinity of the BMR.

#### Model Selection

For each endpoint, the lower confidence limit of the benchmark dose or concentration (BMDL/BMCL), as estimated by the profile likelihood method and Akaike’s information criterion (AIC) value, were used to select a best-fit model from among the models exhibiting adequate fit. If the BMDL/BMCL estimates were “sufficiently close,” that is, differed by at most threefold, the model selected was the one that yielded the lowest AIC value. If the BMDL/BMCL estimates were not sufficiently close, the lowest BMDLBMCL was selected as the POD.

Table C-1 Noncancer endpoints selected for dose-response modeling for ETBE

Endpoint, study | Sex, strain, species | Doses/concentrations and effect data
Oral
Urothelial hyperplasia of the renal pelvis Suzuki et al. (2012); JPEC (2010a) | Male F344 rats | Dose (mg/kg-d) | 0 | 28 | 121 | 542
Urothelial hyperplasia of the renal pelvis Suzuki et al. (2012); JPEC (2010a) | Male F344 rats | Incidence/total | 0/50 | 0/50 | 10/50 | 25/50
Increased absolute kidney weight Suzuki et al. (2012); JPEC (2010a) | Female F344 rats | Dose (mg/kg-d) | 0 | 46 | 171 | 560
Increased absolute kidney weight Suzuki et al. (2012); JPEC (2010a) | Female F344 rats | No. of animals | 36 | 37 | 38 | 38
Increased absolute kidney weight Suzuki et al. (2012); JPEC (2010a) | Female F344 rats | Mean ± SD | 1.81 ± 0.12 | 1.863 ± 0.14 | 1.988 ± 0.19 | 2.057 ± 0.26
Increased absolute kidney weight Miyata et al. (2013); JPEC (2008b) | Male Sprague-Dawley rats | Dose (mg/kg-d) | 0 | 5 | 25 | 100 | 400
Increased absolute kidney weight Miyata et al. (2013); JPEC (2008b) | Male Sprague-Dawley rats | No. of animals | 15 | 15 | 14 | 15 | 13
Increased absolute kidney weight Miyata et al. (2013); JPEC (2008b) | Male Sprague-Dawley rats | Mean ± SD | 3.27 ± 0.34 | 3.29 ± 0.3 | 3.47 ± 0.32 | 3.42 ± 0.48 | 4.09 ± 0.86
Increased absolute kidney weight Miyata et al. (2013); JPEC (2008b) | Female Sprague-Dawley rats | Dose (mg/kg-d) | 0 | 5 | 25 | 100 | 400
Increased absolute kidney weight Miyata et al. (2013); JPEC (2008b) | Female Sprague-Dawley rats | No. of animals | 15 | 15 | 15 | 15 | 15
Increased absolute kidney weight Miyata et al. (2013); JPEC (2008b) | Female Sprague-Dawley rats | Mean ± SD | 1.88 ± 0.2 | 1.89 ± 0.16 | 1.88 ± 0.15 | 2.02 ± 0.21 | 2.07 ± 0.23
Increased absolute kidney weight Gaoua (2004b) | P0 male Sprague-Dawley rats | Dose (mg/kg-d) | 0 | 250 | 500 | 1,000
Increased absolute kidney weight Gaoua (2004b) | P0 male Sprague-Dawley rats | No. of animals | 25 | 25 | 25 | 25
Increased absolute kidney weight Gaoua (2004b) | P0 male Sprague-Dawley rats | Mean ± SD | 3.58 ± 0.413 | 3.96 ± 0.446 | 4.12 ± 0.624 | 4.34 ± 0.434
Increased absolute kidney weight Gaoua (2004b) | P0 female Sprague-Dawley rats | Dose (mg/kg-d) | 0 | 250 | 500 | 1,000
Increased absolute kidney weight Gaoua (2004b) | P0 female Sprague-Dawley rats | No. of animals | 25 | 24 | 22 | 25
Increased absolute kidney weight Gaoua (2004b) | P0 female Sprague-Dawley rats | Mean ± SD | 2.24 ± 0.185 | 2.22 ± 0.16 | 2.29 ± 0.207 | 2.35 ± 0.224
Increased absolute kidney weight Gaoua (2004b) | F1 male Sprague-Dawley rats | Dose (mg/kg-d) | 0 | 250 | 500 | 1,000
Increased absolute kidney weight Gaoua (2004b) | F1 male Sprague-Dawley rats | No. of animals | 24 | 25 | 24 | 25
Increased absolute kidney weight Gaoua (2004b) | F1 male Sprague-Dawley rats | Mean ± SD | 3.38 ± 0.341 | 3.73 ± 0.449 | 4.13 ± 0.64 | 5.34 ± 5.39
Increased absolute kidney weight Gaoua (2004b) | F1 female Sprague-Dawley rats | Dose (mg/kg-d) | 0 | 250 | 500 | 1,000
Increased absolute kidney weight Gaoua (2004b) | F1 female Sprague-Dawley rats | No. of animals | 25 | 24 | 25 | 23
Increased absolute kidney weight Gaoua (2004b) | F1 female Sprague-Dawley rats | Mean ± SD | 2.24 ± 0.178 | 2.34 ± 0.242 | 2.3 ± 0.226 | 2.49 ± 0.284
Increased absolute kidney weight Fujii et al. (2010); JPEC (2008d) | Male Sprague-Dawley rats | Dose (mg/kg-d) | 0 | 100 | 300 | 1,000
Increased absolute kidney weight Fujii et al. (2010); JPEC (2008d) | Male Sprague-Dawley rats | No. of animals | 24 | 24 | 24 | 24
Increased absolute kidney weight Fujii et al. (2010); JPEC (2008d) | Male Sprague-Dawley rats | Mean ± SD | 3.46 ± 0.57 | 3.62 ± 0.45 | 3.72 ± 0.35 | 4.07 ± 0.53
Increased relative kidney weight Fujii et al. (2010); JPEC (2008d) | Male Sprague-Dawley rats | Dose (mg/kg-d) | 0 | 100 | 300 | 1,000
Increased relative kidney weight Fujii et al. (2010); JPEC (2008d) | Male Sprague-Dawley rats | No. of animals | 24 | 24 | 24 | 24
Increased relative kidney weight Fujii et al. (2010); JPEC (2008d) | Male Sprague-Dawley rats | Mean ± SD | 0.546 ± 0.059 | 0.592 ± 0.06 | 0.609 ± 0.042 | 0.689 ± 0.049
Increased absolute kidney weight Fujii et al. (2010); JPEC (2008d) | Female Sprague-Dawley rats | Dose (mg/kg-d) | 0 | 100 | 300 | 1,000
Increased absolute kidney weight Fujii et al. (2010); JPEC (2008d) | Female Sprague-Dawley rats | No. of animals | 21 | 22 | 23 | 19
Increased absolute kidney weight Fujii et al. (2010); JPEC (2008d) | Female Sprague-Dawley rats | Mean ± SD | 2.17 ± 0.18 | 2.13 ± 0.14 | 2.17 ± 0.17 | 2.33 ± 0.24
Increased relative kidney weight Fujii et al. (2010); JPEC (2008d) | Female Sprague-Dawley rats | Dose (mg/kg-d) | 0 | 100 | 300 | 1,000
Increased relative kidney weight Fujii et al. (2010); JPEC (2008d) | Female Sprague-Dawley rats | No. of animals | 24 | 24 | 24 | 24
Increased relative kidney weight Fujii et al. (2010); JPEC (2008d) | Female Sprague-Dawley rats | Mean ± SD | 0.674 ± 0.053 | 0.656 ± 0.048 | 0.668 ± 0.057 | 0.687 ± 0.045
Inhalation
Urothelial hyperplasia of the renal pelvis Saito et al. (2013); JPEC (2010b) | Male F344 rats | Exposure concentration (mg/m^3^) | 0 | 2,090 | 6,270 | 20,900
Urothelial hyperplasia of the renal pelvis Saito et al. (2013); JPEC (2010b) | Male F344 rats | Incidence/total | 2/50 | 5/50 | 16/49 | 41/50
Increased absolute kidney weight Saito et al. (2013); JPEC (2010b) | Female Sprague-Dawley rats | Exposure concentration (ppm) | 0 | 2,090 | 6,270 | 20,900
Increased absolute kidney weight Saito et al. (2013); JPEC (2010b) | Female Sprague-Dawley rats | No. of animals | 37 | 39 | 29 | 30
Increased absolute kidney weight Saito et al. (2013); JPEC (2010b) | Female Sprague-Dawley rats | Mean ± SD | 1.81 ± 0.18 | 1.90 ± 0.20 | 1.92 ± 0.13 | 2.13 ± 0.28
Increased absolute kidney weight JPEC (2008a) | Male Sprague-Dawley rats | Exposure concentration (ppm) | 0 | 150 | 500 | 1,500 | 5,000
Increased absolute kidney weight JPEC (2008a) | Male Sprague-Dawley rats | No. of animals | 10 | 10 | 10 | 10 | 10
Increased absolute kidney weight JPEC (2008a) | Male Sprague-Dawley rats | Mean ± SD | 3.15 ± 0.243 | 3.45 ± 0.385 | 3.49 ± 0.314 | 3.72 ± 0.365 | 3.64 ± 0.353
Increased absolute kidney weight JPEC (2008a) | Female Sprague-Dawley rats | Exposure concentration (ppm) | 0 | 150 | 500 | 1,500 | 5,000
Increased absolute kidney weight JPEC (2008a) | Female Sprague-Dawley rats | No. of animals | 10 | 10 | 10 | 10 | 10
Increased absolute kidney weight JPEC (2008a) | Female Sprague-Dawley rats | Mean ± SD | 1.84 ± 0.129 | 1.85 ± 0.18 | 1.83 ± 0.118 | 1.92 ± 0.173 | 1.97 ± 0.16
Increased absolute kidney weight Medinsky et al. (1999); US EPA (1997) | Male F344 rats | Exposure concentration (ppm) | 0 | 500 | 1,750 | 5,000
Increased absolute kidney weight Medinsky et al. (1999); US EPA (1997) | Male F344 rats | No. of animals | 11 | 11 | 11 | 11
Increased absolute kidney weight Medinsky et al. (1999); US EPA (1997) | Male F344 rats | Mean ± SD | 1.73 ± 0.155 | 1.85 ± 0.137 | 1.903 ± 0.1 | 2.067 ± 0.124
Increased absolute kidney weight Medinsky et al. (1999); US EPA (1997) | Female F344 rats | Exposure concentration (ppm) | 0 | 500 | 1,750 | 5,000
Increased absolute kidney weight Medinsky et al. (1999); US EPA (1997) | Female F344 rats | No. of animals | 10 | 11 | 11 | 11
Increased absolute kidney weight Medinsky et al. (1999); US EPA (1997) | Female F344 rats | Mean ± SD | 1.077 ± 0.069 | 1.125 ± 0.048 | 1.208 ± 0.076 | 1.306 ± 0.055

No. = number; SD = standard deviation.

#### Modeling Results

Below are tables summarizing the modeling results for the noncancer endpoints modeled.

##### Oral exposure endpoints

Table C-2 Summary of benchmark dose (BMD) modeling results for urothelial hyperplasia of the renal pelvis in male F344 rats exposed to ETBE in drinking water for 104 weeks (JPEC, 2010a) modeled with doses as mg/kg-day (calculated by the study authors); benchmark response (BMR) = 10% extra risk

Model^a^ | Goodness of fit | | BMD_10_ (mg/kg-d) | BMDL_10_ (mg/kg-d) | Basis for model selection
Model^a^ | p-value | AIC | BMD_10_ (mg/kg-d) | BMDL_10_ (mg/kg-d) | Basis for model selection
Gamma | 0.196 | 127.93 | 88.1 | 60.9 | Of the models that provided an adequate fit and a valid BMDL estimate, the Quantal-Linear model was selected based on lowest AIC.
Logistic | 1.00 × 10^−3^ | 139.54 | 217 | 177 | Of the models that provided an adequate fit and a valid BMDL estimate, the Quantal-Linear model was selected based on lowest AIC.
Log-Logistic | 0.264 | 127.28 | 85.3 | 49.5 | Of the models that provided an adequate fit and a valid BMDL estimate, the Quantal-Linear model was selected based on lowest AIC.
Probit | 0.0015 | 138.30 | 197 | 162 | Of the models that provided an adequate fit and a valid BMDL estimate, the Quantal-Linear model was selected based on lowest AIC.
Log-Probit | 0.374 | 126.14 | 85.8 | 51.3 | Of the models that provided an adequate fit and a valid BMDL estimate, the Quantal-Linear model was selected based on lowest AIC.
Weibull | 0.202 | 128.00 | 85.7 | 60.7 | Of the models that provided an adequate fit and a valid BMDL estimate, the Quantal-Linear model was selected based on lowest AIC.
Multistage (3 degree)^b^; Multistage (2 degree)^c^ | 0.395 | 126.07 | 79.3 | 60.5 | Of the models that provided an adequate fit and a valid BMDL estimate, the Quantal-Linear model was selected based on lowest AIC.
Quantal-Linear ^c^ | 0.395 | 126.07 | 79.3 | 60.5 | Of the models that provided an adequate fit and a valid BMDL estimate, the Quantal-Linear model was selected based on lowest AIC.

a Selected model in bold; scaled residuals for selected model for doses 0, 28, 121, and 542 mg/kg-d were 0.000, −1.377, 1.024, and −0.187, respectively.

b For the Multistage (3 degree) model, the beta coefficient estimates were 0 (boundary of parameters space), and the model reduced to the Multistage (2 degree) model.

c The Multistage (2 degree) model and Quantal-Linear models appear equivalent; however, differences exist in digits not displayed in the table.

Figure C-1 Plot of incidence rate by dose, with fitted curve for the Quantal Linear Model; dose shown in mg/kg-day

Quantal Linear Model using Weibull Model (Version: 2.16; Date: 2/28/2013)

The form of the probability function is:

P[response] = background + (1 − background) × [1 − exp(− slope × dose)]

Benchmark Dose Computation.

BMR = 10% extra risk

Benchmark dose (BMD) = 79.3147

BMDL at the 95% confidence level = 60.5163

Parameter Estimates

Variable | Estimate | Default initial parameter values
Background | 0 | 0.0192308
Slope | 0.00132839 | 0.00124304
Power | N/A | 1

Analysis of Deviance Table

Model | Log(likelihood) | No. parameters | Deviance | Test df | p-value
Full model | −59.6775 | 4
Fitted model | −62.0369 | 1 | 4.71891 | 3 | 0.1936
Reduced model | −92.7453 | 1 | 66.1356 | 3 | <0.0001

AIC = 126.074

Goodness-of-Fit Table

Dose | Estimated probability | Expected | Observed | Size | Scaled residual
0 | 0 | 0 | 0 | 50 | 0
28 | 0.0365 | 1.826 | 0 | 50 | −1.377
121 | 0.1485 | 7.424 | 10 | 50 | 1.024
542 | 0.5132 | 25.662 | 25 | 50 | −0.187

χ^2^ = 2.98; degrees of freedom (df) = 3; p-value = 0.3948

Table C-3 Summary of benchmark dose (BMD) modeling results for increased absolute kidney weight in female F344 rats exposed to ETBE in drinking water for 104 weeks (JPEC, 2010a); benchmark response (BMR) = 10% relative deviation from the mean

Model^a^ | Goodness of fit | | BMD_10RD_ (mg/kg-d) | BMDL_10RD_ (mg/kg-d) | Basis for model selection
Model^a^ | p-value | AIC | BMD_10RD_ (mg/kg-d) | BMDL_10RD_ (mg/kg-d) | Basis for model selection
Exponential (M2); Exponential (M3)^b^ | 0.00752 | −339.97 | 385 | 290 | The Exponential (M4) model was selected as the only model with a goodness-of-fit p-value > 0.1.
Exponential (M4) | 0.621 | −347.50 | 204 | 120 | The Exponential (M4) model was selected as the only model with a goodness-of-fit p-value > 0.1.
Exponential (M5) | N/A | −345.75 | 192 | 116 | The Exponential (M4) model was selected as the only model with a goodness-of-fit p-value > 0.1.
Hill | N/A | −345.75 | 195 | 107 | The Exponential (M4) model was selected as the only model with a goodness-of-fit p-value > 0.1.
Power^c^; Polynomial (3 degree)^d^; Polynomial (2 degree)^e^; Linear | 0.0115 | −340.82 | 367 | 272 | The Exponential (M4) model was selected as the only model with a goodness-of-fit p-value > 0.1.

a Modeled variance case presented (BMDS Test 3 p-value = <0.8167), selected model in bold; scaled residuals for selected model for doses 0, 46, 171, and 560 mg/kg-d were 0.0259, −0.19, 0.474, and −0.289, respectively.

b For the Exponential (M3) model, the estimate of d was 1 (boundary), and the model reduced to the Exponential (M2) model.

c For the Power model, the power parameter estimate was 1 (boundary), and the model reduced to the Linear model.

d For the Polynomial (3 degree) model, the b3 and b2 coefficient estimates were 0 (boundary), and the model reduced to the Linear model.

e For the Polynomial (2 degree) model, the b2 coefficient estimate was 0 (boundary), and the model reduced to the Linear model.

Figure C-2 Plot of mean response by dose, with fitted curve for the Exponential 4 Model; dose shown in mg/kg-day

Exponential 4 Model. (BMDS Version 1.10; Date: 01/12/2015)

The form of the response function is: P[dose] = a × [c − (c − 1) × exp(−b × dose)]

A modeled variance is fit: Var[i] = exp(log-alpha + log[mean(i)] × rho)

Benchmark Dose Computation.

BMR = 10% relative deviation

BMD = 204 mg/kg-day

BMDL at the 95% confidence level = 120 mg/kg-day

Parameter Estimates

Variable | Model 4 | Standard error
lnalpha | −11.0816 | 1.89029
rho | 11.431 | 2.93477
a | 1.80851 | 0.0173746
b | 0.00518165 | 0.00207201
c | 1.15314 | 0.0322089

Table of Data and Estimated Values of Interest

Dose | N | Observed mean | Estimated mean | Observed standard deviation | Estimated standard deviation | Scaled residual
0 | 37 | 1.809 | 1.809 | 0.122 | 0.116 | 0.02585
46 | 39 | 1.863 | 1.867 | 0.135 | 0.1392 | −0.1903
171 | 29 | 1.988 | 1.971 | 0.189 | 0.1898 | 0.4744
560 | 30 | 2.057 | 2.07 | 0.261 | 0.2511 | −0.2889

Likelihoods of Interest

Model | Log(likelihood) | df | AIC
A1 | 166.6724 | 5 | −323.3449
A2 | 179.0769 | 8 | −342.1539
A3 | 178.8744 | 6 | −345.7488
R | 148.74 | 2 | −293.4799
4 | 178.7521 | 5 | −347.5042

Tests of Interest

Test | −2 × log(likelihood ratio) | Test df | p-value
Test 1 | 60.67 | 6 | <0.0001
Test 2 | 24.81 | 3 | <0.0001
Test 3 | 0.4051 | 2 | 0.8167
Test 6a | 0.2446 | 1 | 0.6209

Table C-4 Summary of benchmark dose (BMD) modeling results for increased absolute kidney weight in male Sprague-Dawley rats exposed to ETBE by daily gavage for 26 weeks (Miyata et al., 2013; JPEC, 2008d); benchmark response (BMR) = 10% relative deviation from the mean

Model^a^ | Goodness of fit | | BMD_10RD_ (mg/kg-d) | BMDL_10RD_ (mg/kg-d) | Basis for model selection
Model^a^ | p-value | AIC | BMD_10RD_ (mg/kg-d) | BMDL_10RD_ (mg/kg-d) | Basis for model selection
Exponential (M2); Exponential (M3)^b^ | 0.752 | −47.963 | 186 | 126 | The Linear model was selected based on lowest AIC.
Exponential (M4); Exponential (M5)^c^ | 0.603 | −46.156 | 157 | 67.7 | The Linear model was selected based on lowest AIC.
Hill | 0.605 | −46.161 | 156 | 63.6 | The Linear model was selected based on lowest AIC.
Power ^d^; Polynomial (2 degree) ^e^; Linear ^f^ | 0.774 | −48.055 | 176 | 115 | The Linear model was selected based on lowest AIC.
Polynomial (3 degree)^g^ | 0.774 | −48.055 | 176 | 115 | The Linear model was selected based on lowest AIC.

a Modeled variance case presented (BMDS Test 3 p-value = <0), selected model in bold; scaled residuals for selected model for doses 0, 5, 25, 100, and 400 mg/kg-d were −0.421, −0.288, 1.29, −0.669, and 0.15, respectively.

b For the Exponential (M3) model, the estimate of d was 1 (boundary), and the model reduced to the Exponential (M2) model.

c For the Exponential (M5) model, the estimate of d was 1 (boundary), and the model reduced to the Exponential (M4) model.

d For the Power model, the power parameter estimate was 1, and the model reduced to the Linear model.

e For the Polynomial (2 degree) model, the b2 coefficient estimate was 0 (boundary of parameters space), and the model reduced to the Linear model.

f The Linear and Polynomial (3 degree) models appear equivalent; however, differences exist in digits not displayed in the table.

g The Linear model, Polynomial (2 degree and 3 degree) models and the Power models appear equivalent; however, differences exist in digits not displayed in the table.

Figure C-3 Plot of mean response by dose, with fitted curve for the Linear Model; dose shown in mg/kg-day

Polynomial Model. (Version: 2.17; Date: 01/28/2013)

The form of the response function is: Y[dose] = beta_0 + beta_1 × dose

A modeled variance is fit.

Benchmark Dose Computation.

BMR = 10% relative deviation

BMD = 176.354

BMDL at the 95% confidence level = 114.829

Parameter Estimates

Variable | Estimate | Default initial parameter values
alpha | −13.8218 | −1.41289
rho | 9.65704 | 0
beta_0 | 3.30477 | 3.30246
beta_1 | 0.00187393 | 0.00193902

Table of Data and Estimated Values of Interest

Dose | N | Observed mean | Estimated mean | Observed standard deviation | Estimated standard deviation | Scaled residual
0 | 15 | 3.27 | 3.3 | 0.34 | 0.32 | −0.421
5 | 15 | 3.29 | 3.31 | 0.3 | 0.325 | −0.288
25 | 14 | 3.47 | 3.35 | 0.32 | 0.343 | 1.29
100 | 15 | 3.42 | 3.49 | 0.48 | 0.418 | −0.669
400 | 13 | 4.09 | 4.05 | 0.86 | 0.859 | 0.15

Likelihoods of Interest

Model | Log(likelihood) | No. parameters | AIC
A1 | 17.455074 | 6 | −22.910149
A2 | 29.755425 | 10 | −39.51085
A3 | 28.583571 | 7 | −43.167142
fitted | 28.027315 | 4 | −48.05463
R | 6.041664 | 2 | −8.083328

Tests of Interest

Test | −2 × log(likelihood ratio) | Test df | p-value
Test 1 | 47.4275 | 8 | <0.0001
Test 2 | 24.6007 | 4 | <0.0001
Test 3 | 2.34371 | 3 | 0.5042
Test 4 | 1.11251 | 3 | 0.7741

Table C-5 Summary of benchmark dose (BMD) modeling results for increased absolute kidney weight in female Sprague-Dawley rats exposed to ETBE by daily gavage for 26 weeks (Miyata et al., 2013; JPEC, 2008d); benchmark response (BMR) = 10% relative deviation from the mean

Model^a^ | Goodness of fit | | BMD_10RD_ (mg/kg-d) | BMDL_10RD_ (mg/kg-d) | Basis for model selection
Model^a^ | p-value | AIC | BMD_10RD_ (mg/kg-d) | BMDL_10RD_ (mg/kg-d) | Basis for model selection
Exponential (M2); Exponential (M3)^b^ | 0.369 | −168.25 | 406 | 271 | The Exponential (M4) model was selected based on lowest BMDL.
Exponential (M4) | 0.670 | −168.60 | 224 | 56.9 | The Exponential (M4) model was selected based on lowest BMDL.
Exponential (M5) | 0.865 | −167.37 | Error^c^ | 0 | The Exponential (M4) model was selected based on lowest BMDL.
Hill | 0.986 | −169.37 | Error^c^ | Error^c^ | The Exponential (M4) model was selected based on lowest BMDL.
Power^d^; Polynomial (3 degree)^e^; Polynomial (2 degree)^f^; Linear | 0.382 | −168.34 | 402 | 263 | The Exponential (M4) model was selected based on lowest BMDL.

a Constant variance case presented (BMDS Test 2 p-value = 0.425), selected model in bold; scaled residuals for selected model for doses 0, 5, 25, 100, and 400 mg/kg-d were 0.2257, 0.2206, −0.737, 0.3806, and −0.08999, respectively.

b For the Exponential (M3) model, the estimate of d was 1 (boundary), and the model reduced to the Exponential (M2) model.

c BMD or BMDL computation failed for this model.

d For the Power model, the power parameter estimate was 1, and the model reduced to the Linear model.

e For the Polynomial (3 degree) model, the b3 coefficient estimate was 0 (boundary of parameters space), and the model reduced to the Polynomial (2 degree) model.

f For the Polynomial (2 degree) model, the b2 coefficient estimate was 0 (boundary of parameters space), and the model reduced to the Linear model.

Figure C-4 Plot of mean response by dose, with fitted curve for the Exponential Model 4; dose shown in mg/kg-day

Exponential Model. (Version: 1.9; Date: 01/29/2013)

The form of the response function is: Y[dose] = a × [c − (c − 1) × exp(−b × dose)]

A constant variance model is fit.

Benchmark Dose Computation.

BMR = 10% relative deviation

BMD = 223.57

BMDL at the 95% confidence level = 56.8917

Parameter Estimates

Variable | Estimate | Default initial parameter values
lnalpha | −3.35462 | −3.36529
rho(S) | N/A | 0
a | 1.86911 | 1.786
b | 0.0100557 | 0.00368689
c | 1.11181 | 1.21697
d | 1 | 1

Table of Data and Estimated Values of Interest

Dose | N | Observed mean | Estimated mean | Observed standard deviation | Estimated standard deviation | Scaled residual
0 | 15 | 1.88 | 1.869 | 0.2 | 0.1869 | 0.2257
5 | 15 | 1.89 | 1.879 | 0.16 | 0.1869 | 0.2206
25 | 15 | 1.88 | 1.916 | 0.15 | 0.1869 | −0.737
100 | 15 | 2.02 | 2.002 | 0.21 | 0.1869 | 0.3806
400 | 15 | 2.07 | 2.074 | 0.23 | 0.1869 | −0.08999

Likelihoods of Interest

Model | Log(likelihood) | No. parameters | AIC
A1 | 88.69837 | 6 | −165.3967
A2 | 90.62918 | 10 | −161.2584
A3 | 88.69837 | 6 | −165.3967
R | 82.20147 | 2 | −160.4029
4 | 88.29837 | 4 | −168.5967

Tests of Interest

Test | −2 × log(likelihood ratio) | Test df | p-value
Test 1 | 16.86 | 8 | 0.03165
Test 2 | 3.862 | 4 | 0.4251
Test 3 | 3.862 | 4 | 0.4251
Test 6a | 0.8 | 2 | 0.6703

Table C-6 Summary of benchmark dose (BMD) modeling results for increased absolute kidney weight in P0 male Sprague-Dawley rats exposed to ETBE by daily gavage for a total of 18 weeks beginning 10 weeks before mating until after weaning of the pups (Gaoua, 2004a); benchmark response (BMR) = 10% relative deviation from the mean

Model^a^ | Goodness of fit | | BMD_10RD_ (mg/kg-d) | BMDL_10RD_ (mg/kg-d) | Basis for model selection
Model^a^ | p-value | AIC | BMD_10RD_ (mg/kg-d) | BMDL_10RD_ (mg/kg-d) | Basis for model selection
Exponential (M2); Exponential (M3)^b^ | 0.155 | −38.410 | 551 | 423 | The Hill model is selected based on lowest BMDL.
Exponential (M4)^c^ | 0.727 | −40.012 | 255 | 123 | The Hill model is selected based on lowest BMDL.
Exponential (M5)^c^ | 0.727 | −40.012 | 255 | 123 | The Hill model is selected based on lowest BMDL.
Hill | 0.811 | −40.077 | 244 | 94.0 | The Hill model is selected based on lowest BMDL.
Power^d^; Polynomial (3 degree)^e^; Polynomial (2 degree)^f^; Linear | 0.199 | −38.902 | 517 | 386 | The Hill model is selected based on lowest BMDL.

a Constant variance case presented (BMDS Test 2 p-value = 0.119), selected model in bold; scaled residuals for selected model for doses 0, 250, 500, and 1,000 mg/kg-d were −0.0247, 0.14, −0.181, and 0.0657, respectively.

b For the Exponential (M3) model, the estimate of d was 1 (boundary), and the model reduced to the Exponential (M2) model.

c The Exponential (M4) model and the Exponential (M5) model appear equivalent; however, differences exist in digits not displayed in the table.

d For the Power model, the power parameter estimate was 1, and the model reduced to the Linear model.

e For the Polynomial (3 degree) model, the b3 coefficient estimate was 0 (boundary of parameters space), and the model reduced to the Polynomial (2 degree) model.

f For the Polynomial (2 degree) model, the b2 coefficient estimate was 0 (boundary of parameters space), and the model reduced to the Linear model.

Figure C-5 Plot of mean response by dose, with fitted curve for the Hill Model; dose shown in mg/kg-day

Hill Model. (Version: 2.17; Date: 01/28/2013)

The form of the response function is: Y[dose] = intercept + v × dose^n^/(k^n^ + dose^n^)

A constant variance model is fit.

Benchmark Dose Computation.

BMR = 10% relative deviation

BMD = 243.968

BMDL at the 95% confidence level = 93.9617

Parameter Estimates

Variable | Estimate | Default initial parameter values
alpha | 0.227462 | 0.236804
rho | N/A | 0
intercept | 3.58236 | 3.58
v | 1.16337 | 0.76
n | 1 | 0.647728
k | 548.322 | 250

Table of Data and Estimated Values of Interest

Dose | N | Observed mean | Estimated mean | Observed standard deviation | Estimated standard deviation | Scaled residual
0 | 25 | 3.58 | 3.58 | 0.413 | 0.477 | −0.0247
250 | 25 | 3.96 | 3.95 | 0.446 | 0.477 | 0.14
500 | 25 | 4.12 | 4.14 | 0.624 | 0.477 | −0.181
1,000 | 25 | 4.34 | 4.33 | 0.434 | 0.477 | 0.0657

Likelihoods of Interest

Model | Log(likelihood) | No. parameters | AIC
A1 | 24.067171 | 5 | −38.134342
A2 | 26.992591 | 8 | −37.985183
A3 | 24.067171 | 5 | −38.134342
fitted | 24.038627 | 4 | −40.077253
R | 9.48179 | 2 | −14.963581

Tests of Interest

Test | −2 × log(likelihood ratio) | Test df | p-value
Test 1 | 35.0216 | 6 | <0.0001
Test 2 | 5.85084 | 3 | 0.1191
Test 3 | 5.85084 | 3 | 0.1191
Test 4 | 0.057089 | 1 | 0.8112

Table C-7 Summary of benchmark dose (BMD) modeling results for increased absolute kidney weight in P0 female Sprague-Dawley rats exposed to ETBE by daily gavage for a total of 18 weeks beginning 10 weeks before mating until after weaning of the pups (Gaoua, 2004a); benchmark response (BMR) = 10% relative deviation from the mean

Model^a^ | Goodness of fit | | BMD_10RD_ (mg/kg-d) | BMDL_10RD_ (mg/kg-d) | Basis for model selection
Model^a^ | p-value | AIC | BMD_10RD_ (mg/kg-d) | BMDL_10RD_ (mg/kg-d) | Basis for model selection
Exponential (M2) | 0.625 | −214.58 | 1,734 | 1,030 | Exponential (M2) model is selected based on lowest AIC; however, BMDL is higher than the maximum dose.
Exponential (M3) | 0.416 | −212.86 | 1,458 | 1,040 | Exponential (M2) model is selected based on lowest AIC; however, BMDL is higher than the maximum dose.
Exponential (M4) | 0.327 | −212.56 | 1,774 | 1,032 | Exponential (M2) model is selected based on lowest AIC; however, BMDL is higher than the maximum dose.
Exponential (M5) | N/A^b^ | −211.39 | Error^c^ | 0 | Exponential (M2) model is selected based on lowest AIC; however, BMDL is higher than the maximum dose.
Hill | 0.715 | −213.39 | Error^c^ | Error^c^ | Exponential (M2) model is selected based on lowest AIC; however, BMDL is higher than the maximum dose.
Power | 0.418 | −212.87 | 1,470 | 1,041 | Exponential (M2) model is selected based on lowest AIC; however, BMDL is higher than the maximum dose.
Polynomial (3 degree) | 0.400 | −212.81 | 1,409 | 1,035 | Exponential (M2) model is selected based on lowest AIC; however, BMDL is higher than the maximum dose.
Polynomial (2 degree) | 0.400 | −212.81 | 1,409 | 1,037 | Exponential (M2) model is selected based on lowest AIC; however, BMDL is higher than the maximum dose.
Linear | 0.619 | −214.56 | 1,774 | 1,032 | Exponential (M2) model is selected based on lowest AIC; however, BMDL is higher than the maximum dose.

a Constant variance case presented (BMDS Test 2 p-value = 0.391), selected model in bold; scaled residuals for selected model for doses 0, 250, 500, and 1,000 mg/kg-d were 0.5052, −0.7974, 0.1844, and 0.1033, respectively.

b No available degrees of freedom to calculate a goodness-of-fit value.

c BMD or BMDL computation failed for this model.

Figure C-6 Plot of mean response by dose, with fitted curve for the Exponential Model 2; dose shown in mg/kg-day

Exponential Model. (Version: 1.9; Date: 01/29/2013)

The form of the response function is: Y[dose] = a × exp(sign × b × dose)

A constant variance model is fit

Benchmark Dose Computation.

BMR = 10% relative deviation

BMD = 1,734.24

BMDL at the 95% confidence level = 1,030.08

Parameter Estimates

Variable | Estimate | Default initial parameter values
lnalpha | −3.29773 | −3.30752
rho(S) | N/A | 0
a | 2.22057 | 2.22078
b | 0.0000549578 | 0.0000546688
c | 0 | 0
d | 1 | 1

Table of Data and Estimated Values of Interest

Dose | N | Observed mean | Estimated mean | Observed standard deviation | Estimated standard deviation | Scaled residual
0 | 25 | 2.24 | 2.221 | 0.185 | 0.1923 | 0.5052
250 | 24 | 2.22 | 2.251 | 0.16 | 0.1923 | −0.7974
500 | 22 | 2.29 | 2.282 | 0.207 | 0.1923 | 0.1844
1,000 | 25 | 2.35 | 2.346 | 0.224 | 0.1923 | 0.1033

Likelihoods of Interest

Model | Log(likelihood) | No. parameters | AIC
A1 | 110.761 | 5 | −211.522
A2 | 112.2635 | 8 | −208.5269
A3 | 110.761 | 5 | −211.522
R | 107.4777 | 2 | −210.9553
2 | 110.2909 | 3 | −214.5817

Tests of Interest

Test | −2 × log(likelihood ratio) | Test df | p-value
Test 1 | 9.572 | 6 | 0.1439
Test 2 | 3.005 | 3 | 0.3909
Test 3 | 3.005 | 3 | 0.3909
Test 4 | 0.9403 | 2 | 0.6249

Table C-8 Summary of benchmark dose (BMD) modeling results for absolute kidney weight in F1 male Sprague-Dawley rats exposed to ETBE by gavage in a two-generation study (Gaoua, 2004b); benchmark response (BMR) = 10% relative deviation from the mean

Model^a^ | Goodness of fit | | BMD_10RD_ (mg/kg-d) | BMDL_10RD_ (mg/kg-d) | Basis for model selection
Model^a^ | p-value | AIC | BMD_10RD_ (mg/kg-d) | BMDL_10RD_ (mg/kg-d) | Basis for model selection
Exponential (M2) | 6.30 × 10^−4^ | 89.912 | 232 | 175 | Of the models that provided an adequate fit and a valid BMDL estimate, the Polynomial (3 degree) model was selected based on lowest AIC.
Exponential (M3) | 0.129 | 79.474 | 335 | 256 | Of the models that provided an adequate fit and a valid BMDL estimate, the Polynomial (3 degree) model was selected based on lowest AIC.
Exponential (M4) | <0.0001 | 98.039 | 263 | 179 | Of the models that provided an adequate fit and a valid BMDL estimate, the Polynomial (3 degree) model was selected based on lowest AIC.
Exponential (M5) | N/A^b^ | 82.504 | 347 | 267 | Of the models that provided an adequate fit and a valid BMDL estimate, the Polynomial (3 degree) model was selected based on lowest AIC.
Hill | N/A^b^ | 82.509 | 347 | 267 | Of the models that provided an adequate fit and a valid BMDL estimate, the Polynomial (3 degree) model was selected based on lowest AIC.
Power | 0.0680 | 80.504 | 347 | 267 | Of the models that provided an adequate fit and a valid BMDL estimate, the Polynomial (3 degree) model was selected based on lowest AIC.
Polynomial (3 degree) | 0.374 | 77.965 | 318 | 235 | Of the models that provided an adequate fit and a valid BMDL estimate, the Polynomial (3 degree) model was selected based on lowest AIC.
Polynomial (2 degree) | 0.0943 | 79.973 | 330 | 251 | Of the models that provided an adequate fit and a valid BMDL estimate, the Polynomial (3 degree) model was selected based on lowest AIC.
Linear | <0.0001 | 96.039 | 263 | 179 | Of the models that provided an adequate fit and a valid BMDL estimate, the Polynomial (3 degree) model was selected based on lowest AIC.

a Modeled variance case presented (BMDS Test 3 p-value = <0), selected model in bold; scaled residuals for selected model for doses 0, 250, 500, and 1,000 mg/kg-d were −0.584, 0.717, 0.225, and −0.837, respectively.

b No available degrees of freedom to calculate a goodness-of-fit value.

Figure C-7 Plot of mean response by dose, with fitted curve for the Polynomial Model; dose shown in mg/kg-day

Polynomial Model. (Version: 2.19; Date: 06/25/2014)

The form of the response function is: Y[dose] = beta_0 + beta_1 × dose + beta_2 × dose^2^ + …

A modeled variance is fit.

Benchmark Dose Computation.

BMR = 10% relative deviation

BMD = 318.084

BMDL at the 95% confidence level = 235.491

Parameter Estimates

Variable | Estimate | Default initial parameter values
lnalpha | −13.8779 | 2.02785
rho | 9.40248 | 0
beta_0 | 3.41732 | 3.38
beta_1 | 0.000881597 | 0.00138667
beta_2 | 2.232 × 10^−28^ | 0
beta_3 | 1.90507 × 10^−9^ | 6.93333 × 10^−9^

Table of Data and Estimated Values of Interest

Dose | N | Observed mean | Estimated mean | Observed standard deviation | Estimated standard deviation | Scaled residual
0 | 24 | 3.38 | 3.42 | 0.341 | 0.313 | −0.584
250 | 25 | 3.73 | 3.67 | 0.449 | 0.436 | 0.717
500 | 24 | 4.13 | 4.1 | 0.64 | 0.734 | 0.225
1,000 | 25 | 5.34 | 6.2 | 5.39 | 5.16 | −0.837

Likelihoods of Interest

Model | Log(likelihood) | No. parameters | AIC
A1 | −146.32249 | 5 | 302.644981
A2 | −32.521507 | 8 | 81.043013
A3 | −33.58656 | 6 | 79.17312
Fitted | −33.982384 | 5 | 77.964768
R | −149.897277 | 2 | 303.794554

Tests of Interest

Test | −2 × log(likelihood ratio) | Test df | p-value
Test 1 | 234.752 | 6 | <0.0001
Test 2 | 227.602 | 3 | <0.0001
Test 3 | 2.13011 | 2 | 0.3447
Test 4 | 0.791648 | 1 | 0.3736

Table C-9 Summary of benchmark dose (BMD) modeling results for absolute kidney weight in F1 female Sprague-Dawley rats exposed to ETBE by gavage in a two-generation study (Gaoua, 2004b); benchmark response (BMR) = 10% relative deviation

Model^a^ | Goodness of fit | | BMD_10RD_ (mg/kg-d) | BMDL_10RD_ (mg/kg-d) | Basis for model selection
Model^a^ | p-value | AIC | BMD_10RD_ (mg/kg-d) | BMDL_10RD_ (mg/kg-d) | Basis for model selection
Exponential (M2) | 0.311 | −180.23 | 978 | 670 | Of the models that provided an adequate fit and a valid BMDL estimate, the Exponential (M2) model was selected based on lowest AIC.
Exponential (M3) | 0.147 | −178.46 | 1,016 | 679 | Of the models that provided an adequate fit and a valid BMDL estimate, the Exponential (M2) model was selected based on lowest AIC.
Exponential (M4) | 0.121 | −178.16 | 980 | 654 | Of the models that provided an adequate fit and a valid BMDL estimate, the Exponential (M2) model was selected based on lowest AIC.
Exponential (M5) | N/A^b^ | −176.44 | 1,019 | 613 | Of the models that provided an adequate fit and a valid BMDL estimate, the Exponential (M2) model was selected based on lowest AIC.
Hill | N/A^b^ | −176.44 | 1,019 | 611 | Of the models that provided an adequate fit and a valid BMDL estimate, the Exponential (M2) model was selected based on lowest AIC.
Power | 0.145 | −178.44 | 1,019 | 666 | Of the models that provided an adequate fit and a valid BMDL estimate, the Exponential (M2) model was selected based on lowest AIC.
Polynomial (3 degree) | 0.184 | −178.80 | 1,001 | 684 | Of the models that provided an adequate fit and a valid BMDL estimate, the Exponential (M2) model was selected based on lowest AIC.
Polynomial (2 degree) | 0.159 | −178.58 | 1,002 | 673 | Of the models that provided an adequate fit and a valid BMDL estimate, the Exponential (M2) model was selected based on lowest AIC.
Linear | 0.301 | −180.16 | 980 | 654 | Of the models that provided an adequate fit and a valid BMDL estimate, the Exponential (M2) model was selected based on lowest AIC.

a Constant variance case presented (BMDS Test 2 p-value = 0.159), selected model in bold; scaled residuals for selected model for doses 0, 250, 500, and 1,000 mg/kg-d were −0.05426, 0.8898, −1.173, and 0.3711, respectively.

b No available degrees of freedom to calculate a goodness-of-fit value.

Figure C-8 Plot of mean response by dose, with fitted curve for the Exponential Model 2; dose shown in mg/kg-day

Exponential Model. (Version: 1.9; Date: 01/29/2013)

The form of the response function is: Y[dose] = a × exp(sign × b × dose)

A constant variance model is fit.

Benchmark Dose Computation.

BMR = 10% relative deviation

BMD = 978.157

BMDL at the 95% confidence level = 669.643

Parameter Estimates

Variable | Estimate | Default initial parameter values
lnalpha | −2.91989 | −2.94397
rho(S) | N/A | 0
a | 2.24252 | 2.24321
b | 0.0000974385 | 0.000096475
c | 0 | 0
d | 1 | 1

Table of Data and Estimated Values of Interest

Dose | N | Observed mean | Estimated mean | Observed standard deviation | Estimated standard deviation | Scaled residual
0 | 25 | 2.24 | 2.243 | 0.178 | 0.2322 | −0.05426
250 | 24 | 2.34 | 2.298 | 0.242 | 0.2322 | 0.8898
500 | 25 | 2.3 | 2.354 | 0.226 | 0.2322 | −1.173
1,000 | 23 | 2.49 | 2.472 | 0.284 | 0.2322 | 0.3711

Likelihoods of Interest

Model | Log(likelihood) | No. parameters | AIC
A1 | 94.28268 | 5 | −178.5654
A2 | 96.87585 | 8 | −177.7517
A3 | 94.28268 | 5 | −178.5654
R | 87.16418 | 2 | −170.3284
2 | 93.11474 | 3 | −180.2295

Tests of Interest

Test | −2 × log(likelihood ratio) | Test df | p-value
Test 1 | 19.42 | 6 | 0.003505
Test 2 | 5.186 | 3 | 0.1587
Test 3 | 5.186 | 3 | 0.1587
Test 4 | 2.336 | 2 | 0.311

Table C-10 Summary of benchmark dose (BMD) modeling results for increased absolute kidney weight in P0 male Sprague-Dawley rats exposed to ETBE by daily gavage for 16 weeks beginning 10 weeks prior to mating (Fujii et al., 2010); benchmark response (BMR) = 10% relative deviation from the mean

Model^a^ | Goodness of fit | | BMD_10RD_ (mg/kg-d) | BMDL_10RD_ (mg/kg-d) | Basis for model selection
Model^a^ | p-value | AIC | BMD_10RD_ (mg/kg-d) | BMDL_10RD_ (mg/kg-d) | Basis for model selection
Exponential (M2); Exponential (M3)^b^ | 0.668 | −41.247 | 648 | 479 | The Hill model was selected based on lowest BMDL. (BMDLs were greater than threefold difference.)
Exponential (M4); Exponential (M5)^c^ | 0.600 | −39.779 | 438 | 163 | The Hill model was selected based on lowest BMDL. (BMDLs were greater than threefold difference.)
Hill | 0.613 | −39.799 | 435 | 139 | The Hill model was selected based on lowest BMDL. (BMDLs were greater than threefold difference.)
Power^d^; Polynomial (3 degree)^e^; Polynomial (2 degree)^f^; Linear | 0.700 | −41.342 | 625 | 448 | The Hill model was selected based on lowest BMDL. (BMDLs were greater than threefold difference.)

a Constant variance case presented (BMDS Test 2 p-value = 0.102), selected model in bold; scaled residuals for selected model for doses 0, 100, 300, and 1,000 mg/kg-d were −0.202, 0.399, −0.232, and 0.0344, respectively.

b For the Exponential (M3) model, the estimate of d was 1 (boundary), and the model reduced to the Exponential (M2) model.

c For the Exponential (M5) model, the estimate of d was 1 (boundary), and the model reduced to the Exponential (M4) model.

d For the Power model, the power parameter estimate was 1, and the model reduced to the Linear model.

e For the Polynomial (3 degree) model, the b3 coefficient estimate was 0 (boundary of parameters space), and the model reduced to the Polynomial (2 degree) model. For the Polynomial (3 degree) model, the b3 and b2 coefficient estimates were 0 (boundary of parameters space), and the model reduced to the Linear model.

f For the Polynomial (2 degree) model, the b2 coefficient estimate was 0 (boundary of parameters space), and the model reduced to the Linear model.

Figure C-9 Plot of mean response by dose, with fitted curve for the Hill Model; dose shown in mg/kg-day

Hill Model. (Version: 2.17; Date: 01/28/2013)

The form of the response function is: Y[dose] = intercept + v × dose^n^/(k^n^ + dose^n^)

A constant variance model is fit.

Benchmark Dose Computation.

BMR = 10% relative deviation

BMD = 434.715

BMDL at the 95% confidence level = 139.178

Parameter Estimates

Variable | Estimate | Default initial parameter values
alpha | 0.223598 | 0.2327
rho | N/A | 0
intercept | 3.47949 | 3.46
v | 1.24601 | 0.61
n | 1 | 0.27452
k | 1,122 | 1,610

Table of Data and Estimated Values of Interest

Dose | N | Observed mean | Estimated mean | Observed standard deviation | Estimated standard deviation | Scaled residual
0 | 24 | 3.46 | 3.48 | 0.57 | 0.473 | −0.202
100 | 24 | 3.62 | 3.58 | 0.45 | 0.473 | 0.399
300 | 24 | 3.72 | 3.74 | 0.35 | 0.473 | −0.232
1,000 | 24 | 4.07 | 4.07 | 0.53 | 0.473 | 0.0344

Likelihoods of Interest

Model | Log(likelihood) | No. parameters | AIC
A1 | 24.027112 | 5 | −38.054223
A2 | 27.13071 | 8 | −38.26142
A3 | 24.027112 | 5 | −38.054223
Fitted | 23.899392 | 4 | −39.798783
R | 14.313578 | 2 | −24.627156

Tests of Interest

Test | −2 × log(likelihood ratio) | Test df | p-value
Test 1 | 25.6343 | 6 | 0.0002604
Test 2 | 6.2072 | 3 | 0.102
Test 3 | 6.2072 | 3 | 0.102
Test 4 | 0.25544 | 1 | 0.6133

Table C-11 Summary of benchmark dose (BMD) modeling results for increased absolute kidney weight in P0 female Sprague-Dawley rats exposed to ETBE by daily gavage for 17 weeks beginning 10 weeks prior to mating until Lactation Day 21 (Fujii et al., 2010); benchmark response (BMR) = 10% relative deviation from the mean

Model^a^ | Goodness of fit | | BMD_10RD_ (mg/kg-d) | BMDL_10RD_ (mg/kg-d) | Basis for model selection
Model^a^ | p-value | AIC | BMD_10RD_ (mg/kg-d) | BMDL_10RD_ (mg/kg-d) | Basis for model selection
Exponential (M2) | 0.483 | −199.73 | 1,135 | 781 | Polynomial (2 degree) is selected based on most parsimonious model with lowest AIC.
Exponential (M3) | 0.441 | −198.60 | 1,089 | 826 | Polynomial (2 degree) is selected based on most parsimonious model with lowest AIC.
Exponential (M4) | 0.217 | −197.67 | 1,144 | 771 | Polynomial (2 degree) is selected based on most parsimonious model with lowest AIC.
Exponential (M5) | N/A^b^ | −196.66 | Error^c^ | 0 | Polynomial (2 degree) is selected based on most parsimonious model with lowest AIC.
Hill | N/A^b^ | −196.66 | Error^c^ | Error^c^ | Polynomial (2 degree) is selected based on most parsimonious model with lowest AIC.
Power | 0.441 | −198.60 | 1,092 | 823 | Polynomial (2 degree) is selected based on most parsimonious model with lowest AIC.
Polynomial (3 degree)^d^; Polynomial (2 degree) | 0.743 | −200.60 | 1,094 | 905 | Polynomial (2 degree) is selected based on most parsimonious model with lowest AIC.
Linear | 0.467 | −199.67 | 1,144 | 771 | Polynomial (2 degree) is selected based on most parsimonious model with lowest AIC.

a Constant variance case presented (BMDS Test 2 p-value = 0.103), selected model in bold; scaled residuals for selected model for doses 0, 100, 300, and 1,000 mg/kg-d were 0.499, −0.579, 0.0914, and −0.00282, respectively.

b No available degrees of freedom to calculate a goodness-of-fit value.

c BMD or BMDL computation failed for this model.

d For the Polynomial (3 degree) model, the b3 coefficient estimate was 0 (boundary of parameters space), and the model reduced to the Polynomial (2 degree) model.

Figure C-10 Plot of mean response by dose, with fitted curve for the Polynomial Model; dose shown in mg/kg-day

Polynomial Model. (Version: 2.17; Date: 01/28/2013)

The form of the response function is: Y[dose] = beta_0 + beta_1 × dose + beta_2 × dose^2^ + …

A constant variance model is fit.

Benchmark Dose Computation.

BMR = 10% relative deviation

BMD = 1,093.86

BMDL at the 95% confidence level = 905.267

Parameter Estimates

Variable | Estimate | Default initial parameter values
alpha | 0.0323691 | 0.0337309
rho | N/A | 0
beta_0 | 2.1504 | 2.15624
beta_1 | 7.16226 × 10^−28^ | 0
beta_2 | 1.79719 × 10^−6^ | 0

Table of Data and Estimated Values of Interest

Dose | N | Observed mean | Estimated mean | Observed standard deviation | Estimated standard deviation | Scaled residual
0 | 21 | 2.17 | 2.15 | 0.18 | 0.18 | 0.499
100 | 22 | 2.13 | 2.15 | 0.14 | 0.18 | −0.579
300 | 23 | 2.17 | 2.17 | 0.17 | 0.18 | 0.0914
1,000 | 19 | 2.33 | 2.33 | 0.24 | 0.18 | −0.00282

Likelihoods of Interest

Model | Log(likelihood) | No. parameters | AIC
A1 | 103.595625 | 5 | −197.191249
A2 | 106.684319 | 8 | −197.368637
A3 | 103.595625 | 5 | −197.191249
fitted | 103.298361 | 3 | −200.596722
R | 96.89324 | 2 | −189.78648

Tests of Interest

Test | −2 × log(likelihood ratio) | Test df | p-value
Test 1 | 19.5822 | 6 | 0.003286
Test 2 | 6.17739 | 3 | 0.1033
Test 3 | 6.17739 | 3 | 0.1033
Test 4 | 0.594528 | 2 | 0.7428

##### Inhalation exposure endpoints

Table C-12 Summary of benchmark concentration (BMC) modeling results for urothelial hyperplasia of the renal pelvis in male F344 rats exposed to ETBE by whole-body inhalation for 6 hours/day, 5 days/week, for 104 weeks (JPEC, 2010b); benchmark response (BMR) = 10% extra risk

Model^a^ | Goodness of fit | | BMC_10_ (mg/m^3^) | BMCL_10_ (mg/m^3^) | Basis for model selection
Model^a^ | p-value | AIC | BMC_10_ (mg/m^3^) | BMCL_10_ (mg/m^3^) | Basis for model selection
Gamma | 0.874 | 164.37 | 2,734 | 1,498 | Of the models that provided an adequate fit and a valid BMCL estimate, the Gamma model was selected based on lowest AIC.
Logistic | 0.146 | 166.30 | 4,329 | 3,522 | Of the models that provided an adequate fit and a valid BMCL estimate, the Gamma model was selected based on lowest AIC.
Log-Logistic | 0.814 | 164.40 | 3,010 | 1,831 | Of the models that provided an adequate fit and a valid BMCL estimate, the Gamma model was selected based on lowest AIC.
Probit | 0.202 | 165.59 | 4,059 | 3,365 | Of the models that provided an adequate fit and a valid BMCL estimate, the Gamma model was selected based on lowest AIC.
Log-Probit | 0.633 | 164.57 | 3,050 | 1,896 | Of the models that provided an adequate fit and a valid BMCL estimate, the Gamma model was selected based on lowest AIC.
Weibull | 0.758 | 164.44 | 2,623 | 1,478 | Of the models that provided an adequate fit and a valid BMCL estimate, the Gamma model was selected based on lowest AIC.
Multistage (3 degree) | 0.565 | 164.69 | 2,386 | 1,412 | Of the models that provided an adequate fit and a valid BMCL estimate, the Gamma model was selected based on lowest AIC.
Multistage (2 degree) | 0.565 | 164.69 | 2,386 | 1,422 | Of the models that provided an adequate fit and a valid BMCL estimate, the Gamma model was selected based on lowest AIC.
Quantal-Linear | 0.269 | 165.16 | 1,541 | 1,227 | Of the models that provided an adequate fit and a valid BMCL estimate, the Gamma model was selected based on lowest AIC.

BMC = benchmark concentration; BMCL = benchmark concentration lower confidence level.

a Selected model in bold; scaled residuals for selected model for concentrations 0, 2,089, 6,268, and 20,893 mg/m^3^ were 0.036, −0.107, 0.104, and −0.040, respectively. Exposure concentrations were converted from 0, 500, 1,500, and 5,000 ppm to mg/m^3^ using the calculation mg/m^3^ = (102.17, molecular weight of ETBE) × ppm ÷ 24.45.

Figure C-11 Plot of incidence rate by concentration, with fitted curve for the Gamma Model; concentration shown in mg/m^3^

Gamma Model. (Version: 2.16; Date: 2/28/2013)

The form of the probability function is:

P[response] = background + (1 − background) × CumGamma[slope × concentration,power], where CumGamma(.) is the cumulative Gamma distribution function.

Power parameter is restricted as power ≥1.

Benchmark Concentration Computation.

BMR = 10% extra risk

BMC = 2,734.41

BMCL at the 95% confidence level = 1,497.7

Parameter Estimates

Variable | Estimate | Default initial parameter values
Background | 0.0390054 | 0.0576923
Slope | 0.000121504 | 0.000132454
Power | 1.59019 | 1.84876

Analysis of Deviance Table

Model | Log(likelihood) | No. parameters | Deviance | Test df | p-value
Full model | −79.1741 | 4
Fitted model | −79.1867 | 3 | 0.0253512 | 1 | 0.8735
Reduced model | −124.987 | 1 | 91.626 | 3 | <0.0001

AIC = 164.373

Goodness-of-Fit Table

Concentration | Estimated probability | Expected | Observed | Size | Scaled residual
0 | 0.039 | 1.95 | 2 | 50 | 0.036
2,089 | 0.1046 | 5.231 | 5 | 50 | −0.107
6,268 | 0.3196 | 15.659 | 16 | 49 | 0.104
20,893 | 0.8222 | 41.109 | 41 | 50 | −0.04

χ^2^ = 0.03; df = 1; p-value = 0.8737

Table C-13 Summary of benchmark concentration (BMC) modeling results for increased absolute kidney weight in female F344 rats exposed to ETBE by whole-body inhalation for 6 hours/day, 5 days/week, for 104 weeks (JPEC, 2010b), benchmark response (BMR) = 10% relative deviation from the mean

Model^a^ | Goodness of fit | | BMC_10RD_ (mg/m^3^) | BMCL_10RD_ (mg/m^3^) | Basis for model selection
Model^a^ | p-value | AIC | BMC_10RD_ (mg/m^3^) | BMCL_10RD_ (mg/m^3^) | Basis for model selection
Exponential (M2); Exponential (M3) ^b^ | 0.1482 | −293.77 | 13,422.9 | 10,431.3 | Of the models that provided an adequate fit and a valid BMCL estimate, the Exponential (M2) model was selected based on lowest AIC.
Exponential (M4) | 0.04944 | −291.73 | 13,028.1 | 7,023.54 | Of the models that provided an adequate fit and a valid BMCL estimate, the Exponential (M2) model was selected based on lowest AIC.
Exponential (M5) | 0.04944 | −291.73 | 13,027.3 | 7,023.54 | Of the models that provided an adequate fit and a valid BMCL estimate, the Exponential (M2) model was selected based on lowest AIC.
Hill | 0.04939 | −291.73 | 13,027.3 | 9,893.86 | Of the models that provided an adequate fit and a valid BMCL estimate, the Exponential (M2) model was selected based on lowest AIC.
Polynomial (2 degree)^c^ | 0.05124 | −291.79 | 13,959.9 | 9,936.46 | Of the models that provided an adequate fit and a valid BMCL estimate, the Exponential (M2) model was selected based on lowest AIC.
Polynomial (3 degree)^d^ | 0.05454 | −291.89 | 14,857.4 | 9,985.31 | Of the models that provided an adequate fit and a valid BMCL estimate, the Exponential (M2) model was selected based on lowest AIC.
Power^e^; Linear | 0.1451 | −293.73 | 13,029.1 | 9,909.08 | Of the models that provided an adequate fit and a valid BMCL estimate, the Exponential (M2) model was selected based on lowest AIC.

BMC = benchmark concentration; BMCL = benchmark concentration lower confidence level.

a Selected model in bold; modeled variance case presented. For this data set variance was modeled as a power function of the mean, but the p-value (BMDS Test 3 p-value = <0.018) was below the threshold criterion for variance testing of 0.1.

b For the Exponential (M3) model, the estimate of d was 1 (boundary), and the model reduced to the Exponential (M2) model.

c For the Polynomial (2 degree) model, the b2 coefficient estimate was 0 (boundary of parameters space), and the model reduced to the Linear model.

d For the Polynomial (3 degree) model, the b3 and b2 coefficient estimates were 0 (boundary), and the model reduced to the Linear model.

e For the Power model, the power parameter estimate was 1, and the model reduced to the Linear model.

Table C-14 Summary of benchmark concentration (BMC) modeling results for increased absolute kidney weight in male Sprague-Dawley rats exposed to ETBE by whole-body inhalation for 6 hours/day, 5 days/week for 13 weeks (JPEC, 2008b); benchmark response (BMR) = 10% relative deviation from the mean

Model^a^ | Goodness of fit | | BMC_10RD_ (ppm) | BMCL_10RD_ (ppm) | Basis for model selection
Model^a^ | p-value | AIC | BMC_10RD_ (ppm) | BMCL_10RD_ (ppm) | Basis for model selection
Exponential (M2); Exponential (M3)^b^ | 0.168 | −43.014 | 1,105 | 750 | Of the models that provided an adequate fit and a valid BMCL estimate, the Hill model was selected based on lowest BMCL; (BMCLs differed by more than 3).
Exponential (M4) | 0.200 | −42.943 | 380 | 1.73 | Of the models that provided an adequate fit and a valid BMCL estimate, the Hill model was selected based on lowest BMCL; (BMCLs differed by more than 3).
Exponential (M5) | 0.200 | −42.943 | 380 | 2.61 | Of the models that provided an adequate fit and a valid BMCL estimate, the Hill model was selected based on lowest BMCL; (BMCLs differed by more than 3).
Hill | 0.294 | −43.484 | 264 | 15.4 | Of the models that provided an adequate fit and a valid BMCL estimate, the Hill model was selected based on lowest BMCL; (BMCLs differed by more than 3).
Power^c^; Polynomial (3 degree)^d^; Polynomial (2 degree)^e^; Linear | 0.178 | −43.133 | 1,071 | 703 | Of the models that provided an adequate fit and a valid BMCL estimate, the Hill model was selected based on lowest BMCL; (BMCLs differed by more than 3).

ppm = 4.18 mg/m^3^

BMC = benchmark concentration; BMCL = benchmark concentration lower confidence level.

a Constant variance case presented (BMDS Test 2 p-value = 0.506), selected model in bold; scaled residuals for selected model for concentrations 0, 150, 500, and 1,500 ppm were −0.13, 0.54, −0.8, 0.38, respectively.

b For the Exponential (M3) model, the estimate of d was 1 (boundary), and the model reduced to the Exponential (M2) model.

c For the Power model, the power parameter estimate was 1, and the model reduced to the Linear model.

d For the Polynomial (3 degree) model, the b3 coefficient estimate was 0 (boundary of parameters space), and the model reduced to the Polynomial (2 degree) model. For the Polynomial (3 degree) model, the b3 and b2 coefficient estimates were 0 (boundary of parameters space), and the model reduced to the Linear model.

e For the Polynomial (2 degree) model, the b2 coefficient estimate was 0 (boundary of parameters space), and the model reduced to the Linear model.

Figure C-12 Plot of mean response by concentration, with fitted curve for the Hill Model; concentration shown in ppm

Hill Model. (Version: 2.17; Date: 01/28/2013)

The form of the response function is:

Y[concentration] = intercept + v × concentration^n^/(k^n^ + concentration^n^)

A constant variance model is fit.

Benchmark Concentration Computation.

BMR = 10% relative deviation

BMC = 264.371

BMCL at the 95% confidence level = 15.4115

Parameter Estimates

Variable | Estimate | Default initial parameter values
alpha | 0.101559 | 0.109774
rho | N/A | 0
intercept | 3.16295 | 3.15
v | 0.600878 | 0.57
n | 1 | 0.169179
k | 237.864 | 157.5

Table of Data and Estimated Values of Interest

Concentration | N | Observed mean | Estimated mean | Observed standard deviation | Estimated standard deviation | Scaled residual
0 | 10 | 3.15 | 3.16 | 0.24 | 0.32 | −0.129
150 | 10 | 3.45 | 3.4 | 0.38 | 0.32 | 0.542
500 | 10 | 3.49 | 3.57 | 0.31 | 0.32 | −0.795
1,500 | 10 | 3.72 | 3.68 | 0.36 | 0.32 | 0.381

Likelihoods of Interest

Model | Log(likelihood) | No. parameters | AIC
A1 | 26.293887 | 5 | −42.587775
A2 | 27.46147 | 8 | −38.922941
A3 | 26.293887 | 5 | −42.587775
Fitted | 25.742228 | 4 | −43.484456
R | 19.334386 | 2 | −34.668772

Tests of Interest

Test | −2 × log(likelihood ratio) | Test df | p-value
Test 1 | 16.2542 | 6 | 0.01245
Test 2 | 2.33517 | 3 | 0.5058
Test 3 | 2.33517 | 3 | 0.5058
Test 4 | 1.10332 | 1 | 0.2935

Table C-15 Summary of benchmark concentration (BMC) modeling results for increased absolute kidney weight in female Sprague-Dawley rats exposed to ETBE by whole-body inhalation for 6 hours/day, 5 days/week for 13 weeks (JPEC, 2008b); benchmark response (BMR) = 10% relative deviation from the mean

Model^a^ | Goodness of fit | | BMC_10RD_ (ppm) | BMCL_10RD_ (ppm) | Basis for model selection
Model^a^ | p-value | AIC | BMC_10RD_ (ppm) | BMCL_10RD_ (ppm) | Basis for model selection
Exponential (M2); Exponential (M3)^b^ | 0.8 | −135.38 | 6,790 | 4,046 | The Linear model is selected based on lowest AIC; however, the BMC is higher than the maximum concentration.
Exponential (M4) | 0.731 | −133.76 | Error^c^ | 0 | The Linear model is selected based on lowest AIC; however, the BMC is higher than the maximum concentration.
Exponential (M5) | 0.760 | −132.29 | Error^c^ | 0 | The Linear model is selected based on lowest AIC; however, the BMC is higher than the maximum concentration.
Hill | 0.760 | −132.29 | Error^c^ | Error^c^ | The Linear model is selected based on lowest AIC; however, the BMC is higher than the maximum concentration.
Power^d^; Polynomial (3 degree)^e^; Polynomial (2 degree)^f^; Linear | 0.806 | −135.40 | 6,840 | 3,978 | The Linear model is selected based on lowest AIC; however, the BMC is higher than the maximum concentration.

ppm = 4.18 mg/m^3^

BMC = benchmark concentration; BMCL = benchmark concentration lower confidence level.

a Constant variance case presented (BMDS Test 2 p-value = 0.623), selected model in bold; scaled residuals for selected model for concentrations 0, 150, 500, 1,500, and 5,000 ppm were −0.0742, 0.0535, −0.578, 0.774, and −0.176, respectively.

b For the Exponential (M3) model, the estimate of d was 1 (boundary), and the model reduced to the Exponential (M2) model.

c BMC or BMCL computation failed for this model.

d For the Power model, the power parameter estimate was 1, and the model reduced to the Linear model.

e For the Polynomial (3 degree) model, the b3 coefficient estimate was 0 (boundary of parameters space), and the model reduced to the Polynomial (2 degree) model.

f For the Polynomial (2 degree) model, the b2 coefficient estimate was 0 (boundary of parameters space), and the model reduced to the Linear model.

Figure C-13 Plot of mean response by concentration, with fitted curve for the Linear Model; concentration shown in ppm

Polynomial Model. (Version: 2.17; Date: 01/28/2013)

The form of the response function is: Y[concentration] = beta_0 + beta_1 × concentration

A constant variance model is fit.

Benchmark Concentration Computation.

BMR = 10% relative deviation

BMC = 6,840.02

BMCL at the 95% confidence level = 3,978.09

Parameter Estimates

Variable | Estimate | Default initial parameter values
alpha | 0.021752 | 0.0236988
rho | N/A | 0
beta_0 | 1.84346 | 1.84346
beta_1 | 0.0000269511 | 0.0000269511

Table of Data and Estimated Values of Interest

Concentration | N | Observed mean | Estimated mean | Observed standard deviation | Estimated standard deviation | Scaled residual
0 | 10 | 1.84 | 1.84 | 0.129 | 0.147 | −0.0742
150 | 10 | 1.85 | 1.85 | 0.18 | 0.147 | 0.0535
500 | 10 | 1.83 | 1.86 | 0.118 | 0.147 | −0.578
1,500 | 10 | 1.92 | 1.88 | 0.173 | 0.147 | 0.774
5,000 | 10 | 1.97 | 1.98 | 0.16 | 0.147 | −0.176

Likelihoods of Interest

Model | Log(likelihood) | No. parameters | AIC
A1 | 71.192285 | 6 | −130.384569
A2 | 72.502584 | 10 | −125.005168
A3 | 71.192285 | 6 | −130.384569
Fitted | 70.701239 | 3 | −135.402478
R | 67.96809 | 2 | −131.93618

Tests of Interest

Test | −2 × log(likelihood ratio) | Test df | p-value
Test 1 | 9.06899 | 8 | 0.3365
Test 2 | 2.6206 | 4 | 0.6232
Test 3 | 2.6206 | 4 | 0.6232
Test 4 | 0.982091 | 3 | 0.8056

Table C-16 Summary of benchmark concentration (BMC) modeling results for increased absolute kidney weight in male F344 rats exposed to ETBE by whole-body inhalation for 6 hours/day, 5 days/week, for 13 weeks (Medinsky et al., 1999; US EPA, 1997); benchmark response (BMR) = 10% relative deviation from the mean

Model^a^ | Goodness of fit | | BMC_10RD_ (ppm) | BMCL_10RD_ (ppm) | Basis for model selection
Model^a^ | p-value | AIC | BMC_10RD_ (ppm) | BMCL_10RD_ (ppm) | Basis for model selection
Exponential (M2); Exponential (M3)^b^ | 0.184 | −129.97 | 3,107 | 2,439 | The Hill model was selected based on lowest BMCL.
Exponential (M4); Exponential (M5)^c^ | 0.199 | −129.71 | 1,798 | 808 | The Hill model was selected based on lowest BMCL.
Hill | 0.224 | −129.89 | 1,667 | 603 | The Hill model was selected based on lowest BMCL.
Power^d^ Polynomial (3 degree)^e^; Polynomial (2 degree)^f^; Linear | 0.208 | −130.22 | 2,980 | 2,288 | The Hill model was selected based on lowest BMCL.

ppm = 4.18 mg/m^3^

BMC = benchmark concentration; BMCL = benchmark concentration lower confidence level.

a Constant variance case presented (BMDS Test 2 p-value = 0.540), selected model in bold; scaled residuals for selected model for concentrations0, 500, 1,750, and 5,000 ppm were −0.441, 0.91, −0.635, and 0.166, respectively.

b For the Exponential (M3) model, the estimate of d was 1 (boundary), and the model reduced to the Exponential (M2) model.

c For the Exponential (M5) model, the estimate of d was 1 (boundary), and the model reduced to the Exponential (M4) model.

d For the Power model, the power parameter estimate was 1, and the model reduced to the Linear model.

e For the Polynomial (3 degree) model, the b3 coefficient estimate was 0 (boundary of parameters space), and the model reduced to the Polynomial (2 degree) model.

f For the Polynomial (2 degree) model, the b2 coefficient estimate was 0 (boundary of parameters space), and the model reduced to the Linear model.

Figure C-14 Plot of mean response by concentration, with fitted curve for the Hill Model; concentration shown in ppm

Hill Model. (Version: 2.17; Date: 01/28/2013)

The form of the response function is:

Y[concentration] = intercept + v × concentration^n^/(k^n^ + concentration^n^)

A constant variance model is fit.

Benchmark Concentration Computation.

BMR = 10% relative deviation

BMC = 1,666.92

BMCL at the 95% confidence level = 603.113

Parameter Estimates

Variable | Estimate | Default initial parameter values
alpha | 0.0160221 | 0.0170425
rho | N/A | 0
intercept | 1.74684 | 1.73
v | 0.521534 | 0.337
n | 1 | 0.225826
k | 3,309.8 | 1,856.13

Table of Data and Estimated Values of Interest

Concentration | N | Observed mean | Estimated mean | Observed standard deviation | Estimated standard deviation | Scaled residual
0 | 11 | 1.73 | 1.75 | 0.155 | 0.127 | −0.441
500 | 11 | 1.85 | 1.82 | 0.137 | 0.127 | 0.91
1,750 | 11 | 1.9 | 1.93 | 0.1 | 0.127 | −0.635
5,000 | 11 | 2.07 | 2.06 | 0.124 | 0.127 | 0.166

Likelihoods of Interest

Model | Log(likelihood) | No. parameters | AIC
A1 | 69.681815 | 5 | −129.36363
A2 | 70.76062 | 8 | −125.521241
A3 | 69.681815 | 5 | −129.36363
Fitted | 68.943332 | 4 | −129.886663
R | 55.026208 | 2 | −106.052416

Tests of Interest

Test | −2 × log(likelihood ratio) | Test df | p-value
Test 1 | 31.4688 | 6 | <0.0001
Test 2 | 2.15761 | 3 | 0.5403
Test 3 | 2.15761 | 3 | 0.5403
Test 4 | 1.47697 | 1 | 0.2242

Table C-17 Summary of benchmark concentration (BMC) modeling results for increased absolute kidney weight in female F344 rats exposed to ETBE by whole-body inhalation for 6 hours/day, 5 days/week, for 13 weeks (Medinsky et al., 1999; US EPA, 1997); benchmark response (BMR) = 10% relative deviation from the mean

Model^a^ | Goodness of fit | | BMC_10RD_ (ppm) | BMCL_10RD_ (ppm) | Basis for model selection
Model^a^ | p-value | AIC | BMC_10RD_ (ppm) | BMCL_10RD_ (ppm) | Basis for model selection
Exponential (M2); Exponential (M3)^b^ | 0.0630 | −187.67 | 2,706 | 2,275 | The Exponential (M4) model was selected as the most parsimonious model of adequate fit.
Exponential (M4); Exponential (M5)^c^ | 0.956 | −191.20 | 1,342 | 816 | The Exponential (M4) model was selected as the most parsimonious model of adequate fit.
Hill | N/A^d^ | −189.20 | 1,325 | 741 | The Exponential (M4) model was selected as the most parsimonious model of adequate fit.
Power^e^; Polynomial (3 degree)^f^; Polynomial (2 degree)^g^; Linear | 0.0928 | −188.45 | 2,552 | 2,111 | The Exponential (M4) model was selected as the most parsimonious model of adequate fit.

ppm = 4.18 mg/m^3^

BMC = benchmark concentration; BMCL = benchmark concentration lower confidence level.

a Constant variance case presented (BMDS Test 2 p-value = 0.428), selected model in bold; scaled residuals for selected model for concentrations 0, 500, 1,750, and 5,000 ppm were −0.0252, 0.043, −0.02385, and 0.004872, respectively.

b For the Exponential (M3) model, the estimate of d was 1 (boundary), and the model reduced to the Exponential (M2) model.

c For the Exponential (M5) model, the estimate of d was 1 (boundary), and the model reduced to the Exponential (M4) model.

d No available degrees of freedom to calculate a goodness-of-fit value.

e For the Power model, the power parameter estimate was 1, and the model reduced to the Linear model.

f For the Polynomial (3 degree) model, the b3 coefficient estimate was 0 (boundary of parameters space), and the model reduced to the Polynomial (2 degree) model.

g For the Polynomial (2 degree) model, the b2 coefficient estimate was 0 (boundary of parameters space), and the model reduced to the Linear model.

Figure C-15 Plot of mean response by concentration, with fitted curve for the Exponential Model 4; concentration shown in ppm

Exponential Model. (Version: 1.9; Date: 01/29/2013)

The form of the response function is: Y[concentration] = a × [c − (c − 1) × exp(−b × concentration)]

A constant variance model is fit.

Benchmark Concentration Computation.

BMR = 10% relative deviation

BMC = 1,341.66

BMCL at the 95% confidence level = 815.742

Parameter Estimates

Variable | Estimate | Default initial parameter values
lnalpha | −5.63259 | −5.63266
rho(S) | N/A | 0
a | 1.07748 | 1.02315
b | 0.000383798 | 0.000348471
c | 1.24847 | 1.34027
d | 1 | 1

Table of Data and Estimated Values of Interest

Concentration | N | Observed mean | Estimated mean | Observed standard deviation | Estimated standard deviation | Scaled residual
0 | 10 | 1.077 | 1.077 | 0.069 | 0.05983 | −0.0252
500 | 11 | 1.125 | 1.124 | 0.048 | 0.05983 | 0.043
1,750 | 11 | 1.208 | 1.208 | 0.076 | 0.05983 | −0.02385
5,000 | 11 | 1.306 | 1.306 | 0.055 | 0.05983 | 0.004872

Likelihoods of Interest

Model | Log(likelihood) | No. parameters | AIC
A1 | 99.60217 | 5 | −189.2043
A2 | 100.9899 | 8 | −185.9798
A3 | 99.60217 | 5 | −189.2043
R | 75.30605 | 2 | −146.6121
4 | 99.60063 | 4 | −191.2013

Tests of Interest

Test | −2 × log(likelihood ratio) | Test df | p-value
Test 1 | 51.37 | 6 | <0.0001
Test 2 | 2.775 | 3 | 0.4276
Test 3 | 2.775 | 3 | 0.4276
Test 6a | 0.003077 | 1 | 0.9558

### C.1.2 Cancer Endpoints

For the Multistage Cancer models, the coefficients were restricted to be nonnegative (beta ≥0). For each endpoint, Multistage Cancer models were fitted to the data using the maximum likelihood method. Each model was tested for goodness of fit using a chi-square goodness-of-fit test (χ^2^ p-value < 0.05^3^ indicates lack of fit). Other factors were used to assess model fit, such as scaled residuals, visual fit, and adequacy of fit in the low-dose region and in the vicinity of the BMR.

For each endpoint, the BMDL/BMCL estimate (95% lower confidence limit on the BMD/BMC, as estimated by the profile likelihood method) and AIC value were used to select a best-fit model from among the models exhibiting adequate fit. If the BMDL/BMCL estimates were “sufficiently close,” that is, differed by more than threefold, the model selected was the one that yielded the lowest AIC value. If the BMDL/BMCL estimates were not sufficiently close, the lowest BMDL/BMCL was selected as the POD.

The incidence of liver tumors in male F344 rats was found to be statistically significantly increased following a 2-year inhalation exposure; hepatocellular adenomas and a single hepatocellular carcinoma in the high-dose group were combined in modeling the data set. The data were modeled using two different exposure metrics: administered concentration as ppm as mg/m^3^.

Table C-18 Cancer endpoints selected for dose-response modeling for ETBE

Species/sex endpoint | Concentration and effect data
Hepatocellular adenomas and carcinomas in male rats; JPEC (2010b) | Exposure concentration (ppm) | 0 | 500 | 1,500 | 5,000
Hepatocellular adenomas and carcinomas in male rats; JPEC (2010b) | Exposure concentration (mg/m^3^) | 0 | 2,089 | 6,268 | 20,893
Hepatocellular adenomas and carcinomas in male rats; JPEC (2010b) | Incidence/total | 0/50 | 2/50 | 1/49 | 10/50

#### Modeling Results

Below are tables summarizing the modeling results for the cancer endpoints modeled.

Table C-19 Summary of benchmark concentration (BMC) modeling results for hepatocellular adenomas and carcinomas in male F344 rats exposed to ETBE by whole-body inhalation for 6 hours/day, 5 days/week, for 104 weeks; modeled with concentrations as administered, exposure concentration in ppm (JPEC, 2010b); benchmark response (BMR) = 10% extra risk

Model^a^ | Goodness of fit | | | BMC_10_ (ppm) | BMCL_10_ (ppm) | Basis for model selection
Model^a^ | p-value | Scaled residuals | AIC | BMC_10_ (ppm) | BMCL_10_ (ppm) | Basis for model selection
3 degree | 0.0991 | −0.030, 1.382, −0.898, and 0.048 | 84.961 | 2,942 | 1,735 | Multistage (1 degree) was selected based on lowest AIC.
2 degree | 0.264 | 0.000, 1.284, −1.000, and 0.137 | 83.093 | 2,756 | 1,718 | Multistage (1 degree) was selected based on lowest AIC.
1 degree | 0.490 | 0.000, 1.009, −1.144, and 0.309 | 81.208 | 2,605 | 1,703 | Multistage (1 degree) was selected based on lowest AIC.

BMC = benchmark concentration; BMCL = benchmark concentration lower confidence level.

a Selected model in bold.

Figure C-16 Plot of incidence rate by concentration, with fitted curve for the Multistage Model; concentration shown in ppm

Multistage Model. (Version: 3.4; Date: 05/02/2014)

The form of the probability function is:

P[response] = background + (1 − background) × [1 − exp(−beta1 × concentration^1^−beta2 × concentration^2^…)]

The parameter betas are restricted to be positive.

Benchmark Concentration Computation.

BMR = 10% extra risk

BMC = 2,604.82

BMCL at the 95% confidence level = 1,703.47

Benchmark concentration upper confidence limit (BMCU) at the 95% confidence level = 4,634.52

Collectively, (1,703.47, 4,634.52) is a 90% two-sided confidence interval for the BMC.

Multistage cancer slope factor = error

Parameter Estimates

Variable | Estimate | Default initial parameter values
Background | 0 | 0
Beta(1) | 4.04483 × 10^−4^ | 4.38711 × 10^−4^

Analysis of Deviance Table

Model | Log(likelihood) | No. parameters | Deviance | Test df | p-value
Full model | −38.2989 | 4
Fitted model | −39.6042 | 1 | 2.61063 | 3 | 0.4556
Reduced model | −48.0344 | 1 | 19.4711 | 3 | 0.0002184

AIC = 81.2084

Goodness-of-Fit Table

Concentration | Estimated probability | Expected | Observed | Size | Scaled residual
0 | 0 | 0 | 0 | 50 | 0
500 | 0.02 | 1.001 | 2 | 50 | 1.009
1,500 | 0.0589 | 2.885 | 1 | 49 | −1.144
5,000 | 0.1831 | 9.155 | 10 | 50 | 0.309

χ^2^ = 2.42; df = 3; p-value = 0.4898

Table C-20 Summary of benchmark concentration (BMC) modeling results for hepatocellular adenomas and carcinomas in male F344 rats exposed to ETBE by whole-body inhalation for 6 hours/day, 5 days/week, for 104 weeks; modeled with concentrations as mg/m^3^ (JPEC, 2010b); benchmark response (BMR) = 10% extra risk

Model^a^ | Goodness of fit | | | BMC_10_ (mg/m^3^) | BMCL_10_ (mg/m^3^) | Basis for model selection
Model^a^ | p-value | Scaled residuals | AIC | BMC_10_ (mg/m^3^) | BMCL_10_ (mg/m^3^) | Basis for model selection
3 degree | 0.0991 | −0.040, 1.382, −0.897, and 0.048 | 84.961 | 12,300 | 7,251 | Multistage (1 degree) was selected based on lowest AIC
2 degree | 0.264 | 0.000, 1.284, −1.000, and 0.137 | 83.093 | 11,514 | 7,179 | Multistage (1 degree) was selected based on lowest AIC
1 degree | 0.490 | 0.000, 1.009, −1.144, and 0.309 | 81.209 | 10,884 | 7,118 | Multistage (1 degree) was selected based on lowest AIC

BMC = benchmark concentration; BMCL = benchmark concentration lower confidence level.

a Selected model in bold.

Figure C-17 Plot of incidence rate by concentration, with fitted curve for the Multistage Model; concentration shown in mg/m^3^

Multistage Model. (Version: 3.4; Date: 05/02/2014)

The form of the probability function is:

P[response] = background + (1 − background) × [1 − exp(−beta1 × concentration^1^− beta2 × concentration^2^…)]

The parameter betas are restricted to be positive.

Benchmark Concentration Computation.

BMR = 10% extra risk

BMC = 10,884.4

BMCL at the 95% confidence level = 7,118.08

BMCU at the 95% confidence level = 19,366.3

Collectively, (7,118.08, 19,366.3) is a 90% two-sided confidence interval for the BMC.

Multistage cancer slope factor = error

Parameter Estimates

Variable | Estimate | Default initial parameter values
Background | 0 | 0
Beta(1) | 9.6799 × 10^−6^ | 1.04989 × 10^−4^

Analysis of Deviance Table

Model | Log(likelihood) | No. parameters | Deviance | Test df | p-value
Full model | −38.2989 | 4
Fitted model | −39.6044 | 1 | 2.61098 | 3 | 0.4556
Reduced model | −48.0344 | 1 | 19.4711 | 3 | 0.0002184

AIC = 81.2087

Goodness-of-Fit Table

Concentration | Estimated probability | Expected | Observed | Size | Scaled residual
0 | 0 | 0 | 0 | 50 | 0
2,089 | 0.02 | 1.001 | 2 | 50 | 1.009
6,268 | 0.0589 | 2.885 | 1 | 49 | −1.144
20,893 | 0.1831 | 9.155 | 10 | 50 | 0.309

χ^2^ = 2.42; df = 3; p-value = 0.4897

1 Unless otherwise specified, all available BMDS dichotomous models besides the alternative and nested dichotomous models were fitted. The following parameter restrictions were applied: for the Log-Logistic model, restrict slope ≥1; for the Gamma and Weibull models, restrict power ≥1.

2 Unless otherwise specified, all available BMDS continuous models were fitted. The following parameter restrictions were applied: for the Polynomial models, restrict the coefficients b1 and higher to be nonnegative or nonpositive if the direction of the adverse effect is upward or downward, respectively; for the Hill, Power, and Exponential models, restrict power ≥1.

3 A significance level of 0.05 is used for selecting cancer models because the model family (Multistage) is selected a priori; see Benchmark Dose Technical Guidance Document (U.S. EPA, 2012).