# APPENDIX B INFORMATION IN SUPPORT OF HAZARD IDENTIFICATION AND DOSE-REPONSE ANALYSIS

## B.1 TOXICOKINETICS

### B.1.1 Absorption

#### Absorption in Humans

Most of the available human data on the uptake of ethyl tertiary butyl ether (ETBE) were obtained from volunteers. Nihlén et al. (1998) exposed eight healthy male volunteers (average age: 29 years) to 5, 25, or 50 ppm (20.9, 104, or 210 mg/m^3^) ETBE by inhalation for 2 hours. Each volunteer was exposed at each concentration in sequence with 2-week intervals between exposures. The study was performed according to the Declaration of Helsinki after approval by the Regional Ethical Committee of the institution where the study was performed, and written informed consent was obtained from the volunteers. The volunteers performed light physical exercise (50 watts) on a bicycle ergometer during exposure. Exhaled air was collected before exposure, every 30 minutes during exposure, and 6 times after exposure. The concentrations of ETBE and one of its primary metabolites, tert-butanol (TBA), were determined in exhaled air samples. Blood was drawn before exposure, approximately every 10 minutes during exposure, approximately every 30 minutes from 1 to 4 hours after exposure, and an additional 4 times up to 48 hours after exposure. Urine was collected before exposure, at 0 and 2 hours, and at approximately 4, 7, 11, 20, 22, and 46 hours after exposure. ETBE, tert-butanol, and acetone (an ETBE metabolite) concentrations were determined in blood and urine. The blood profiles of the parent compound and metabolites were similar at all three exposure levels and reflected exposure concentrations, as judged by linear increases in blood area-under-the-curve (AUC) values for the concentration-time curve calculated (but only reported in graphical form by the authors).

Acetone levels were highly variable and seemed to reflect not only ETBE exposure, but also the physical activity of the volunteers. Nihlén et al. (1998) calculated the ETBE doses to the volunteers to be 0.58, 2.9, and 5.8 mmol for the 20.9-, 104-, and 210-mg/m^3^ exposure levels, respectively. The concentrations of ETBE in blood rose sharply during the first 30 minutes of exposure and kept rising at a lower rate until the end of exposure, reaching peak concentrations of about 10, 5.4, and 1.1 μM at 210, 104, and 20.9 mg/m^3^, respectively. By 6 hours, the concentrations of ETBE had fallen to very low levels (<1 μM), even after the 210-mg/m^3^ exposure. Based on blood AUC values for ETBE, the authors calculated two types of respiratory uptake: (1) net respiratory uptake = (concentration in inhaled air − concentration in exhaled air) multiplied by the pulmonary ventilation and (2) respiratory uptake = net respiratory uptake + amount exhaled during the exposure. During the 2 hours of exposure, the authors calculated that 32−34% of each dose was retained by the volunteers (respiratory uptake), and the net respiratory uptake was calculated to be 26% of the dose at all three exposure levels. Over 24 hours, the respiratory expiration was calculated as 45−50% of the respiratory uptake, and because the net respiratory uptake and expiration do not consider the amount of ETBE cleared during exposure, the net respiratory excretion was lower, at 30−31% of the net respiratory uptake. These authors determined that the ETBE blood:air partition coefficient in humans was 11.7.

Amberg et al. (2000) exposed six volunteers (three males and three females, average age 28 ± 2 years) to 4.5 ppm (18.8 mg/m^3^) and 40.6 ppm (170 mg/m^3^) ETBE. The exposures lasted 4 hours, and the two concentrations were administered to the same volunteers 4 weeks apart. These volunteers were healthy nonsmokers and were asked to refrain from alcohol and medication intake from 2 days before the experiment until its end. The study was performed according to the Declaration of Helsinki after approval by the Regional Ethical Committee of the institution where the study was performed, and written informed consent was obtained from the volunteers. Urine was collected at 6-hour intervals for 72 hours. Blood was drawn immediately after exposure and thereafter every 6 hours for 48 hours. Levels of ETBE and its primary metabolite, tert-butanol, were determined in blood. The same two substances, plus additional metabolites of tert-butanol, were assessed in urine. The authors estimated the retained doses to be 1,090 μmol following 170-mg/m^3^ ETBE exposure and 121 μmol following 18.8-mg/m^3^ exposure. These estimates were derived using a resting human respiratory rate of 9 L/minute (13 m^3^/day) and a retention factor for ETBE of 0.3, which was based on data reported by Nihlén et al. (1998). These estimates of retained dose are lower than those reported during light exercise (Nihlén et al., 1998).

#### Absorption in Animals

Amberg et al. (2000) exposed F344 NH rats (5/sex/dose group) concurrent with the human volunteers in the same exposure chamber. Blood was taken from the tail vein of each rat at the end of the exposure period, and urine was collected for 72 hours at 6-hour intervals following exposure. The authors reported that immediately after the 4-hour exposure period blood levels of ETBE were lower in the rats than in humans, although the exact values were not reported. The authors estimated that the rats received doses of 20.5 and 2.3 μmol at the 170- and 18.8-mg/m^3^ exposures, respectively, using an alveolar ventilation rate of 0.169 L/minute and a retention factor of 0.3 for rats.

No published oral dosing studies of the absorption of ETBE in humans were identified. The Japan Petroleum Energy Center (JPEC), however, conducted an oral dosing study of the absorption of ETBE in rats after single and repeated dosing for 14 days (JPEC, 2008e, f). Seven-week-old Crl:CD(SD) male rats (4/dose group) were administered either a single oral dose of 5, 50, or 400 mg/kg [^14^C]ETBE via gavage or 5 mg/kg-day [^14^C]ETBE daily for 14 days. In the single-dose study by JPEC (2008f), plasma levels were compared with those observed after a single intravenous dose of 5 mg/kg-day [^14^C]ETBE. There is no indication that a similar comparison was conducted in the repeated-dose study (JPEC, 2008e). Plasma radioactivity was measured in rats at 1, 2, 4, 6, 8, 10, and 24 hours after the first exposure in the repeated-dose study; 8 and 24 hours after the second to 13th exposures; and at 1, 2, 4, 6, 8, 10, 12, 24, 32, 48, 72, 96, 120, 144, and 168 hours after the last exposure in the repeated-dose study and after the single-dose study.

Plasma radioactivity levels increased following a single dose of [^14^C]ETBE; this increase was not proportional as the dose increased, especially at the high dose (i.e., the peak plasma radioactivity levels were 2,800, 22,100, and 89,900 ng equivalents of ETBE/mL [ng equivalent ETBE/mL] in the 5-, 50-, and 400-mg/kg dose groups, respectively). Maximum plasma [^14^C]ETBE levels (C_max_) were estimated to be reached at 9.0, 11.5, and 8.0 hours after administration in the 5-, 50-, and 400-mg/kg dose groups, respectively. The [^14^C]ETBE levels in the plasma were higher following oral exposure than after intravenous exposure (see Table B-2). The estimated elimination plasma half-lives were 17.5, 19.8, and 9.9 hours for the 5-, 50-, and 400-mg/kg dose groups, respectively. With repeated dosing of 5 mg/kg-day [^14^C]ETBE (JPEC, 2008e), the C_max_ was achieved 6 hours after the first exposure and increased until it reached a steady state around the fifth day of exposure. After the last exposure on Day 14, the C_max_ of 6,660 ± 407 ng equivalent ETBE/mL was achieved 10 hours after administration of [^14^C]ETBE, and plasma radioactivity steadily decreased after this point. The elimination plasma half-life from C_max_ to 24 hours was 17.9 hours after the first dose and 14.2 hours after the final dose. The elimination half-life from C_max_ to 168 hours after the final dose following repeated dosing was 24.7 hours. Based on radioactivity levels measured in urine and exhalation, more than 90% of the administered dose was absorbed.

In two parallel studies, the pharmacokinetics of ETBE was studied in mice (Sun and Beskitt, 1995a) and male Fischer 344 (F344) rats (Sun and Beskitt, 1995b). The study authors investigated the pharmacokinetics of [^14^C]ETBE in mice and rats (3/sex/dose) exposed by nose-only inhalation at target concentrations of 500, 750, 1,000, 1,750, 2,500, and 5,000 ppm (2,090, 3,130, 4,180, 7,310, 10,450, and 20,900 mg/m^3^) for a single 6-hour period (the true doses differed by less than 10% from the targets). Specific activity of the administered [^14^C]ETBE and localization of the label were not reported. Note, that in the absence of the specific activity and localization of the label, it is not clear how the “mg ETBE equivalents” were calculated in the Sun and Beskitt (1995a, 1995b) report or for the specific tissues. Of the three animals per sex exposed concurrently, two were used to determine blood and tissue concentrations of radiolabel, and the third was kept in a metabolism cage for up to 118 hours to quantify radiolabel excretion in urine, feces, exhaled carbon dioxide (CO_2_), and as volatiles in expired air. Exhaled organic volatiles were trapped in charcoal filters. Exhaled CO_2_ was trapped in aqueous 1 M KOH. Samples from the 20,900-mg/m^3^ treated animals were collected at 3, 6, 12, 18, 24, 48, 72, 96, and 118 hours after termination of exposure. At the lower exposure concentrations listed above, the samples were collected at fewer time points, generally at full-day intervals up to 96 hours. Animals were euthanized either immediately after exposure or after being removed from the metabolic cages, and blood and kidneys were collected. The cages were washed, and the wash fluid collected. Charcoal traps were eluted with methanol. Urine, cage wash, trapped ^14^CO_2_, and charcoal filter eluates were measured directly by liquid scintillation spectrometry. Blood and kidney tissue from rats and blood and liver tissue from mice were combusted in a sample oxidizer and analyzed by liquid scintillation spectrometry.

Immediately upon cessation of exposure, radiolabel was quantified in the blood and kidneys of two rats and in the blood and liver of two mice. Results in Table B-1 demonstrate the absorption of radiolabel expressed as mg equivalents of ETBE into blood. Because the ETBE carbon(s) bearing the radiolabel was not identified, further speciation is not possible. The concentration of radiolabel in rat blood is proportionate with exposure concentration to the highest concentration (20,894 mg/m^3^), although in mice, such proportionality is absent at concentrations of 10,447 mg/m^3^ and above. These data indicate that ETBE is well absorbed following inhalation exposure, but that higher concentrations (e.g., 10,447 mg/m^3^ and above) could result in reduced respiration rates or otherwise affect mechanisms of inhalation uptake. Additional support for reduction of absorption is presented in Table B-1, demonstrating the excretion of the radiolabel from rats and mice in these studies (Sun and Beskitt, 1995a, b).

Table B-1 Radioactivity in blood and kidney of rats and blood and liver of mice, following 6 hours of [^14^C]ETBE inhalation exposure

Exposure level (mg/m^3^) | F344 rat^a^ | | CD-1 mouse^a^
Exposure level (mg/m^3^) | Blood^b^ | Kidney^c^ | Blood^b^ | Liver^c^
2,089 | 0.037 | 0.074 | 0.154 | 0.208
3,134 | 0.062 | 0.094 | 0.340 | 0.348
4,179 | 0.080 | 0.116 | 0.336 | 0.540
7,313 | 0.124 | 0.152 | 0.481 | 0.724
10,447 | 0.156 | 0.185 | 0.474 | 0.628
20,894 | 0.114 | 0.182 | 0.408 | 0.592

a Mean values of one male and one female per rat/mouse.

b In mg [^14^C]ETBE equivalents per gram blood.

c In mg [^14^C]ETBE equivalents.

Sources:Sun and Beskitt (1995a) and Sun and Beskitt (1995b).

In contrast, Borghoff and Asgharian (1996) evaluated the disposition of ^14^C radiolabel in F344 rats and CD-1 mice after whole-body and nose-only inhalation exposure to 500, 1,750, or 5,000 ppm [^14^C]ETBE. Besides recovery of total radioactivity in urine, feces, and expired air, air and urine samples were analyzed for ETBE and tert-butanol. Urine samples were also analyzed for tert-butanol metabolites hydroxyisobutyric acid (HBA) and 2-methyl-1,2-propanediol (MPD), and ^14^CO_2_ was measured in exhaled air. Results obtained after both a single 6-hour exposure or after 13 days of preexposure to 0, 500, or 5,000 ppm ETBE indicate that total inhalation uptake increases linearly with exposure concentration over this range, although there are dose- and preexposure-related shifts in the form and route of excretion. Because the later study used four rats per sex and exposure level, rather than just two, it should be given higher weight.

No studies investigating dermal absorption of ETBE were identified, but because dermal absorption of homologous organic substances is thought to be a function of the octanol:water partition coefficient, ETBE might be assumed to penetrate rat skin relatively well. For humans, Potts and Guy (1992) proposed an equation to calculate the dermal permeability coefficient, K_p_:

log K_p_ ( cm / sec ) = − 6.3 + 0.71 × log K_ow_ − 0.0061 × ( molecular weight ) (B-1)

Using the log K_ow_ [identified as K_oct_ in Potts and Guy (1992)] values for ETBE [0.95−2.2; Drogos and Diaz (2001)] and converting cm/second values to cm/hour, the estimated K_p_ values are 0.0020−0.016 cm/hour for ETBE.

ETBE is moderately absorbed following inhalation exposure in rats and humans, and blood levels of ETBE approached―but did not reach―steady-state concentrations within 2 hours. Nihlén et al. (1998) calculated the net respiratory uptake of ETBE in humans to be 26%. The AUC for the concentration-time curve was linearly related to the ETBE exposure level, suggesting linear kinetics up to 209 mg/m^3^. The JPEC studies (JPEC, 2008e, f) demonstrated that ETBE is readily absorbed following oral exposure in rats with >90% of a single dose (5−400 mg/kg-day) or repeated doses (5 mg/kg-day) estimated to be absorbed. In the repeated-dose study, peak plasma [^14^C]ETBE levels were reached 6 hours after the first dose and 10 hours after the final (14th) dose, and the maximum plasma concentration reached a steady state on Day 5. No data are available on dermal absorption of ETBE.

Table B-2 Plasma radioactivity after a single oral or intravenous dose of [^14^C]ETBE to male Crl:CD(SD) rats

Time (h) | Radioactive concentration (ng eq of ETBE/mL)
Time (h) | Oral | | Intravenous
Dose administered | 5 mg/kg | 50 mg/kg | 400 mg/kg | 5 mg/kg
0.083 | − | − | − | 918 ± 188^a^
0.25 | − | − | − | 822 ± 165
0.5 | − | − | − | 914 ± 156
1 | 2,150 ± 281 | 11,100 ± 1,007 | 47,000 ± 11,900 | 907 ± 143
2 | 2,400 ± 151 | 12,100 ± 883 | 58,200 ± 7,340 | 923 ± 158
4 | 2,620 ± 109 | 14,800 ± 659 | 73,300 ± 6,800 | 929 ± 193
6 | 2,750 ± 146 | 18,700 ± 1,550 | 82,900 ± 12,500 | 981 ± 216
8 | 2,760 ± 265 | 19,900 ± 2,430 | 89,900 ± 16,300 | 973 ± 196
10 | 2,710 ± 303 | 21,400 ± 2,830 | 87,300 ± 15,300 | 943 ± 203
12 | 2,660 ± 426 | 22,000 ± 3,060 | 78,500 ± 18,100 | 862 ± 205
24 | 1,330 ± 419 | 10,800 ± 2,820 | 17,200 ± 6,460 | 383 ± 184
32 | 1,170 ± 424 | 9,310 ± 2,510 | 13,100 ± 6,580 | 334 ± 190
48 | 443 ± 271 | 3,900 ± 1,480 | 3,180 ± 1,480 | 144 ± 93.8
72 | 204 ± 165 | 1,660 ± 845 | 2,000 ± 1,820 | 65.2 ± 34.0
96 | 81.3 ± 70.3 | 792 ± 338 | N.D. | 31.3 ± 11.4
120 | 35.9 ± 44.0 | 385 ± 110 | N.D. | 16.1 ± 3.8
144 | 19.6 ± 26.0 | 179 ± 129 | N.D. | 11.9 ± 13.8
168 | N.D. | 85.4 ± 103 | N.D. | N.D.

− = not measured; N.D. = not detected.

a Mean ± standard deviation; n = 4.

Source: JPEC (2008e).

### B.1.2 Distribution

There are no in vivo data on the tissue distribution of ETBE in humans. Nihlén et al. (1995) measured the partitioning of ETBE and tert-butanol in air into human blood from 10 donors (5 males, 5 females), saline, or oil inside of sealed vials. Also, human tissue-to-blood partitioning coefficients were estimated in brain, fat, liver, kidney, lung, and muscle based on their relative water and fat contents. Kaneko et al. (2000) conducted a similar series of in vitro studies to measure the partitioning of ETBE and tert-butanol in air to various rat tissues (5 male Wistar rats), including blood, brain, fat, liver, kidney, lung, muscle, and testis. The blood:air partition coefficients for ETBE were much lower than for tert-butanol. Both studies reported efficient uptake of these substances from air into blood, with blood:air partition coefficients of 11.7 and 11.6 for ETBE and 462 and 531 for tert-butanol in humans and rats, respectively. Nihlén et al. (1995) also estimated oil:water partition (log K_ow_) coefficients and obtained values of 0.278 for tert-butanol and 22.7 for ETBE. These values have a similar ranking, but are not identical, to those listed in a report by Drogos and Diaz (2001) (namely, 0.35 for tert-butanol and 1.48−1.74 for ETBE). Nihlén et al. (1995) used the coefficients of tissue:air and blood:air partition coefficients to calculate human tissue:blood partition coefficients. These values are listed in Table B-3.

Table B-3 Blood:tissue partition coefficients for ETBE and tert-butanol

Partition coefficient | tert-Butanol | ETBE
Blood:air | 462 | 11.7
Brain:blood | 1.05 | 2.34
Muscle:blood | 1.06 | 1.78
Fat:blood | 0.646 | 11.6
Lung:blood | 1.02 | 0.835
Kidney:blood | 1.06 | 1.42
Liver:blood | 1.05 | 1.44

Source: Nihlén et al. (1998).

The JPEC (2008e, 2008f) study examined the distribution of radioactivity in 7-week-old Crl:CD(SD) male rats (4/dose group) following either a single oral dose of 5 or 400 mg/kg [^14^C]ETBE via gavage or a repeated dose of 5 mg/kg-day for 7 or 14 days. Tissue samples were collected at 8, 24, 72, and 168 hours after a single dose; 8 and 24 hours after 7 days of repeated dosing; and 8, 24, 72, and 168 hours after 14 days of repeated dosing. Although the highest radioactivity levels were generally detected in plasma, [^14^C]ETBE was also detected in all tissues examined (brain, peripheral nerve, eyes, submaxillary gland, thyroid gland, thymus, lungs, kidneys, heart, liver, adrenal glands, spleen, pancreas, bone marrow, mesenteric lymph node, prostate, epididymis, testes, muscle, skin, adipose tissue, stomach, large intestines, and small intestines). Tissue concentrations after a single 400 mg/kg dose of [^14^C]ETBE were higher than after a single 5 mg/kg dose; however, the percentage distribution of radioactivity in tissues was lower with the higher dose. Tissue radioactivity levels reached a maximum at 8 hours after a single dose of either 5 or 400 mg/kg [^14^C]ETBE and rapidly decreased by 72 hours. In the repeated-dose study, the radioactivity was the same 8 hours after the seventh administration when compared to 8 hours after the 14th administration. The levels of [^14^C]ETBE in the tissues declined steadily from 8 hours through 168 hours after the last exposure except in adipose tissue. In adipose tissue, there was a rapid decline between 8 and 24 hours, but the levels remained consistent between the 24- and 168-hour time points. The percentage of radioactivity found in red blood cells was estimated to be 20−27% within 72 hours of administration, and little was found to be bound to plasma proteins.

Sun and Beskitt (1995a) and Sun and Beskitt (1995b) studied the distribution of radiolabel derived from [^14^C]ETBE in rats and mice, respectively. The animals were subjected to a single nose-only inhalation exposure to [^14^C]ETBE for 6 hours. Immediately upon cessation of exposure, radiolabel was quantified in the blood and kidneys of two rats and in the blood and liver of two mice. Results in Table B-1 (shown earlier) demonstrate the distribution of radiolabel expressed as mg equivalents of ETBE from blood to kidney (rats) and liver (mice) during exposure. The concentration of radiolabel in rat kidney and mouse liver parallels the concentration of radiolabel in blood of the respective species, leading to an expectation of the proportionate distribution of ^14^C from ETBE to rat kidney and mouse liver up to exposure concentrations of 7,313 mg/m^3^ in rats and 10,447 mg/m^3^ in mice. Because radiolabel levels do not distinguish between parent ETBE and its metabolites, these results need to be interpreted with some caution, as the distribution of individual chemical species may differ.

Leavens and Borghoff (2009) evaluated the distribution of the structurally similar compound, methyl tert-butyl ether (MTBE), and the common metabolite, tert-butanol, after inhalation exposure to those two compounds, specifically in the brain, kidney, and liver of male and female rats and testis of male rats. Concentrations of MTBE and tert-butanol were similar in the female rat brain, kidney, and liver, and concentrations in the male rat brain, liver, and testes, were similar for exposure level and across time points, indicating an even distribution of MTBE and tert-butanol in those tissues/sexes. While total concentrations of MTBE and tert-butanol were higher in male rat kidneys than other tissues, consistent with the mechanism of binding to alpha 2u-globulin for those two compounds (Leavens and Borghoff, 2009), the overall observations are consistent with the conclusion that unbound ETBE and tert-butanol distribute rapidly and evenly through the body, although additional accumulation of material bound to alpha 2u-globulin occurs for tert-butanol and may occur for ETBE in the male rat kidney.

### B.1.3 Metabolism

The metabolism of ETBE has been studied in rats and humans using both in vivo and in vitro methods. A schematic of the proposed metabolism of ETBE is presented in Figure B-1. Based on elucidated structures of urinary metabolites from rats that were exposed to ETBE by inhalation, ETBE is initially metabolized by cytochrome P450 (CYP450) enzymes via oxidative deethylation by the addition of a hydroxyl group to the α-carbon of the ethyl ether group (Bernauer et al., 1998). The resulting hemiacetal is unstable and decomposes spontaneously into tert-butanol and acetaldehyde. In human liver microsome preparations, this step is catalyzed mainly by CYP2A6, with some contribution from CYP3A4 and CYP2B6 and possible contribution from CYP2E1 (Le Gal et al., 2001; Hong et al., 1999a). Using data from rat hepatic microsome preparations, Turini et al. (1998) suggested that CYP2B1 is the primary enzyme responsible for this step in rats but that CYP2A1 may also have an important role. Acetaldehyde is oxidized to acetic acid by aldehyde dehydrogenase enzymes (some of which are polymorphically expressed) and eventually to CO_2_. tert-Butanol can be sulfated, glucuronidated, and excreted into urine, or it can undergo further oxidation by the CYP enzymes (but not by alcohol dehydrogenases) to form MPD, and 2-hydroxyisobutyrate (HIBA), acetone, and formaldehyde (Bernauer et al., 1998). Note also that these metabolites have been identified in studies using liver preparations from human or rat studies using ETBE, MTBE, or tert-butanol (Bernauer et al., 1998; Cederbaum and Cohen, 1980); however, all the enzymes that perform these metabolic steps have not been fully described. Excretion studies indicate that final metabolism to CO_2_ plays only a minor role (see Section Error! Reference source not found.).

Figure B-1 Proposed metabolism of ETBE

Source: Adapted from Dekant et al. (2001), NSF International (2003), ATSDR (1996), Bernauer et al. (1998), Amberg et al. (1999), and Cederbaum and Cohen (1980).

Zhang et al. (1997) used computer models to predict the metabolites of ETBE. The metabolism model correctly predicted cleavage into tert-butanol and acetaldehyde and that tert-butanol would undergo glucuronidation and sulfation. For the further metabolism of tert-butanol, however, the computer model predicted reductive steps leading to metabolites that have not been identified in vivo or in vitro. The software did not predict the formation of MPD or HIBA, which have been found in vivo.

#### Metabolism in Humans

##### Metabolism of ethyl tertiary butyl ether (ETBE) in humans in vivo

Nihlén et al. (1998) exposed eight healthy male volunteers (average age: 29 years) to 0, 20.9, 104, or 209 mg/m^3^ ETBE by inhalation for 2 hours. Profiles of ETBE, tert-butanol, and acetone were established for blood throughout exposure and for up to 22 hours thereafter. The blood profiles of parent compounds and metabolites were similar at all three exposure levels and reflected exposure concentrations, as judged by linear increases in concentration-time AUC values calculated by the authors (only reported graphically). Acetone levels were highly variable before, during, and after the exposure period, and the variation could likely be due to variations in endogenous acetone production due to diet or physical activity.

The concentration of ETBE in blood rose sharply during the first 30 minutes of exposure and kept rising at a lower rate until the end of exposure to reach peak concentrations of about 10, 5, and 1 μM at 209, 104, and 20.9 mg/m^3^, respectively. By 6 hours, ETBE concentrations had fallen to low levels even after exposure to 209 mg/m^3^. The blood concentration of tert-butanol continued to rise for the full 2-hour exposure period, with peak values of about 12 and 7 μM at 209 and 104 mg/m^3^, respectively. Blood concentrations leveled off for 3−4 hours and then began a slow decline to less than one-half maximum levels by 24 hours (tert-butanol levels could not be determined following 20.9 mg/m^3^ exposure). Acetone blood levels began to increase after about 1 hour of exposure and continued to increase after the end of exposure (high dose) or leveled off for about 1.5 hours after exposure (lower doses and controls). Blood acetone levels fell rapidly during the next half hour but remained slightly above normal for the exposed volunteers until 4 hours after exposure when measurements were terminated.

Amberg et al. (2000) exposed six volunteers (three males and three females; average age: 28 ± 2 years) to 18.8 and 170 mg/m^3^ of ETBE. The exposures lasted 4 hours, and the two concentrations were administered to the same volunteers 4 weeks apart. Urine was collected at 6-hour intervals for 72 hours. Blood was drawn immediately, at 4 or 6 hours after exposure, and thereafter every 6 hours for 48 hours. Levels of parent ETBE and its primary metabolite, tert-butanol, were determined in blood and urine. In urine, two further metabolites of tert-butanol, MPD and HIBA, were also assayed.

At 170 mg/m^3^, the mean peak blood concentration of ETBE was 12.1 ± 4.0 μM, although for tert-butanol it was 13.9 ± 2.2 μM. The corresponding values at 18.8 mg/m^3^ were 1.3 ± 0.7 and 1.8 ± 0.2 μM, respectively. The time courses of metabolite appearance in urine after 170 and 18.8 mg/m^3^ were similar, but relative urinary levels of metabolites after 18.8 mg/m^3^ differed from those after 170 mg/m^3^. Using parent ETBE as the reference, molar ratios for total urinary excretion (ETBE:tert-butanol:MPD:HIBA) were 1:25:107:580 after 170 mg/m^3^, and 1:17:45:435 after 18.8 mg/m^3^. Individual variations were large, but the authors did not report any sex differences in the metabolism of ETBE based on data from only three subjects of each sex.

##### In vitro metabolism of ethyl tertiary butyl ether (ETBE) using human enzyme preparations

The metabolism of ETBE has been studied in vitro using microsomal protein derived from human liver and from genetically engineered cells expressing individual human CYP isozymes. Hong et al. (1997b) coexpressed human CYP2A6 or CYP2E1 with human CYP reductase in insect SF9 cells. In this heterologous expression system, in the presence of 1 mM ETBE, tert-butanol was formed at rates of 13.6 nmol/min-nmol CYP2A6 and 0.8 nmol/min-nmol CYP2E1, indicating a greater capacity for ETBE metabolism by CYP2A6 than by CYP2E1 at high (e.g., 1 mM) concentrations of ETBE.

Hong et al. (1999a) obtained hepatic microsomal protein preparations from 15 human donor liver microsomal samples and used them to evaluate the contributions of several CYP enzymes to ETBE metabolism. The 15 samples displayed very large interindividual variations in metabolic activities towards ETBE ranging from 179 to 3,130 pmol/minute-mg protein. Michaelis-Menten constant (Km) values, estimated in three human liver microsomal samples using MTBE, ranged from 28 to 89 μM, with maximum substrate turnover velocity (V_max_) values ranging from 215 to 783 pmol/minute-mg protein. The V_max_:Km ratios, however, varied only between 7.7 and 8.8. After evaluating the activities of multiple different CYP forms in the 15 donor samples, the study authors demonstrated that the metabolism of ETBE was highly correlated with certain CYP forms. The highest degree of correlation was found for CYP2A6, which also displayed the highest metabolic capacity for ETBE.

As part of CYP inhibition studies in the same paper, human liver microsomes were coincubated with ETBE in the presence of chemical inhibitors or specific antibodies against either CYP2A6 or CYP2E1. For chemical inhibition, coumarin was added to the liver microsomes prior to initiation of the reaction. For antibody inhibition, monoclonal antibodies against human CPY2A6 or CYP2E1 were preincubated with liver microsomes prior to incubation with the rest of the reaction mixture. Methanol alone caused approximately 20% inhibition of the metabolism of ETBE, and coumarin, a CYP2A6 substrate, caused a significant dose-dependent inhibition of ETBE metabolism, which reached a maximal inhibition of 99% at 100-μM coumarin. The antibody against CYP2A6 inhibited metabolism by greater than 75% but did not do so against CYP2E1.

In the same paper, several specific human CYPs were expressed into human β-lymphoblastoid cells which were used to evaluate ETBE metabolism. Based on the ETBE metabolizing activities in the 15 human liver microsomes and the enzyme activity profiles towards known CYP specific substrates, correlation coefficients (ranging from 0.94 for CYP2A6 to 0 for CYP2D6) were calculated for each CYP enzyme. The correlation ranking for ETBE metabolism by nine human CYP isozymes was as follows:

2A6 > 3A4 ≈ 2B6 ≈ 3A4/5 >> 2C9 > 2E1 ≈ 2C19 >> 1A2 ≈ 2D6. The reported direct enzyme activities towards ETBE by the heterologous expression systems (in pmol tert-butanol formed per minute per pmol CYP enzyme) were 1.61 for CYP2A6; 0.34 for CYP2E1; 0.18 for CYP2B6; and 0.13 for CYP1A2. CYPs 1B1, 2C8, 2C9, 2C19, and 2D6 were not investigated. CYP3A4 and 1A1 did not metabolize ETBE. The authors concluded that CYP2A6 is the major enzyme responsible for the oxidative metabolism of ETBE in human livers. Furthermore, they concluded that the results of the correlation analysis and antibody inhibition study strongly suggest that CYP2E1 is not a major enzyme responsible for metabolism of ETBE. Le Gal et al. (2001) used similar human cytochrome preparations as Hong et al. (1999a) (i.e., from human donors) or used genetically modified human β-lymphoblastoid cell lines transfected with CYP2A6, CYP2B6, CYP3A4, or CYP2E1 and human CYP reductase to elucidate the metabolism of ETBE, MTBE, and tertiary amyl methyl ether. They identified acetaldehyde and tert-butanol as primary metabolites from ETBE.

#### Metabolism in Animals

##### Metabolism of ethyl tertiary butyl ether (ETBE) in animals in vivo

Bernauer et al. (1998) studied the metabolism and excretion of [^13^C]ETBE and tert-butanol in rats. F344 rats, 2/sex, were exposed via inhalation to 2,000 ppm (8,400 mg/m^3^) ETBE; three male F344 rats received 250 mg/kg tert-butanol by gavage. Urine was collected for 48 hours. The excretion profile for ETBE metabolites was

MPD > HIBA > tert-butanol-sulfate > tert-butanol-glucuronide. Oral administration of tert-butanol produced a similar metabolite profile, with

HIBA > tert-butanol-sulfate > MPD >> tert-butanol-glucuronide ≈ tert-butanol. tert-Butanol could not be detected in urine following inhalation exposure to ETBE. Traces of acetone were also detected in urine. Amberg et al. (2000) exposed F344 NH rats, 5/sex/dose, to ETBE in the same exposure chamber described earlier for the human volunteers. Urine was collected for 72 hours following exposure. Blood samples were drawn from the tail vein every 6 hours up to 48 hours. Peak blood levels of ETBE and tert-butanol were 5.3 ± 1.2 and 21.7 ± 4.9 μM at 170 mg/m^3^ and 1.0 ± 0.7 and 5.7 ± 0.8 μM at 18.8 mg/m^3^, respectively. Peak levels of tert-butanol were higher in rats than in humans. Like humans, rats excreted mostly HIBA in urine, followed by MPD and tert-butanol. The molar ratios for total urinary excretion of tert-butanol:MPD:HIBA were 1:2.3:15 after exposure to 170 mg/m^3^ and 1:1.5:11 after exposure to 18.8 mg/m^3^. Parent ETBE was not identified in rat urine in this study.

In a review covering mostly their own work on fuel oxygenate metabolism, Dekant et al. (2001) focused on aspects of ETBE metabolism that were considered quantitatively similar in humans and rats, with no sex-dependent differences and no likely accumulation of metabolites or parent compound. They reported that at a high exposure level (8,400 mg/m^3^ ETBE), rats predominantly excreted the glucuronide of tert-butanol in urine; however, at low exposure levels (16.7 or 167.1 mg/m^3^ ETBE), the relative concentration of tert-butanol to the received dose was much smaller. This result seems to indicate that at high exposure levels, the normally rapid metabolism of tert-butanol to MPD and HIBA became saturated, forcing more of the tert-butanol through the glucuronidation pathway. The apparent final metabolite of ETBE was HIBA, which can undergo further metabolism to acetone. The latter process appeared to play a minor role in the overall metabolism of ETBE. Dekant et al. (2001) also noted that many metabolites of the fuel oxygenate ethers, such as formaldehyde, acetaldehyde, tert-butanol, HIBA, or acetone, occur naturally in normal mammalian physiology, providing a highly variable background that needs to be accounted for in metabolic experiments.

JPEC (2008e, 2008f) measured metabolite distribution in the plasma and urine of 7-week-old Crl:CD(SD) male rats (4/dose group) following either a single oral dose of 5 or 400 mg/kg [^14^C]ETBE via gavage or a repeated dose of 5 mg/kg-day for 7 or 14 days. The metabolites were measured in the plasma 8 hours after single or repeated dosing and measured in urine collected on Days 1, 7, and 14 after repeated dosing or during a 24-hour period after administration of the single dose. The number of doses did not appear to affect the metabolic pattern. The study authors determined the identities of five metabolites, and the results in plasma and urine are summarized in Table B-4 and Table B-5, respectively. When combined with what is known of the metabolic pathway for ETBE, these data indicate that ETBE is efficiently metabolized to tert-butanol, which is then metabolized to tert-butanol glucuronide, 2-methyl-1,2-propanediol, and finally to 2-hydroxyisobutyrate.

Although Sun and Beskitt (1995a) did not identify the radiolabel excreted, their investigations do yield information pertinent to determining whether metabolic saturation might occur under bioassay conditions. In their single-exposure protocol, rats and mice were exposed via inhalation to ETBE. These investigators reported the fraction of absorbed dose that was excreted in urine and feces, as expired volatiles, and as expired CO_2_ from one rat and one mouse. At inhaled concentrations between 4,180 and 7,310 mg/m^3^ a shift in the primary route of excretion was observed, as demonstrated by a marked decrease in the fraction of radiolabel excreted in urine and a marked increase in the fraction of radiolabel eliminated as volatiles in expired air, and (in rats) a doubling of the fraction eliminated as exhaled CO_2_. Given the different solubilities, molecular size, and other characteristics of ETBE and its multiple metabolites, it is thought that this shift in the excretion pattern of radiolabel is indicative of a shift in metabolism at these exposure levels.

Considering the potential shift in metabolic pattern relative to the pattern of toxicity can be informative, especially related to species and dose extrapolation. These data might still be considered preliminary because they are from one animal of each species, have not been replicated by other study authors, and the radiolabel has not been speciated as to chemical form. The unfortunate limitation of the application of the physiologically based pharmacokinetic (PBPK) model for human inhalation precludes its combination with rat PBPK models to complete species extrapolation. The inhalation toxicity study by Saito et al. (2013), however, demonstrated an increased incidence of urothelial hyperplasia at an exposure concentration of 6,270 mg/m^3^ and higher, and an increased incidence of hepatocellular adenoma or carcinoma only at an exposure concentration of 20,900 mg/m^3^. Additional data are required to determine whether increases in incidence could be related to pharmacokinetic effects (e.g., metabolic saturation).

Table B-4 Unchanged ETBE and its metabolites in plasma 8 hours after a single oral dose or repeated (7 or 14) daily oral dosing of [^14^C]ETBE to male Crl:CD(SD) rats

Compound | Metabolite | Percentage of dose
Compound | Metabolite | 1 Dose | | 7 Doses | 14 Doses
Compound | Metabolite | 5 mg/kg-d | 400 mg/kg-d | 5 mg/kg-d | 5 mg/kg-d
Unchanged ETBE | ETBE | N.D. | N.D. | N.D. | N.D.
P-1 | 2-Hydroxyisobutyrate | 75.4 ± 8.1^a^ | 35.7 ± 2.5 | 71.4 ± 4.7 | 69.8 ± 7.3
P-2 | tert-Butanol glucuronide | N.D. | N.D. | N.D. | N.D.
P-3 | Not enough to determine | N.D. | N.D. | N.D. | N.D.
P-4 | 2-Methyl-1,2-propanediol | 9.7 ± 2.4 | 9.328 ± 0.9 | 9.1 ± 0.8 | 8.1 ± 1.4
P-5 | tert-Butanol | 12.9 ± 3.1 | 55.0 ± 2.9 | 18.2 ± 3.8 | 22.2 ± 6.0

N.D. = not detected.

a Mean ± standard deviation; n = 4.

Source: JPEC (2008e, 2008f) unpublished reports.

Table B-5 Unchanged ETBE and its metabolites in the urine (measured 0−24 hours) after a single oral dose or repeated (7 or 14) daily oral dosing of [^14^C]ETBE to male Crl:CD(SD) rats

Compound | Metabolite | Percentage of dose
Compound | Metabolite | 1 Dose | | 7 Doses | 14 Doses
Compound | Metabolite | 5 mg/kg-d | 400 mg/kg-d | 5 mg/kg-d | 5 mg/kg-d
Unchanged ETBE | ETBE | 0.7 ± 0.5^a^ | N.D. | 0.9 ± 0.6 | 1.4 ± 0.4
P-1 | 2-Hydroxyisobutyrate | 53.0 ± 3.4 | 55.4 ± 4.7 | 58.9 ± 4.2 | 56.0 ± 5.2
P-2 | tert-Butanol glucuronide | 29.2 ± 3.0 | 25.9 ± 4.6 | 22.8 ± 3.2 | 25.2 ± 5.8
P-3 | Not enough to determine | 2.5 ± 0.2 | 1.7 ± 0.4 | 2.2 ± 0.3 | 1.7 ± 0.4
P-4 | 2-Methyl-1,2-propanediol | 13.1 ± 0.6 | 13.3 ± 2.5 | 13.4 ± 1.5 | 13.9 ± 2.3
P-5 | tert-Butanol | 1.5 ± 0.5 | 3.7 ± 0.6 | 1.9 ± 0.2 | 1.8 ± 0.0

N.D. = not detected.

a Mean ± standard deviation; n = 4.

Source: JPEC (2008e, 2008f) unpublished reports.

Borghoff and Asgharian (1996) evaluated the disposition of a ^14^C radiolabel in F344 rats and CD-1 mice after whole-body and nose-only inhalation exposure to 500, 1,750, or 5,000 ppm [^14^C]ETBE. Besides recovery of total radioactivity in urine, feces, and expired air, the air and urine samples were analyzed for ETBE and tert-butanol. Urine samples were also analyzed for tert-butanol metabolites, HBA and MPD. Results obtained after both a single 6-hour exposure or after 13 days of preexposure to 0, 500, or 5,000 ppm ETBE indicated dose- and preexposure-related shifts in the form and route, likely due to metabolic factors. Excretion shifted from being primarily in the urine after 500 ppm exposure to primarily by exhalation at 5,000 ppm in naïve rats, indicating a saturation of metabolism of ETBE to TBA. This shift was greater in female rats than in males. However, in rats preexposed to 5,000 ppm ETBE for 13 days, most of the excretion was in the urine even at 5,000 ppm. Rats preexposed to 500 ppm ETBE also showed a shift from exhalation to urinary excretion in comparison to naïve rats, but to a smaller degree than elicited by 5,000 ppm preexposure. The changes in excretion after preexposure indicated an induction of the metabolism of ETBE to tert-butanol. As with rats, the fraction of radiolabel in exhaled volatiles in mice increased with exposure level, while the fraction excreted in urine decreased. The exhalation pattern observed in rats showed levels of ETBE falling ~90% in the first 8 hours postexposure, whereas levels of TBA exhaled actually rose between 0 and 3 hours postexposure and then fell more slowly between 3 and 16 hours, particularly after 5,000 ppm ETBE exposure. The increase in TBA between 0 and 3 hours postexposure can be explained by the continued metabolism of ETBE during that period. The slower decline after 3 hours can be explained as a result of the generally slower clearance of TBA, which is saturated by the higher ETBE exposure levels.

##### Metabolism of ETBE in animal tissues in vitro

Using microsomal protein isolated from the olfactory epithelium from male Sprague-Dawley (S-D) rats, Hong et al. (1997a) measured ETBE metabolism as the formation of TBA. They found that metabolism occurred only in microsomal protein (not in cytosol) and only in the presence of an nicotinamide adenine dinucleotide phosphate (NADP)-regenerating system. The metabolic activity was inhibited by 80% after treating the microsomal preparation with carbon monoxide and by 87% in the presence of coumarin (a CYP2A6 inhibitor), which indicates CYP involvement. Using an in vitro concentration of 1 mM ETBE, metabolic activity could not be detected in microsomal protein from the olfactory bulb, lungs, or kidneys. Activity toward ETBE was 8.78, 0.95, and 0.24 nmol/minute-mg microsomal protein in olfactory mucosa, respiratory mucosa, and liver, respectively. In olfactory mucosa, the study authors reported a Km value of 125 μM for ETBE.

Hong et al. (1999b) used hepatic microsomal protein derived from Cyp2e1 knockout mice to investigate whether this enzyme plays a major role in ETBE metabolism. They compared the metabolizing activity of liver microsomes (incubated for 30 minutes at 37°C and with 0.1 mM ETBE) between the Cyp2e1 knockout mice and their parental lineage strains using four or five female mice (7 weeks of age) per group. The ETBE-metabolizing activities were not significantly different between the Cyp2e1 knockout strain (0.51 ± 0.24 nmol/minute-mg protein) compared with those observed in the Cyp2e1 wild-type parental strains (0.70 ± 0.12 for C57BL/6N mice, and 0.66 ± 0.14 for 129/Sv mice). Therefore, microsomal protein from mice that did not express any CYP2E1 did not differ from microsomal protein derived from wild-type animals in their ability to metabolize ETBE in vitro, suggesting that CYP2E1 might contribute only little to ETBE metabolism in vivo. Furthermore, these authors evaluated potential sex- and age-dependent differences for the metabolism of 1 mM concentrations of ETBE by hepatic microsomal protein. Although activities in female knockout mice were approximately 60% of those in male knockout mice, the difference did not reach the level of statistical significance. Finally, observed rates of ETBE metabolism (approximately 0.5 to 0.9 nmol/min/mg microsomal protein) did not seem to differ when assayed at 0.1 or 1 mM, indicating that for mouse hepatic microsomal ETBE metabolism, saturation can occur at concentrations no higher than 0.1 mM in vitro, and that Km values would be expected to be lower than 0.1 mM in vitro.

Turini et al. (1998) investigated the effects of ETBE exposure on P450 content and activities, and characteristics of ETBE metabolism in hepatic microsomal protein from male Sprague-Dawley rats in an attempt to elucidate the role of CYP2E1 in ETBE metabolism. Administration of ETBE at 200 or 400 mg/kg for 4 days did not alter hepatic CYP profiles, but the administration of 2 mL ETBE/kg resulted in significant increases of metabolic activities toward substrates characteristic for CYP2B and CYP2E1 (p-NPH) forms, but not of activities catalyzed by CYP3A or 1A forms. Studies of ETBE metabolism were based on high-performance liquid chromatography detection of the acetaldehyde ETBE metabolite. Induction of CYP2B forms in vivo via the administration of phenobarbital slightly reduced the Km value and produced a significant, approximate threefold increase in V_max_; in these preparations; chemical inhibition of CYP2B forms resulted in significant inhibition of ETBE metabolism. Studies with CYP enzymes purified from rats confirmed metabolic competency of several CYP forms, with the activity of purified rat CYP forms 2B1 > 2E1 > 1A1 > 2C11. Chemical inhibition of CYP2E1 did not reduce ETBE metabolic activity; CYP2A forms were not evaluated. In microsomal preparations from rats treated with phenobarbital (a CYP2B inducer), incubation with chemical inhibitors of CYP2B forms produced a significant decrease in ETBE metabolism. Pretreatment of rats with chemicals known as inducers of CYP2E1, CYP3A, and CYP1A forms did not result in significant changes in Km or V_max_ values for ETBE metabolism, as measured in vitro. The results of these investigations indicate that, in rats, CYP2E1 is apparently minimally involved in ETBE metabolism, and that under some conditions, CYP2B forms can contribute to ETBE metabolism. The role of CYP2A forms was not studied in this investigation. This study also investigated the kinetic constants for ETBE metabolism in control rat hepatic microsomal protein, indicating a Km value of 6.3 mM and a V_max_ value of 0.93 nmol/min/mg microsomal protein. When compared with the kinetic constants indicated by the results of Hong et al. (1999b), the rate of ETBE metabolism at in vitro concentrations below 1 mM are expected to be higher in mouse than in rat microsomal preparations.

The enzymes that metabolize tert-butanol to MPD, HIBA, and even acetone, have not been fully characterized; however, tert-butanol is not subject to metabolism by alcohol dehydrogenases (Dekant et al., 2001).

### B.1.4 Excretion

#### Excretion in Humans

Nihlén et al. (1998) exposed eight healthy male volunteers (average age 29 years) to 20.9, 104, and 209 mg/m^3^ ETBE by inhalation for 2 hours. ETBE, and two metabolites (tert-butanol and acetone) were measured in urine for up to 22 hours after exposure. The blood profiles of the parent compound and metabolites were similar at all three exposure levels and reflected exposure concentrations. The study authors estimated the inhaled amount of ETBE in the volunteers to be 0.58, 2.9, and 5.8 mmol for the 20.9-, 104-, and 209-mg/m^3^ exposure levels, respectively. Based on blood AUC values for ETBE and metabolites, the authors calculated respiratory uptake to be 32−34% in humans and the net uptake (which excludes ETBE exhaled during exposure) to be 26% of the dose at all three exposure levels. During the 24 hours following the start of inhalation exposure, respiratory expiration was calculated at 45−50% of the inhaled ETBE (respiratory uptake), and net respiratory expiration was 31% (of the net respiratory uptake), of which tert-butanol accounted for only 1.4−3.8%. Urinary excretion of parent ETBE (as percentage of the respiratory uptake of ETBE) accounted for even less: 0.12, 0.061, and 0.056% after the exposures to 20.9, 104, and 209 mg/m^3^, respectively. The authors identified four phases of excretion of ETBE from blood, with half-lives of about 2 and 20 minutes and 1.7 and 28 hours. Only one phase for excretion of tert-butanol from blood was identified with a half-life of 12 hours compared with 10 hours in another study with volunteers (Johanson et al., 1995). In urine, ETBE displayed two phases of excretion, with half-lives of about 8 minutes and 8.6 hours. The half-life of tert-butanol in urine was determined to be 8 hours (Johanson et al., 1995).

ETBE displayed a multiphasic excretion from blood. The first phase likely indicates uptake into highly perfused tissues. The other phases could indicate uptake into less perfused tissues and fat or result from metabolism events. The apparent total body clearance of ETBE (based on the net respiratory uptake) was 0.57 L/hour-kg (average of the three exposure levels). The metabolic clearance was calculated as 0.39 L/hour-kg and the exhalation clearance as 0.35 L/hour-kg. These authors reported that the kinetics of ETBE in humans was linear over the range of concentrations studied (Nihlén et al., 1998).

In the study by Amberg et al. (2000) that was described earlier, two excretion half-lives were found for ETBE (1.1 ± 0.1 and 6.2 ± 3.3 hours) at the high exposure concentration (170 mg/m^3^), although tert-butanol displayed only one half-life (9.8 ± 1.4 hours). At the low exposure concentration (18.8 mg/m^3^), only the short half-life for ETBE could be measured at 1.1 ± 0.2 hours, although that for tert-butanol was 8.2 ± 2.2 hours. The predominant urinary metabolite, identified was HIBA, was excreted in urine at 5−10 times the amount of MPD and 12−18 times the amount of tert-butanol (note: urine samples had been treated with acid before analysis to cleave conjugates). Excretion of unchanged ETBE in urine was minimal. The time courses of urinary excretion for 170 and 18.8 mg/m^3^ were similar, but relative urinary levels of HIBA after 18.8 mg/m^3^ were higher, although those for MPD were lower, as compared to 170 mg/m^3^. HIBA in urine showed a broad maximum at 12−30 hours after exposure to both concentrations, with a slow decline thereafter. MPD in urine peaked at 12 and 18 hours after 170 and 18.8 mg/m^3^, respectively, although tert-butanol peaked at 6 hours after both concentrations. The time to peak of the three metabolites reflected the sequence of their formation and interconversion as ETBE is metabolized. Interindividual variations were large, but the authors did not report differences in the toxicokinetics of ETBE by sex. Amberg et al. (2000) calculated that 43 ± 12% of the 170 mg/m^3^ dose and 50 ± 20% of the 18.8 mg/m^3^ dose had been excreted in urine by 72 hours. Respiratory elimination was not monitored.

#### Excretion in Animals

Amberg et al. (2000) exposed F344 NH rats, 5/sex/dose, concurrent with the human volunteers in the same exposure chamber. Urine was collected for 72 hours following exposure. Like humans, rats excreted mostly HIBA in urine, followed by MPD and tert-butanol. Parent ETBE was not identified in rat urine. The half-life for tert-butanol in rat urine was 4.6 ± 1.4 hours at 170 mg/m^3^ but could not be calculated at 18.8 mg/m^3^. Corresponding half-lives were 2.6 ± 0.5 and 4.0 ± 0.9 hours for MPD, and 3.0 ± 1.0 and 4.7 ± 2.6 hours for HIBA. The authors concluded that rats excreted ETBE considerably faster than humans. Urinary excretion accounted for 53 ± 15 and 50 ± 30% of the estimated dose at 170- and 18.8-mg/m^3^ exposures, respectively, with the remainder of the dose being eliminated via exhalation, as suggested by the study authors.

Bernauer et al. (1998) studied the excretion of [^13^C]ETBE and MTBE in rats. F344 rats, 2/sex, were exposed via inhalation to 8,400 mg/m^3^ ETBE or 7,200 mg/m^3^ MTBE for 6 hours, or 3 male F344 rats received 250 mg/kg tert-butanol by gavage. Urine was collected for 48 hours, and the ETBE metabolite prevalence in urine was

MPD > HIBA > tert-butanol-sulfate > tert-butanol-glucuronide. Oral administration of tert-butanol produced a similar metabolite profile, with relative amounts of

HIBA > tert-butanol-sulfate > MPD >> tert-butanol-glucuronide ≈ tert-butanol.

Although there are several unpublished reports relevant to the elimination of ETBE following inhalation exposure, no additional peer-reviewed publications were identified. Unpublished reports have not gone through the public peer-review process and are of unknown quality. They are included here as additional information only.

During 96 hours in metabolic cages, rats excreted approximately 60% of the radioactivity in urine, approximately 38% was recovered as exhaled organic volatiles, and approximately 1% as exhaled CO_2_. This pattern was maintained at an exposure concentration of 4,180 mg/m^3^; above that, urinary excretion of radioactivity decreased to 34% of the recovered radioactivity, although exhalation of organic volatiles increased to 63%. A shift in the excretion profile of radiolabel was seen at concentrations of 7,310 mg/m^3^ and above, which remained fairly constant to the highest exposure of 20,900 mg/m^3^. In this range of concentrations, approximately 39% of the excreted radiolabel was found in urine, approximately 58% was exhaled as organic volatiles, and 2% was eliminated as exhaled CO_2_.

A review of the data demonstrating the percentage of recovered radiolabel via various routes of elimination demonstrate, in the rat and mouse, a pattern indicative of metabolic saturation occurring at inhaled concentrations above 4,180 mg/m^3^.

In rats, the time course of excretion indicated that exhalation of organic volatiles was essentially complete by 24 hours, although urinary excretion of ETBE-derived radioactivity displayed a broad peak at 12−48 hours. The bulk of each dose was excreted within 48 hours after the end of exposure. At 20,900 mg/m^3^, ^14^CO_2_ exhalation and fecal excretion of radioactivity remained rather constant from 12 to 118 hours. In comparing the total radiolabel excreted to the inhaled concentrations (see Table B-6), a proportionate relationship is observed in rats at all concentrations, but less than proportionate excretion of total radiolabel at the highest concentration in mice. The complete data set led the study authors to conclude that saturation of the inhalation absorptive processes might have occurred at concentrations of approximately 7,310 mg/m^3^. The findings of Sun and Beskitt (1995a) in mice at 20,900 mg/m^3^ were essentially confirmed by Borghoff (1996) (unpublished report, a pilot study) and Borghoff and Asgharian (1996) (unpublished report, final study), which used the identical species, experimental protocol, materials, and methods but which were conducted later at a different laboratory (see Table B-6).

Table B-6 Excretion of [^14^C]ETBE-derived radioactivity from rats and mice within 96 hours following a single 6-hour inhalation exposure

Exposure level (mg/m^3^) | Volatile organics^a^ | Exhaled CO_2_^a^ | Urine^a^ | Feces^a^ | Total^b^
F344 rat ^c^
2,090^d^ | 37; [28, 32] | 1; [1.2, 1.3] | 60; [59, 59] | 2; [2.8, 1.0] | 9.9; [16.1, 13.6]
3,130 | 36 | 1 | 62 | 2 | 17.5
4,180 | 42 | 1 | 56 | 2 | 22.1
7,310^d^ | 58; [41, 52] | 2; [1.5, 1.7] | 38; [53, 41] | 3; [0.7, 0.5] | 56.9; [45, 31]
10,400 | 52 | 2 | 45 | 2 | 56.2
20,900^d,e^ | 63; (51); [51, 64] | 2; (1); [1.6, 2.0] | 34; (44); [45, 30] | 1; (3); [0.2, 0.2] | 97.5; (116); [143, 94]
CD-1 mouse ^f^
2,090^d^ | 10; [12.7, 26.8] | 1; [1.2, 1.2] | 74; [81.3, 67.2] | 16; [3.2, 2.3] | 6.38; [10.4, 6.8]
3,130 | 28 | 2 | 60 | 10 | 7.9
4,180 | 29 | 2 | 64 | 6 | 12.8
7,310^d^ | 42; [23, 36] | 2; [2.2, 1.9] | 46; [71, 61] | 10; [1.1, 0.6] | 13.7; [22.4, 17.3]
10,400 | 42 | 2 | 47 | 10 | 22.7
20,900^d,e^ | 44; (37); [40, 47] | 5; (2); [2.9, 3.3] | 39; (57); [53, 47] | 12; (2); [0.6, 0.8] | 18.9; (28); [37.1, 25.2]

a Percentage of total excreted radioactivity; mean of one male and one female.

b In mg [^14^C]ETBE equivalents.

c Sun and Beskitt (1995b).

d Values in brackets: [males, females], nose-only exposures, excretion up to 48 h Borghoff and Asgharian (1996).

e Values in parentheses: Borghoff (1996).

f Sun and Beskitt (1995b).

Similarities between rats (Sun and Beskitt, 1995b) and mice (Sun and Beskitt, 1995a) are evident. Both species demonstrate similar excretion pathways and present evidence of saturation of metabolic pathways at concentrations lower than those that demonstrate saturation of absorptive pathways. Metabolic saturation (evidenced as a shift from urine as the predominant excretion pathway and an increase in the fraction of dose eliminated via exhalation) occurred in both species at concentrations approximating 7,310 mg/m^3^. Noteworthy differences between the two species were that, in general, mice excreted a smaller percentage of the dose in the form of volatile organics and a higher amount in urine, at least up to 4,180 mg/m^3^ (see Table B-6), compared with rats and that mice excreted about five times as much [^14^C]ETBE-derived radioactivity via feces than did rats. The total amounts of excreted radioactivity (mg equivalents) were considerably higher in rats than in mice; however, the values in the respective columns of Table B-6 are not corrected for body weight (BW). When normalized to body weight, it is apparent that mice absorbed a higher dose than rats; however, the total excreted radioactivity at 20,900 mg/m^3^ showed no further increase over the values at 10,450 mg/m^3^, indicating that the absorptive capacities of mice had become saturated; however, this analysis conducted in rats does not indicate a saturation of absorptive capacities over the range of concentrations studied.

Borghoff (1996), in an unpublished report, conducted studies to establish experimental conditions for future bioassays of ETBE, based on the two studies previously conducted by Sun and Beskitt (1995a, 1995b). The experimental protocol and materials were identical to the ones used by Sun and Beskitt (1995a, 1995b); however, in this pilot study, only three male F344 rats and three male CD-1 mice were used per experiment, with only one exposure level at 20,900 mg/m^3^. Also, only blood was collected from the animals, while the whole carcasses were liquefied and assayed for retained radioactivity immediately after exposure and after the end of the animals’ stay in metabolic cages. The carbon at “the central position of the tert-butyl group” was radiolabeled. Radioactive ETBE was obtained by mixing [^14^C]ETBE with unlabeled material in the gas phase for a specific activity of 2.74 μCi/mmol. The rats, when assayed immediately after exposure, were found to have absorbed 2.57 ± 0.14 μCi radioactivity, although the balance of radioactivity after 96 hours in metabolic cages from other animals accounted for 3.17 ± 0.08 μCi (mean ± standard deviation [SD], n = 3). The authors could not make any suggestion as to the origin of this discrepancy. Absorbed doses in mice were 0.85 ± 0.08 μCi immediately after exposure and 0.77 ± 0.16 μCi for other mice placed in metabolism cages. Excretion values detected in these rats and mice are shown in parentheses in Table B-6; the percentage values shown in this table were based on the total body burden of the individual animals from which the excretion data were obtained, not on group means.

Mice had excreted most of the dose within 12 hours after exposure, rats within 24 hours. Organic volatiles collected on charcoal filters were analyzed for ETBE and tert-butanol contents. Rats exhaled 22% of the absorbed ETBE within 1 hour after exposure, 12% during the following 2 hours, and only another 3% during the next 3 hours. tert-Butanol exhalation accounted for 1% of the total during the first hour, 3% during the following 2 hours, and 4% during the last 3 hours of the experimental period. Mice, on the other hand, exhaled 16% of the unmetabolized ETBE within 1 hour after exposure and 1% during the following 2 hours, with immeasurable amounts thereafter. tert-Butanol exhalation made up 6% of total during the first hour, 8% in the next 2 hours, and 4% during the final 3 hours. Excretion of ETBE, tert-butanol, HIBA, and MPD in urine were assayed. During 24 hours of collection, the rats excreted about 7 times as much tert-butanol as ETBE in urine; in mice, the ratio was >60. HIBA was detected in urine of both species but could not be quantified. MPD was not detected. These results could be interpreted as suggesting that mice metabolize, and hence excrete, ETBE faster than rats.

A subsequent larger study by Borghoff and Asgharian (1996) (see previous details) essentially confirmed the results of the pilot study (Borghoff, 1996). F344 rats and CD-1 mice were exposed by inhalation to 500, 1,750, or 5,000 ppm [^14^C]ETBE. Concentrations of ETBE and tert-butanol were measured in exhaled breath up to 16 hours postexposure. The exhalation pattern observed in rats showed levels of ETBE falling ~90% in the first 8 hours postexposure, while levels of TBA exhaled actually rose between 0 and 3 hours postexposure and then fell more slowly between 3 and 16 hours, particularly after 5,000 ppm ETBE exposure. The increase in TBA between 0 and 3 hours postexposure can be explained by the continued metabolism of ETBE during that period. The slower decline after 3 hours can be explained by the generally slower clearance of TBA, which is saturated by the higher ETBE exposure levels. Exhaled breath levels declined much more rapidly in mice than in rats.

Unpublished reports by JPEC (2008e) determined that following oral exposure of 7-week-old Crl:CD(SD) male rats to [^14^C]ETBE, the largest amount of radioactivity was recovered in expired air, followed by urinary excretion, with very little excretion occurring via the feces. With increasing dose, increasing proportions of radioactivity were found in expired air. The total radioactivity recovered by 168 hours after a single dose of 5 mg/kg [^14^C]ETBE was 39.16% in the urine, 0.58% in the feces, and 58.32% in expired air, and, after a single dose of 400 mg/kg, 18.7% in the urine, 0.15% in the feces, and 78.2% in expired air. With repeated dosing, the recovery of radioactivity through excretion increased through Day 6 when a steady state was achieved; however, the radioactivity level in the feces increased throughout the 14 days, but the level was too low to affect the total recovery. After 14 days, 36.3% of the administered dose was recovered in the urine, 2.33% was recovered in the feces, and 56.7% was recovered in expired air.

### B.1.5 Physiologically Based Pharmacokinetic Models

Two PBPK models have been developed specifically for describing the absorption, distribution, metabolism, and excretion of ETBE in rats (Borghoff et al., 2016; Salazar et al., 2015). A detailed summary of these and other toxicokinetic models is provided in U.S. EPA (2017). The PBPK model described in Borghoff et al. (2016) and in U.S. EPA (2017) was considered to conduct a route-to-route extrapolation based on an equivalent internal dose (the rate of ETBE metabolism in the liver), but was not ultimately used for this purpose because of feedback from external peer review by EPA’s Science Advisory Board (SAB). The SAB recommended that in the absence of a consistent dose-response relationship for ETBE when combining oral and inhalation studies to assess liver tumors, extrapolation between inhalation and oral routes of exposure not be performed. Regarding the extrapolation from animals to humans, the existing human PBPK model was not considered adequate (see below); therefore, default methodologies were applied to extrapolate toxicologically equivalent exposures from adult laboratory animals to adult humans.

The PBPK model described in Borghoff et al. (2016) and in U.S. EPA (2017) includes a possible adjustment for induction of tert-butanol metabolism; however, this induction has only been observed in mice exposed directly to tert-butanol (McComb and Goldstein, 1979). Furthermore, implementing metabolic induction does not allow for dependence on exposure or dose, nor for any de-induction that might occur during periods without exposure, such as weekends during 5 days/week exposures. Finally, because induction is expected to have an equal impact on oral and inhalation exposures―and only if tert-butanol levels or metabolism is used as a dose metric―induction’s potential impact on risk evaluation for ETBE is considered minimal. Therefore, this adjustment was not turned off in the model; instead, the maximum induction level was set to zero.

While model simulations accounted for variations during the day and week (e.g., 6 hours/day, 5 days/week inhalation exposure), simulations reached a condition of “periodicity” by the second week, such that the time course of internal doses were identical between the second week and subsequent weeks of exposure with metabolic induction turned off. However, to ensure applicability should metabolic induction is considered (predicted to take 2−3 weeks), simulations were generally run for 7 weeks, with results for the last 1−2 weeks used to estimate average tissue or blood concentrations or metabolic rates.

For simulating exposure to drinking water, the water consumption was modeled as episodic, based on the pattern of drinking observed in rats (Spiteri, 1982). In particular, rats were assumed to ingest water in pulses or “bouts,” which were treated as periods of continuous ingestion, interspersed with periods of no ingestion. During the active dark period (12 hours/day), 80% of total daily ingestion is assumed to occur in 45-minute bouts alternating with 45 minutes of other activity. During the relatively inactive light period (12 hours/day), the remaining 20% of daily ingestion is assumed to occur; the bouts are only assumed to last 30 minutes, with 2.5 hours between. This pattern is thought to be more realistic than assuming continuous 24 hours/day ingestion. The resulting ingestion rate for one exposure is shown in Figure B-2.

Figure B-2 Example oral ingestion pattern for rats exposed via drinking water

PBPK modeling was also used to evaluate a variety of internal dose metrics (daily average TBA blood concentration, daily amount of TBA metabolized in liver, daily average of ETBE blood concentration, and daily amount of ETBE metabolized in liver) to assess the correlation with different endpoints following exposure to ETBE or TBA (Salazar et al., 2015). Administering ETBE either orally or via inhalation achieved similar or higher levels of TBA blood concentrations or TBA metabolic rates as those induced by direct TBA administration. Altogether, the PBPK model-based analysis by Salazar et al. (2015)[which applied a model structurally similar to Borghoff et al. (2016)] indicated a consistent dose-response relationship between kidney weight, urothelial hyperplasia, and chronic progressive nephropathy (CPN) and TBA blood concentration (as the dose metric for both ETBE and TBA). Kidney and liver tumors, however, were not consistently correlated with any dose metric. These data are consistent with TBA mediating the noncancer kidney effects following ETBE administration, but additional factors besides internal dose are necessary to explain the induction of liver and kidney tumors.

Figure B-3 Comparisons of liver tumors in male rats following 2-year oral or inhalation exposure to ETBE or tert-butanol with internal dose metrics calculated from the PBPK model

Results applying the model of Salazar et al. (2015) (top) and Borghoff et al. (2016) (bottom).

Salazar et al. (2015)

Borghoff et al. (2016)

Dose metrics expressed are metabolism rate of tert-butanol (A) and metabolism rate of ETBE (B). Liver tumor incidences following ETBE oral or inhalation exposure did not present a consistent dose-response relationship using either the ETBE or tert-butanol metabolism rate dose metric, and the correlation coefficients was not statistically significant. These data indicate that internal dose is inadequate to explain differences in tumor response across these studies.

### B.1.6 Physiologically Based Pharmacokinetic (PBPK) Model Code

The PBPK acslX model code is available electronically through EPA’s Health and Environmental Research Online (HERO) database. All model files may be downloaded in a zipped workspace from HERO (U.S. EPA, 2016).

### B.1.7 Physiologically Based Pharmacokinetic (PBPK) Model Evaluation

All available PBPK models of ETBE and its principal metabolite tert-butanol were evaluated for potential use in the assessment.

#### Overview of Available Models

A PBPK model of ETBE and its principal metabolite tert-butanol has been developed for humans exposed while performing physical work (Nihlén and Johanson, 1999). The Nihlén and Johanson model is based on measuring blood concentrations of 8 individuals exposed to 5, 25, and 50 ppm ETBE for 2 hours while physically active. This model differs from conventional PBPK models in that the tissue volumes and blood flows are calculated from individual data on body weight and height. Additionally, to account for physical activity, blood flows to tissues are expressed as a function of the workload. These differences from typical PBPK models preclude allometric scaling of this model to other species for cross-species extrapolation. As there are no oral exposure toxicokinetic data in humans, this model does not have a mechanism for simulating oral exposures, which prevents its use in animal-to-human extrapolation for that route.

A number of PBPK models were developed previously for the related compound, MTBE and the metabolite tert-butanol that is common to both MTBE and ETBE (Borghoff et al., 2010; Leavens and Borghoff, 2009; Blancato et al., 2007; Kim et al., 2007; Rao and Ginsberg, 1997; Borghoff et al., 1996). A PBPK model for ETBE and tert-butanol in rats was then developed by the EPA (Salazar et al., 2015) by integrating information from across these earlier models. Another model for ETBE and tert-butanol was published by Borghoff et al. (2016), adapted with modest structural differences from the Leavens and Borghoff (2009) MTBE/tert-butanol model. Brief descriptions below highlight the similarities and differences between the MTBE/tert-butanol models of Blancato et al. (2007) and Leavens and Borghoff (2009), and the ETBE/tert-butanol models of Salazar et al. (2015), and Borghoff et al. (2016).

#### The Models of Blancato et al. (2007) and Leavens and Borghoff (2009)

The Blancato et al. (2007) model is an update of the earlier Rao and Ginsberg (1997) model, and the Leavens and Borghoff (2009) model is an update of the Borghoff et al. (1996) model. Both the Blancato et al. (2007) and Leavens and Borghoff (2009) models are flow-limited models that predict amounts and concentrations of MTBE and its metabolite tert-butanol in blood and six tissue compartments: liver, kidney, fat, brain, and rapidly and slowly perfused tissues. These tissue compartments are linked through blood flow, following an anatomically accurate, typical, physiologically based description (Andersen, 1991). The parent (MTBE) and metabolite (tert-butanol) models are linked by the metabolism of MTBE to tert-butanol in the liver. Oral and inhalation routes of exposure are included in the models for MTBE; Leavens and Borghoff (2009) also included oral and inhalation exposure to tert-butanol. Oral doses are assumed to be 100% bioavailable and 100% absorbed from the gastrointestinal tract represented with a first-order rate constant. Following inhalation of MTBE or tert-butanol, the chemical is assumed to enter the systemic blood supply directly, and the respiratory tract is assumed to be at pseudo-steady state. Metabolism of MTBE by CYP450s to formaldehyde and tert-butanol in the liver is described with two Michaelis-Menten equations representing high- and low-affinity enzymes. tert-Butanol is either conjugated with glucuronide or sulfate or further metabolized to acetone through MPD and HBA; the total metabolic clearance of tert-butanol by both processes is described by a single Michaelis-Menten equation in the models. All model assumptions are considered valid for MTBE and tert-butanol.

In addition to differences in fixed parameter values between the two models and the addition of exposure routes for tert-butanol, the Leavens and Borghoff (2009) model has three features not included in the Blancato et al. (2007) model: (1) the alveolar ventilation was reduced during exposure, (2) the rate of tert-butanol metabolism was increased over time to account for induction of CYP enzymes, and (3) binding of MTBE and tert-butanol to alpha 2u-globulin was simulated in the kidney of male rats. The Blancato et al. (2007) model was configured through EPA’s PBPK modeling framework, Exposure-Related Dose Estimating Model, which includes explicit pulmonary compartments. The modeling assumptions related to alveolar ventilation, explicit pulmonary compartments, and induction of metabolism of tert-butanol are discussed in the model evaluation section below.

MTBE and tert-butanol binding to alpha 2u-globulin in the kidneys of male rats were incorporated in the PBPK model of MTBE by Leavens and Borghoff (2009). Binding to alpha 2u-globulin is one hypothesized mode of action for the observed kidney effects in MTBE-exposed animals. For a detailed description of the role of alpha 2u-globulin and other modes of action in kidney effects, see the kidney mode-of-action section of the Toxicological Review. In the Leavens and Borghoff (2009) model, binding of MTBE to alpha 2u-globulin was applied to describe sex differences in kidney concentrations of MTBE and tert-butanol, but acceptable estimates of MTBE and tert-butanol pharmacokinetics in the blood are predicted in other models that did not consider alpha 2u-globulin binding. Moreover, as discussed below, the EPA’s implementation of the Leavens and Borghoff (2009) model did not adequately fit the available tert-butanol i.v. dosing data, adding uncertainty to the parameters they estimated.

The Blancato et al. (2007) and Leavens and Borghoff (2009) PBPK models for MTBE were specifically evaluated by comparing predictions from the tert-butanol portions of the models with the tert-butanol i.v. data of Poet et al. (1997) (see Figure B-4). Neither model adequately represented the tert-butanol blood concentrations. Modifications of model assumptions for alveolar ventilation, explicit pulmonary compartments, and induction of metabolism of tert-butanol did not significantly improve model fits to the data.

Figure B-4 Comparison of the tert-butanol portions of existing methyl tertiary butyl ether models with tert-butanol blood concentrations from i.v. exposure byPoet et al. (1997)

Neither the (A) Blancato et al. (2007) nor the (B) Leavens and Borghoff (2009) model adequately represents the measured tert-butanol blood concentrations.

(A)

(B)

#### The Model of Salazar et al. (2015)

To better account for the tert-butanol blood concentrations after intravenous tert-butanol exposure, the model by Leavens and Borghoff (2009) was modified by adding a pathway for reversible sequestration of tert-butanol in the blood (Salazar et al., 2015). Sequestration of tert-butanol was modeled using an additional blood compartment, into which tert-butanol can enter reversibly, represented by a differential mass balance (see Figure B-5). Other differences in model structure are that the brain was included in the other richly perfused tissues compartment and that binding to alpha 2u-globulin was not included. Binding to alpha 2u-globulin was neglected because it was assumed to not significantly affect the blood concentration or metabolic rate of ETBE to TBA, the two dose metrics being used for route-to-route extrapolation. This model improved the fit to tert-butanol blood concentrations after tert-butanol i.v. exposures [see Salazar et al. (2015)]. Additionally, the model adequately estimated the tert-butanol blood concentrations after inhalation and gavage exposures. The ETBE submodel was based on the MTBE component of the Leavens and Borghoff (2009) model. The model assumed two-pathways for metabolism of ETBE to TBA, and the metabolic parameters were optimized to fit toxicokinetic data. Partition coefficients of ETBE were based on data of Nihlén and Johanson (1999).

Figure B-5 Schematic of theSalazar et al. (2015) PBPK model for ETBE and its major metabolite tert-butanol in rats

Exposure can be via multiple routes including inhalation, oral, or i.v. dosing. Metabolism of ETBE and tert-butanol occur in the liver and are described by Michaelis-Menten equations with two pathways for ETBE and one for tert-butanol. ETBE and tert-butanol are cleared via exhalation, and tert-butanol is additionally cleared via urinary excretion.

#### The Model of Borghoff et al. (2016)

The Borghoff et al. (2016) models for ETBE and tert-butanol were based on Leavens and Borghoff (2009), including binding of ETBE and TBA to alpha 2u-globulin and induction of tert-butanol metabolism, with some structural changes. The revised model lumped gastrointestinal tract tissue and brain tissue into the richly perfused compartment [Leavens and Borghoff (2009) modeled these compartments separately]. Borghoff et al. (2016) assumed that urinary clearance was a function of central venous blood concentration and effectively occurs from that compartment, as opposed to clearance from the kidney venous blood assumed by Leavens and Borghoff (2009). Using the new structure, urinary clearance was reparameterized to fit the intravenous data by Poet et al. (1997). The model assumed a single oxidative metabolic pathway for metabolism of ETBE to tert-butanol using parameters from Rao and Ginsberg (1997), instead of the two-pathway models assumed by Leavens and Borghoff (2009) (for MTBE) and Salazar et al. (2015). The model did not incorporate the tert-butanol blood sequestration kinetics included in the tert-butanol model. It did, however, incorporate the oral absorption rate of tert-butanol estimated by Salazar et al. (2015). Partition coefficients for ETBE were obtained from Kaneko et al. (2000) and from metabolic parameters. Rate constants for binding of ETBE to alpha 2u-globulin and its dissociation were assumed to be the same as estimated for MTBE by Leavens and Borghoff (2009). Finally, unlike Leavens and Borghoff (2009), Borghoff et al. (2016) assumed a lower-bound alveolar ventilation for all times and exposures, not just during periods of inhalation exposure.

To simulate induction of tert-butanol metabolism, the default metabolic rate of tert-butanol clearance is multiplied by an exponential function of the form [1 + A(1 − e^−kt^)], where A is the maximum fold increase above baseline metabolism, k is the rate constant for the ascent to maximum induction, and t is time. Because metabolic induction does not occur instantaneously, but involves a delay for induction of ribonucleic acid transcription and translation, Borghoff et al. (2016) assumed that induction did not begin until 24 hours after the beginning of exposure. But the computational implementation then treated the effect as if the enzyme activity suddenly jumped each 24 hours to the level indicated by the time-dependent equation shown in the paper. This stepwise increase in activity was not considered realistic. Therefore, in evaluating the impact of induction, the EPA treated the induction as occurring continuously with time but beginning at 12 hours after the start of exposure. This change would not affect long-term steady-state or periodic simulations, in particular those used to characterize bioassay conditions, but has a modest effect on simulations between 12 and 24 hours, which are compared to experimental data below for the purpose of model validation. However, with further review of the existing data on liver histology (which would also reflect metabolic induction if it occurs, as detailed below), the EPA determined that it is likely to only occur at the very highest exposure levels and hence not at levels where the model is applied for route-to-route extrapolation. Therefore, the maximal induction was set to zero unless otherwise noted.

The form of the equations for hepatic metabolism in the Borghoff et al. (2016) model was revised to be a function of the free liver concentration, specifically the concentration in the venous blood leaving the liver, rather than the concentration in the liver tissue. To maintain the integrity of all prior model simulations and parameter estimations, EPA updated the Michaelis-Menten constants (Km’s) for ETBE and TBA by scaling them by the liver:blood partition coefficients. As a result, the model produces identical results as before without reestimating a fitted parameter.

Finally, a discrepancy between the pulmonary ventilation value as described by Borghoff et al. (2016), in particular as the lower limit of values reported by Brown et al. (1997), should be noted. Borghoff et al. (2016) claimed that an allometric coefficient of 18.9 L/hour/kg^0.75^ (allometric coefficient provided here reflects actual use in model code) is the lower limit. For a 0.25 kg rat, this value yields an absolute ventilation rate of 6.6822 L/hour or 111.37 mL/min. In Table 31 of Brown et al. (1997), the mean and range of values given for the rat are 52.9 and 31.5−137.6 mL/min/(100 g BW). From the text immediately following this table, it is clear that these mean and range values are not scaled to BW^0.75^, but exactly as indicated. Hence for a 250 g rat they correspond to 132.25 and 78.75−344 mL/min. Use of 18.9 L/hour/kg^0.75^ corresponds to a ventilation rate 61% of the way between the lower limit and the mean for a 0.25 kg rat. Note that 31.5 mL/min/100 g BW, the actual lower limit, equals 18.9 L/hour/kg^1.0^ (i.e., the respiration per kg BW, not per kg BW^0.75^). Thus, the discrepancy appears due to a mistaken translation in allometric scaling.

The fact that Borghoff et al. (2016) and Leavens and Borghoff (2009) used a ventilation rate closer to the mean than the lower limit may explain why it was also necessary to incorporate a fraction of TBA available for alveolar absorption of 0.6. From considering the plots of model simulations versus data below, it appears that model fits to the data would be improved by further decreasing ventilation, which could now be justified. But EPA has chosen to keep the value of alveolar ventilation (QPC) and absorption fraction as published by Borghoff et al. (2016).

Figure B-6 Schematic of the Borghoff et al. (2016) PBPK model for ETBE and its major metabolite tert-butanol in rats

Table B-7 PBPK model physiological parameters and partition coefficients^a^

Parameter | Value | Source or reference
Body weight and organ volumes as fraction of body weight
Body weight (kg) | 0.25 | Brown et al. (1997)
Liver | 0.037 | Brown et al. (1997)
Kidney | 0.0073 | Brown et al. (1997)
Fat | 0.35 × BW + 0.00205 | Brown et al. (1997)
Richly perfused (total) | 0.136 | Brown et al. (1997)
Richly perfused | 0.0177 | ^b^
Poorly perfused (total) | 0.757 | Brown et al. (1997)
Poorly perfused | 0.75495 − 0.35 × BW
Blood | 0.074 | Brown et al. (1997)
Rest of body (not perfused) | 0.107 | Brown et al. (1997)
Cardiac output and organ blood flows as fraction of cardiac output
Cardiac output (L/h-kg) | 18.9 | Brown et al. (1997) ^c^
Alveolar ventilation (L/h-kg) | 18.9 | Brown et al. (1997) ^c^
Liver | 0.174 | Brown et al. (1997) ^d^
Kidney | 0.141 | Brown et al. (1997)
Fat | 0.07 | Brown et al. (1997)
Richly perfused (total) | 0.47 | ^e^
Richly perfused | 0.155 | ^f^
Poorly perfused (total) | 0.53 | Brown et al. (1997)
Poorly perfused | 0.46 | ^g^
Partition coefficients for ETBE
Blood:air | 11.6 | Kaneko et al. (2000)
Liver:blood | 2.9 | Kaneko et al. (2000)
Fat:blood | 11.7 | Kaneko et al. (2000)
Richly perfused:blood | 2.9 | Kaneko et al. (2000)
Poorly perfused:blood | 1.9 | ^h^
Kidney:blood | 2.9 | ^i^
Partition coefficients for tert-butanol
Blood:air | 481 | Borghoff et al. (1996)
Liver:blood | 0.83 | Borghoff et al. (1996)
Fat:blood | 0.4 | Borghoff et al. (1996)
Richly perfused:blood | 0.83 | Borghoff et al. (1996)
Poorly perfused:blood | 1.0 | Borghoff et al. (1996)
Kidney:blood | 0.83 | Borghoff et al. (2001)

a Values have been updated to incorporate corrections from a quality assurance review and to include values to the number of digits used in the model code.

b 0.165 − Σ(kidney, liver, blood).

c Lower limit of alveolar ventilation for rat reported in Brown et al. (1997); alveolar ventilation is set equal to cardiac output.

d Sum of liver and gastrointestinal blood flows.

e Brown et al. (1997) only accounts for 94% of the blood flow. This assumes unaccounted 6% is richly perfused.

f 0.47 − Σ(kidney, liver).

g 0.53 − fat.

h Set equal to muscle tissue (Borghoff et al., 2016).

i Set equal to richly perfused tissue (Borghoff et al., 2016).

Table B-8 PBPK model rate constants

Parameter | Value | Source or reference
tert-Butanol rate constants
TBA first-order absorption constant (1/h) | 5.0 | Salazar et al. (2015)
Fraction of TBA absorbed in alveolar region | 0.6 | Medinsky et al. (1993)
Urinary clearance of TBA (L/h/kg^0.75^) | 0.015 | Borghoff et al. (2016)
Scaled maximum metabolic rate of TBA (μmol/h/kg) | 54 | Borghoff et al. (1996), Rao and Ginsberg (1997)
Michaelis-Menten constant (μmol/L) | 457^a^ | Borghoff et al. (1996), Rao and Ginsberg (1997)
Maximum percentage increase in metabolic rate | 0.0 | 124.9 used by Leavens and Borghoff (2009)
Rate constant for ascent to maximum (1/d)^b^ | 0.3977 | Leavens and Borghoff (2009)
ETBE rate constants
ETBE first-order absorption constant (1/h) | 1.6 | Leavens and Borghoff (2009)
Scaled maximum metabolic rate of ETBE (μmol/h/kg^0.75^) | 499 | Rao and Ginsberg (1997)
Michaelis-Menten constant for ETBE (μmol/L) | 430^a^ | Rao and Ginsberg (1997)
Alpha 2u-globulin binding parameters
Steady-state free kidney alpha 2u-globulin (μmol/L) | 550^c^ | Leavens and Borghoff (2009)
First-order constant for hydrolysis of free alpha 2u-globulin (1/h) | 0.31 | Leavens and Borghoff (2009)
First-order constant for hydrolysis of bound alpha 2u-globulin (1/h) | 0.11 | Leavens and Borghoff (2009)
Second-order binding constant for TBA to alpha 2u-globulin (L/μmol/h) | 1.3 | Leavens and Borghoff (2009)
Alpha 2u-globulin dissociation constant for TBA (μmol/L) | 120 | Leavens and Borghoff (2009)
First-order constant for unbinding of TBA from alpha 2u-globulin (1/h) | Calculated^d^
Second-order binding constant for ETBE to alpha 2u-globulin (L/μmol/h) | 0.15 | Leavens and Borghoff (2009)
Alpha 2u-globulin dissociation constant for ETBE (μmol/L) | 1 | Leavens and Borghoff (2009)
First-order constant for unbinding of ETBE from alpha 2u-globulin (1/h) | Calculated^e^

a Based on dividing the original values in Borghoff et al. (1996) and Rao and Ginsberg (1997)[used by Borghoff et al. (2016)] by the corresponding liver partition coefficients: 379/0.83 = 457 for tert-butanol kinetics, and 1,248/2.9 = 430 for ETBE kinetic pathway 1.

b Note: model revised from a daily stepwise induction change to a continuous change (with a 12-h time lag), while still maintaining the default parameters.

c Based on values ranging from ~160 to 1,000 μmol/L (Carruthers et al., 1987; Charbonneau et al., 1987; Olson et al., 1987; Stonard et al., 1986).

d Product of alpha 2u-globulin dissociation constant for tert-butanol and second-order binding constant for tert-butanol to alpha 2u-globulin.

e Product of alpha 2u-globulin dissociation constant for ETBE and second-order binding constant for ETBE to alpha 2u-globulin.

### B.1.8 Toxicokinetic Data Extraction and Selected Model Outputs

#### Data Extraction and Adjustments

A study by ARCO (1983) reported tert-butanol blood levels after gavage exposure, primarily as tert-butanol equivalents based on total ^14^C activity, which does not distinguish between tert-butanol and its metabolites. However, for oral doses of 1 and 500 mg/kg, the fraction of activity identifiable as tert-butanol was also reported, although not at identical time points. To estimate total equivalents at other times, the study authors used empirical bi-exponential curves (see Figure B-7) to interpolate between the time points at which total tert-butanol equivalents were measured. The total equivalents calculated this way were then multiplied by the fraction of tert-butanol reported at 0.5, 3, 6, and 12 hours for 1 mg/kg [ARCO (1983), Table 24] and 500 mg/kg [ARCO (1983), Table 25] to obtain the data used for PBPK modeling (see Table B-10).

Figure B-7 tert-Butanol PK data for 1 and 500 mg/kg oral exposures fromARCO (1983)

Time-course data and empirical regressions for tert-butanol equivalents in rats following oral exposure to 1 or 500 mg/kg [^14^C]TBA (ARCO, 1983). For 1 mg/kg, the single exponential regression reported by ARCO (1983) was 1.73 × exp(−0.0946t) (dashed line), but it did not appear to adequately fit the data. A bi-exponential regression (solid line) was found by minimizing the sum of square errors between the regression and data in Excel: 0.4874 × exp(−0.7055t) + 1.404 × exp(−0.06983t). For 500 mg/kg, the bi-exponential regression reported by ARCO (1983) appeared sufficient: 554 × exp(−0.0748t) − 426 × exp(−3.51t).

The single-dose data from JPEC (2008f) were taken from Appendix Table 12 of that report. The values for the P-5 component were converted from ETBE equivalents to mg/L tert-butanol. For example, at 5 mg/kg-day, 416 ng ETBE eq/mL is reported for P-5 in animal # 17. The corresponding concentration in mg/L for tert-butanol are then calculated as (416 ng ETBE eq/mL) × (1,000 mL/L) × (10^−6^ mg/ng) × (74.12 [MW tert-butanol])/(102.17 [MW ETBE]) = 0.302 mg tert-butanol eq/L, where MW represents molecular weight. Likewise the data for the repeated-dose study (JPEC, 2008e), Days 7 and 14, were converted from the P-5 values in Appendix Table 7, p. 53 of that report (The data from the single-dose study were combined with the Day 7 and 14 data from the multiple dose study for comparison with model simulations of 14-day dosing.).

The JPEC (2008a) and JPEC (2008b) studies measured tert-butanol in plasma only, unlike the Poet et al. (1997) and Leavens and Borghoff (2009) studies, which measured tert-butanol in whole blood. Based on the measurements of plasma and whole blood by JPEC (2008a, 2008b), the concentration of tert-butanol in plasma is approximately 130% of the concentration in whole blood (see Table B-11). The tert-butanol plasma concentrations measured by JPEC were therefore divided by 1.3 to obtain the expected concentration in whole blood for comparison with the PBPK model.

Table B-9 Summary of pharmacokinetic data used for model calibration and evaluation

Exposure | | Measured | | Data source | Figure no. in Salazar et al. (2015) | Conversion | Notes
Chemical | Route | Chemical | Medium | Data source | Figure no. in Salazar et al. (2015) | Conversion | Notes
TBA | i.v. | TBA | Blood | Poet et al. (1997) Figure 1 and 2 | 3A | μM to mg/L | Digitized from the figure
TBA | Inhalation | TBA | Blood | Leavens and Borghoff (2009) Figure 8A−B | 3B | μM to mg/L | Digitized from the figure, showing only 1 d of exposure
TBA | Gavage | TBA | Blood | ARCO (1983), % total TBA, Tables 24−25; TBA equivalents, Figure 6 | 3C | TBA equivalents to TBA concentration
ETBE | Gavage | TBA | Blood | JPEC (2008f) Appendix 12 | 4A | ETBE equivalents to mg/L TBA | “P5” is TBA
ETBE | Gavage | TBA | Urine | JPEC (2008f) Appendix 13 | 4B | ETBE equivalents to mg/L TBA | “P5” is TBA
ETBE | Inhalation | ETBE | Blood | Amberg et al. (2000) Table 5 | 4C | μM to mg/L
ETBE | Inhalation | TBA | Blood | Amberg et al. (2000) Table 5 | 4D | μM to mg/L
ETBE | Inhalation | TBA | Urine | Amberg et al. (2000) Table 6 and Figure 4 | 4E | μM to mg/L
ETBE | Inhalation | ETBE | Exhaled air | Borghoff (1996) | 4F | μmoles to mg | Cumulative mass
ETBE | Inhalation | TBA | Exhaled air | Borghoff (1996) | 4G | μmoles to mg | Cumulative mass
TBA | Inhalation | TBA | Blood | Leavens and Borghoff (2009) Figure 8B | 5A−B | μM to mg/L | Digitized from the figure
TBA | Inhalation | TBA | Blood | Leavens and Borghoff (2009) Figure 8A | 5C−D | μM to mg/L | Digitized from the figure
ETBE | Gavage | TBA | Blood | JPEC (2008f) Appendix 12 | 5E | ETBE equivalents to mg/L TBA | “P5” is TBA

Table B-10 Conversion of ARCO (1983) total tert-butanol (TBA) equivalents and serum fraction data to TBA concentrations

Time (h) | % TBA^a^ | Total TBA equivalents interpolated (μg/mL)^b^ | TBA concentration using interpolated equivalents (μg/mL = mg/L)^c^ | Total TBA equivalents measured at nearest time point (time measured)^d^ | TBA concentration using nearest time point (mg/L)^e^
1 mg/kg data
0.5 | 57.3 | 1.6982 | 0.9731 | 1.69 (0.5 h) | 0.9684
3 | 25 | 1.1972 | 0.2993 | 1.26 (2.67 h) | 0.3150
6 | 18.1 | 0.9304 | 0.1684 | 0.97 (5.33 h) | 0.1756
12 | 1 | 0.6074 | 0.006074 | 0.68 (10.67 h) | 0.006800
500 mg/kg data
0.5 | 22.9 | 460.0 | 105.34 | 445 (0.5 h) | 101.91
3 | 20.4 | 442.6 | 90.30 | 438 (2.67 h) | 89.35
6 | 18.7 | 353.7 | 66.14 | 393 (5.33 h) | 73.49
12 | 18.5 | 225.8 | 41.77 | 269 (10.67 h) | 49.77

a From Table 24, p. 48 of ARCO (1983) (1 mg/kg) and Table 25, p. 49 of ARCO (1983) (500 mg/kg).

b Using bi-exponential functions.

c Values used in PBPK modeling; %TBA × total TBA equivalents interpolated.

d From Table 14, p. 32 of ARCO (1983) (1 mg/kg) and Table 11, p. 27 of ARCO (1983) (500 mg/kg).

e %TBA × total TBA equivalents at nearest time point.

Table B-11 Ratio of ^14^C activity in blood vs. plasma after [^14^C]ETBE exposures in rats JPEC (2008a) JPEC (2008b)

Time (h) | Animal no. | Plasma (ng ^14^C eq/mL) | Blood (ng ^14^C eq/mL) | Plasma/blood (%)
Single dose, JPEC (2008f) Appendix Table 5, p. 94
8 | 97 | 78,133 | 40,667 | 192.1
8 | 98 | 95,533 | 80,000 | 119.4
8 | 99 | 89,367 | 64,667 | 138.2
8 | 100 | 72,400 | 62,333 | 116.2
24 | 37 | 10,900 | 8,800 | 123.9
24 | 38 | 19,133 | 14,433 | 132.6
24 | 39 | 19,433 | 15,400 | 126.2
24 | 40 | 30,767 | 22,967 | 134.0
72 | 41 | 2,133 | 1,600 | 133.3
72 | 42 | 2,833 | 3,033 | 93.4
72 | 43 | 4,033 | 3,200 | 126.0
72 | 44 | 3,167 | 2,333 | 135.7
| | | Mean ± SD | 130.9 ± 22.8
Single dose, JPEC (2008f) Appendix Table 3, p. 91
8 | 17 | 2,853 | 1,784 | 159.9
8 | 18 | 2,850 | 1,802 | 158.2
8 | 19 | 2,629 | 1,568 | 167.7
8 | 20 | 3,918 | 2,718 | 144.2
24 | 21 | 1,692 | 1,255 | 134.8
24 | 22 | 846.7 | 642.9 | 131.7
24 | 23 | 1,048 | 785 | 133.5
24 | 24 | 761.7 | 591.3 | 128.8
72 | 25 | 49.6 | 40 | 124.0
72 | 26 | 34.2 | 29.2 | 117.1
72 | 27 | 79.2 | 60.8 | 130.3
72 | 28 | 107.9 | 84.6 | 127.5
168 | 29 | 12.9 | 13.3 | 97.0
168 | 30 | 17.5 | 13.8 | 126.8
168 | 31 | 26.7 | 24.2 | 110.3
168 | 32 | 40 | 35.8 | 111.7
| | | Mean ± SD | 131.5 ± 18.9
Repeated dose, JPEC (2008e), Appendix Table 3, p. 49
8 (7 d dosing) | | 3,789 | 3,029 | 125.1
8 (7 d dosing) | | 5,041 | 3,988 | 126.4
8 (7 d dosing) | | 4,914 | 3,938 | 124.8
8 (7 d dosing) | | 5,608 | 4,638 | 120.9
24 (7 d dosing) | | 2,740 | 1,908 | 143.6
24 (7 d dosing) | | 3,433 | 2,575 | 133.3
24 (7 d dosing) | | 2,488 | 1,888 | 131.8
24 (7 d dosing) | | 963.3 | 812.5 | 118.6
8 (14 d dosing) | | 5,665 | 4,546 | 124.6
8 (14 d dosing) | | 5,175 | 4,075 | 127.0
8 (14 d dosing) | | 3,889 | 3,058 | 127.2
8 (14 d dosing) | | 5,090 | 3,858 | 131.9
24 (14 d dosing) | | 2,003 | 1,508 | 132.8
24 (14 d dosing) | | 2,121 | 1,692 | 125.4
24 (14 d dosing) | | 1,948 | 1,354 | 143.9
24 (14 d dosing) | | 1,037 | 804.2 | 128.9
72 (14 d dosing) | | 1,378 | 1,138 | 121.1
72 (14 d dosing) | | 301.3 | 245.8 | 122.6
72 (14 d dosing) | | 110 | N.D.
72 (14 d dosing) | | 421.3 | 337.5 | 124.8
| | | Mean ± SD | 128.1 ± 6.85

N.D. = not detected.

#### Selected Model Comparisons Applying the Borghoff et al. (2016) Model

The modeling code was obtained by the authors of Borghoff et al. (2016). The modeling language and platforms is acslX (Advanced Continuous Simulation Language, Aegis, Inc., Huntsville, AL).

The following modifications were made:

1) Periodic drinking water pathway was incorporated into the continuous simulation language (CSL) file, and the continuous oral dose rate function was modified slightly to improve flexibility of the model.
2) For simulations showing the effect of including enzyme induction, the code was modified slightly in the CSL file to improve continuity. Daily step functions in metabolic chances were replaced with a continuous function but delayed by 12 hours.
3) Otherwise, enzyme induction was not used (set to zero).
4) In the PBPK model code, the changes to the Michaelis-Menten constants described as footnotes in Table B-8 above were not made in the PBPK parameter script (MTBEparam.m). Instead, parameters were redefined in the core model *CSL file as scaling calculations in the parameters section of the INITIAL bloc:
  a. Km1vetbe = Km1etbe/Pletbe
  b. Km2vetbe = Km2etbe/Pletbe
  c. Kmvtba = Kmtba/Pltba
5) Tissue volumes and the rate of hydrolysis of free alpha 2u-globulin were corrected (slightly) to values shown in Table B-7.
6) All model scripts previously used to evaluate model fits of the Salazar et al. (2015) model were adapted to run the Borghoff et al. (2016) model. Model parameters were set to uniform values for all simulations highlighted in this section, unless otherwise noted.
7) Digitized data from Amberg et al. (2000) were updated after a quality assurance (QA) review.
8) Tabulated data from Borghoff and Asgharian (1996) were updated subsequent to a QA review.

The PBPK acslX model code is available electronically through EPA’s HERO database. All model files may be downloaded in a zipped workspace from HERO (U.S. EPA, 2016). The model contains workspaces for EPA’s implementation of the Salazar et al. (2015) model, the unchanged version of the of Borghoff et al. (2016) model, and the EPA implementation of the Borghoff et al. (2016) model.

Selected model outputs compared with experimental data sets are provided below.

Figure B-8 Comparison of theBorghoff et al. (2016) model predictions with measured tert-butanol blood concentrations for i.v., inhalation, and gavage exposure to tert-butanol

(A)

(B)

(C)

Source: (A) i.v. data from Poet et al. (1997); (B) inhalation data from Leavens and Borghoff (2009); and (C) gavage data from ARCO (1983).

The model results for the i.v. data are significantly improved from the Blancato et al. (2007) and Leavens and Borghoff (2009) model results presented previously. As evident here and in the Borghoff et al. (2016) study, the Borghoff et al. (2016) model generally overpredicts TBA blood and urine concentrations. Some attempts were made to improve model fit in the EPA model implementation (such as adjusting inhalation, urinary, and induction parameter values); however, the default values were maintained in the final model.

Figure B-9 Comparison of Borghoff et al. (2016) model predictions with measured amounts of tert-butanol after gavage of ETBE

The data points show the measurements from the four individual rats in the JPEC (2008f) study. The concentrations of tert-butanol in blood are shown in (A). The amount of tert-butanol in urine is shown in (B). Note that the overprediction of tert-butanol in urine (B) is by a factor of 3- to 10-fold.

The predictions of the model are compared with amounts measured by Amberg et al. (2000) after ETBE inhalation in Figure B-10A. The predicted tert-butanol blood concentrations are slightly higher than the measured ones. The tert-butanol blood concentration would be reduced if the exposed animals were reducing their breathing rate or other breathing parameters, but the exposure concentration of ETBE are unlikely to be high enough to cause a change in breathing parameters, because at the much higher ETBE concentration in the ARCO (1983) study (5,000 ppm), changes in breathing were not noted. The model already uses a lower bound estimate of respiration rate and cardiac output for all simulations, and the model predictions fit most measured concentrations well. However, the urinary excretion of tert-butanol is significantly overestimated (~3- to 10-fold) by the tert-butanol submodel (see Figure B-10B).

Figure B-10 Comparison of Borghoff et al. (2016) model predictions with measured amounts after a 4-hour inhalation exposure to 4 and 40 ppm ETBE

Concentrations in blood are shown in (A) for ETBE and (B) for tert-butanol. The amount of tert-butanol in urine is shown in (C) for the 40-ppm exposure. The data are from Amberg et al. (2000).

Figure B-11 Comparison of Borghoff et al. (2016) model predictions with measured amounts of ETBE and tert-butanol in exhaled breath after a 6-hour inhalation exposure to 500, 1,750, and 5,000 ppm ETBE

The data points are from the Borghoff and Asgharian (1996) study. The model significantly overpredicted the concentrations of both ETBE and tert-butanol in the exhaled breath of male rats and of tert-butanol in female rats following ETBE inhalation exposure. The model currently assumes that 100% of inhaled ETBE, though only 60% of inhaled tert-butanol, is available for alveolar absorption. The inhalation availability may have a significant impact on estimated exhaled breath amounts but was not adjusted to fit this data set.

The increased tert-butanol metabolism better estimates the measured tert-butanol blood concentrations as shown in a comparison of the model predictions and experimental measurements in Figure B-12. The male rats have lower tert-butanol blood concentrations after repeated exposures than female rats, and this difference could indicate greater induction of tert-butanol metabolism in males or other physiologic changes such as ventilation or urinary excretion.

Figure B-12 Comparison of the Borghoff et al. (2016) model predictions with measured amounts of tert-butanol in blood after repeated inhalation exposure to tert-butanol

Male rats were exposed to 239, 444, or 1,726 ppm and female rats were exposed to 256, 444, or 1,914 ppm tert-butanol for up to 8 consecutive days (Borghoff et al., 2001). tert-Butanol blood concentrations are better predicted by the model after 8 days of exposure with enzyme induction (right panels) than without enzyme induction (left panels).

Figure B-13 Comparison of EPA model predictions with measured amounts of tert-butanol in blood after 5 mg/kg-day ethyl tertiary butyl ether (ETBE) gavage for up to 14 days in male rats

The data show the individual measurements of the four rats in the JPEC (2008e, 2008f) study. Adding enzyme induction to the model has a small effect on the predicted tert-butanol blood concentrations and the model predictions are closer to measured data when induction is not included.

## B.2 OTHER PERTINENT TOXICITY INFORMATION

### B.2.1 Other Toxicological Effects

#### Synthesis of Other Effects

The database for effects other than kidney, liver, reproduction, and cancer contain only 11 rodent studies. These effects included decreased body weight, increased adrenal weights, altered spleen weights, and increased mortality. All selected studies used inhalation, gavage, or drinking water exposures for ≥90 days. Shorter duration, multiple-exposure studies that examined immunological endpoints were also included. No studies were removed for methodological concerns.

##### Kidney effects

Absolute kidney-weight data are presented in Table B-12.

Table B-12 Evidence pertaining to absolute kidney-weight effects in animals exposed to ETBE

Reference and study design | Results (percentage change compared to control)
Fujii et al. (2010); JPEC (2008d); Rat, Sprague-Dawley; Oral―gavage; P0, male (24/group): 0, 100, 300, or 1,000 mg/kg-d; Daily for 16 wk beginning 10 wk prior to mating; P0, female (24/group): 0, 100, 300, or 1,000 mg/kg-d; Daily for 17 wk beginning 10 wk prior to mating to LD 21 | P0, Male | | P0, Female
| Dose (mg/kg-d) | Absolute weight (%) | Dose (mg/kg-d) | Absolute weight (%)
| 0 | − | 0 | −
| 100 | 5 | 100 | −2
| 300 | 8 | 300 | 0
| 1,000 | 18^a^ | 1,000 | 7^a^
Gaoua (2004b); Rat, Sprague-Dawley; Oral―gavage; P0, male (25/group): 0, 250, 500, or 1,000 mg/kg-d; Daily for a total of 18 wk beginning 10 wk before mating until after weaning of the pups; P0, female (25/group): 0, 250, 500, or 1,000 mg/kg-d; Daily for a total of 18 wk beginning 10 wk before mating until PND 21; F1, males and females (25/group/sex): via P0 dams in utero daily through gestation and lactation, then F1 doses beginning PND 22 until weaning of the F2 pups | P0, Male | | P0, Female
| Dose (mg/kg-d) | Absolute weight (%) | Dose (mg/kg-d) | Absolute weight (%)
| 0 | − | 0 | −
| 250 | 11^a^ | 250 | −1
| 500 | 15^a^ | 500 | 2
| 1,000 | 21^a^ | 1,000 | 5
| F1, Male | | F1, Female
| Dose (mg/kg-d) | Absolute weight (%) | Dose (mg/kg-d) | Absolute weight (%)
| 0 | − | 0 | −
| 250 | 10 | 250 | 4
| 500 | 22^a^ | 500 | 3
| 1,000 | 58^a^ | 1,000 | 11^a^
Hagiwara et al. (2011); JPEC (2008c); Rat, F344; Oral―gavage; Male (12/group): 0 or 1,000 mg/kg-d; Daily for 23 wk | Male
Hagiwara et al. (2011); JPEC (2008c); Rat, F344; Oral―gavage; Male (12/group): 0 or 1,000 mg/kg-d; Daily for 23 wk | Dose (mg/kg-d) | Absolute weight (%)
Hagiwara et al. (2011); JPEC (2008c); Rat, F344; Oral―gavage; Male (12/group): 0 or 1,000 mg/kg-d; Daily for 23 wk | 0 | −
Hagiwara et al. (2011); JPEC (2008c); Rat, F344; Oral―gavage; Male (12/group): 0 or 1,000 mg/kg-d; Daily for 23 wk | 1,000 | 19^a^
Miyata et al. (2013); JPEC (2008b); Rat, Crl:CD(SD); Oral―gavage; Male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; Daily for 26 wk | Male | | Female
Miyata et al. (2013); JPEC (2008b); Rat, Crl:CD(SD); Oral―gavage; Male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; Daily for 26 wk | Dose (mg/kg-d) | Absolute weight (%) | Dose (mg/kg-d) | Absolute weight (%)
Miyata et al. (2013); JPEC (2008b); Rat, Crl:CD(SD); Oral―gavage; Male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; Daily for 26 wk | 0 | − | 0 | −
Miyata et al. (2013); JPEC (2008b); Rat, Crl:CD(SD); Oral―gavage; Male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; Daily for 26 wk | 5 | 1 | 5 | 1
Miyata et al. (2013); JPEC (2008b); Rat, Crl:CD(SD); Oral―gavage; Male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; Daily for 26 wk | 25 | 6 | 25 | 0
Miyata et al. (2013); JPEC (2008b); Rat, Crl:CD(SD); Oral―gavage; Male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; Daily for 26 wk | 100 | 5 | 100 | 7
Miyata et al. (2013); JPEC (2008b); Rat, Crl:CD(SD); Oral―gavage; Male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; Daily for 26 wk | 400 | 25^a^ | 400 | 10^a^
Suzuki et al. (2012); JPEC (2010a); Rat, F344; Oral―water; Male (34−37/group): 0, 625, 2,500, or 10,000 ppm (0, 28, 121, or 542 mg/kg d); Female (36−38/group): 0, 625, 2,500, or 10,000 ppm (0, 46, 171, or 560 mg/kg-d); Daily for 104 wk; (Organ weights measured for animals surviving to study termination) | Male | | Female
| Dose (mg/kg-d) | Absolute weight (%) | Dose (mg/kg-d) | Absolute weight (%)
| 0 | − | 0 | −
| 28 | −4 | 46 | 3
| 121 | 5 | 171 | 10^b^
| 542 | 18^b^ | 560 | 14^b^
Saito et al. (2013); JPEC (2010b); Rat, F344; Inhalation―vapor; Male (30−44/group); Female (29−39/group); 0, 500, 1,500, or 5,000 ppm (0, 2,090, 6,270, or 20,900 mg/m^3^)^b^; Dynamic whole-body inhalation; 6 h/d, 5 d/wk for 104 wk; generation method, analytical concentration reported; (Organ weights measured for animals surviving to study termination) | Male | | Female
| Dose (mg/m^3^) | Absolute weight (%) | Dose (mg/m^3^) | Absolute weight (%)
| 0 | − | 0 | −
| 2,090 | 5 | 2,090 | 5
| 6,270 | 8 | 6,270 | 6^a^
| 20,900 | 18^a^ | 20,900 | 18^b^
JPEC (2008a); Rat, Crl:CD(SD); Inhalation―vapor; Male (NR): 0, 150, 500, 1,500, or 5,000 ppm (0, 627, 2,090, 6,270, or 20,900 mg/m^3^); female (NR): 0, 150, 500, 1,500, or 5,000 ppm (0, 627, 2,090, 6,270, or 20,900 mg/m^3^);; Dynamic whole-body chamber; 6 h/d, 5 d/wk for 13 wk; generation method, analytical concentration and method were reported | Male | | Female
| Dose (mg/m^3^) | Absolute weight (%) | Dose (mg/m^3^) | Absolute weight (%)
| 0 | − | 0 | −
| 627 | 10 | 627 | 1
| 2,090 | 11 | 2,090 | −1
| 6,270 | 18^a^ | 6,270 | 4
| 20,900 | 16^a^ | 20,900 | 7
JPEC (2008a); Rat, Crl:CD(SD); Inhalation―vapor; Male (6/group): 0 or 5,000 ppm (0 or 20,900 mg/m^3^);^c^ female (6/group): 0 or 5,000 ppm (0 or 20,900 mg/m^3^)^c^; Dynamic whole-body chamber; 6 h/d, 5 d/wk for 13 wk followed by a 28 d recovery period; generation method, analytical concentration and method were reported | Male | | Female
| Dose (mg/m^3^) | Absolute weight (%) | Dose (mg/m^3^) | Absolute weight (%)
| 0 | − | 0 | −
| 20,900 | 19 | 20,900 | 8
Medinsky et al. (1999); US EPA (1997); Rat, F344; Inhalation―vapor; Male (11/group): 0, 500, 1,750, or 5,000 ppm (0, 2,090, 7,320, or 20,900 mg/m^3^);^c^ female (10-11/group): 0, 500, 1,750, or 5,000 ppm (0, 2,090, 7,320, or 20,900 mg/m^3^)^c^; Dynamic whole-body chamber; 6 h/d, 5 d/wk for 13 wk; generation method, analytical concentration and method were reported | Male | | Female
| Dose (mg/m^3^) | Absolute weight (%) | Dose (mg/m^3^) | Absolute weight (%)
| 0 | − | 0 | −
| 2,090 | 7 | 2,090 | 4
| 7,320 | 10^a^ | 7,320 | 12^a^
| 20,900 | 19^a^ | 20,900 | 21^a^
Medinsky et al. (1999); Bond et al. (1996); Mice, CD-1; Inhalation―vapor; Male (40/group): 0, 500, 1,750, or 5,000 ppm (0, 2,090, 7,320, or 20,900 mg/m^3^);^b^ female (40/group): 0, 500, 1,750, or 5,000 ppm (0, 2,090, 7,320, or 20,900 mg/m^3^)^b^; Dynamic whole-body chamber; 6 h/d, 5 d/wk for 13 wk; generation method, analytical concentration and method were reported | Male | | Female
| Dose (mg/m^3^) | Absolute weight (%) | Dose (mg/m^3^) | Absolute weight (%)
| 0 | − | 0 | −
| 2,090 | 9 | 2,090 | 0
| 7,320 | 10 | 7,320 | 6
| 20,900 | 5 | 20,900 | 4

− = for controls, no response relevant; for other doses, no quantitative response reported; LD = lactation day; n = number evaluated from group; NR = not reported; PND = postnatal day.

a Result is statistically significant (p < 0.05) based on analysis of data by study authors.

b 4.18 mg/m^3^ = 1 ppm.

##### Body weight

As presented in Table B-12, body weights were significantly reduced compared with vehicle controls following 2-year oral and inhalation exposures to ETBE (Saito et al., 2013; Suzuki et al., 2012; JPEC, 2010a, b). Reductions were also reported in studies of exposure durations shorter than 2 years (Banton et al., 2011; Hagiwara et al., 2011; Fujii et al., 2010; JPEC, 2008a, b; Gaoua, 2004b; Medinsky et al., 1999); however, these effects were frequently not statistically significant. Food consumption did not correlate well with body weight (Saito et al., 2013; Suzuki et al., 2012; JPEC, 2010a, b). Water consumption was reduced in the 2-year oral exposure study (JPEC, 2010a). Reduced water consumption due to ETBE exposure and the chemical’s unpalatability might contribute to the reduced body weight, particularly for dietary or drinking water exposures. Hypersalivation, which is frequently observed with unpalatable chemicals following gavage, was observed in rats gavaged for 18 weeks (Gaoua, 2004b). Body-weight changes are poor indicators of systemic toxicity but are important when evaluating relative organ-weight changes.

##### Adrenal weight

Adrenal weights were increased in the 13- and 23-week studies (see Table B-13). For instance, a 13-week inhalation study found that absolute adrenal weights were increased in male and female rats (Medinsky et al., 1999). In another study, absolute and relative adrenal weights were increased in male rats (Hagiwara et al., 2011). None of the observed organ-weight changes corresponded with functional or histopathological changes; thus, adrenal effect data are inadequate to draw conclusions as a human hazard of ETBE exposure.

##### Immune system

In general, functional immune assays represent clear evidence of immunotoxicity and outweigh immune organ weight and cell population effects when establishing hazard [WHO (2012); see Table B-15]. The single published functional assay available for ETBE reported that the number of IgM^+^ sheep red blood cell (SRBC)-specific antibody forming cells was not significantly affected after a 28-day oral exposure to ETBE (Banton et al., 2011). Relative spleen weights were inconsistently affected in male and female rats following oral and inhalation >13-week exposures to ETBE (see Table B-15). The only dose-responsive changes in spleen weights were increased relative weights in male rats and decreased absolute weights in female rats following 2-year inhalation exposure (Saito et al., 2013; JPEC, 2010b) and increased relative weights in female rats following 2-year oral exposure (Suzuki et al., 2012; JPEC, 2010a). Spleen weights are heavily influenced by the proportion of red blood cells, which do not impact immune function of the organ (Elmore, 2006). Thus, spleen-weight changes must be correlated with histopathological and functional changes for evidence of immunotoxicity (Elmore, 2006), none of which are observed for ETBE. CD3^+^, CD4^+^, and CD8^+^ T cells were modestly reduced in male mice after 6 or 13 weeks of ETBE exposure via inhalation but are not correlated with any change in T cell function as indicated by the SRBC assay (Li et al., 2011). No other indicators of histopathological or functional changes were reported with a single chemical exposure. The ETBE database contains no evidence of altered immune function that correlate with modest T cell population reductions and altered splenic organ weights; thus, the immune effect data are inadequate to draw conclusions as a human hazard of ETBE exposure.

Table B-13 Evidence pertaining to body-weight effects in animals exposed to ETBE

Reference and study design | Results (percentage change compared to control)
Banton et al. (2011); Rat, Sprague-Dawley; Oral―gavage; Female (10/group): 0, 250, 500, or 1,000 mg/kg-d; Daily for 28 consecutive d | Female
Banton et al. (2011); Rat, Sprague-Dawley; Oral―gavage; Female (10/group): 0, 250, 500, or 1,000 mg/kg-d; Daily for 28 consecutive d | Dose (mg/kg-d) | Body weight (%)
Banton et al. (2011); Rat, Sprague-Dawley; Oral―gavage; Female (10/group): 0, 250, 500, or 1,000 mg/kg-d; Daily for 28 consecutive d | 0 | −
Banton et al. (2011); Rat, Sprague-Dawley; Oral―gavage; Female (10/group): 0, 250, 500, or 1,000 mg/kg-d; Daily for 28 consecutive d | 250 | 3
Banton et al. (2011); Rat, Sprague-Dawley; Oral―gavage; Female (10/group): 0, 250, 500, or 1,000 mg/kg-d; Daily for 28 consecutive d | 500 | 5
Banton et al. (2011); Rat, Sprague-Dawley; Oral―gavage; Female (10/group): 0, 250, 500, or 1,000 mg/kg-d; Daily for 28 consecutive d | 1,000 | −1
Fujii et al. (2010); JPEC (2008d); Rat, Sprague-Dawley; Oral―gavage; P0, male (24/group): 0, 100, 300, or 1,000 mg/kg-d; Daily for 16 wk beginning 10 wk prior to mating; P0, female (24/group): 0, 100, 300, or 1,000 mg/kg-d; Daily for 17 wk beginning 10 wk before mating to LD 21 | P0, Male | | P0, Female
| Dose (mg/kg-d) | Body weight (%) | Dose (mg/kg-d) | Body weight (%)
| 0 | − | 0 | −
| 100 | −4 | 100 | 1
| 300 | −4 | 300 | 1
| 1,000 | −7 | 1,000 | 5
Gaoua (2004b); Rat, Sprague-Dawley; Oral―gavage; P0, male (25/group): 0, 250, 500, or 1,000 mg/kg-d; Daily for a total of 18 wk beginning 10 wk before mating until after weaning of the pups; P0, female (25/group): 0, 250, 500, or 1,000 mg/kg-d; Daily for a total of 18 wk beginning 10 wk before mating until PND 21; F1, male (25/group): 0, 250, 500, or 1,000 mg/kg-d; Dams dosed daily through gestation and lactation, then F1 doses beginning PND 22 until weaning of the F2 pups; F1, female (24−25/group): 0, 250, 500, or 1,000 mg/kg-d; P0 dams dosed daily through gestation and lactation, then F1 dosed beginning PND 22 until weaning of the F2 pups | P0, Male | | P0, Female
| Dose (mg/kg-d) | Final body weight (%) | Dose (mg/kg-d) | Final body weight (%)
| 0 | − | 0 | −
| 250 | −1 | 250 | −7
| 500 | −3 | 500 | −2
| 1,000 | −5^a^ | 1,000 | 0
| F1, Male | | F1, Female
| Dose (mg/kg-d) | Final body weight (%) | Dose (mg/kg-d) | Final body weight (%)
| 0 | − | 0 | −
| 250 | 0 | 250 | −2
| 500 | 3 | 500 | −3
| 1,000 | 1 | 1,000 | 2
Hagiwara et al. (2011); JPEC (2008c); Rat, F344; Oral―gavage; Male (12/group): 0 or 1,000 mg/kg-d; Daily for 23 wk | Male
Hagiwara et al. (2011); JPEC (2008c); Rat, F344; Oral―gavage; Male (12/group): 0 or 1,000 mg/kg-d; Daily for 23 wk | Dose (mg/kg-d) | Final body weight (%)
Hagiwara et al. (2011); JPEC (2008c); Rat, F344; Oral―gavage; Male (12/group): 0 or 1,000 mg/kg-d; Daily for 23 wk | 0 | −
Hagiwara et al. (2011); JPEC (2008c); Rat, F344; Oral―gavage; Male (12/group): 0 or 1,000 mg/kg-d; Daily for 23 wk | 1,000 | −5^a^
Miyata et al. (2013); JPEC (2008b); Rat, Crl:CD(SD); Oral―gavage; Male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; Daily for 26 wk | Male | | Female
Miyata et al. (2013); JPEC (2008b); Rat, Crl:CD(SD); Oral―gavage; Male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; Daily for 26 wk | Dose (mg/kg-d) | Body weight (%) | Dose (mg/kg-d) | Body weight (%)
Miyata et al. (2013); JPEC (2008b); Rat, Crl:CD(SD); Oral―gavage; Male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; Daily for 26 wk | 0 | − | 0 | −
Miyata et al. (2013); JPEC (2008b); Rat, Crl:CD(SD); Oral―gavage; Male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; Daily for 26 wk | 5 | −6 | 5 | −5
Miyata et al. (2013); JPEC (2008b); Rat, Crl:CD(SD); Oral―gavage; Male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; Daily for 26 wk | 25 | 0 | 25 | −2
Miyata et al. (2013); JPEC (2008b); Rat, Crl:CD(SD); Oral―gavage; Male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; Daily for 26 wk | 100 | −5 | 100 | −2
Miyata et al. (2013); JPEC (2008b); Rat, Crl:CD(SD); Oral―gavage; Male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; Daily for 26 wk | 400 | 2 | 400 | −3
Maltoni et al. (1999); Rat, Sprague-Dawley; Oral―gavage; Male (60/group): 0, 250, or 1,000 mg/kg-d; female (60/group): 0, 250, or 1,000 mg/kg-d; 4 d/wk for 104 wk; observed until natural death | Male; No significant difference at any dose; Female; No significant difference at any dose
Suzuki et al. (2012); JPEC (2010a); Rat, F344; Oral―water; Male (50/group): 0, 625, 2,500, or 10,000 ppm (0, 28, 121, or 542 mg/kg-d);^b^ female (50/group): 0, 625, 2,500, or 10,000 ppm (0, 46, 171, or 560 mg/kg-d)^b^; Daily for 104 wk | Male | | Female
| Dose (mg/kg-d) | Terminal body weight (%) | Dose (mg/kg-d) | Terminal body weight (%)
| 0 | − | 0 | −
| 28 | −4 | 46 | −10^a^
| 121 | −7^a^ | 171 | −11^a^
| 542 | −9^a^ | 560 | −17^a^
JPEC (2008a); Rat, Crl:CD(SD); Inhalation―vapor; Male (NR): 0, 150, 500, 1,500, or 5,000 ppm (0, 627, 2,090, 6,270, or 20,900 mg/m^3^);^c^ female (NR): 0, 150, 500, 1,500, or 5,000 ppm (0, 627, 2,090, 6,270, or 20,900 mg/m^3^); Dynamic whole-body chamber; 6 h/d, 5 d/wk for 13 wk; generation method, analytical concentration and method were reported | Male | | Female
| Dose (mg/m^3^) | Body weight (%) | Dose (mg/m^3^) | Body weight (%)
| 0 | − | 0 | −
| 627 | 0 | 627 | −6
| 2,090 | 1 | 2,090 | −7
| 6,270 | −1 | 6,270 | −7
| 20,900 | −7 | 20,900 | −11
JPEC (2008a); Rat, Crl:CD(SD); Inhalation―vapor; Male (6/group): 0 or 5,000 ppm (0 or 20,900 mg/m^3^);^c^ female (6/group): 0 or 5,000 ppm (0 or 20,900 mg/m^3^)^c^; Dynamic whole-body chamber; 6 h/d, 5 d/wk for 13 wk followed by a 28 d recovery period; generation method, analytical concentration and method were reported | Male | | Female
| Dose (mg/m^3^) | Body weight (%) | Dose (mg/m^3^) | Body weight (%)
| 0 | − | 0 | −
| 20,900 | 3 | 20,900 | 4
Medinsky et al. (1999); US EPA (1997); Rat, F344; Inhalation―vapor; Male (48/group): 0, 500, 1,750, or 5,000 ppm (0, 2,090, 7,320, or 20,900 mg/m^3^);^c^ female (48/group): 0, 500, 1,750, or 5,000 ppm (0, 2,090, 7,320, or 20,900 mg/m^3^)^c^; Dynamic whole-body chamber; 6 h/d, 5 d/wk for 13 wk; generation method, analytical concentration and method were reported | Male | | Female
| Dose (mg/m^3^) | Body weight (%) | Dose (mg/m^3^) | Body weight (%)
| 0 | − | 0 | −
| 2,090 | 2 | 2,090 | −3
| 7,320 | 4 | 7,320 | 3
| 20,900 | 2 | 20,900 | 6^a^
Medinsky et al. (1999); US EPA (1997); Mice, CD-1; Inhalation―vapor; Male (40/group): 0, 500, 1,750, or 5,000 ppm (0, 2,090, 7,320, or 20,900 mg/m^3^);^c^ female (40/group): 0, 500, 1,750, or 5,000 ppm (0, 2,090, 7,320, or 20,900 mg/m^3^)^c^; Dynamic whole-body chamber; 6 h/d, 5 d/wk for 13 wk; generation method, analytical concentration and method were reported | Male | | Female
| Dose (mg/m^3^) | Body weight (%) | Dose (mg/m^3^) | Body weight (%)
| 0 | − | 0 | −
| 2,090 | 0 | 2,090 | −2
| 7,320 | −1 | 7,320 | −1
| 20,900 | −3 | 20,900 | 2
Saito et al. (2013); JPEC (2010b); Rat, F344; Inhalation―vapor; Male (50/group): 0, 500, 1,500, or 5,000 ppm (0, 2,090, 6,270, or 20,900 mg/m^3^);^c^ female (50/group): 0, 500, 1,500, or 5,000 ppm (0, 2,090, 6,270, or 20,900 mg/m^3^)^c^; Dynamic whole-body inhalation; 6 h/d, 5 d/wk for 104 wk; generation method, analytical concentration, and method were reported | Male | | Female
| Dose (mg/m^3^) | Body weight (%) | Dose (mg/m^3^) | Body weight (%)
| 0 | − | 0 | −
| 2,090 | −7^a^ | 2,090 | −6^a^
| 6,270 | −7^a^ | 6,270 | −10^a^
| 20,900 | −26^a^ | 20,900 | −23^a^

− = for controls, no response relevant; for other doses, no quantitative response reported; NR = not reported; PND = postnatal day.

a Result is statistically significant (p < 0.05) based on analysis of data by study authors.

b Conversion performed by study authors.

c 4.18 mg/m^3^ = 1 ppm.

Percentage change compared to controls calculated as 100 × [(treated value − control value) ÷ control value].

Table B-14 Evidence pertaining to adrenal effects in animals exposed to ETBE

Reference and study design | Results (percentage change compared to control)
Adrenal weight
Hagiwara et al. (2011); JPEC (2008c); Rat, F344; Oral―gavage; Male (12/group): 0, 1,000 mg/kg-d; Daily for 23 wk | Male
Hagiwara et al. (2011); JPEC (2008c); Rat, F344; Oral―gavage; Male (12/group): 0, 1,000 mg/kg-d; Daily for 23 wk | Dose (mg/kg-d) | Absolute weight (%) | Relative weight (%)
Hagiwara et al. (2011); JPEC (2008c); Rat, F344; Oral―gavage; Male (12/group): 0, 1,000 mg/kg-d; Daily for 23 wk | 0 | − | −
Hagiwara et al. (2011); JPEC (2008c); Rat, F344; Oral―gavage; Male (12/group): 0, 1,000 mg/kg-d; Daily for 23 wk | 1,000 | 16^a^ | 19^a^
Medinsky et al. (1999); US EPA (1997); Rat, F344; Inhalation―vapor; Male (48/group): 0, 500, 1,750, 5,000 ppm (0, 2,090, 7,320, 20,900 mg/m^3^);^b^ female (48/group): 0, 500, 1,750, 5,000 ppm (0, 2,090, 7,320, 20,900 mg/m^3^)^b^; dynamic whole-body chamber; 6 h/d, 5 d/wk for 13 wk; generation method, analytical concentration and method were reported | Male | | Female
| Dose (mg/m^3^) | Absolute weight (%) | Dose (mg/m^3^) | Absolute weight (%)
| 0 | − | 0 | −
| 2,090 | 11 | 2,090 | 7
| 7,320 | 9 | 7,320 | 7
| 20,900 | 34^a^ | 20,900 | 18^a^
Medinsky et al. (1999); Bond et al. (1996); Mice, CD-1; Inhalation―vapor; Male (40/group): 0, 500, 1,750, 5,000 ppm (0, 2,090, 7,320, 20,900 mg/m^3^);^b^ female (40/group): 0, 500, 1,750, 5,000 ppm (0, 2,090, 7,320, 20,900 mg/m^3^)^b^; Dynamic whole-body chamber; 6 h/d, 5 d/wk for 13 wk; generation method, analytical concentration and method were reported | Male | | Female
| Dose (mg/m^3^) | Absolute weight (%) | Dose (mg/m^3^) | Absolute weight (%)
| 0 | − | 0 | −
| 2,090 | 0 | 2,090 | −8
| 7,320 | 50 | 7,320 | 8
| 20,900 | 0 | 20,900 | −8

− = for controls, no response relevant; for other doses, no quantitative response reported; n = number evaluated from group.

a Result is statistically significant (p < 0.05) based on analysis of data by study authors.

b 4.18 mg/m^3^ = 1 ppm.

Table B-15 Evidence pertaining to immune effects in animals exposed to ETBE

Reference and study design | Results (percentage change compared to control)
Functional immune effects
Banton et al. (2011); Rat, Sprague-Dawley; Oral―gavage; Female (10/group): 0, 250, 500, or 1,000 mg/kg-d; Daily for 28 consecutive d; Immunized i.v. 4 d prior to sacrifice with sheep red blood cells | Female
Banton et al. (2011); Rat, Sprague-Dawley; Oral―gavage; Female (10/group): 0, 250, 500, or 1,000 mg/kg-d; Daily for 28 consecutive d; Immunized i.v. 4 d prior to sacrifice with sheep red blood cells | Dose (mg/kg-d) | | IgM antibody forming cells/10^6^ spleen cells (%) | | IgM antibody forming cells/spleen (%)
Banton et al. (2011); Rat, Sprague-Dawley; Oral―gavage; Female (10/group): 0, 250, 500, or 1,000 mg/kg-d; Daily for 28 consecutive d; Immunized i.v. 4 d prior to sacrifice with sheep red blood cells | 0 | | − | | −
Banton et al. (2011); Rat, Sprague-Dawley; Oral―gavage; Female (10/group): 0, 250, 500, or 1,000 mg/kg-d; Daily for 28 consecutive d; Immunized i.v. 4 d prior to sacrifice with sheep red blood cells | 250 | | −21 | | −20
Banton et al. (2011); Rat, Sprague-Dawley; Oral―gavage; Female (10/group): 0, 250, 500, or 1,000 mg/kg-d; Daily for 28 consecutive d; Immunized i.v. 4 d prior to sacrifice with sheep red blood cells | 500 | | 42 | | 36
Banton et al. (2011); Rat, Sprague-Dawley; Oral―gavage; Female (10/group): 0, 250, 500, or 1,000 mg/kg-d; Daily for 28 consecutive d; Immunized i.v. 4 d prior to sacrifice with sheep red blood cells | 1,000 | | 8 | | 8
Immune cell populations
Li et al. (2011); Mice, 129/SV; Inhalation―vapor; Male (6/group): 0, 500, 1,750, or 5,000 ppm (0, 2,090, 7,320, or 20,900 mg/m^3^)^a^; Whole body, 6 h/d for 5 d/wk over 6 wk; generation method not reported; analytical concentration and method were reported | Male
| Dose (mg/m^3^) | Number of CD3^+^ T cells (%) | | Number of CD4^+^ T cells (%) | | Number of CD8^+^ T cells (%)
| 0 | − | | − | | −
| 2,090 | −18^b^ | | −16 | | −13
| 7,320 | −16 | | −11 | | −14
| 20,900 | −21^b^ | | −17^b^ | | −25
Li et al. (2011); Mice, C57BL/6; Inhalation―vapor; Male (6/group): 0, 500, 1,750, or 5,000 ppm (0, 2,090, 7,320, or 20,900 mg/m^3^)^a^; Whole body, 6 h/d for 5 d/wk over 6 wk; generation method not reported; analytical concentration and method were reported | Male
| Dose (mg/m^3^) | Number of CD3^+^ T cells (%) | | Number of CD4^+^ T cells (%) | | Number of CD8^+^ T cells (%)
| 0 | − | | − | | −
| 2,090 | −14 | | −15 | | −12
| 7,320 | −13 | | −11 | | −13^b^
| 20,900 | −24^b^ | | −23^b^ | | −23^b^
Li et al. (2011); Mice, C57BL/6; Inhalation―vapor; Male (5/group): 0, 500, 1,750, or 5,000 ppm (0, 2,090, 7,320, or 20,900 mg/m^3^)^a^; Whole body, 6 h/d for 5 d/wk over 13 wk; generation method not reported; analytical concentration and method were reported | Male
| Dose (mg/m^3^) | Number of CD3^+^ T cells (%) | | Number of CD4^+^ T cells (%) | | Number of CD8^+^ T cells (%)
| 0 | − | | − | | −
| 2,090 | −9 | | −11 | | −8
| 7,320 | −17^b^ | | −28^b^ | | −12
| 20,900 | −24^b^ | | −37^b^ | | −20
Spleen weight
Banton et al. (2011); Rat, Sprague-Dawley; Oral―gavage; Female (10/group): 0, 250, 500, or 1,000 mg/kg-d; Daily for 28 consecutive d | | | | Female
Banton et al. (2011); Rat, Sprague-Dawley; Oral―gavage; Female (10/group): 0, 250, 500, or 1,000 mg/kg-d; Daily for 28 consecutive d | | | | Dose (mg/kg-d) | Absolute weight (%) | Relative weight (%)
Banton et al. (2011); Rat, Sprague-Dawley; Oral―gavage; Female (10/group): 0, 250, 500, or 1,000 mg/kg-d; Daily for 28 consecutive d | | | | 0 | − | −
Banton et al. (2011); Rat, Sprague-Dawley; Oral―gavage; Female (10/group): 0, 250, 500, or 1,000 mg/kg-d; Daily for 28 consecutive d | | | | 250 | −3 | 0
Banton et al. (2011); Rat, Sprague-Dawley; Oral―gavage; Female (10/group): 0, 250, 500, or 1,000 mg/kg-d; Daily for 28 consecutive d | | | | 500 | −15 | −18
Banton et al. (2011); Rat, Sprague-Dawley; Oral―gavage; Female (10/group): 0, 250, 500, or 1,000 mg/kg-d; Daily for 28 consecutive d | | | | 1,000 | −9 | 0
Fujii et al. (2010); JPEC (2008d); Rat, Sprague-Dawley; Oral―gavage; P0, male (24/group): 0, 100, 300, or 1,000 mg/kg-d; Daily for 16 wk beginning 10 wk prior to mating; P0, female (24/group): 0, 100, 300, or 1,000 mg/kg-d; Daily for 17 wk beginning 10 wk prior to mating to LD 21 | P0, Male | | | P0, Female
| Dose (mg/kg-d) | Absolute weight (%) | Relative weight (%) | Dose (mg/kg-d) | Absolute weight (%) | Relative weight (%)
| 0 | − | − | 0 | − | −
| 100 | −4 | −1 | 100 | 0 | −2
| 300 | −2 | 2 | 300 | −2 | −3
| 1,000 | 0 | 8 | 1,000 | −1 | −5
Hagiwara et al. (2011); JPEC (2008c); Rat, F344; Oral―gavage; Male (12/group): 0 or 1,000 mg/kg-d; Daily for 23 wk | Male
Hagiwara et al. (2011); JPEC (2008c); Rat, F344; Oral―gavage; Male (12/group): 0 or 1,000 mg/kg-d; Daily for 23 wk | Dose (mg/kg-d) | Absolute weight (%) | Relative weight (%)
Hagiwara et al. (2011); JPEC (2008c); Rat, F344; Oral―gavage; Male (12/group): 0 or 1,000 mg/kg-d; Daily for 23 wk | 0 | − | −
Hagiwara et al. (2011); JPEC (2008c); Rat, F344; Oral―gavage; Male (12/group): 0 or 1,000 mg/kg-d; Daily for 23 wk | 1,000 | −5 | 0
Suzuki et al. (2012); JPEC (2010a); Rat, F344; Oral―water; Male (50/group): 0, 625, 2,500, or 10,000 ppm (0, 28, 121, or 542 mg/kg-d);^a^ female (50/group): 0, 625, 2,500, or 10,000 ppm (0, 46, 171, or 560 mg/kg-d)^a^; Daily for 104 wk | Male | | | Female
| Dose (mg/kg-d) | Absolute weight (%) | Relative weight (%) | Dose (mg/kg-d) | Absolute weight (%) | Relative weight (%)
| 0 | − | − | 0 | − | −
| 628 | −3 | −35 | 46 | −35 | 2
| 121 | 19 | 3^b^ | 171 | −1 | 28
| 542 | 39 | −45 | 560 | −50^b^ | 55^b^
JPEC (2008a); Rat, Crl:CD(SD); Inhalation―vapor; Male (NR): 0, 150, 500, 1,500, or 5,000 ppm (0, 627, 2,090, 6,270, or 20,900 mg/m^3^);^c^ female (NR): 0, 150, 500, 1,500, or 5,000 ppm (0, 627, 2,090, 6,270, or 20,900 mg/m^3^); Dynamic whole-body chamber; 6 h/d, 5 d/wk for 13 wk; generation method, analytical concentration and method were reported | Male | | | Female
| Dose (mg/m^3^) | Absolute weight (%) | Relative weight (%) | Dose (mg/m^3^) | Absolute weight (%) | Relative weight (%)
| 0 | − | − | 0 | − | −
| 627 | 0 | 0 | 627 | −9 | −3
| 2,090 | 7 | 5 | 2,090 | −2 | 5
| 6,270 | −1 | 1 | 6,270 | −5 | 1
| 20,900 | −9 | −2 | 20,900 | 1 | 12
JPEC (2008a); Rat, Crl:CD(SD); Inhalation―vapor; Male (6/group): 0 or 5,000 ppm (0 or 20,900 mg/m^3^);^c^ female (6/group): 0 or 5,000 ppm (0 or 20,900 mg/m^3^)^c^; Dynamic whole-body chamber; 6 h/d, 5 d/wk for 13 wk followed by a 28-d recovery period; generation method, analytical concentration and method were reported | Male | | | Female
| Dose (mg/m^3^) | Absolute weight (%) | Relative weight (%) | Dose (mg/m^3^) | Absolute weight (%) | Relative weight (%)
| 0 | − | − | 0 | − | −
| 20,900 | 10 | 6 | 20,900 | 6 | 0
Saito et al. (2013); JPEC (2010b); Rat, F344; Inhalation―vapor; Male (50/group): 0, 500, 1,500, or 5,000 ppm (0, 2,090, 6,270, or 20,900 mg/m^3^);^c^ female (50/group): 0, 500, 1,500, or 5,000 ppm (0, 2,090, 6,270, or 20,900 mg/m^3^)^c^; Dynamic whole-body inhalation; 6 h/d, 5 d/wk for 104 wk; generation method, analytical concentration and method were reported | Male | | | Female
| Dose (mg/m^3^) | Absolute weight (%) | Relative weight (%) | Dose (mg/m^3^) | Absolute weight (%) | Relative weight (%)
| 0 | − | − | 0 | − | −
| 2,090 | 4 | 15 | 2,090 | 5 | 30
| 6,270 | 32 | 43^b^ | 6,270 | −39 | −31
| 20,900 | 17 | 66^b^ | 20,900 | −43^b^ | −25
Medinsky et al. (1999); US EPA (1997); Rat, F344; Inhalation―vapor; Male (48/group): 0, 500, 1,750, or 5,000 ppm (0, 2,090, 7,320, or 20,900 mg/m^3^);^c^ female (48/group): 0, 500, 1,750, or 5,000 ppm (0, 2,090, 7,320, or 20,900 mg/m^3^)^c^; Dynamic whole-body chamber; 6 h/d, 5 d/wk for 13 wk; generation method, analytical concentration and method were reported | Male | | | Female
| Dose (mg/m^3^) | Absolute weight (%) | | Dose (mg/m^3^) | Absolute weight (%)
| 0 | − | | 0 | −
| 2,090 | 6 | | 2,090 | −3
| 7,320 | 3 | | 7,320 | 3
| 20,900 | 5 | | 20,900 | 0
Medinsky et al. (1999); Bond et al. (1996); Mice, CD-1; Inhalation―vapor; Male (40/group): 0, 500, 1,750, or 5,000 ppm (0, 2,090, 7,320, or 20,900 mg/m^3^);^c^ female (40/group): 0, 500, 1,750, or 5,000 ppm (0, 2,090, 7,320, or 20,900 mg/m^3^)^c^; Dynamic whole-body chamber; 6 h/d, 5 d/wk for 13 wk; generation method, analytical concentration and method were reported | Male | | | Female
| Dose (mg/m^3^) | Absolute weight (%) | | Dose (mg/m^3^) | Absolute weight (%)
| 0 | − | | 0 | −
| 2,090 | −5 | | 2,090 | −11
| 7,320 | 0 | | 7,320 | −2
| 20,900 | −15 | | 20,900 | −11

− = for controls, no response relevant; for other doses, no quantitative response reported; LD = lactation day; n = number evaluated from group; NR = not reported.

a Conversion performed by the study authors.

b Result is statistically significant (p < 0.05) based on analysis of data by the study authors.

c 4.18 mg/m^3^ = 1 ppm.

Table B-16 Evidence pertaining to mortality in animals exposed to ETBE

Reference and study design | Results (percentage change compared to control)
Maltoni et al. (1999); Rat, Sprague-Dawley; Oral―gavage; Male (60/group): 0, 250, or 1,000 mg/kg-d; female (60/group): 0, 250, or 1,000 mg/kg-d; 4 d/wk for 104 wk; observed until natural death | Male | | Female
Maltoni et al. (1999); Rat, Sprague-Dawley; Oral―gavage; Male (60/group): 0, 250, or 1,000 mg/kg-d; female (60/group): 0, 250, or 1,000 mg/kg-d; 4 d/wk for 104 wk; observed until natural death | Dose (mg/m^3^) | Survival at 104 wk (%) | Dose (mg/m^3^) | Survival at 104 wk (%)
Maltoni et al. (1999); Rat, Sprague-Dawley; Oral―gavage; Male (60/group): 0, 250, or 1,000 mg/kg-d; female (60/group): 0, 250, or 1,000 mg/kg-d; 4 d/wk for 104 wk; observed until natural death | 0 | − | 0 | −
Maltoni et al. (1999); Rat, Sprague-Dawley; Oral―gavage; Male (60/group): 0, 250, or 1,000 mg/kg-d; female (60/group): 0, 250, or 1,000 mg/kg-d; 4 d/wk for 104 wk; observed until natural death | 250 | −8 | 250 | −8
Maltoni et al. (1999); Rat, Sprague-Dawley; Oral―gavage; Male (60/group): 0, 250, or 1,000 mg/kg-d; female (60/group): 0, 250, or 1,000 mg/kg-d; 4 d/wk for 104 wk; observed until natural death | 1,000 | −54 | 1,000 | 18
Suzuki et al. (2012); JPEC (2010a); Rat, F344; Oral―water; Male (50/group): 0, 625, 2,500, or 10,000 ppm (0, 28, 121, or 542 mg/kg-d);^a^ female (50/group): 0, 625, 2,500, or 10,000 ppm (0, 46, 171, or 560 mg/kg-d)^a^; Daily for 104 wk | Male | | Female
| Dose (mg/kg-d) | Percentage survival (%) | Dose (mg/kg-d) | Percentage survival (%)
| 0 | − | 0 | −
| 628 | −3 | 46 | 3
| 121 | −11 | 171 | 6
| 542 | −11 | 560 | 6
Saito et al. (2013); JPEC (2010b); Rat, F344; Inhalation―vapor; Male (50/group): 0, 500, 1,500, or 5,000 ppm (0, 2,090, 6,270, or 20,900 mg/m^3^);^b^ female (50/group): 0, 500, 1,500, or 5,000 ppm (0, 2,090, 6,270, or 20,900 mg/m^3^)^b^; Dynamic whole-body inhalation; 6 h/d, 5 d/wk for 104 wk; generation method, analytical concentration and method were reported | Male | | Female
| Dose (mg/m^3^) | Survival at 104 wk (%) | Dose (mg/m^3^) | Survival at 104 wk (%)
| 0 | − | 0 | −
| 2,090 | −14 | 2,090 | 3
| 6,270 | −9 | 6,270 | −21^c^
| 20,900 | −32^c^ | 20,900 | −21^c^

− = for controls, no response relevant; for other doses, no quantitative response reported; n = number evaluated from group.

a Conversion performed by the study authors.

b 4.18 mg/m^3^ = 1 ppm.

c Result is statistically significant (p < 0.05) based on analysis of data by the study authors.

Figure B-14 Exposure-response array of body-weight effects following oral exposure to ETBE

Figure B-15 Exposure-response array of body-weight effects following inhalation exposure to ETBE

##### Mortality

Mortality was significantly increased in male and female rats following a 2-year ETBE inhalation exposure (Saito et al., 2013; JPEC, 2010b) but not significantly affected following a 2-year drinking water exposure (Suzuki et al., 2012; JPEC, 2010a). Increased mortality in male rats correlated with increased CPN severity in the kidney. The study authors attributed increased mortality in females to pituitary tumors; however, pituitary tumors were not dose responsively increased by ETBE exposure. Survival was also reduced in a lifetime gavage study at the highest exposure in males and females after 72 weeks (data not shown), and after 104 weeks, survival was reduced 54% in males at the highest dose (Maltoni et al., 1999). After 104 weeks, however, survival in the controls was approximately 25% in males and 28% in females, percentages that are much lower than expected for a 2-year study (Maltoni et al., 1999). The survival data in this study was likely confounded by chronic respiratory infections, which could have contributed to the reduced survival (Malarkey and Bucher, 2011). These data do not suggest that mortality was increased in these studies due to excessively high exposure concentrations of ETBE; thus, the mortality data are inadequate to draw conclusions as a human hazard of ETBE exposure.

#### Mechanistic Evidence

No relevant mechanistic data are available for these endpoints.

#### Summary of Other Toxicity Data

EPA concluded that the evidence is insufficient to support body-weight changes, adrenal and immunological effects, and mortality as potential human hazards of ETBE exposure based on confounding factors, lack of progression, and study quality concerns.

### B.2.2 Genotoxicity Studies

#### Bacterial Systems

The mutagenic potential of ETBE has been tested by Zeiger et al. (1992) using different Salmonella typhimurium strains for 311 chemicals, including ETBE, both in the absence and presence of metabolic activation (S9). Preincubation protocol was followed and precaution was exercised to account for the volatility of the compound. Five doses ranging from 100 to 10,000 μg/plate were tested using different Salmonella strains, including TA97, TA98, TA100, and TA1535. The results showed that the ETBE did not cause mutations in any of the Salmonella strains tested. It should be noted that TA102, a sensitive strain for oxidative metabolite, was not used in this study. The available genotoxicity data for ETBE are discussed below, and the summary of the data is provided in Table B-17.

Table B-17 Summary of genotoxicity (both in vitro and in vivo) studies of ETBE

Species | Test system | Dose/concentration | Results^a^ | | Comments | Reference
Species | Test system | Dose/concentration | −S9 | +S9 | Comments | Reference
Bacterial systems
Salmonella typhimurium (TA97, TA98, TA100, TA1535) | Mutation assay | 100, 333, 1,000, 3,333, 10,000 μg/plate | − | − | Preincubation procedure was followed. Experiment was conducted in capped tubes to control for volatility | Zeiger et al. (1992)
In vitro systems
Chinese hamster ovary cells (hgprt locus) | Gene mutation assay | 100, 300, 1,000, 3,000, 5,000 μg/mL | − | − | Experiments conducted both with and without metabolic activation | Vergnes and Kubena (1995b) (unpublished report)
Chinese hamster ovary cells | Chromosomal aberration assay | 100, 300, 1,000, 3,000, 5,000 μg/mL | − | − | Experiments conducted both with and without metabolic activation | Vergnes (1995) (unpublished report)
In vivo animal studies
CD-1 mice (male and female) | Bone marrow micronucleus test | 0, 400, 2,000, 5,000 ppm (0, 1,670, 8,360, 20,900 mg/m^3^)^b^ | − | | Whole-body inhalation, 6 h/d, 5 d, 5/sex/group | Vergnes and Kubena (1995a) (unpublished report)
B6C3F_1_ mice (male) | Bone marrow micronucleus test | 0, 1,300, 1,700, 2,100, 2,500 mg/kg | − | | Intraperitoneal injection 3×, 72 h; 5/group, 3 animals in dose 1,700 mg/kg dose. Surviving animals were not scored at doses of 2,100 and 2,500 mg/kg | NTP (1996a)
F344 rats (male) | Bone marrow micronucleus test | 0, 625, 1,250, 2,500 mg/kg | − | | Intraperitoneal injection 3×, 72 h; 5/group, 3 animals in 2,500 mg/kg dose group | NTP (1996b)
F344 rats (male and female) | Bone marrow micronucleus test | 0, 500, 1,000, 2,000 mg/kg-d | − | | Gavage, 24 h apart, 2 d, 5/sex/group | JPEC (2007b) (unpublished report)
F344 rats (male and female) | Bone marrow micronucleus test | 0, 250, 500, 1,000, 2,000 mg/kg-d | − | | Intraperitoneal injection, 24 h apart, 2 d, 5/sex/group | Noguchi et al. (2013); JPEC (2007b), unpublished report
F344 rats (male and female) | Bone marrow micronucleus test | 0, 1,600, 4,000, 10,000 ppm (0, 101, 259, 626 mg/kg-d in males; 0, 120, 267, 629 mg/kg-d in females)^c^ | − | | Drinking water, 13 wk, 10/sex/group | Noguchi et al. (2013); JPEC (2007d), unpublished report
F344 rats (male and female) | Bone marrow micronucleus test | 0, 500, 1,500, 5,000 ppm (0, 2,090, 6,270, 20,900 mg/m^3^)^b^ | − | | Whole-body inhalation, 6 h/d, 5 d/wk, 13 wk. 10/sex/group | Noguchi et al. (2013); JPEC (2007d), unpublished report
C57BL/6 WT and Aldh2 KO mice | DNA strand breaks (alkaline comet assay); leukocytes | 0, 500, 1,750, 5,000 ppm | Male WT/KO | +^d^/+ | Whole-body inhalation, 6 h/d, 5 d/wk, 13 wk | Weng et al. (2011)
C57BL/6 WT and Aldh2 KO mice | DNA strand breaks (alkaline comet assay); leukocytes | 0, 500, 1,750, 5,000 ppm | Female WT/KO | −/+^d^ | Whole-body inhalation, 6 h/d, 5 d/wk, 13 wk | Weng et al. (2011)
C57BL/6 WT and Aldh2 KO mice | DNA strand breaks (alkaline comet assay) | 0, 500, 1,750, 5,000 ppm | Male WT/KO | +^d^/+ | Whole-body inhalation, 6 h/d, 5 d/wk, 13 wk | Weng et al. (2012)
C57BL/6 WT and Aldh2 KO mice | DNA strand breaks (alkaline comet assay) | 0, 500, 1,750, 5,000 ppm | Female WT/KO | −/+^d^ | Whole-body inhalation, 6 h/d, 5 d/wk, 13 wk | Weng et al. (2012)
C57BL/6 WT and Aldh2 KO mice | Micronucleus assay; erythrocytes | 0, 500, 1,750, 5,000 ppm | Male^e^ WT/KO | +^d^/+ | Whole-body inhalation, 6 h/d, 5 d/wk, 13 wk | Weng et al. (2013)
C57BL/6 WT and Aldh2 KO mice | Micronucleus assay; erythrocytes | 0, 500, 1,750, 5,000 ppm | Female^e^ WT/KO | −/+ | Whole-body inhalation, 6 h/d, 5 d/wk, 13 wk | Weng et al. (2013)
C57BL/6 WT and Aldh2 KO mice | DNA strand breaks (alkaline comet assay); sperm | 0, 50, 200, 500 ppm | WT/HT/KO | −/+/+ | Whole-body inhalation, 6 h/d, 5 d/wk, 9 wk | Weng et al. (2014)
C57BL/6 WT and Aldh2 KO mice | DNA strand breaks (alkaline comet assay); sperm | 0, 500, 1,750, 5,000 ppm | WT/KO | +/+ | Whole-body inhalation, 6 h/d, 5 d/wk, 13 wk | Weng et al. (2014)

KO = knockout; WT = wild type.

a + = positive; − = negative; (+) = equivocal.

b 4.18 mg/m^3^ = 1 ppm.

c Conversions performed by study authors.

d Positive in highest dose tested.

e When the data of ETBE-induced MNRETs were normalized with corresponding control, the effect disappeared.

#### In Vitro Mammalian Studies

The two available studies in in vitro mammalian systems were unpublished reports. Vergnes and Kubena (1995b) evaluated the mutagenicity of ETBE using the hypoxanthine-guanine phosphoribosyltransferase (HGPRT) forward mutation assay in Chinese hamster ovary K1-BH4 cells. Duplicate cultures were treated with five concentrations of ETBE (>98% purity; containing 13 ppm AO22, an antioxidant stabilizer) ranging from 100 to 5,000 μg/mL, both in the presence and absence of S9 activation. No statistically significant or concentration-related increase in the HGPRT mutation frequencies were observed at any of the ETBE concentrations tested, either in the absence or in the presence of metabolic (S9) activation.

The same authors [Vergnes and Kubena (1995b) unpublished report] studied the clastogenic potential of ETBE in vitro using a chromosome aberration assay in Chinese hamster ovary cells. The cells were exposed from 100 to 5,000 μg/mL of ETBE in culture medium, both in the presence and absence of S9 metabolic activation system. No statistically significant or concentration-related increase in the frequency of chromosomal aberrations, in the presence or absence of the S9 metabolic activation system, was observed. Neither the effect of the antioxidant stabilizer used in ETBE nor control for volatility of the compound was described for both studies although capped glass bottles were used in the experiments.

#### In Vivo Animal Studies

In vivo studies were conducted by the same authors that tested ETBE for in vitro genotoxicity. Vergnes and Kubena (1995a), in an unpublished report, performed an in vivo bone marrow micronucleus (MN) test in mice in response to ETBE exposure. Male and female CD-1 mice (5/sex/group) were exposed to ETBE by inhalation at target concentrations of 0, 400, 2,000, or 5,000 ppm (0, 1,671, 8,357, or 20,894 mg/m^3^) for 6 hours/day, for 5 days. Following treatment, polychromatic erythrocytes (PCE) from bone marrow were analyzed for micronucleus formation. The results showed that no statistically significant increases in the mean percentages of micronucleated polychromatic erythrocytes (MNPCE) were observed in mice (male or female) when exposed to ETBE.

In addition to Vergnes and Kubena (1995a), four animal studies were conducted by JPEC in rats using different routes of exposure (oral, inhalation, intraperitoneal, or drinking water) to detect micronucleus as a result of exposure to ETBE [JPEC (2007a, 2007b, 2007c, 2007d) published as Noguchi et al. (2013)].

The first two studies (oral and intraperitoneal injection) were part of an acute (2-day) exposure. In the first study, both male and female F344 rats (5/sex/dose group) were administered ETBE (99.3% pure) via gavage in olive oil at doses of 0, 500, 1,000, or 2,000 mg/kg-day every 24 hours [JPEC (2007a), unpublished report]. The animals were sacrificed, and bone marrow smears were collected and stained 24 hours after the final administration. Following treatment, polychromatic erythrocytes from bone marrow were analyzed for MN formation. The results were expressed as the ratio of PCE to total erythrocytes. No treatment-related effects on the number of MNPCE or the ratio of PCE to total erythrocytes were found. ETBE was determined to be negative for micronuclei induction in rat bone marrow cells after acute oral exposure.

In the second study (intraperitoneal injection), male and female F344 rats (5/sex/dose group) were administered two ETBE intraperitoneal injections separated by 24 hours at doses of 0, 250, 500, 1,000, or 2,000 mg/kg-day in olive oil (Noguchi et al., 2013; JPEC, 2007b). The animals were sacrificed, and bone marrow smears were collected and stained 24 hours after the final injection. All animals in the 2,000 mg/kg-day group died on the first day of treatment. There were no treatment-related effects on either the number of MNPCEs or the ratio of polychromatic erythrocytes to total erythrocytes. In addition, no dose-dependent tendencies for the increase in the MNPCE to PCE ratio or alterations in the ratios of PCE to total erythrocytes were noted in either sex of the treated groups. ETBE was determined to be negative for micronuclei induction in rats after acute intraperitoneal exposure.

The next two studies (drinking water and inhalation) were part of 13-week toxicity studies in rats in which the effects of ETBE on the micronuclei in PCE were examined at the end of the study. In the first 13-week study, male and female F344 rats (10/sex/dose group) were given drinking water containing 0, 1,600, 4,000, or 10,000 ppm ETBE for 13 weeks (Noguchi et al., 2013; JPEC, 2007c). The concentrations were stated to be equivalent to 0, 101, 259, and 626 mg/kg-day in males and 0, 120, 267, and 629 mg/kg-day in females. Following treatment, polychromatic erythrocytes from bone marrow were analyzed for MN formation. The results were expressed as the ratio of PCE to total erythrocytes. There were no treatment-related effects on the number of MNPCEs or the ratio of PCE to total erythrocytes.

In the second 13-week study (inhalation), male and female F344 rats (10/sex/dose group) were exposed to ETBE (99.2−99.3% pure) through whole-body inhalation exposure at 0, 500, 1,500, or 5,000 ppm (0, 2,089, 6,268, or 20,894 mg/m^3^) for 6 hours/day, 5 days/week (Noguchi et al., 2013; JPEC, 2007b). Normochromatic and polychromatic erythrocytes and micronuclei were counted as in the previous study. There were no treatment-related effects on the number of MNPCE or the ratio of PCE to total erythrocytes. ETBE was determined to be negative for micronuclei induction in rat bone marrow cells after a 13-week inhalation exposure.

Furthermore, NTP (1996a, 1996b) performed an in vivo bone marrow micronucleus test in both B6C3F_1_ mice and Fischer rats. The animals were exposed through intraperitoneal injection 3 times in a period of 72 hours (n = 5). Doses for the mice were 0, 1,300, 1,700, 2,100, or 2,500 mg/kg, and the doses for rats were 0, 625, 1,250, or 2,500 mg/kg. No increase in micronucleated PCEs were observed in either mice or rats. Two of five mice died in the 1,700 mg/kg dose group, while 3 of 5 and 4 of 5 animals died in the 2,100 and 2,500 mg/kg dose groups, respectively, and the surviving animals in the two highest dose groups were not scored. In the rat study, 2 of 5 animals died in the highest dose group.

Weng et al. (2011) conducted several studies evaluating the differences in genotoxicity of ETBE in various tissues or systems (i.e., erythrocytes, leukocytes, liver, and sperm) in C57BL/6 wild type and Aldh2 knockout mice after subchronic inhalation exposure. All studies used the same exposures (i.e., 0, 500, 1,750, or 5,000 ppm ETBE for 6 hours/day, 5 days/week for 13 weeks). Deoxyribonucleic acid (DNA) strand breaks were observed in leukocytes of male (all concentrations) and female (high dose only) Aldh2 knockout mice and with the high dose in wild-type male mice (Weng et al., 2011).

Weng et al. (2012) studied the differential genotoxic effects of subchronic exposure to ETBE in the liver of C57BL/6 wild-type and Aldh2 knockout mice. DNA strand breaks in the hepatocytes of male and female with different Aldh2 genotypes were determined using the alkaline comet assay. In addition, 8-hydroxyguanine DNA-glycosylase (hOGG1)-modified oxidative base modification, and 8-hydroxydeoxyguanosine were determined as endpoints for genetic damage. There was significant increase in damage in all three exposure groups in the knockout male mice, although the increase was only found in the 5,000-ppm exposure group for the knockout female mice. In the wild type, significant DNA damage was seen only in males in the 5,000-ppm group, but not in females. This indicates the sensitivity of sex differences both in knockout and wild-type mice.

Another study by the same authors performed in vivo micronucleus tests (on what appear to be the same set of animals), in addition to the DNA strand breaks, 8-hydroxyguanine DNA glycosylase 1 (8-hOGG1)-modified oxidative base modification, and 8-hydroxydeoxyguanosine (Weng et al., 2013). The mice (wild type and knockout, males and females) were exposed to 0, 500, 1,750, or 5,000 ppm ETBE for 6 hours/day, 5 days/week for 13 weeks. Peripheral blood samples were obtained and processed to detect micronucleated reticulocytes (MNRETs) and micronuclei in the mature normochromatic erythrocyte population. The results indicate that ETBE significantly affected frequencies of MNRETs in male and female mice. In knockout male mice, the frequencies of MNRETs of the 1,750- and 5,000-ppm exposure groups were significantly increased when compared with the control group. In the wild-type male mice, however, only the 5,000-ppm group had a higher frequency of MNRETs than that of the control group. In female wild-type mice, there was no difference in the frequencies of MNRETs between exposure groups and the control group. In the same exposure group (5,000 ppm), the knockout mice had a higher frequency of MNRETs than the wild type. These results inform the influence of Aldh2 and sex difference on genotoxicity as a result of exposure to ETBE.

In yet another study by the same authors (Weng et al., 2014), DNA strand breaks and 8-hydroxyguanine DNA glycosylase 1 (8-hOGG1)-modified oxidative base modification were measured in sperm collected from the left cauda epididymis. In addition to the 13-week protocol used in the other studies, Weng et al. (2014) included a 9-week study in which the male mice (wild type, knockout, and heterogeneous [HT]) were exposed to 0, 50, 200, or 500 ppm ETBE for 6 hours/day, 5 days/week. In the 13-week study, there were significant increases in damage in all three exposure groups in the knockout male mice, but only in the two highest dose groups in the wild-type males. In the 9-week study, there was no change in the wild-type mice, but both the heterogeneous and the knockout mice had significant increases in the two highest doses.

#### Summary

Limited studies have been conducted to understand the genotoxic potential of ETBE. Most studies indicate that ETBE does not induce genotoxicity in the systems tested. More recently, Weng and coauthors illustrated the influence of Aldh2 on the genotoxic effects of ETBE. With respect to overall existing database, it should be noted that the array of genotoxic tests conducted are limited. The inadequacy of the database is two dimensional: (1) the coverage of the studies across the genotoxicity tests needed for proper interpretation of the weight of evidence of the data is sparse and (2) the quality of the available data is questionable. With respect to the array of types of genotoxicity tests available, ETBE has only been tested in one bacterial assay. Only two in vitro studies are available. The existing in vivo studies have tested only for the micronucleus assay, DNA strand breaks, or both. Key studies on chromosomal aberrations and DNA adducts are missing. Additionally, the few existing studies are unpublished reports lacking peer review. Given the above limitations (i.e., the significant deficiencies and sparse database both in terms of quality and quantity), the database is insufficient to draw a definitive conclusion on the genotoxic effects of ETBE.

## B.3 SUPPLEMENTAL ORGAN-WEIGHT DATA

### B.3.1 Relative Kidney-Weight Data

Table B-18 Evidence pertaining to relative kidney-weight effects in animals exposed to ETBE

Reference and study design | Results (percentage change compared to control)
Fujii et al. (2010); JPEC (2008d); Rat, S-D; Oral―gavage; P0, male (24/group): 0, 100, 300, or 1,000 mg/kg-d; Daily for 16 wk beginning 10 wk prior to mating; P0, female (24/group): 0, 100, 300, or 1,000 mg/kg-d; Daily for 17 wk beginning 10 wk prior to mating to LD 21 | P0, Male | | P0, Female
| Dose (mg/kg-d) | Relative weight (%) | Dose (mg/kg-d) | Relative weight (%)
| 0 | − | 0 | −
| 100 | 8^a^ | 100 | −3
| 300 | 12^a^ | 300 | −1
| 1,000 | 26^a^ | 1,000 | 2
Gaoua (2004b); Rat, S-D; Oral―gavage; P0, male (25/group): 0, 250, 500, or 1,000 mg/kg-d; Daily for a total of 18 wk beginning 10 wk before mating until after weaning of the pups; P0, female (25/group): 0, 250, 500, or 1,000 mg/kg-d; Daily for a total of 18 wk beginning 10 wk before mating until PND 21; F1, males and females (25/group/sex): via P0 dams in utero daily through gestation and lactation, then F1 doses beginning PND 22 until weaning of the F2 pups | P0, Male | | P0, Female
| Dose (mg/kg-d) | Relative weight (%) | Dose (mg/kg-d) | Relative weight (%)
| 0 | − | 0 | −
| 250 | 11^a^ | 250 | 9
| 500 | 18^a^ | 500 | 5
| 1,000 | 28^a^ | 1,000 | 3
| F1, Male | | F1, Female
| Dose (mg/kg-d) | Relative weight (%) | Dose (mg/kg-d) | Relative weight (%)
| 0 | − | 0 | −
| 250 | 10^a^ | 250 | 6
| 500 | 19^a^ | 500 | 6
| 1,000 | 58^a^ | 1,000 | 10^a^
Hagiwara et al. (2011); JPEC (2008c); Rat, F344; Oral―gavage; Male (12/group): 0 or 1,000 mg/kg-d; Daily for 23 wk | Male
Hagiwara et al. (2011); JPEC (2008c); Rat, F344; Oral―gavage; Male (12/group): 0 or 1,000 mg/kg-d; Daily for 23 wk | Dose (mg/kg-d) | Relative weight (%)
Hagiwara et al. (2011); JPEC (2008c); Rat, F344; Oral―gavage; Male (12/group): 0 or 1,000 mg/kg-d; Daily for 23 wk | 0 | −
Hagiwara et al. (2011); JPEC (2008c); Rat, F344; Oral―gavage; Male (12/group): 0 or 1,000 mg/kg-d; Daily for 23 wk | 1,000 | 25^a^
Miyata et al. (2013); JPEC (2008b); Rat, Crl:CD(SD); Oral―gavage; Male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; Daily for 26 wk | Male | | Female
Miyata et al. (2013); JPEC (2008b); Rat, Crl:CD(SD); Oral―gavage; Male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; Daily for 26 wk | Dose (mg/kg-d) | Relative weight (%) | Dose (mg/kg-d) | Relative weight (%)
Miyata et al. (2013); JPEC (2008b); Rat, Crl:CD(SD); Oral―gavage; Male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; Daily for 26 wk | 0 | − | 0 | −
Miyata et al. (2013); JPEC (2008b); Rat, Crl:CD(SD); Oral―gavage; Male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; Daily for 26 wk | 5 | 8 | 5 | 7
Miyata et al. (2013); JPEC (2008b); Rat, Crl:CD(SD); Oral―gavage; Male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; Daily for 26 wk | 25 | 6 | 25 | 4
Miyata et al. (2013); JPEC (2008b); Rat, Crl:CD(SD); Oral―gavage; Male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; Daily for 26 wk | 100 | 12^a^ | 100 | 11^a^
Miyata et al. (2013); JPEC (2008b); Rat, Crl:CD(SD); Oral―gavage; Male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; Daily for 26 wk | 400 | 21^a^ | 400 | 15^a^
Suzuki et al. (2012); JPEC (2010a); Rat, F344; Oral―water; Male (50/group): 0, 625, 2,500, or 10,000 ppm (0, 28, 121, or 542 mg/kg-d);^b^ female (50/group): 0, 625, 2,500, or 10,000 ppm (0, 46, 171, or 560 mg/kg-d)^b^; Daily for 104 wk | Male | | Female
| Dose (mg/kg-d) | Relative weight (%) | Dose (mg/kg-d) | Relative weight (%)
| 0 | − | 0 | −
| 28 | 0 | 46 | 13^a^
| 121 | 12^a^ | 171 | 22^a^
| 542 | 31^a^ | 560 | 37^a^
JPEC (2008a); Rat, Crl:CD(SD); Inhalation―vapor; Male (NR): 0, 150, 500, 1,500, or 5,000 ppm (0, 627, 2,090, 6,270, or 20,900 mg/m^3^);^c^ female (NR): 0, 150, 500, 1,500, or 5,000 ppm (0, 627, 2,090, 6,270, or 20,900 mg/m^3^); Dynamic whole-body chamber; 6 h/d, 5 d/wk for 13 wk; generation method, analytical concentration and method were reported | Male | | Female
| Dose (mg/m^3^) | Relative weight (%) | Dose (mg/m^3^) | Relative weight (%)
| 0 | − | 0 | −
| 627 | 10 | 627 | 8
| 2,090 | 9 | 2,090 | 7
| 6,270 | 20^a^ | 6,270 | 12^a^
| 20,900 | 24^a^ | 20,900 | 20^a^
JPEC (2008a); Rat, Crl:CD(SD); Inhalation―vapor; Male (6/group): 0 or 5,000 ppm (0 or 20,900 mg/m^3^);^c^ female (6/group): 0 or 5,000 ppm (0 or 20,900 mg/m^3^)^c^; Dynamic whole-body chamber; 6 h/d, 5 d/wk for 13 wk followed by a 28 d recovery period; generation method, analytical concentration and method were reported | Male | | Female
| Dose (mg/m^3^) | Relative weight (%) | Dose (mg/m^3^) | Relative weight (%)
| 0 | − | 0 | −
| 20,900 | 15^a^ | 20,900 | 5
Saito et al. (2013); JPEC (2010b); Rat, F344; Inhalation―vapor; Male (50/group): 0, 500, 1,500, or 5,000 ppm (0, 2,090, 6,270, or 20,900 mg/m^3^);^c^ female (50/group): 0, 500, 1,500, or 5,000 ppm (0, 2,090, 6,270, or 20,900 mg/m^3^)^c^; Dynamic whole-body inhalation; 6 h/d, 5 d/wk for 104 wk; generation method, analytical concentration and method were reported | Male | | Female
| Dose (mg/m^3^) | Relative weight (%) | Dose (mg/m^3^) | Relative weight (%)
| 0 | − | 0 | −
| 2,090 | 19^a^ | 2,090 | 11^a^
| 6,270 | 26^a^ | 6,270 | 16^a^
| 20,900 | 66^a^ | 20,900 | 51^a^

− = for controls, no response relevant; for other doses, no quantitative response reported; LD = lactation day; NR = not reported; PND = postnatal day.

a Result is statistically significant (p < 0.05) based on analysis of data by the study authors.

b Conversion performed by the study authors.

c 4.18 mg/m^3^ = 1 ppm.

Percentage change compared to controls calculated as 100 × [(treated value − control value) ÷ control value].

### B.3.2 Absolute Liver-Weight Data

Table B-19 Evidence pertaining to absolute liver-weight effects in animals exposed to ETBE

Reference and study design | Results (percentage change compared to control)
Fujii et al. (2010); JPEC (2008d); Rat, S-D; Oral―gavage; P0, male (24/group): 0, 100, 300, or 1,000 mg/kg-d; daily for 16 wk beginning 10 wk before mating; P0, female (24/group): 0, 100, 300, or 1,000 mg/kg-d; Daily for 17 wk beginning 10 wk before mating to LD 21 | P0, Male | | P0, Female
| Dose (mg/kg-d) | Absolute weight (%) | Dose (mg/kg-d) | Absolute weight (%)
| 0 | − | 0 | −
| 100 | −3 | 100 | −1
| 300 | −1 | 300 | 3
| 1,000 | 13^a^ | 1,000 | 14^a^
Gaoua (2004b); Rat, S-D; Oral―gavage; P0, male (25/group): 0, 250, 500, or 1,000 mg/kg-d; Daily for a total of 18 wk beginning 10 wk before mating until after weaning of the pups; P0, female (25/group): 0, 250, 500, or 1,000 mg/kg-d; Daily for a total of 18 wk beginning 10 wk before mating until PND 21; F1, male (25/group): 0, 250, 500, or 1,000 mg/kg-d; P0 dams dosed daily through gestation and lactation, then F1 doses beginning PND 22 until weaning of the F2 pups; F1, female (24−25/group): 0, 250, 500, or 1,000 mg/kg-d; P0 dams dosed daily through gestation and lactation, then F1 dosed beginning PND 22 until weaning of the F2 pups | P0, Male | | P0, Female
| Dose (mg/kg-d) | Absolute weight (%) | Dose (mg/kg-d) | Absolute weight (%)
| 0 | − | 0 | −
| 250 | 2 | 250 | −1
| 500 | 2 | 500 | 4
| 1,000 | 17^a^ | 1,000 | 6
| F1, Male | | F1, Female
| Dose (mg/kg-d) | Absolute weight (%) | Dose (mg/kg-d) | Absolute weight (%)
| 0 | − | 0 | −
| 250 | 0 | 250 | 1
| 500 | 14^a^ | 500 | 3
| 1,000 | 27^a^ | 1,000 | 10^a^
Hagiwara et al. (2011); JPEC (2008c); Rat, F344; Oral―gavage; Male (12/group): 0 or 1,000 mg/kg-d; Daily for 23 wk | Male
Hagiwara et al. (2011); JPEC (2008c); Rat, F344; Oral―gavage; Male (12/group): 0 or 1,000 mg/kg-d; Daily for 23 wk | Dose (mg/kg-d) | Absolute weight (%)
Hagiwara et al. (2011); JPEC (2008c); Rat, F344; Oral―gavage; Male (12/group): 0 or 1,000 mg/kg-d; Daily for 23 wk | 0 | −
Hagiwara et al. (2011); JPEC (2008c); Rat, F344; Oral―gavage; Male (12/group): 0 or 1,000 mg/kg-d; Daily for 23 wk | 1,000 | 21^a^
Miyata et al. (2013); JPEC (2008b); Rat, Crl:CD(SD); Oral―gavage; Male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; Daily for 26 wk | Male | | Female
Miyata et al. (2013); JPEC (2008b); Rat, Crl:CD(SD); Oral―gavage; Male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; Daily for 26 wk | Dose (mg/kg-d) | Absolute weight (%) | Dose (mg/kg-d) | Absolute weight (%)
Miyata et al. (2013); JPEC (2008b); Rat, Crl:CD(SD); Oral―gavage; Male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; Daily for 26 wk | 0 | − | 0 | −
Miyata et al. (2013); JPEC (2008b); Rat, Crl:CD(SD); Oral―gavage; Male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; Daily for 26 wk | 5 | −2 | 5 | −4
Miyata et al. (2013); JPEC (2008b); Rat, Crl:CD(SD); Oral―gavage; Male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; Daily for 26 wk | 25 | 7 | 25 | −1
Miyata et al. (2013); JPEC (2008b); Rat, Crl:CD(SD); Oral―gavage; Male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; Daily for 26 wk | 100 | 4 | 100 | 2
Miyata et al. (2013); JPEC (2008b); Rat, Crl:CD(SD); Oral―gavage; Male (15/group): 0, 5, 25, 100, or 400 mg/kg-d; female (15/group): 0, 5, 25, 100, or 400 mg/kg-d; Daily for 26 wk | 400 | 19 | 400 | 9
Suzuki et al. (2012); JPEC (2010a); Rat, F344; Oral―water; Male (50/group): 0, 625, 2,500, or 10,000 ppm (0, 28, 121, or 542 mg/kg-d);^b^ female (50/group): 0, 625, 2,500, or 10,000 ppm (0, 46, 171, or 560 mg/kg-d)^b^; Daily for 104 wk | Male | | Female
| Dose (mg/kg-d) | Absolute weight (%) | Dose (mg/kg-d) | Absolute weight (%)
| 0 | − | 0 | −
| 28 | −11^a^ | 46 | −5
| 121 | −4 | 171 | −2
| 542 | 2 | 560 | −10
JPEC (2008a); Rat, Crl:CD(SD); Inhalation―vapor; Male (NR): 0, 150, 500, 1,500, or 5,000 ppm (0, 627, 2,090, 6,270, or 20,900 mg/m^3^);^c^ female (NR): 0, 150, 500, 1,500, or 5,000 ppm (0, 627, 2,090, 6,270, or 20,900 mg/m^3^); Dynamic whole-body chamber; 6 h/d, 5 d/wk for 13 wk; generation method, analytical concentration, and method were reported | Male | | Female
| Dose (mg/m^3^) | Absolute weight (%) | Dose (mg/m^3^) | Absolute weight (%)
| 0 | − | 0 | −
| 627 | 5 | 627 | −3
| 2,090 | 6 | 2,090 | −8
| 6,270 | 4 | 6,270 | −2
| 20,900 | 2 | 20,900 | 5
JPEC (2008a); Rat, Crl:CD(SD); Inhalation―vapor; Male (6/group): 0 or 5,000 ppm (0 or 20,900 mg/m^3^);^c^ female (6/group): 0 or 5,000 ppm (0 or 20,900 mg/m^3^)^c^; Dynamic whole-body chamber; 6 h/d, 5 d/wk for 13 wk followed by a 28 d recovery period; generation method, analytical concentration, and method were reported | Male | | Female
| Dose (mg/m^3^) | Absolute weight (%) | Dose (mg/m^3^) | Absolute weight (%)
| 0 | − | 0 | −
| 20,900 | 13 | 20,900 | 11
Saito et al. (2013); JPEC (2010b); Rat, F344; Inhalation―vapor; Male (50/group): 0, 500, 1,500, or 5,000 ppm (0, 2,090, 6,270, or 20,900 mg/m^3^);^c^ female (50/group): 0, 500, 1,500, or 5,000 ppm (0, 2,090, 6,270, or 20,900 mg/m^3^)^c^; Dynamic whole-body inhalation; 6 h/d, 5 d/wk for 104 wk; generation method, analytical concentration, and method were reported | Male | | Female
| Dose (mg/m^3^) | Absolute weight (%) | Dose (mg/m^3^) | Absolute weight (%)
| 0 | − | 0 | −
| 2,090 | 1 | 2,090 | −3
| 6,270 | 11^a^ | 6,270 | −8
| 20,900 | 10 | 20,900 | 1
Medinsky et al. (1999); US EPA (1997); Rat, F344; Inhalation―vapor; Male (48/group): 0, 500, 1,750, or 5,000 ppm (0, 2,090, 7,320, or 20,900 mg/m^3^);^c^ female (48/group): 0, 500, 1,750, or 5,000 ppm (0, 2,090, 7,320, or 20,900 mg/m^3^)^c^; Dynamic whole-body chamber; 6 h/d, 5 d/wk for 13 wk; generation method, analytical concentration, and method were reported | Male | | Female
| Dose (mg/m^3^) | Absolute weight (%) | Dose (mg/m^3^) | Absolute weight (%)
| 0 | − | 0 | −
| 2,090 | 6 | 2,090 | 2
| 7,320 | 14^a^ | 7,320 | 9
| 20,900 | 32^a^ | 20,900 | 26^a^
Medinsky et al. (1999); Bond et al. (1996); Mice, CD-1; Inhalation―vapor; Male (40/group): 0, 500, 1,750, or 5,000 ppm (0, 2,090, 7,320, or 20,900 mg/m^3^);^c^ female (40/group): 0, 500, 1,750, or 5,000 ppm(0, 2,090, 7,320, or 20,900 mg/m^3^)^c^; Dynamic whole-body chamber; 6 h/d, 5 d/wk for 13 wk; generation method, analytical concentration, and method were reported | Male | | Female
| Dose (mg/m^3^) | Absolute weight (%) | Dose (mg/m^3^) | Absolute weight (%)
| 0 | − | 0 | −
| 2,090 | 4 | 2,090 | 2
| 7,320 | 13^a^ | 7,320 | 19^a^
| 20,900 | 18^a^ | 20,900 | 33^a^

− = for controls, no response relevant; for other doses, no quantitative response reported; NR = not reported; PND = postnatal day.

a Result is statistically significant (p < 0.05) based on analysis of data by study authors.

b Conversion performed by study authors.

c 4.18 mg/m^3^ = 1 ppm.

Percentage change compared to controls calculated as 100 × [(treated value − control value) ÷ control value].