# APPENDIX A OTHER AGENCY AND INTERNATIONAL ASSESSMENTS

Table A-1 Health assessments and regulatory limits by other national and international health agencies

Organization | Toxicity value
National Institute for Public Health and the Environment (Bilthoven, The Netherlands) | Oral noncancer tolerable daily intake: 0.25 mg/kg-d; Inhalation noncancer tolerable concentration in air: 1.9 mg/m^3^