# ABBREVIATIONS

ADAF: age-dependent adjustment factor
ADJ: adjusting experimental exposure concentrations to a value reflecting continuous exposure duration
ADME: absorption, distribution, metabolism, excretion
AIC: Akaike’s information criterion
ALDH: aldehyde dehydrogenase
ALP: alkaline phosphatase
ALT: alanine aminotransferase/transaminase
AST: aspartate aminotransferase/transaminase
atm: atmosphere
ATSDR: Agency for Toxic Substances and Disease Registry
AUC: area-under-the-curve
BBN: N-butyl-N-(hydroxybutyl)nitrosamine
BMC: benchmark concentration
BMCL: benchmark concentration lower confidence limit
BMD: benchmark dose
BMDL: benchmark dose lower confidence limit
BMDS: Benchmark Dose Software
BMR: benchmark response
BUN: blood urea nitrogen
BW: body weight
CAAC: Chemical Assessment Advisory Committee
CAR: constitutive androstane receptor
CASRN: Chemical Abstracts Service registry number
C_max_: maximum concentration
CPHEA: Center for Public Health and Environmental Assessment
CPN: chronic progressive nephropathy
CSL: continuous simulation language
CYP450: cytochrome P450
DAF: dosimetric adjustment factor
DEN: diethylnitrosamine
df: degrees of freedom
DHPN: N-bis(2-hydroxypropyl)nitrosamine
DMH: 1,2-dimethylhydrazine dihydrochloride
DNA: deoxyribonucleic acid
EHEN: N-ethyl-N-hydroxyethylnitrosamine
EPA: Environmental Protection Agency
ETBE: ethyl tertiary butyl ether
GD: gestation day
GGT: γ-glutamyl transferase
GLP: good laboratory practice
HBA: hydroxyisobutyric acid
HEC: human equivalent concentration
HED: human equivalent dose
HERO: Health and Environment Research on Online
HGPRT: hypoxanthine-guanine phosphoribosyltransferase
HIBA: 2-hydroxyisobutyrate
HT: heterogeneous
IARC: International Agency for Research on Cancer
IRIS: Integrated Risk Information System
i.v.: intravenous
JPEC: Japan Petroleum Energy Center
Km: Michaelis-Menten constant
KO: knockout
LD: lactation day
LOAEL: lowest-observed-adverse-effect level
MN: micronucleus, micronucleated
MNPCE: micronucleated polychromatic erythrocytes
MNU: N-methyl-N-nitrosourea
MOA: mode of action
MPD: 2-methyl-1,2-propanediol
MTBE: methyl tert-butyl ether
MTD: maximum tolerated dose
N.D.: not detected
No.: number
NOAEL: no-observed-adverse-effect level
NR: not reported
NTP: National Toxicology Program
OECD: Organisation for Economic Co-operation and Development
ORD: Office of Research and Development
OSF: oral slope factor
PBPK: physiologically based pharmacokinetic
PCE: polychromatic erythrocyte
PND: postnatal day
PNW: postnatal week
POD: point of departure
PPARα: peroxisome proliferator-activated receptor α
PXR: pregnane X receptor
QA: quality assurance
QSAR: quantitative structure-activity relationship
RD: relative deviation
RfC: inhalation reference concentration
RfD: oral reference dose
rho: Spearman’s rank coefficient
RNA: ribonucleic acid
S-D: Sprague-Dawley
SAB: Science Advisory Board
SD: standard deviation
SE: standard error
SRBC: sheep red blood cell
SS IICA: Stoddard Solvent IICA
TBA: tert-butyl alcohol, tert-butanol
TSCATS: Toxic Substances Control Act Test Submissions
TWA: time-weighted average
UF: uncertainty factor
UF_A_: animal-to-human uncertainty factor
UF_C_: composite uncertainty factor
UF_D_: database deficiencies uncertainty factor
UF_H_: human variation uncertainty factor
UF_L_: LOAEL-to-NOAEL uncertainty factor
UF_S_: subchronic-to-chronic uncertainty factor
USGS: U.S. Geological Survey
V_max_: maximum substrate turnover velocity
VOC: volatile organic compounds
WT: wild type
wt: weight