# References

Ashland County Land Conservation Committee and Department. 2010. Land and water resource management plan for Ashland County, WI. For implementation 2020 – 2029. 118 pp. Accessed 06.15.2022. https://co.ashland.wi.us/vertical/sites/%7B215E4EAC-21AA-4D0B-8377-85A847C0D0ED%7D/uploads/Ashland_LWRM_Plan_2020_FINAL(1).pdf
Bad River Watershed Association (BRWA). 2010. Field Findings Report – Marengo River Watershed. Technical Capacity Mini-grants, Center for Watershed Protection. Ashland, WI.
BRWA. 2011. Marengo River Watershed Partnership Watershed Action Plan. 205 p. Accessed 6.15.2022. https://dnr.wi.gov/water/wsSWIMSDocument.ashx?documentSeqNo=158277165
Bad River Band of the Lake Superior Tribe of Chippewa Indians, 2011. Bad River Band of the Lake Superior Tribe of Chippewa Indians Water Quality Standards. Accessed 6.15.2022. https://www.epa.gov/sites/production/files/2014-12/documents/bad_river_band_wqs.pdf.
J. S. Bailly, P. Lagacherie, C. Millier, C. Puech & P. Kosuth. 2008. Agrarian landscapes linear features detection from LiDAR: application to artificial drainage networks. International Journal of Remote Sensing, 29.12, 3489–3508, DOI: 10.1080/01431160701469057
Bayfield County Land Conservation Committee and Land and Water Conservation Department. 2010. Land and water resource management plan for Bayfield County, WI. For implementation 2010 – 2020. 58 pp. Accessed 06.15.2022. https://www.bayfieldcounty.wi.gov/DocumentCenter/View/1058/LWRMP-full?bidId=
Benck, K., A. Robertson, and K. Stark. 2018. Nemadji River Watershed Habitat Assessment using LiDAR. GeoSpatial Services, Saint Mary’s University of Minnesota. Winona, MN. Accessed 6.16.2022 https://files4.revize.com/pinecountymn/document_center/agendas%20&%20Minutes/2020/Nemadji%20Draft%20Plan%20&%20Appendicies.pdf
Betts, H., L.J. Brown, G.H. Stewart. 2005. Forest canopy gap detection and characterization of by the use of high-resolution digital elevation models. New Zealand Journal of Ecology 29.95–103.
Brazner, J. C., D. K. Tanner, N. E. Detenbeck, S. L. Batterman, S. L. Start, L. A. Jagger, and V. M. Snarski. 2004. Regional, watershed, and site specific environmental influences on fish assemblage structure and function in western Lake Superior tributaries. Canadian Journal of Fisheries and Aquatic Sciences 62. 1254–1270.
Bro, K. and T. Fratt. 2011. Fish Creek watershed restoration and management plan. Ashland County Land and Water Conservation Department, Ashland, WI. 84 pp.
Carpenter, S.R., N.F. Caraco, D.L. Correll, R.W. Howarth, A.N. Sharpley, and V.H. Smith. 1998. Nonpoint pollution of surface waters with phosphorus and nitrogen. Ecological Applications 83. 559–568.
Cohen, J.G., M.A. Kost, B.S. Slaughter, D.A. Albert, J.M. Lincoln, A.P. Kortenhoven, C.M. Wilton, H.D. Enander, and K.M. Korroch. 2020. Michigan Natural Community Classification [web application]. Michigan Natural Features Inventory, Michigan State University Extension, Lansing, Michigan. Accessed 6.15.2022. https://mnfi.anr.msu.edu/communities/classification.
Community GIS. 2009. Nemadji Community Open Lands Assessment. Contracted by Wisconsin Department of Natural Resources.
Dadson, S.J., Hall, J.W., Murgatroyd, A., Acreman, M., Bates, P., Beven, K., Heathwaite, L., Holden, J., Holman, I.P., Lane, S.N. and O’Connell, E. 2017. A restatement of the natural science evidence concerning catchment-based ‘natural’ flood management in the UK. Proceedings of the Royal Society A: Mathematical, Physical and Engineering Sciences 473. p.20160706.
Davidson, D.W., L.A. Kapustka and R.G. Koch. 1989. The role of plant root distribution and strength in moderating erosion of red clay in the Lake Superior watershed. Wisconsin Academy of Sciences, Arts and Letters. 51 – 63.
Detenbeck, N.E., C.M. Elonen, D.L. Taylor, L.E. Anderson, T.M. Jicha and S.L Batterman. 2003. Effects of hydrogeomorphic region, catchment storage and mature forest on baseflow and snowmelt stream water quality in second-order Lake Superior basin tributaries. Freshwater Biology 48. 912–927.
Devereux, B. J., G. S. Amable, P. Crow, and A. A. Cliff. 2005. The potential of airborne lidar for detection of archaeological features under woodland canopies. Antiquity 79. 648–660.
Douglas County Land Conservation Committee and Land and Water Conservation Department. 2009. Land and water resource management plan For Douglas County, WI. For implementation 2010 – 2020. 58 pp. Accessed 6.15.2022. http://www.douglascountywi.org/DocumentCenter/Home/View/357
Douglas Count Land and Water Conservation Department. 2016. A Watershed Approach to Wetland Management in the Lake Superior Basin. 56pp. Accessed 6.16.2022. https://www.douglascountywi.org/DocumentCenter/View/8288/Final-LS-Watershed-based-Plan-5_9_16?bidId=
Duncan, S., and Krawczyk, T. 2018. Keyline Water Management: Field Research & Education in the Capital Region, Soil Indicators Program. Report prepared for the BC Agriculture & Food Climate Action Initiative Farm Adaptation Innovator Program. Accesssed 06.15.2022. https://climateagriculturebc.ca/app/uploads/FI09-Keyline-Water-Management-CRD-2018-report.pdf.
EPA (Environmental Protection Agency). 2008. Water Quality Trading Evaluation: Final Report. U.S. Environmental Protection Agency. Accessed 6.15.2022. https://www.epa.gov/sites/production/files/2016-04/documents/wqt.pdf
Epstein, E.E. 2017. Natural communities, aquatic features, and selected habitats of Wisconsin. Chapter 7 in: The ecological landscapes of Wisconsin: An assessment of ecological resources and a guide to planning sustainable management. Wisconsin Department of Natural Resources, PUB-SS-1131H 2017, Madison.
Fitzpatrick, F. A. and J. C. Knox. 2000. Spatial and temporal sensitivity of hydrogeomorphic response and recovery to deforestation, agriculture, and floods. Physical Geography 21. 89–108.
Fitzpatrick, F. A., J. C. Knox, and H. E. Whitman. 1999. Effects of historical land cover changes on flooding and sedimentation, North Fish Creek, Wisconsin. U.S. Geological Survey, Water Resources Division Publication. Water Resources Investigation Report No. 99–4083. Middleton, WI.
Fitzpatrick, F. A. 2005. Investigation of erosion, sedimentation, channel migration, and streamflow trends in the Bad River Basin, Wisconsin. Project Update 3/7/2005.
Fitzpatrick, F.A., M. C. Peppler, H. E. Schwar, J. A. Hoopes, and M. W. Diebel. 2005. Monitoring channel morphology and bluff erosion at two installations of flow-deflecting vanes, North Fish Creek, Wisconsin, 2000–03. U.S. Geological Survey Scientific Investigations Report 2004–5272. 34 pp.
Fitzpatrick, F.A., M.C. Peppler, D. A. Saad, D. M. Pratt, and B. N. Lenz. 2015. Geomorphic, flood, and groundwater-flow characteristics of Bayfield Peninsula streams, Wisconsin, and implications for brook-trout habitat: U.S. Geological Survey Scientific Investigations Report 2014–5007, 80 pp.
Forsyth, D, CM Riseng, KE Wehrly, LA Mason, J Gaiot, T Hollenhorst, CM Johnston, C Wyrzykowski, G Annis, C Castiglione, K Todd, M Robertson, DM Infante, L Wang, JE McKenna, G Whelan, 2016. The Great Lakes Hydrography Dataset: consistent, binational watershedsfor the Laurentian Great Lakes Basin. Journal of the American Water Resources Association 52. 1068–1088.
Gergely, K.J., and McKerrow, A., 2016. PAD-US—National inventory of protected areas (ver. 1.1, August 2016): U.S. Geological Survey Fact Sheet 2013–3086, 2 pp, https://pubs.usgs.gov/fs/2013/3086/.
Hapner, J. A. 2006. Development of methods to assess and monitor small wetlands restored on private lands. Final report to U.S. EPA – Region V, Wetland program grant #CD96509801-0. 62 pp.
Harman, W., R. Starr, M. Carter, K. Tweedy, M. Clemmons, K. Suggs, C. Miller. 2012. A function-based framework for stream assessment and restoration projects. US Environmental Protection Agency, Office of Wetlands, Oceans, and Watersheds, Washington, DC EPA 843-K-12-006.
Henley, W.F., Patterson, M.A., Neves, R.J. and Lemly, A.D. 2000. Effects of sedimentation and turbidity on lotic food webs: a concise review for natural resource managers. Reviews in Fisheries Science, 8. 125–139.
Hollenhorst, T. and M. J. Hudson. 2011. Modeling peak discharge within the Marengo River Watershed – lessons for restoration in the Saint Louis River Watershed. Poster presentation at the Saint Louis River Estuary Summit.
Interfluve, Inc. 2003. Bayfield Peninsula stream assessment. Final Report: Fluvial geomorphology, hydrology and management recommendations. Prepared for Trout Unlimited. 93 pp.
Jereczek, J. C. Wagner, N. Larson and T. Ledder. 2011. STF: a regional assessment and management strategy for Wisconsin’s lakeshore. Poster presentation at International Association of Great Lakes Research Conference, 2011.
Johnson, C. A., N. E. Detenbeck, and G. Niemi. 1990. The cumulative effect of wetlands on stream water quality and quantity. A landscape approach. Biogeochemistry 10. 105–141.
Lake Superior Basin Partner Team. 2007. Marengo River watershed test case: Assessing the hydrologic condition of the Marengo River Watershed, Wisconsin. Prepared for Wisconsin Lake Superior Basin Partner Team by Stable Solutions, LLC. and Community GIS, Inc. Accessed 6.15.2022. https://documents.pub/document/marengo-marengo-rriver-watershed-iver-watershed-ttest-caseest-caseclean-wateruwexedupubspdf.html
Lane, S.N. 2017. Natural flood management. Wiley Interdisciplinary Reviews: Water 4. p.e1211.
Lenz, B. N., D. A. Saad and F. A. Fitzpatrick. 2003. Simulation of ground-water flow and rainfall runoff with emphasis on the effects of land cover, Whittlesey Creek, Bayfield County, Wisconsin, 1999–2001. Water-Resources Investigations Report 03–4130. 47 pp.
Lewandowski, A., L. Everett, C. Lenhart, K. Terry, M. O Ringer, and R. Moore. 2015. Fields to streams. Managing water in rural landscapes. Part Two, Managing Sediment and Water. A publication of the University of Minnesota Water Resources Center. University of Minnesota Extension. 39 pp.
Meals, D.W., S.A. Dresing. 2016. Monitoring and Evaluating Nonpoint Source Watershed Projects. Chapter 6. Accessed 6.16. 2022. https://www.epa.gov/sites/default/files/2016-06/documents/chapter_6_may_2016_508.pdf
MNDNR, MPCA, and WDNR. 2020. St. Louis River Area of Concern 2020 Remedial Action Plan Reflects amendments to the 2019 RAP October 1, 2019 – September 30, 2020. Accessed 6.15.2022. https://www.pca.state.mn.us/sites/default/files/wq-ws1-34.pdf
Murphy, M.L., and Koski, K.V. 1989. Input and depletion of woody debris in Alaska streams and implications for streamside management. North American Journal of Fisheries Management 9. 427–436.
Muss, J. 2011. Forested watershed hydrology: How forest pattern and canopy structure control snow accumulation and melt processes in northwestern Wisconsin. University of Wisconsin, Madison Dissertation, 206 pp.
NRCS (Natural Resources Conservation Service). 1998. Nemadji River Basin project report. USDA Natural Resources Conservation Service, St Paul, MN.
Nejadhashemi, A., B. Wardynski, J. Munoz, and A. Nejadhashemi. 2012. Large-scale Hydrologic Modeling of the Michigan and Wisconsin agricultural regions to study impacts of land use changes. Transactions of the American Society of Agricultural and Biological Engineers 55. 821–838.
Passalacqua, P., P. Belmont, and E. Foufoula-Georgiou. 2012. Automatic geomorphic feature extraction from lidar in flat and engineered landscapes. Water Resources Research, 48.
Poff, N. L., Allan, J. D., Bain, M. B., Karr, J. R., Prestegaard, K. L., Richter, B. D., Sparks, R. E., & Stromberg, J. C. 1997. The Natural Flow Regime. BioScience 47. 769–784. 10.2307/1313099
Poff, N. L. and J. V. Ward. 1989. Implications of streamflow variability and predictability for lotic community structure: A regional analysis of streamflow patterns. Canadian Journal of Fisheries and Aquatic Sciences 46. 1805–1818.
RCIC (Red Clay Interagency Committee). 1964. Second progress report: Madison, Wis., Soil Conservation Board, 40 p.
RCIC (Red Clay Interagency Committee). 1971. Preliminary report: erosion and sedimentation control, Lake Superior Basin, Wisconsin: Madison. Wis., Soil Conservation Board.
RCIC (Red Clay Interagency Committee). 1979. Impact of nonpoint pollution control on western Lake Superior; Final Report on the Red Clay Project-Summray Report: Madison, Wis., Soil Conservation Board, 56 pp. https://www.lakesuperiorstreams.org/streams/SLR/info/red_clay_proj_rep._sum_i.pdf
Rapinel, S., L., Hubert-Moy, B. Clément, L. Nabucet, and C. Cudennec. 2015. Ditch network extraction and hydrogeomorphological characterization using LiDAR-derived DTM in wetlands. Hydrology Research 46. 276–290.
Richards, K., J. Brasington, and F. Hughes. 2002. Geomorphic dynamics of floodplains: ecological implications and a potential modelling strategy. Freshwater Biology 47. 559–579.
Seeger, M., M. P Errea, S. Beguerıa, J. Arnáez, C. Martí, and J. Garcíá-Ruiz. 2004. Catchment soil moisture and rainfall characteristics as determinant factors for discharge/suspended sediment hysteretic loops in a small headwater catchment in the Spanish Pyrenees. Journal of Hydrology 288. 299–311.
Srinivas, R., Drewitz, M. and Magner, J. 2020. Evaluating watershed-based optimized decision support framework for conservation practice placement in Plum Creek Minnesota. Journal of Hydrology 583. p.124573.
Stark, K. J., and A. Robertson. 2014. A watershed framework for the assessment of wetland functions in the Lake Superior Basin portion of Douglas County, Wisconsin. GeoSpatial Services, Saint Mary’s University of Minnesota. Winona, MN.
Steen-Adams, M.M., D. Mladenoff, N. Langston, F. Liu, and J. Zhu. 2011. Influence of biophysical factors and differences in Ojibwe reservation versus Euro-American social histories on forest landscape change in northern Wisconsin, USA. Landscape Ecology 26. 1165–1178
Trettin, C. C., D. M. Amatya, C. Kaufman, N. Levine, and R. T. Morgan. 2009. Recognizing change in hydrologic functions and pathways due to historical agricultural use–implications to hydrologic assessments and modeling. The Third Interagency Conference on Research in the Watersheds, 8-11 September 2008, Estes Park, CO: 273–277.
VanBergen, G., and L. Nguyen. 2018. Tribal Nonpoint Source Management plan. Red Cliff Band of Lake Superior Chippewa. Water Resources Program. https://cms9files.revize.com/redcliffband/Document%20Center/Division/Treaty%20Natural%20Resources/Environmental%20Department/Water%20Resources/RedCliffNPS_ManagementPlan_Final.pdf
USDA, 2015. CropScape – Cropland Data Layer. U.S. Department of Agriculture. Accessed 6.15.2022. http://nassgeodata.gmu.edu/CropScape/
USGS. 2016. Surface runoff and the water cycle. In USGS Science Water Science School. Accessed 6.15.2022. http://water.usgs.gov/edu/watercyclerunoff.html
US Forest Service (USFS), 2020. Great Lakes Road Stream Crossing Inventory Instructions. Updated from original version. Accessed on 11/30/2020: https://www2.dnr.state.mi.us/Publications/pdfs/ArcGISOnline/Guides/Stream_Crossing/Great_Lakes_Stream_Crossing_Inventory_Instructions.pdf
Velasquez, Mark & Hester, Patrick. 2013. An analysis of multi-criteria decision making methods. International Journal of Operations Research. 10. 56–66.
Verry, E.S. 2001. Land fragmentation and impacts to streams and fish in the central and upper Midwest. In: Proceedings, Society of American Foresters 2000 National Convention. SAF Publ. 01-02. Bethesda, MD. Society of American Foresters, p. 38–44.
“Watersheds.” Great Lakes Aquatic Habitat Framework, SCHOOL FOR ENVIRONMENT & SUSTAINABILITY, https://www.glahf.org/watersheds/.
WDNR (Wisconsin Department of Natural Resources). 2007a. Managing woodlands on the Lake Superior’s red clay plain: Slowing the flow of runoff. Wisconsin Department of Natural Resources PUB-FR-385-2007.
WDNR (Wisconsin Department of Natural Resources). 2007b. Management recommendations for forestry practices along Wisconsin coastal trout streams. Wisconsin Department of Natural Resources PUB-FR-386-2007.
WDNR (Wisconsin Department of Natural Resources). 2008. Maintaining soil quality in woodlands. A lake states field guide. Wisconsin Department of Natural Resources PUB-FR-409-2008.
WDNR (Wisconsin Department of Natural Resources). 2010. Wisconsin’s Forestry Best Management Practices for Water Quality. Field Manual for loggers, landowners and land managers. Wisconsin Department of Natural Resources PUB FR-093-2010. 162 pp.
Wisconsin Department of Natural Resources. 2015. The ecological landscapes of Wisconsin: An assessment of ecological resources and a guide to planning sustainable management. Wisconsin Department of Natural Resources, PUB-SS-1131 2015, Madison
Walker, J. F. and W. R. Krug. 2003. Flood frequency characteristics of Wisconsin streams. US Geological Survey. Water-Resources Investigations Report 03–4250. 37 pp.
Walker, J.F., Peppler, M.C., Danz, M.E., and Hubbard, L.E. 2017. Flood-frequency characteristics of Wisconsin streams (ver. 2.2, April 2020): Reston, Virginia, U.S. Geological Survey Scientific Investigations Report 2016–5140, 33 p., 1 plate, 2 appendixes, 10.3133/sir20165140.
Wheaton J.M., Bennett S.N., Bouwes, N., Maestas J.D. and Shahverdian S.M. (Editors). 2019. Low-Tech Process- Based Restoration of Riverscapes: Design Manual. Version 1.0. Utah State University Restoration Consortium. Logan, UT. Accessed 6.15.2022. http://lowtechpbr.restoration.usu.edu/manual
Wheeler, M. C., J. Gallagher, D. Kafura, M. Wick, T. Bernthal, D. Veen, J. Mineau, K. Brewster, M. Hudson, T. Hollenhorst, and T. Fratt. 2014. Recommended practices for water quality/STF restoration in the Lake Superior Basin. Prepared for the Lake Superior Landscape Restoration Partnership by the STF team, 5 pp.
Wilkinson, M.E., Addy, S., Quinn, P.F. and Stutter, M. 2019. Natural flood management: small-scale progress and larger-scale challenges. Scottish Geographical Journal 135. 23–32.
Wisconsin Extension Natural Resources Institute Evaluation Unit. 2021. Lake Superior Basin Natural Flood Management Initiatives. Accessed 6.15.2022 https://www.wisconsinwetlands.org/wp-content/uploads/2021/11/REM-NFM-Report-11-8-21.pdf.