# Acknowledgements

Technical support for this report was provided by:

- Ted Angradi, US Environmental Protection Agency (retired)
- Faith Fitzpatrick, United State Geological Survey
- Jason Fischbach, University of Wisconsin Extension
- Karen Gran, University of Minnesota, Duluth
- Nichol Martin, Wisconsin Department of Natural Resources
- Andy Robertson, Kevin Stark, St. Mary’s University
- Naomi Tillison, Bad River Department of Natural Resources