# In Memory of Michele Wheeler

(1974 – 2020)

This report was conceived and largely written by Michele Wheeler, our colleague, mentor, and friend. Michele was passionate about protecting the Great Lakes and waterways of Northern Wisconsin, and dedicated her life to it for many years, as a fish biologist for the Great Lakes Fish and Wildlife Commission, a fisheries biologist for the Fish and Wildlife Service, the Executive Director for the Bad River Watershed Association, and as the Lake Superior Program Coordinator for the Lakewide Action & Management Plan (LAMP) for the Wisconsin Department of Natural Resources (WDNR). Besides being an exceptional biologist, Michele had extraordinary skills in listening, bringing stakeholders together, and making everyone feel like an equal partner. She was a real listener and had a talent for balancing diverse perspectives and finding common ground. We looked forward to meetings with Michele because of the energy she brought to her work. Michele made any day in the field feel like a fun adventure. She lived by her motto, “Work hard, have fun, and be nice to someone that needs it.” Everyone loved Michele for her big, fun, and caring heart. Michele passed away in 2020 after a nine-year battle with cancer, which she courageously shared with the world through her blog, Crack in the Wall: Letting in Light on Hard Times, and memoir, The Throbbing Moon and the Three Season Tango. She leaves behind an inspiring legacy of work to restore and protect Lake Superior and northern Wisconsin’s streams and rivers. It has been an honor to complete this paper to help Michele’s legacy live on through continued conservation efforts in the basin that she was so passionate about.

- The Coauthors