# Conclusion

We advocate for a strategic watershed approach for implementing slow the flow efforts in the Lake Superior basin. Challenges to accomplishing this include variation across the basin in biophysical attributes of the landscape, (native land cover, geology), the socio-political culture, and the history of land use change. Watersheds within the basin differ in their recent history of public and private engagement in land conservation. These and other factors contribute to the complexity of carrying out a basin-scale strategic approach. In support of this goal, we have summarized the main parameters that can guide prioritization of slow the flow efforts across the basin. These parameters and criteria can be applied as needed for local management across the basin, or potentially combined in a decision support tool to provide basin-wide recommendations.