# Recommendations

We have summarized a substantial body of literature on the relationships among land use/land cover and hydrologic responses relevant for management of the Lake Superior basin in Wisconsin, this can be found in Appendix 2. In general, the best available practices seek to slow runoff and reduce peak flows through increasing upland infiltration, watershed storage, upland roughness, and in-channel roughness. In this chapter, we summarize our recommendations derived from this literature review by land use category. We discuss the need for a watershed-scale strategic approach and summarize the state of the science for identifying priority locations for slow the flow work in the basin. To implement this type of approach, a decision matrix could be used to incorporate multiple metrics and prioritize needs by subwatershed. We present some of the data needed to do that here. We also describe additional desktop and field assessments, and research that is needed to develop a complete, holistic decision matrix for prioritizing slow the flow efforts at the basin scale.

## Established recommendations and work to date

### Watershed storage and wetland restoration

Increasing watershed storage via wetland restoration or water and sediment control basins is a high priority throughout the basin (Bro and Fratt, 2011, BRWA 2011). The U.S. Fish and Wildlife Service has been a partner on 94 wetland restoration and/or enhancement projects within the basin over the last 15 years. Sites range in size from less than 0.2 hectares to 13.7 hectares and average 1.6 hectares (just over 16,000 square meters). The average depth of most restored and/or enhanced wetlands is 1 meter deep. Most of the projects have been implemented on the Lake Superior clay plain, but some have occurred in suitable areas of mixed glacial till in higher elevation areas as well as in sandier locations and barrens habitat. Typically, within the drier locations, groundwater near the surface is needed to provide a reasonable water source. Types of projects include levee construction to block drainage ditches and removing sediment from low depressional areas (Figure 2) and maintenance of water control structures on impounded wetlands and small flowages. Funding for these projects has been provided by a myriad of partners including private landowners, non-government organizations, county governments, and federal agencies. Wetland projects conducted in partnership with the U.S. Fish and Wildlife Service have focused on maximizing aquatic habitat for migratory birds and waterfowl that prefer water depths of 1 meter or less because these areas are inhabited by many types of aquatic invertebrates and produce rich aquatic plant growth. Most sites occur in agriculture fields that were previously hayed on an annual basis.

Figure 2 Wetland restoration project in Wisconsin’s Lake Superior basin a) pasture and drainage ditches pre-restoration and b) seven years post-restoration

We recommend targeting wetland restoration efforts to maximize an increase in overall watershed storage, including where wetlands can maximize storage and help desynchronize flows. In particular, we recommend the following:

- Use Height Above Nearest Drainage (HAND) analysis to identify priority floodplain wetlands for restoration and protection (see discussion under Parameter data sources and analysis below).
- Protect high-functioning watershed storage and hydrologic processes in existing wetlands and floodplains.
- Investigate potential opportunities to install wetlands, grassed waterways, and two-stage ditches in agricultural fields.
- Install multiple smaller projects in headwater areas, in parallel along multiple tributaries, for a greater cumulative increase in storage as opposed to restoring a large single site lower in the watershed.
- Design low-tech process-based restoration approaches (Wheaton et al., 2019).
- Design wetland restoration sites to include flow dispersal and grade control structures that enable natural water level fluctuations, rewetting degraded areas with flood pulses and excess flows, and reconnecting other wetland areas to the site and stream channel.

Additional recommendations:

We also recommend exploring the Wisconsin Wetland Conservation Trust (WWCT) as a potential source of funding for future wetland restoration work in the basin. It is the statewide in-lieu fee program administered by the Wisconsin DNR for the mitigation of wetlands. Through the purchase of credits from the WWCT, permitees can mitigate unavoidable impacts to wetlands. The WWCT then invests that funding in wetland restoration projects across the state. No restoration projects have been done in the Lake Superior service area since the WWCT was created in 2014. However, credits have been sold in the Lake Superior service area, and the WWCT is a potential source of funding for wetland restoration in the future.

### Upland and in-channel roughness

To increase upland and in-channel roughness:

Implement forestry BMPs ( Table 1 ) to maintain infiltration and vegetative cover.

Wisconsin DNR has made recommendations and described BMPs to maintain the filter function of the forest floor and protect the natural systems (WDNR, 2007a, WDNR, 2007b, WDNR, 2008 and others). Continued adherence to these BMPs is recommended.

Table 1 BMPs that reduce peak stream flows impacts on water system from Lewandowski et al., 2015

| Effects
BMPs | Increase spring transpiration | Increase filtration | Increase soil water holding capacity | Increase open water evaporation | Reduce peak flows | Reduce in-stream velocity
1. Infield: crop and soil management
Perennial crops, and crop rotations with perennials or winter annuals | • | • | • | | •
Cover crops | • | • | • | | •
Reduced tillage, contour cropping, and residue management | | • | •
Compaction management | | • | •
Manure application | | • | •
2. Infield: drainage water management
Alternative drainage design (depth, spacing, capacity) | | | | | •
Controlled drainage | | | | | •
Alternative tile inlets | | • | | | •
3. Infield and edge-of-field: surface flow management
Grassed waterways | • | • | | | •
Filter strips, contour buffer strips | • | • | | | •
4. Infield and edge-of-field: water storage and infiltration
Saturated buffers | | • | | | •
Restored and constructed wetlands | | • | | • | •
WASCOBs, terraces, and detention basins | | • | | | •
Ponds and irrigation reservoirs | | | | • | •
Large retention basins | | • | | • | •
5. Ditch channel: water retention
Structures for water control, including weirs and restricted size culverts | | | | | • | •
Two-stage ditch with restricted size culverts | | | | | • | •
6: Riparian area: restoration and protection
Riparian vegetation | • | •
Streambank, bluff, and shoreline protection
Restore channel meanders | | | | | | •

Map gully type and apply appropriate restoration actions for groundwater- or surface water-driven gullies.

The type of gully erosion and sediment loading differs throughout the basin and has not yet been well characterized (Fithzpatrick et al., 2005) LIDAR data, which is available for many parts of the basin, should be used to locate and identify gully types as groundwater sapping or overland flow driven types. In groundwater-driven gullies, restoration should focus on increasing interception with coniferous tree planting. In surface water-driven gullies, increased roughness elements to promote increased infiltration should be prioritized. Vegetative filter strips that slow runoff and detention basins that store runoff are recommended for the head of ephemeral gullies.

Implement in-channel work consistent with geomorphic studies, with a focus on low-tech solutions.

In-channel projects to increase roughness should be used cautiously and selectively in the basin, based on the mixed success of previous projects. Sediment loading is substantial in many systems and installed roughness elements may be quickly buried, with little lasting ecological effect. Likewise, increasing peak flows due to a changing climate could wash out projects not designed for changing flow conditions. This type of restoration should only occur in watersheds and locations where geomorphic conditions and sediment dynamics are well-understood and should focus on low-tech designs simulating natural processes (Wheaton et al., 2019).

### Forestry

We recommend working collaboratively with LS stakeholders to:

Implement existing guidelines for Forestry BMPs.

There are multiple guidelines and best management practices (BMPs) that have been developed to help land managers implement practices designed to protect natural systems at national, statewide, and Lake Superior basin scales (Table 2 of Appendix 4). Forestry-related BMPs that slow surface runoff in the Lake Superior basin include maintaining forest cover, promoting mature forest types, protecting adequate riparian zones, and managing steep, erodible slopes.

Establish an open lands percentage threshold for hydrology and water quality protection, and establish standard, repeatable methods for assessing open lands by subwatershed.

Several efforts have identified target minimum percent open land area thresholds for protecting hydrology and water quality in the basin (i.e., thresholds percentages of open land that should not be exceeded). In 2009, the Wisconsin DNR compiled the amount of open land in hydrologic units identified in Wheeler et. al., 2014 throughout Wisconsin’s Lake Superior Basin. WDNR (2010) described open land as young forests, agricultural lands, and urban areas. In areas currently below 40% open land, timber harvest and forest opening were supported for a variety of benefits. Caution is recommended in subwatershed units currently with 40% to 55% open lands. Creating additional open land in areas currently greater than 55% open land is not recommended. WDNR (2010) emphasizes the importance of scale in evaluating the proportion of open lands. HUC 12 watersheds were used to determine larger focal areas, and smaller hydrologic units used in the analysis were delineated by Verry (approximately 2.5 km^2^ in area, Benck et al., 2018) to evaluate the potential for open lands to have downstream effects on hydrologic integrity (WDNR 2010). The Nemadji Basin Plan established a target of less than 40% open land area in subwatersheds approximately 10 square miles in size (NRCS, 1998). Likewise, a target of less than 40% open land area was identified for the Marengo River watershed (BRWA, 2010). The Douglas County Land and Water Conservation Plan 2010 – 2020 (Douglas County, 2009) recommends converting open lands, particularly marginal pastures, to mature conifer forests to minimize the impacts of snowmelt runoff. The plan recommended maintaining a minimum of 40% forest cover in HUC 14 watersheds (Douglas County, 2019). Most recently, efforts to focus on watershed-scale hydrologic restoration under the Landscape Restoration Partnership targeted hydrologic units with 40 to 55% open lands using Verry’s subwatersheds (Wheeler et al., 2014).

A single open lands threshold should be identified for consistency across the basin. In addition, standard, repeatable methods for assessing open lands should be identified. One issue with past analyses is that HUCs are not always full watersheds and sometimes have additional HUCs upstream or downstream that they flow to or receive flows from. Calculating the proportion of open lands for HUCs could result in misleading estimates of the proportion of open lands and how they might affect watershed hydrology. Instead, the percent open lands could be calculated using GLAHF hydrologic data layers, which are a standard nested Great Lakes hydrologic framework (see Forsyth et al., 2016 and “watersheds (https://www.glahf.org/watersheds/)”).

Clarify the delineation of the Riparian Management Zones (RMZs) to determine consistent standards for width and allowable practices in RMZs.

Recommendations from federal, state, and regional initiatives on the size of RMZs differ greatly (See Table 2 in Appendix 2), and a standard definition is needed to prioritize STF efforts. Most methods describe RMZs as a linear feature with a width that varies between 10 – 30 meters from the waterline or ordinary high-water mark (OHWM). The Nemadji River Basin Project defines riparian zones in the red clay plain as the entire floodplain and adjacent slopes that are 20% or greater, including intermittent channels (NRCS, 1998). Management approaches in RMZs also vary, but most existing recommendations include encouraging forest composition that mimics pre-European settlement mixtures of deciduous and coniferous trees, with an emphasis on mature, older-successional, and shade-tolerant species. Murphy and Koski (1989) found that nearly all large wood in stream channels is derived from within 30 meters of the stream channel. Interfluve (2003) therefore recommended no harvest of live or dead trees in this zone to promote wood recruitment to stream channels where it functions as a roughness element, promotes nutrient cycling, and provides habitat for many species. Interfluve (2003) also recommends buffers at the top of valley-edge erosion points to reduce surface runoff volumes, consistent with recommendations in the Fish Creek watershed to stabilize drainages from farmlands to waterways (Bro and Fratt, 2011).

Establish a consistent definition of unproductive steep slopes for private and public lands and promote BMPs at those sites.

The steep clay slopes in the Lake Superior basin are highly erodible. When adjacent to stream channels, mass wasting of these slopes leads to sediment inputs to stream channels. There is currently no consensus on the definition of steep erodible slopes, nor on appropriate BMPs for these sites. WDNR (2007a) defines steep slopes as areas with an overall rise of 15% over 15 meters or more or areas with greater than 27% slope over any distance. No commercial forest harvest is recommended for these slopes. These sites would benefit from BMPs that consider the stabilizing capacity of specific species; late successional species are found to have the greatest root tensile strength (Davidson et al., 1989).

Additional recommendations.

As a secondary priority, the distribution of deciduous versus conifer tree species should be considered as they retain water at different rates (Nejadhashemi et al., 2012). A minimum percentage of coniferous cover should be established as a management target for the basin.

### Agriculture

STF efforts on agricultural lands must accommodate the reality that the traditional crops that form the basis of the agricultural economy depend on rapidly removing excess moisture from farm fields. Within that context, we recommend the following prioritized approach:

Pursue opportunities to harness transitional agricultural areas to increase interception, infiltration, and retention

Some farmland in the basin is converting back to forestland (discussed further below). Such “transitional” land includes low-intensity hay production or pastureland that is farmed as a hobby or to maintain agricultural use assessment and lower property taxes (Figures 3 and 4). It also includes fields that are no longer actively farmed and are in the early stages of old field succession. These transitional lands are candidates for wetland restoration or for woody biomass crops that can provide economic returns to owners while also decreasing runoff. The effectiveness of such plantings could be increased if legacy soil compaction was addressed before planting and if the biomass crops were planted in concert with subsurface plowing to de-compact soils (i.e., keyline plowing, Duncan and Krawczyk, 2018). More research is needed to understand the potential of these methods.

Figure 3 Example of identifying lands not managed for row crops to identify opportunities for wetland or forest conversion

Figure 4 Fields in the early stages of transition out of agricultural production could be used to help slow the flow through wetland restoration or conversion to biomass plantings designed to improve infiltration, interception, and retention

Incentivize STF flow practices and non-point source runoff trading

The trading of water quality credits is an established practice in many parts of the U.S. and typically involves point source discharges of pollutants (such as wastewater treatment plants) paying landowners within the same watershed to reduce the non-point discharge of pollutants (EPA, 2008). Such programs are most effective when the cost of reducing the non-point discharge is less than the cost of reducing the point source discharge. Phosphorus trading is the most common form of water quality trading (EPA, 2008). Typically, the non-point phosphorus credits are generated by farmers implementing best management practices to reduce soil erosion or by installing clean-water diversions to reduce manure and nutrient losses from barnyards (EPA, 2008). A phosphorus trading program for the Chequamegon Bay region (where agriculture in the Lake Superior basin is focused) would likely be structured differently. Studies indicate most of the phosphorus discharge occurs during storm events and most of that phosphorus comes not from agricultural lands themselves, but sediment eroded from within stream channels (EPA, 2008). The channel or bank erosion is caused, in part, by increased or rapid runoff from agricultural lands. Thus, generating phosphorus credits from agricultural lands in the Lake Superior basin could be done by implementing actions that slow the flow, reduce peak flow events, and reduce stream bank and bluff erosion.

The key to any water-quality trading program is sufficient monetization of the generated credits to provide an incentive for making land use changes or implementing the practices (EPA, 2008). Typically, the monetization results from point-source dischargers being compelled to reduce loading through a local, state, or federal permitting process. No point-source dischargers are currently facing such mandated reductions in the Chequamegon Bay region. Instead, one option to monetize phosphorus or slow the flow credits would be for local municipalities to implement either a mandated or voluntary no-net increase or reduction in phosphorus losses from permitted land uses. For example, an agricultural operation or new building project that would result in increased runoff rates could be compelled or asked to voluntarily offset such an increase by purchasing “slow the flow” credits from a landowner that implements practices to slow the flow such as wetland restoration or conversion of pasture to trees.

Another model to incentivize targeted BMPs for slow the flow efforts would be for resource managers/funders to focus cost-share dollars in areas known to have a high proportion of intensive agriculture and have flashy streams. For example, to focus wetland restoration on transitional agricultural lands within the same watersheds as those identified as having a greater percentage of intensive agriculture.

Implement best management practices on intensive farmlands

On high-intensity farmland involving tillage and production of annual row crops, there are well-established best management practices that should be encouraged to help reduce runoff rates. These recommended practices are summarized by Lewandowski et al. (2015) and listed in Table 1. Of all the listed practices, the production of perennial crops is likely the most effective as the perennial roots improve infiltration and the overwintering biomass improves surface roughness. The use of annual cover crops to “perennialize” the agricultural lands can also be effective, particularly after corn silage harvest where there are very little crop residue and harvesting equipment traffic compacts the soil.

### Urban and rural residential

For urban and rural residential settings, we recommend focusing most slow the flow efforts in the upper portion of the basin, while also addressing important coastal resiliency needs to protect life and property in urban areas:

Identify and prioritize STF efforts upstream of urban centers that will reduce peak flows and flooding in developed areas.

Since the largest urban areas in the basin, Superior and Ashland, are in the lower portions of watersheds, the effects of urban BMPs would be limited to the local areas and Lake Superior’s nearshore. Slow the flow efforts in the upper portions of the watershed would result in cumulative benefits for the urban communities downstream.

Implement bioretention and stormwater management approaches to help protect urban infrastructure.

Urban communities are, however, affected by their coastal locations. Flooding during storm events is exacerbated by high lake levels and storm surges, as well as by elevated peak flows. Existing urban infrastructure is often not designed to accommodate increasing peak flows, and damage to infrastructure due to storm events can and has had major costs to coastal communities. Bioretention systems can capture and store surface runoff in urban and rural settings. Simplistic designs can capture roof runoff in rain barrels and/or rain gardens. In more commercial sites, green roofs or stormwater storage ponds have the capacity for larger flows (Bro and Fratt, 2011). Implementation of green infrastructure projects would increase resiliency to storm events in urban areas.

Continue assessments to identify and prioritize replacement or upgrades of road-stream crossings that have undersized culverts, are barriers to organism passage, or have eroding soils.

There are several ongoing efforts in the basin to address the need for increasing the capacity of culverts to manage increased and increasing peak flows. The US Forest Service established standard methods for assessing road-stream crossings for capacity, effects on stream health, stability, aquatic organism passage, or erosion issues (USFS, 2020). These methods are currently used to inventory crossings in the Great Lakes including in the Lake Superior basin in Wisconsin. In addition, the University of Wisconsin and Wisconsin Coastal Management Program have established a culvert mapping community of practice to share data and methods (https://www.wicdi.org/). Continuing these efforts will contribute to reducing damage to infrastructure. and sources of erosion. Building a stream-crossing inventory has been a priority across the Great Lakes: https://great-lakes-stream-crossing-inventory-michigan.hub.arcgis.com/.

### Receiving waters

Historically, upland work has focused on upland problems, however, protection or impairment of receiving waters may also be an important driver of upland conservation efforts. This could include communities identified as endangered, threatened, or of special concern such as poor fens, which are sedge-dominated wetlands found on strongly acid-saturated peat (Cohen et al., 2020). We recommend to:

Prioritize STF efforts in watersheds that drain to poor fen coastal wetlands.

Poor (acidic) fens commonly occur along the coast of Lake Superior but also occur in kettle depressions and flat areas of glacial outwash or lake plains (WDNR, 2015; Cohen et al., 2020). These ecosystems deserve protection because they contain high species diversity and provide spawning and nursery habitat for a rich assemblage of native and sport fishes (Epstein, 2017). Poor fens can be distinguished by their weakly minerotrophic peatland soils influenced by surface and/or groundwater and relatively high species diversity (Epstein, 2017). They are similar to open bogs, but have a higher pH and a decreased presence of leatherleaf and Sphagnum species (Epstein, 2017). In the Lake Superior basin, the vegetation in open bogs is slightly elevated above the influence of mineral-rich groundwater by the growth and influence of Sphagnum hummocks (Epstein, 2017). Sphagnum hummocks wick water upwards, but also actively acidify the rooting zone and causes nutrient availability to be extremely low (Epstein, 2017). Protection of fen hydrology is the paramount conservation consideration to ensure that water levels remain within a range of natural variability and that saturation of the peat is constant (Epstein, 2017). Runoff laden with sediment, nutrients, or pollutants can alter the chemistry of ground and surface waters and affect the suitability for the sensitive peatland biota (Epstein, 2017).

## A watershed-scale strategic approach

The landscape-scale processes described above interact in complex ways to affect hydrology. Therefore, a strategic and targeted watershed approach is recommended to best reduce runoff and address corresponding habitat and water quality problems. By this, we mean that funding and effort should be focused on locations across the basin where they will have the greatest effect on water quality problems at a basin scale. In this section, we describe the capacity and precedent for taking a watershed-scale strategic approach in the Lake Superior basin in Wisconsin.

There is growing momentum and capacity for this type of approach to restoration and protection in the Lake Superior basin of Wisconsin. The Lake Superior Collaborative (https://fyi.extension.wisc.edu/lakesuperiorcollaborative/) was formed in 2018 from historical partnerships dedicated to partnered conservation and restoration work in northern Wisconsin. The LSC is currently coordinated by a UW-Extension staff position that is financially supported by UW-Extension, the US Forest Service, the Natural Resource Conservation Service, and the Lake Superior National Estuarine Research Reserve. The LSC was established to continue and sustain watershed-scale efforts to protect and restore Lake Superior and its basin in Wisconsin. It consists of government, academic, tribal, and non-profit organizations working in the basin. The shared vision of the partnership is: “The communities and ecosystems of Wisconsin’s Lake Superior Basin are climate resilient and supported by sustained and collaborative conservation partnerships and projects.” The organization aims to fulfill this vision by aligning conservation priorities with the Lake Superior Lakewide Action & Management Plan (LAMP), implementing projects to reduce pollution, improve habitat, and increase climate resiliency, facilitating exchange among partners, and conducting public outreach to encourage watershed stewardship. With the vision and partnerships established by the LSC, partners in the region are well-poised to develop and implement a strategic and targeted watershed approach to reduce runoff and address related habitat and water quality problems.

Funding is a key component of any implementation strategy. A major source of potential funding is Clean Water Act Section 303(d) funding, which addresses water quality issues and advocates a watershed approach to planning. In Wisconsin, to access Clean Water Act Section 303(d) funding, watersheds must first develop a “9 Key Element Plan,” which includes specific requirements defined by the US Environmental Protection Agency. The state can approach a city and/or county to address TMDL or impaired waters. Cities and/or counties can also approach the state if they see a need for a 9 Key Element Plan in their jurisdiction. To create a 9 Key Element Plan for a watershed the local government and the state work together to solve common problems. The state assists with the development of the plan, by helping determine what the needs are, identifying areas of prioritization, and defining the scale of the watershed project. The state leads the project only when it is addressing a TMDL. The completion of a 9 Key Element Plan allows for cities and counties to apply for EPA 303(d) funds and restore their watershed. Wisconsin only has the capacity to conduct a limited number of 9 Key Element Plans at one time. To date, most of the plans have been focused on priority watersheds in the southern part of the state. In the Lake Superior basin, there are two 9 Key Element Plans efforts currently underway: The Marengo watershed which was completed in 2013 and Douglas County/City of Superior 9 Key Element Plans which is currently about 1 year into their planning.

The Marengo 9 Key Element Plan included multiple stakeholders organized into a Citizen Involvement Team, a Technical Team, and a Steering Committee. Nearly 30 different local state and federal agencies and organizations participated in the plan. The resulting Marengo River Watershed Action Plan (BRWA 2010) used a combination of open lands data and National Streamflow Statistics Program modeling outputs to identify priority locations for implementation of slow the flow practices. Analysis conducted for the plan estimated 2-year peak discharge normalized by watershed area in 30 nested, pour-point Marengo subwatersheds (Fig. 5) (Hollenhorst and Hudson, 2011) combined with a summary of the percent of open lands in those same 30 watersheds (Table 2). Results identified areas susceptible to excessive peak flow volumes and corresponding erosion and sedimentation (Fig.6). This approach used the 2003 USGS flood frequency regression equations that include evaluation of soil permeability, snowfall, percent storage, and slope (Walker and Krug, 2003).

Table 2 National Streamflow Statistics Program (Walker and Krug, 2003) model inputs predicted twoyear peak discharge (cubic feet per second) results, and discharge results normalized per square mile of area for each of 30 subwatersheds within the Marengo River Watershed

Also included within each subwatershed is percent open land and forests <16 years old (Community GIS, 2009). Highlighted subwatersheds had a discharge greater than 20 cfs/mile^2^ and greater than 20% open lands.

Watershed ID | Drainage area (sq. miles) | Soil Permeability | Annual Snowfall | Storage (%) | SLOPE (ft./mile) | Peak Discharge (2 yr.) | Discharge per mile | Percent open lands
1 | 217.3 | 1.16 | 85.20 | 14.50 | 21.56 | 2500 | 11.507 | 20.9
2 | 103.7 | 1.09 | 79.64 | 10.64 | 17.44 | 1330 | 12.821 | 25.8
3 | 84.3 | 1.47 | 88.41 | 21.14 | 27.15 | 1020 | 12.032 | 10.0
4 | 65.1 | 1.60 | 86.03 | 24.60 | 25.50 | 740 | 11.373 | 4.4
5 | 69.1 | 1.53 | 86.34 | 23.20 | 25.50 | 803 | 11.620 | 7.1
6 | 15.5 | 1.21 | 97.81 | 12.18 | 86.91 | 418 | 27.054 | 23.4
7 | 4.0 | 0.46 | 91.80 | 0.64 | 57.38 | 264 | 66.218 | 50.1
8 | 4.9 | 0.10 | 89.33 | 32.22 | 24.06 | 147 | 29.982 | 30.4
9 | 194.1 | 1.23 | 83.90 | 15.00 | 21.21 | 2190 | 11.282 | 19.8
10 | 200.5 | 1.20 | 84.07 | 15.31 | 21.21 | 2260 | 11.273 | 20.3
11 | 9.1 | 1.26 | 101.77 | 5.22 | 57.62 | 298 | 32.634 | 31.0
12 | 4.3 | 0.10 | 74.40 | 0.16 | 46.11 | 391 | 90.123 | 44.4
13 | 4.8 | 0.18 | 77.50 | 1.41 | 49.08 | 307 | 63.859 | 41.0
14 | 9.2 | 0.14 | 76.09 | 0.81 | 63.64 | 659 | 72.005 | 42.6
15 | 69.1 | 1.42 | 78.92 | 13.32 | 15.96 | 801 | 11.599 | 11.6
16 | 59.6 | 1.63 | 79.32 | 15.21 | 28.10 | 772 | 12.954 | 6.8
17 | 5.9 | 0.84 | 82.17 | 4.31 | 31.17 | 181 | 30.572 | 31.8
18 | 9.5 | 1.65 | 89.25 | 12.84 | 33.98 | 185 | 19.374 | 5.0
19 | 47.7 | 1.65 | 85.02 | 30.40 | 16.59 | 466 | 9.771 | 1.3
20 | 33.8 | 1.65 | 76.91 | 18.44 | 9.65 | 326 | 9.651 | 1.5
21 | 13.8 | 1.65 | 86.00 | 9.55 | 46.69 | 295 | 21.453 | 4.7
22 | 28.1 | 1.65 | 81.13 | 37.97 | 4.19 | 184 | 6.538 | 1.2
23 | 5.6 | 1.65 | 84.50 | 28.67 | 31.53 | 88 | 15.788 | 1.9
24 | 6.8 | 1.65 | 80.44 | 23.02 | 12.55 | 84 | 12.308 | 0.3
25 | 10.6 | 1.65 | 76.15 | 21.65 | 33.96 | 162 | 15.307 | 0.2
26 | 5.4 | 1.65 | 77.14 | 35.17 | 3.52 | 42 | 7.786 | 1.7
27 | 12.1 | 1.65 | 81.17 | 43.03 | 3.30 | 80 | 6.625 | 2.0
28 | 6.9 | 1.65 | 79.80 | 38.77 | 2.71 | 48 | 6.919 | 2.6
29 | 4.9 | 1.65 | 82.88 | 49.10 | 28.10 | 64 | 13.183 | 1.3
30 | 58.1 | 1.65 | 79.27 | 15.34 | 13.85 | 616 | 10.605 | 6.2

Figure 5 Results from National Streamflow Statistics Program (Walker and Krug, 2003) modeling for 30 subwatersheds in the Marengo River watershed ranked from largest to smallest

The plot shows the mean discharge (green bars), mean discharge greater than 20cfs/sq.mile and 20% open lands (blue bars), percent open lands (red squares), and each subwatershed’s percentage (blue diamonds) of total Marengo River Watershed land area.

Figure 6 Results from National Streamflow Statistics Program (Walker and Krug, 2003) modeling for 30 subwatersheds in the Marengo River watershed

The dots, or “pour points” (many of which overlap) for each watershed are sized based on the predicted 2-year peak discharge per square mile. Blue highlighted subwatersheds are those with a predicted 2-year peak discharge per square mile greater than 20 cfs and that have at least 20% open lands.

Other regions are implementing effective approaches for strategic and targeted watershed management. The state of Vermont uses a similar STF approach based on applying the concepts described in this report to reduce flood risk by implementing measures that emulate the natural functions of subwatersheds, wetlands, floodplains, rivers, and coasts. Vermont has conducted more than 150 different stream geomorphic assessments with the data maintained in the Stream Geomorphic Assessment Data Management System (available at https://anrweb.vt.gov/DEC/SGA/default.aspx) and organized within the Vermont Flood Ready website (https://floodready.vermont.gov) which also maintains data about community flood risk assessments, funding sources, and other flood resiliency planning resources. Wisconsin Wetlands Association (WWA) is currently using Vermont’s efforts as a model for a strategic approach to watershed management in the Lake Superior basin.

In the aftermath of the 2016 flood, the Wisconsin Wetlands Association (WWA) made the case for protecting vulnerable infrastructure through Natural Flood Management (NFM). NFM is an approach similar to “slow the flow” that originated in the UK and focuses on three methods: reducing the rate of runoff generated on uplands, storing water in uplands during high flow periods, and increasing roughness between runoff sources and potential flood inundation areas (Lane, 2017). NFM is effective at lowering peak flows in small subwatersheds, although study results are less conclusive at larger subwatershed scales and for managing extreme floods (Wilkinson et al., 2019; Dadson et al., 2017). For a review of NFM, see Dadson et al. (2017). With the help of Wisconsin Coastal Management Program’s (WCMP) 309-funding and other funds, WWA has built partnerships to explore NFM, increase awareness, share solutions, and demonstrate results to community members, collaborators, and policymakers in Wisconsin. WWA recently completed a “ripple effects mapping” exercise, which measured how their efforts in NFM have improved or influenced the work of partners in the basin since 2016 (Wisconsin Extension, 2021).

## Decision-making and prioritization

One objective of this report is to provide stakeholders and managers in the Lake Superior basin with the best available information and data to make decisions about how to address runoff and water quality problems. Based on our review of the literature, important metrics to address slow the flow include watershed storage, land cover, geologic setting, and downstream habitat. Additional logistic or social factors can also be considered, including the likelihood of future land use conversion and property ownership. In this section, we summarize and describe each of the parameters and relevant thresholds we have identified, along with the best available datasets and/or analyses available to evaluate those parameters for prioritizing slow the flow efforts. These results are summarized in Table 3.

These parameters can be used on their own or in a multi-metric decision matrix to prioritize where BMPs, restoration, and protection activities will be most effective and have the largest positive impact in the basin. Multi-metric decision matrices are a common approach to address the challenge of prioritizing restoration and protection efforts based on many complex and interacting variables (Velasquez and Hester, 2013, see an example of application in Srinivas et al., 2020). The use of a multi-metric decision support matrix would allow the evaluation of multiple metrics with relevant published thresholds by subwatershed. Weighting can be used if certain metrics are more judged important than others in a particular context. Based on the metrics and thresholds included, the priority subwatersheds for slow the flow work can then be identified.

Some of the parameters below have multiple criteria identified in the literature or management documents. Due to incomplete information and analyses, we do not identify single thresholds for these parameters to prioritize work at the basin scale. For now, threshold selection should be made based on context-specific decision-making needs. However, we outline additional research, analysis, and monitoring needs with the ultimate goal of identifying basin-wide thresholds to prioritize STF work at the basin scale. After desktop assessments, the next step would be to confirm priority project areas and subwatersheds with field assessments and site-specific project design and engineering plans.

Table 3 Summary of recommended parameters to consider for prioritization of STF efforts in the Lake Superior Basin

Parameters are listed in three groups: primary criteria that can be used to identify priority watersheds and subwatersheds; secondary criteria to rank subwatersheds within priority watersheds; tertiary considerations can be used to further narrow priorities. Wisconsin Wetland Inventory (WWI), Potentially restorable wetlands (PRW)

| Parameter | Data source | Criteria or ranking method | Criteria source
Primary ranking criteria
1.1 | Percent storage by subwatershed | WWI, NHD | <10% | Johnson et al., 1990
1.2 | Peak discharge/subwatershed area ratio | USGS StreamStats | Ranked by subwatershed | Walker et al., 2017
1.3 | Percent open lands by subwatershed | Community GIS analysis, ongoing data needs described in text | >40%(Douglas Co.) | Douglas County, 2016
Secondary ranking criteria
2.1 | Percent of total wetland area with surface water attenuation by subwatershed | Functional Wetland Assessment (only available in Nemadji and Marengo) | Ranked by subwatershed | Benck et al., 2018
2.2 | Proportion of riparian area not mapped as wetland by subwatershed | Height above nearest drainage (HAND) analysis described in text | Ranked by subwatershed | Proposed by authors
2.3 | Proportion of forested riparian areas of total riparian area | Uses output of HAND analysis | Ranked by subwatershed | Proposed by authors
Tertiary considerations
3.1 | Inactive farmland | Analysis described in text | Prioritize locations on inactive farmland | Proposed by authors
3.2 | Transitional zone and soil permeability | Wisconsin ecological Land Type Association | Prioritize locations in the geologic transition zone (229 – 33 m) | Proposed by authors
3.3 | Downstream coastal ecosystem/habitat type | DNR Natural Heritage Inventory | Prioritize wetlands draining to poor fen coastal wetlands | Proposed by authors
3.4 | Land ownership type | USGS Protected Areas Database of the United States | Public, private, tribal | Proposed by authors.

### Parameter data sources and analysis

#### Watershed storage parameters

Watershed storage-related criteria include the existing watershed storage, percentage of wetlands lost, and measures of existing wetland functions with an emphasis on wetlands that provide surface water attenuation benefits. Existing and potential acreage of wetlands that provide storage in Wisconsin’s Lake Superior basin can be described by using two spatial wetland data layers: the Wisconsin Wetland Inventory (WWI), and Potentially Restorable Wetlands (PRW). The WWI describes the existing distribution and extent of wetlands digitized from leaf-off, black and white, and infrared aerial photos taken in 2012 for Douglas and Bayfield counties, and in 2013 for Ashland and Iron counties. Based on the WWI there are 393,224 acres of wetlands in the Lake Superior basin. The statewide Potentially Restorable Wetlands (PRW) layer uses mapped hydric soils, flow accumulation pathways, and slope from digital elevation models to identify areas that are not currently mapped as wetlands but were probably wetlands in the past. The PRW layer estimates 81,023 acres of original wetlands that have been drained and could potentially be restored. However, in the Lake Superior basin, soils (particularly in the clay plain) are mapped as soil complexes that lump clay soils in with other soil types, likely underestimating the extent of original wetlands. Combining the WWI and PRW produces an estimate of total pre-settlement wetlands of 486,918 acres or nearly 25% of Wisconsin’s Lake Superior basin. Potentially restorable wetlands occur throughout the basin. There are significant opportunities to restore wetlands on private lands in the clay plain and headwaters areas, emphasizing the need for other socioeconomic factors to be considered in determining site-specific projects.

While nearly all wetlands contribute to slowing the flow in watersheds, some sites provide that function more than others. Functional wetland assessment techniques can be used to estimate and map the extent to which existing wetlands provide flood attenuation and peak flow reduction functions, as well as fish and wildlife habitat, streamflow maintenance, sediment retention, and nutrient transformation. Functional wetland assessments, which build on lower resolution statewide wetlands data, have been conducted in Douglas County and the Marengo Watershed, led by Saint Mary’s University of Minnesota GeoSpatial Services (Saint Mary’s GSS).

The National Wetland Inventory Plus (NWI+) classification, which is based on each wetland’s geomorphology and relationship to the stream/lake network, was created through the conversion of the Wisconsin Wetland Inventory layer and additional photointerpretation. In NWI+, each wetland and waterbody is characterized by its landscape position, landform, water body type, and water flow path (referred to as LLWW). For Douglas County, Saint Mary’s GSS used high-resolution imagery, aerial photograph interpretation, elevation data, land cover, and soil unit classification to produce a series of spatial datasets that can be used to characterize the contribution of individual wetlands and wetland complexes to surface flow attenuation (Stark and Robertson, 2014). This work improved the statewide PRW data layer by using aerial photograph interpretation to look for additional wetland indicators such as April flooding and August ponding, along with enhanced mapping of surface hydrology and ditch networks. One output of this work is a map that displays the location of PRWs that will likely provide surface water detention functions (Figure 8). NWI+ outputs that identify PRWs most likely to achieve surface water detention could improve the effectiveness of wetland restoration intended to reduce peak flows (Stark and Robertson, personal communication). The Height Above Nearest Drainage (HAND) method can also be used to more completely map riparian and floodplain wetlands for priority restoration and preservation efforts (Figure 7). Initial HAND Analyses in the Marengo River watershed used 10m elevation data, but future efforts could include higher resolution LiDAR-derived 1-3m elevation data.

Figure 7 Height Above Drainage (HAND) analysis for south shore watersheds

Areas in pink are less than 1 meter above the nearest drainage.

The Wisconsin Department of Natural Resources and Saint Mary’s GSS conducted a similar watershed-scale wetland functional assessment and restoration prioritization for the Marengo River Watershed, which is a focus of restoration efforts funded through the Great Lakes Restoration Initiative. They mapped agricultural surface ditches, existing wetlands, and potentially restorable wetlands following the methodology used by Stark and Robertson (2014). They also created functional assessments for existing wetlands aimed at advancing the ability to assess current wetland condition and function, assess changes over time, evaluate current restoration and protection options, and validate a GIS decision support tool developed to assess wetland functionality. The purpose of this project was to provide a strong scientific basis for a feasible wetland monitoring program.

Figure 8 Potentially restorable wetland areas in Douglas County that are likely to provide water attenuation functions

Map created by Saint Mary’s GSS.

In the Nemadji watershed in Douglas County, a cooperative project supporting the delisting of the St. Louis River Area of Concern (MNDNR, MPCA, and WDNR, 2020) focused on the analysis of LiDAR elevation data, as well as other existing datasets to assess how wetlands, conifer/native forest, and stream riparian corridors can be managed to address the STF concerns in the watershed (Benck et al., 2018). The objectives of the project were to identify priority habitat restoration and protection sites in the Nemadji River watershed using geographic information system (GIS) analysis to support a decision support system (Benck et al., 2018). The information from this project can be used to inform future restoration and protection efforts in the Nemadji River watershed. The key component of this project was a multi-criteria feasibility matrix used to assess habitat restoration and protection opportunities. This matrix helps prioritize and direct investments in restoration and protection actions based on factors such as watershed needs, available funding, local planning, land ownership, historic and predicted climate patterns, and habitat location. The matrix is comprised of a set of protection and restoration criteria and thresholds for identifying and/or prioritizing management actions for riparian, forest, and wetland habitats. The matrix can be used to target communications to landowners in priority restoration and protection locations and can provide government decision-makers with data to support planning, zoning, and bylaw decisions.

#### Subwatershed peak flow estimates

To identify watersheds with accelerated watershed runoff, we calculated 2-year peak discharge using the National Streamflow Statistics (NSS) program (Walker and Krug, 2003). The NSS is an easy-to-use program that provides regression equations for every state in the US to estimate streamflow statistics including peak discharge at ungauged sites. NSS uses multiple regression analysis on log-transformed data from continuous gaging stations and crest gage sites with at least 10 years of data to estimate relationships between flood peaks and watershed characteristics for regions within a state. The NSS regression equation for northern Wisconsin was calculated using data through the year 2000 from nearly all of Bayfield, Iron, Ashland, and Douglas Counties, and includes guage site data from northern portions of Burnett, Washburn, and Vilas Counties. Forest cover and precipitation were evaluated in developing this equation but were determined to not be significant terms in estimating discharge. Using this program, we calculated 2-year peak discharges using the equation:

PeakQ 2 = 2.69 × ( Watershed shd. Area )^0.864^ × ( Storage + 1 )^0.296^ × ( Stream Slope )^0.279^ × ( Soil Permeability )^− 0.25^ × ( Annual Snowfall )^0.49^

Where contributing drainage area is measured in square miles; storage, in percent of basin area plus 1.0; the main-channel slope is measured in feet per mile; soil permeability is for the least-permeable soil horizon in inches per hour; mean annual snowfall for 1961 through 1990 in inches; from Walker and Krug, 2003.

We evaluated NHD+ subwatersheds, hydrologic units defined by Wheeler et al. (2014), and pour point watersheds as potential summary units for watershed characterization and discharge estimation. We decided to use pour point watersheds because they encompass the entire contributing area to a given location and allow for consideration of the cumulative effects of multiple land uses throughout that contributing area. We used the ArcHydro toolbox to delineate watersheds using 30-meter resolution National Elevation Data across Wisconsin’s four Lake Superior counties. We delineated and calculated the area for 1,615 nested and overlapping pour point watersheds in Wisconsin’s portion of the Lake Superior basin. Storage was estimated as the surface area of wetlands (Wisconsin Wetlands Inventory) and lakes (WDNR Hydro data layer). Stream slope was calculated for each watershed as the difference in elevation at 15% and 85% of the watershed from the digital elevation model. Soil permeability data and annual snowfall data were from Walter & Krug, 2003.

The Wisconsin Lake Superior Basin Partner Team and Technical Work Group (Lake Superior Basin Partner Team, 2007) identified the peak discharge to watershed area ratio as an appropriate metric for identifying priority subwatersheds for STF efforts. This was based on Verry (2001) who showed that channel-forming flows occur at a peak discharge to drainage area ratio of greater than 15.

Figure 9 Modeled peak discharge to drainage area ratios (cubic feet/second)/square miles) for WI Lake Superior south shore watersheds

Symbol size for peak discharge/drainage area reflects subwatershed “flashiness.”

A map of this metric (figure 7) shows smaller watersheds near the coast consistently had the highest discharge/drainage area ratios. The Marengo River had a series of small watersheds aligned along the Marengo’s main stem with higher discharge/drainage ratios.

#### Open lands

Community GIS (2009 completed several analyses of the south shore in Wisconsin and portions thereof aimed to identify open areas (defined as developed areas, agricultural land, and forests less than 15 years in age), to estimate the proportion of area they occupy by subwatershed, and prioritize subwatersheds for STF efforts based on the threshold discussed above. Because recently harvested forests are typically managed for logging and rapidly re-forested with early successional species, they are only visible in remote imagery for a short period of time and thus are difficult to identify without intensive analysis. However, they are not negligible, with approximately 39% of all open lands in the south shore basin classified as recently harvested forest in 2008.

To analyze open lands, Community GIS collected LANDSAT imagery for the prior 15 years, and heads-up digitized any forest harvests in those 15 years, along with agricultural land and developed areas. Open lands were then summarized as percent area by subwatershed. This approach has several drawbacks. The analysis has been conducted and repeated based on need and funding availability at various spatial and temporal scales (Table 4). This results in incomplete and out-of-date assessments for a large portion of the basin. The assessment is difficult and expensive because it is extremely time-consuming to digitize 15 years of satellite data. Seeking funding to repeat the assessment regularly is not practical. The subwatersheds used in the assessment were derived by hand from topographic maps by the original researcher, Sandy Verry, and are not reproducible, nor compatible with standard hydrologic frameworks like the GLAHF framework (Forsyth et al., 2016) or USGS hydrologic map units. These factors limit the reproducibility and transparency of the assessment. Lastly, the subwatersheds used in the assessment are not cumulative along streams and rivers. In other words, subwatersheds in the upper basin with high percent open lands are not accounted for in subwatersheds downstream. For those reasons, an alternative affordable, regularly produced means of identifying open lands including young forests at multiple scales would be beneficial to managers. We evaluated several land cover datasets as potential options for this.

Table 4 Availability of Community GIS Open Lands analysis for the South Shore Lake Superior basin

Name | Area of Coverage | Years of forest harvests evaluated | Completed by
Nemadji Open Lands Assessment | Nemadji Watershed | 1999-2014 | Community GIS
Nemadji Open Lands Assessment | Nemadji Watershed | 1986-2002 | Community GIS
Lake Superior Basin Open Lands Assessment | Entire Lake Superior basin in Wisconsin | 1994-2008 | Community GIS
Lake Superior Basin Open Lands Assessment | Entire Lake Superior basin in Wisconsin | 1990-2004 | Community GIS

There are several widely produced land use/land cover datasets. We reviewed the following datasets to evaluate if they could support the assessment of open lands:

- National Land Cover Database 2011 (NLCD – https://www.mrlc.gov/)
- WiscLand 2 (http://dnr.wi.gov/maps/gis/datalandcover.html)
- National Agriculture Statistics Service CropScape Cropland Data Layer (CropScape – https://nassgeodata.gmu.edu/CropScape)

We found that the CropScape dataset had the most potential for identifying open lands because it is produced annually and has the most detailed crop classifications (USDA, 2015). We used the CropScape data to identify open lands in 2014 based on the available CropScape data which included 2007 – 2014. We summarized the data for the subwatersheds used in the Community GIS analysis and compared the results to the Community GIS analysis for the same years. For additional details about the methods used in the comparison, see Appendix 3.

The summaries of open lands by subwatershed using the two methods present similar themes: steep narrow subwatersheds in the geologic transition zone between the main stem, and 1^st^ order streams generally have the highest proportion of open lands (Figure 9). However, the percent open area of subwatersheds varied between the two estimates, often by more than 10%, with the CropScape data estimating lower percent open areas than the Community GIS analysis, especially in the upper basin.

These areas are commonly forested and logged. In a few small subwatersheds, the Community GIS analysis estimated about twice the percent open lands as the CropScape analysis.

The CropScape and Community GIS layers generally agree on agriculture and urban lands (Figure 10). However, the two datasets differ in young forests. Many young forests identified in the Community GIS analysis through an intensive review of satellite imagery were classified as forest in CropScape in all years, and thus not identified by the CropScape analysis. The Community GIS assessment was specifically designed to identify those lands directly from remote imagery, while the purpose of CropScape is generally focused on agricultural land uses, so CropScape is less accurate than the Community GIS analysis in identifying recent harvests/young forests. This is true for both the single year we reviewed (2014) as well as for the combined young forests identified using 2007 – 2014 satellite imagery.

Figure 10 Summary of percent open lands in the Nemadji River watershed by subwatershed using the Community GIS analysis (top) and the CropScape data (bottom)

Figure 11 Comparison of CropScape open lands (pink) with urban, agricultural, and harvested lands digitized for the Community GIS analysis

The top map shows data for an individual year, 2014, while the lower map shows data for 2007 – 2014, with earlier harvest data from the Community GIS analysis shown in grey (1999 – 2006).

The WISCLAND 2 and NLCD land cover datasets also were challenged to consistently distinguish forested wetlands/shrubland/deciduous forest, so even if those datasets were reproduced regularly, they are unlikely to effectively identify young forest harvests. CropScape data may be useful for identifying watershed-wide priorities based on agricultural and developed land uses. However, if prioritization is based only on existing agriculture and developed lands, WISCLAND 2 is a higher quality dataset (with increased quality assurance and ground truthing) and should be used rather than CropScape.

Currently, the Community GIS analysis is the only available layer that includes young forests. However, it is cost-prohibitive, time-consuming, and impractical to reproduce regularly. Evaluating open lands based on agriculture and developed lands from satellite imagery, paired with recent forest harvest records, could allow managers to identify individual subwatersheds that are a priority for STF work. If this approach is used, managers should also evaluate subwatersheds in sequence, and prioritize watersheds with high open lands including recent forest harvest in the immediate subwatershed as well as in upstream subwatersheds.

Several additional methods to evaluate open lands could also be explored. Both classified LiDAR point clouds and surface elevation data can be used with thresholds to identify open lands at the time of data collection. Young forests could also potentially be classified if height (and/or density for point clouds) thresholds for young aspen stands can be determined. This continuous data could then be evaluated cumulatively to summarize the percent of open lands/young forests upstream at any location along the stream network. This effort could yield a highly accurate evaluation of open lands upstream, but still has the caveat of only representing the time of data collection and has a limited ability to be updated through time. Other methods that could be promising include the use of stereo pairs of National Agriculture Imagery Program (NAIP) imagery (collected annually), or high-resolution Digital Globe imagery to develop canopy surface elevation maps that could be analyzed to identify forest disturbance like clear cuts and wind falls (Betts et al., 2005).

#### Land use/land cover metrics

The same land use/land cover datasets mentioned above (WISCLAND 2, NASS CropScape, and NLCD 2016) can be used for standard metrics such as calculating the proportion of agriculture or forest by subwatershed or to identify subwatersheds that drain into certain land uses such as urban areas, poor fens, and coastal wetlands. Wisconsin Ecological Landscapes (WDNR, 2015) can be used to identify subwatersheds bridging the geologic transition zone between soil types. The Wisconsin Natural Heritage Inventory (https://dnr.wisconsin.gov/topic/NHI) can be used to identify sensitive and threatened ecosystems to help prioritize efforts.

While best management practices are important for agricultural areas, large amounts of land in high-intensity agriculture will increase peak flows within that subwatershed compared to the forest. By planning at a watershed scale, we can attempt to offset increases in peak flows on high-intensity agriculture by looking for opportunities to slow the flow on other land cover types within agricultural subwatersheds. We investigated these opportunities by identifying “transitional agriculture” lands. We define these as open land cover types that are not currently being utilized for high-intensity agriculture (row crops). These properties may be managed for open space to facilitate recreation or may have recently been taken out of agricultural production. In either case, these properties may have landowners amenable to integrating STF into their management to enhance the property’s ability to retain water on the landscape.

To identify opportunities associated with transitional agriculture, we evaluated the same land cover datasets mentioned above and determined that CropScape was also the best dataset to use for this analysis. Despite the limited ground-truthing, CropScape data has more type classes for agriculture allowing us to break out high and low-intensity agriculture, and it is produced every year, which allows analysis of change through time. For this analysis, we assumed that properties not used for intensive crop production in the last five to ten years may be less likely to be used for production in the future, so these areas may be good targets for restoration. We first reclassified all the original CropScape classes present in the Lake Superior basin from 2003 – 2016 (Table 5).

Table 5 Reclassification of CropScape classes for transitional agriculture analysis

Reclassified | CropScape Classes (2003 – 2016)
Transitional Agriculture | Alfalfa; Other Hay/Non-alfalfa; Clover/Wildflowers | Fallow/Idle Cropland; Barren; Pasture/Grass | Shrubland; Vetch
High-Intensity/Row Crops | Barley; Camelina; Canola; Corn; Dbl Crop Barley/Sorghum; Dbl Crop Soybeans/Oats; Dbl Crop WinWht/Corn; Dbl Crop; WinWht/Soybeans; Dry Beans; Durum Wheat | Flaxseed; Herbs; Millet; Misc Vegs & Fruits; Oats; Other Crops; Other Small Grains; Peas; Potatoes; Triticale; Winter Wheat | Pumpkins; Rye; Safflower; Sod/Grass Seed; Sorghum; Soybeans; Spring Wheat; Sunflower; Sweet Corn
Other | Apples; Aquaculture; Background | Blueberries; Christmas Trees; Clouds/No Data | Cranberries; Nonag/Undefined
Forest | Deciduous Forest; Evergreen Forest | Forest; Mixed Forest
Developed | Developed; Developed/High-Intensity | Developed/Low Intensity; Developed/Med Intensity | Developed/Open space
Wet | Herbaceous Wetlands; Open Water | Wetlands; Woody Wetlands

The most important reclassifications for this analysis include transitional agriculture and high-intensity agriculture. Transitional agriculture included all classes that represent open lands that are not intensively farmed (e.g., alfalfa, hay, prairie, idle cropland, pasture, barren, shrubland). High-intensity agriculture included all classes that represent row crops and intensive agriculture.

Based on our definition of transitional agriculture, recently logged lands could be included in the reclassification. For example, recently logged lands could be classified as barren or shrubland for 0 – 15 years after logging. These properties are managed for forestry and are typically reforested or allowed to naturally restock. Forestry BMPs should be applied, but that is not the focus of this analysis. To focus our analysis on opportunities to mitigate agricultural runoff, we also identified properties that are currently classified as transitional agriculture and were previously classified as high-intensity agriculture.

We can also overlay the results of this transitional agriculture analysis with property ownership like the Protected Areas Database, which is an inventory of protected lands in the U.S. in public ownership (Figure 15, PAD-US, produced by the USGS Gap Analysis Program, Gergely and McKerrow, 2016). From this layer, we can identify the priority transitional agricultural areas in public ownership to work with local, state, and federal government agencies for conservation efforts. For areas that do not fall within protected areas, we can work with local government units to identify and contact private landowners.

As of 2016, transitional agriculture was widespread throughout the basin, forming a swath generally corresponding to the geologic transition zone between clay and sandy soils (Figure 11). Areas that are currently classified as transitional agriculture located within Forest Service and county forest lands south of the Bayfield Peninsula and Chequamegon Bay are areas that have likely been recently logged. Areas that have been converted from high-intensity agriculture to transitional agriculture represent a reduced portion of the total current transitional agriculture and are focused in the Marengo watershed, where high-intensity agriculture is found (Figure 32). Most of the areas converted to transitional agriculture from high-intensity agriculture are on private lands, as would be expected. Approximately 27% of the areas classified as transitional agriculture in 2016 were classified as transitional agriculture for the entire period of analysis (2006 – 2016).

Figure 12 Properties that were classified as transitional agriculture classes in every year of the most recent five years (2012 – 2016)

Figure 13 Properties that were classified as transitional agriculture classes in every year of the most recent five years (2012 – 2016) and were classified as high-intensity agriculture in the year prior (2011)

## Future needs

There are many challenges to implementing a watershed-scale strategic approach to slowing the flow in Wisconsin’s Lake Superior Basin. Here we summarize some of the biggest challenges and the research, monitoring, or collaboration needs to address them, by land use type. We received a lot of valuable ideas from reviewers and resource managers during a Slow the Flow discussion session at the April 2022 Lake Superior Collaborative Symposium. We were not able to incorporate all the feedback provided into this report, but we include documentation of this feedback in Appendix 1 to help inform future work.

### Watershed storage and wetland restoration

We recommend identifying and mapping ditch networks throughout the Lake Superior Basin. The availability of high-resolution LiDAR data throughout the majority of the Lake Superior Basin will allow managers to remotely map current and historic ditch networks throughout the watershed (e.g., Bailly et al., 2008; Rapinel et al., 2015; Passalacqua et al., 2012; Trettin et al., 2009; Devereux et al., 2005). Generally, to map ditch networks, a drainage network is derived from the LiDAR-derived Digital Elevation Model (DEM) and then cross-checked with high-resolution imagery and LiDAR intensity data. Exact methods are generally developed for specific regions/watersheds and then field-verified, to account for differences in vegetative communities, soils, and other landscape characteristics. Once methods are established for a given region, procedures to delineate ditches can be semi-automated to increase efficiency. The derivation of an inventory of historic and current/active ditches would allow managers to identify areas that are unlikely to be used for agriculture in the future and target wetland re-establishment in historic ditches.

Limited monitoring has occurred on USFWS wetland restoration sites in the basin, mainly consisting of construction specification monitoring and before and after photos. We recommend enhanced monitoring to include and determine the surface water retention capacity of restored wetlands. Hapner (2006) published a protocol for monitoring wetland restoration sites that could be adopted to estimate the storage capacity of restored wetland sites.

There are many high-quality wetlands throughout the basin that should be prioritized for protection. Although this report focuses on the hydrologic restoration of streams, the protection of existing watershed storage is extremely important. The wetland datasets discussed herein could be used to identify priorities for the protection of existing watershed storage to incorporate into a watershed-scale strategic approach.

### Forestry

The Lake Superior basin in Wisconsin is mostly forested. At a smaller spatial scale, there are areas of non-forest lands that have a disproportionate influence on stream flow in the region. To use the extent and composition of land cover and a dynamic management tool, we need a repeatable and readily available mechanism to characterize the amount of open land in the basin. The previous approach, described above in Parameter data sources: Open lands is time-consuming, requires specific expertise, and is expensive. Repeating this analysis regularly is not feasible. Obtaining reliable data for open lands and young forests may depend on establishing direct partnerships with the forestry community to map and understand where logging occurred to prioritize BMPs for these temporarily open lands.

LiDAR data was acquired in 2015 -2016 for all of the Lake Superior basin counties of Wisconsin. LiDAR data can be used to characterize many attributes of forest stands (see review in Muss, 2011), although it may be less useful for characterizing open lands. Other remote sensing techniques for characterizing land cover have been developed. NOAA’s Office for Coastal Management supports a Coastal Change Analysis Program (C-CAP) that describes regional land cover and changes in land cover types (https://coast.noaa.gov/digitalcoast/data/ccapregional.html). C-CAP datasets are updated every 5 years by deriving land cover type from remotely sensed Landsat imagery. Land cover is classified into 25 land use categories at 30-meter resolution. Online data visualization tools summarize change by HUC 8 watershed; however, data can be downloaded to examine conditions at smaller spatial scales. Recently NOAA has begun to provide high-resolution (1m) C-CAP data for selected areas. Currently, this is not yet available in our area of interest but may be in the future.

More research is needed on the effects of Emerald Ash Borer on streams including the effects of ash tree die-off on stream flow and sediment loading. Research should also continue focusing on the impacts of climate change on forest and riparian ecosystems especially projected shifts in forest species distributions, and how these impacts affect hydrology and streamflow.

### Agriculture

Research is needed to better understand causal relationships between BMPs and hydrology. Long-term monitoring is required to detect changes in hydrology resulting from even the extensive implementation of BMPs (Meals and Dressing, 2016). Evaluation of the effectiveness of BMPs in influencing hydrology must consider that the effectiveness of BMPs may vary seasonally. For example, practices that increase overland roughness (grassed waterways, conservation tillage) may not be effective during early spring snowmelt or rain on snow events. Other practices, such as grade stabilization structures may be more effective during these time periods.

Specifically, we recommend implementing research and monitoring programs that will:

- Quantify the extent and severity of soil compaction in the agricultural regions on the clay soils within the Lake Superior basin with a focus on seasonal soil surface compaction and sub-soil compaction from traditional moldboard plowing.
- Quantify the change in infiltration rates achieved by various methods to remove the compaction and extrapolate the resultant impact on peak flows.
- Implement field-edge monitoring to develop a local understanding of the impacts of waterway management and the conversion of perennial forages to annual row crops on peak flows.
- Quantify the impact of short-rotation woody biomass plantings on snowmelt and runoff in comparison to early-succession fields, traditional agricultural crops, and young aspen stands.
- Investigate key-line (subsoil) plowing and other hardscape management practices that retain water on the landscape without forming ponds or other retention basins.
- Determine the extent to which concentrated flow areas have developed in existing filter strips.

Lastly, existing state and federal agricultural regulations do not prohibit the conversion of upland forests to agricultural lands, except as it relates to federal “swampbuster” rules. The swampbuster rules allow for farming former wetlands converted to farming before 1985. With the extensive drainage networks remaining in reverted forestlands in the basin, it is unclear whether new clearing of this forestland and maintenance of the drainage networks would fall under the prior converted provisions. Clarifying this issue is important. Prohibiting the clearing of forestlands that would be forested wetlands in the absence of the relic drainage networks would help mitigate the hydrologic impacts of new forest clearing. Since 1985, farmers that fill or drain wetlands, including forested wetlands, risk losing USDA program benefits. If additional forest clearing is anticipated in the region, it will be important for USDA and WDNR staff to inform farm producers of the federal swampbuster rules and ensure compliance.

### Additional needs

#### Ongoing and increased collaboration

In general, for regulated industries like forestry and agriculture, complying with existing policies can undermine profitability. Expecting high compliance with additional watershed protection measures is unrealistic. It will require a major collaborative effort across the basin including education of land owners and managers on new approaches and tools to aid in the implementation of watershed management. Another major limitation is that 303(d) funding for watershed restoration work requires a 9 Key Element Plan, which requires initial resources and funding to develop.

To address these several challenges, it will be necessary to bring together stakeholders from all relevant fields. The Lake Superior Collaborative has the capacity to do this. The collaborative can begin establishing relationships and partnerships with forestry and agriculture managers and advocate for watershed considerations in land-use planning on forestry and agriculture lands, across the basin. The collaborative also can obtain funding to advance watershed planning efforts.

Building on existing relationships with Tribal natural resource agencies to support treaty rights is a priority. Both Bad River and Red Cliff have active environmental and natural resources departments in the basin that are regularly engaged in regional partnerships. Both departments work closely with EPA and other Federal agencies. The Bad River Tribe obtained CWA authority of 303(c)/401 in 2009 and has had EPA approved water quality standards since September 2011. Both Red Cliff and Bad River have a CWA 319 non-point source program, as well as CWA 106 authority (Bad River Band, 2011; VanBergen and Nguyen 2018).

This report and the recommendations herein are based on a review of primary scientific and institutional literature. We also recommend considering Indigenous and local community knowledge as equal to and complementary to institutional knowledge in decision-making. Indigenous Knowledge and traditional ecological knowledge are place-based and have evolved through generations of knowing and living in a place. These knowledge systems are held by local communities, are often sensitive, and can be sacred. Elevating the role of these ways of knowing in decision-making will also likely require building on existing relationships with Indigenous and local communities. It may be helpful to establish norms for the ethical incorporation of multiple ways of knowing in decision-making. In addition to supporting treaty rights, it is also important to fulfill trust responsibilities to tribes in areas where the state is implementing authority delegated from the federal government for, example, CWA and CAA delegated authority.

#### Monitoring and data management

Another major need is ongoing monitoring and data management so that the effectiveness of BMPs implemented at a watershed scale can be quantitatively evaluated. This means continued and possibly expanded funding for stream gauges and flow monitoring. Evaluation of slow the flow effort effectiveness should include characterization of full cost per acre benefits, including time to recruit and convince landowners to restore wetlands. This cost could then be projected to a scale at which such restoration projects would have a meaningful impact on slowing the flow. In addition, ecosystem service and human well-being indicators should be explored to evaluate how efforts translate to benefits for communities, especially in partnership with the Lake Superior Collaborative and basin-wide partners.

Funding and coordination of a data management system are also a need. Many existing systems host data relevant to slow the flow efforts but are unable to integrate multiple datasets in a single place where they can be easily reviewed, analyzed, or shared. There is potential with ArcGIS Online and other available platforms to manage existing and future datasets, but this requires staff time and funding, which have yet to be identified.