# Introduction

## Background

To protect tributary and Great Lake water quality and habitat for aquatic organisms, conservation must address land cover and land use practices in uplands and the headwater portions of watersheds. Without work to reduce overland flow and runoff, any downstream efforts to promote healthy fisheries and water quality will have limited results.

Watershed hydrology and streamflow are major determinants of the composition, structure, and dynamics of aquatic and riparian ecosystems (Poff and Ward, 1989, Richards et al., 2002, Seeger et al., 2004, Harman et al., 2012). A combination of climate, geology, and landscape-scale watershed conditions affect the volume, velocity, and timing of streamflow. Air temperature, humidity, topography, land cover, and soil composition determine rates of evaporation, infiltration, and runoff that influence streamflow response to precipitation events (USGS, 2016). Contributions of groundwater to streams influence baseflow characteristics between runoff events. Low flow and high flow events, along with the variability in flow regime across seasons and years define the hydrologic character of streams and rivers.

Hydrology, in turn, affects sediment erosion and transport, water quality, and in-stream habitat for a huge number of species (Fitzpatrick and Knox 2000, Carpenter et al., 1998, Detenbeck et al., 2003, Brazner et al., 2004, and others). Both resident and migratory fish species are affected by hydrology in Lake Superior streams. High sediment loads carried by floodwaters are deposited on streambeds, smothering spawning gravel and filling in deep pools favored by fish. In-stream sedimentation also limits macroinvertebrate production, a food source for many fish species (Henley et al., 2010). Seasonal hydrologic patterns trigger life history events for many species, with high flows in spring triggering spawning runs for many species like walleye and sturgeon, and low flow events encouraging organisms to seek adequate habitat and preferred temperatures (Poff et al., 1997).

Changes in land use and land cover affect hydrology. At the time of European contact, the Ojibwe people inhabited the region for centuries, with lifestyles and economies based on forest and wetland resources. Ojibwe land management practices helped shape the ecosystems of the region (Steen-Adams et al., 2011). Today, there are two reservations within the Wisconsin region of the Lake Superior Chippewa reservations in the basin, the Bad River Reservation east of Chequamegon Bay, and the Red Cliff Reservation on the northern tip of the Bayfield Peninsula.

European settlers had a large impact on basin land cover starting in the late 1800s with extensive forest clearing, followed by agricultural development and repeated clear-cut logging. These practices have altered stream channels and streamflow patterns, as well as sediment dynamics of erosion and deposition in streams for nearly 200 years (Fitzpatrick et al., 1999, Fitzpatrick and Knox, 2000, Lenz et al., 2003, Fitzpatrick, 2005, Fitzpatrick et al., 2015). Fitzpatrick’s studies implicate changes in flood magnitudes resulting from land cover change including forest conversion and wetland drainage as the main cause of valley bluff failures along steep stream channel segments. Consequently, sedimentation rates in river mouths at Lake Superior also increased.

Agencies in Wisconsin’s Lake Superior basin began conservation efforts to improve watershed quality about 60 years ago (Red Clay Interagency Committee, 1964, 1971, 1979). The Red Clay Interagency Committee (RCIC) was formed in 1956 with members from many federal, state, and local agencies to identify solutions to erosion problems in the red clay area of the Lake Superior basin. In 1971, at the request of the Governor of Wisconsin, the RCIC developed a Wisconsin-wide plan to reduce erosion and sedimentation in Lake Superior tributaries, which later expanded to Minnesota for a total of 5 counties throughout the red clay region. The RCIC worked with private landowners to implement and assess the efficacy of a variety of projects intended to reduce erosion and sedimentation, (see review in Fitzpatrick et al., 2015). These efforts have largely focused on restoring and protecting hydrology by “slowing the flow.” The slow the flow (STF) approach seeks to reduce peak stream flows by using a watershed-scale hydrologic restoration approach that increases in-channel roughness and channel sinuosity, subwatershed land surface roughness, water storage in wetlands, and infiltration. Local natural resource managers have implemented forest management, wetland restoration, channel restoration, agricultural best management practices (BMPs), and green infrastructure projects to restore a natural hydrologic regime, with an expectation of improvements to water quality and habitat. Demonstration and restoration projects in the Lake Superior basin have been implemented since the mid-20th century.

Many local organizations seek to continue STF efforts in the basin (Ashland County, 2010, Bayfield County, 2010, Bro and Fratt, 2011, BRWA 2011, Douglas County, 2009, Jereczek et al., 2011). Multiple partnerships have supported STF efforts in the Lake Superior basin of Wisconsin, including the Lake Superior Basin Partner Team (1998-2012), the Chequamegon Bay Area Partnership (2009-2017), and the Lake Superior Landscape Restoration Partnership or “Joint Chiefs’ Project” (2014-2017). Through the Joint Chiefs’ Landscape Restoration Partnership, the Forest Service (USFS) and Natural Resources Conservation Service (NRCS) worked together to improve the health of forest land connected to privately owned lands. This included restoring landscapes by reducing wildfire threats to communities and landowners and protecting water quality and enhancing wildlife habitat. Building on these prior partnerships, the Lake Superior Collaborative (LSC) was formed in 2018 to coordinate protection and restoration efforts in Wisconsin’s Lake Superior watershed and promote climate resiliency.

## Purpose and scope

DNR and many regional partners have sought to improve the strategic approach of slow the flow efforts through the Landscape Restoration Partnership and the Lake Superior Collaborative. A team of resource professionals from the region identified priority subwatersheds for restoration (Wheeler et al., 2014). The effort identified a few criteria for prioritizing subwatersheds including the amount of open land and its position in the watershed, with emphasis on watersheds with known hydrologic degradation and accelerated sedimentation. The team also identified best management practices for those locations. With landscape-scale maps of where to work, the team began to consider identifying the desired future condition of these subwatersheds and restoration activities to achieve these conditions. This led to questions about how to refine criteria, how to link criteria to priority actions, what level of change will result in the desired response in condition, and what the indicators of success should be.

To help answer these questions, this report compiles the existing scientific information on the causal links between watershed condition and streamflow, with an emphasis on research from the Lake Superior basin of northern Wisconsin (Figure 1). Hydrologic, geomorphic, chemical, and biological attributes of lotic systems are highly interdependent. A complete discussion of the relationships between hydrology and these other components is beyond the scope of this report. Instead, we intend that this report provides a useful overview of stream hydrology as a proximate driver of sediment and biological interactions in lotic systems. This paper focuses primarily on reviewing the hydrologic effects of land use and land cover from published studies. From this, we suggest a framework for prioritizing STF efforts across Wisconsin’s Lake Superior basin.

Figure 1 Land ownership in Wisconsin’s Lake Superior basin

Source: https://maps.usgs.gov/padus/ USGS Protected Areas Database of the United States. Manager types from top to bottom include: Bureau of Land Management, City, County, U.S. Fish and Wildlife Service, Non-Governmental Organization, National Parks Service, Others, Private, Regional Agency, State DNR, U.S Forest Service, Tribal